# Dietary Reference Intakes

Vitamin or mineral | Other names | Group | Age (years)^*^ | RDA | UL
Vitamin A (mcg/d) | Vitamin A, retinol, retinal | Males | 9–13 | 600 | 1700
Vitamin A (mcg/d) | Vitamin A, retinol, retinal | Males | 14–18 | 900 | 2800
Vitamin A (mcg/d) | Vitamin A, retinol, retinal | Males | ≥19 | 900 | 3000
Vitamin A (mcg/d) | Vitamin A, retinol, retinal | Females | 9–13 | 600 | 1700
Vitamin A (mcg/d) | Vitamin A, retinol, retinal | Females | 14–18 | 700 | 2800
Vitamin A (mcg/d) | Vitamin A, retinol, retinal | Females | ≥19 | 700 | 3000
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Males | 9–13 | 0.9 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Males | ≥14 | 1.2 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Females | 9–13 | 0.9 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Females | 14–18 | 1.0 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Females | ≥19 | 1.1 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Males | 9–13 | 0.9 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Males | ≥14 | 1.3 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Females | 9–13 | 0.9 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Females | 14–18 | 1.0 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Females | ≥19 | 1.1 | ND
Vitamin B_6_ (mg/d) | None | Males | 9–13 | 1.0 | 60
Vitamin B_6_ (mg/d) | None | Males | 14–18 | 1.3 | 80
Vitamin B_6_ (mg/d) | None | Males | 19–50 | 1.3 | 100
Vitamin B_6_ (mg/d) | None | Males | ≥51 | 1.7 | 100
Vitamin B_6_ (mg/d) | None | Females | 9–13 | 1.0 | 60
Vitamin B_6_ (mg/d) | None | Females | 14–18 | 1.2 | 80
Vitamin B_6_ (mg/d) | None | Females | 19–50 | 1.3 | 100
Vitamin B_6_ (mg/d) | None | Females | ≥51 | 1.5 | 100
Vitamin B_12_ (mcg/d) | Cobalamin | Males | 9–13 | 1.8 | ND
Vitamin B_12_ (mcg/d) | Cobalamin | Males | ≥14 | 2.4 | ND
Vitamin B_12_ (mcg/d) | Cobalamin | Females | 9–13 | 1.8 | ND
Vitamin B_12_ (mcg/d) | Cobalamin | Females | ≥14 | 2.4 | ND
Vitamin C (mg/d) | L-ascorbic acid, ascorbate, dehydroascorbic acid (DHA) | Males | 9–13 | 45 | 1200
Vitamin C (mg/d) | L-ascorbic acid, ascorbate, dehydroascorbic acid (DHA) | Males | 14–18 | 75 | 1800
Vitamin C (mg/d) | L-ascorbic acid, ascorbate, dehydroascorbic acid (DHA) | Males | ≥19 | 90 | 2000
Vitamin C (mg/d) | L-ascorbic acid, ascorbate, dehydroascorbic acid (DHA) | Females | 4–8 | 75 | 1200
Vitamin C (mg/d) | L-ascorbic acid, ascorbate, dehydroascorbic acid (DHA) | Females | 9–18 | 65 | 1800
Vitamin C (mg/d) | L-ascorbic acid, ascorbate, dehydroascorbic acid (DHA) | Females | ≥19 | 75 | 2000
Vitamin D (mcg/d) | Calciferol | Males | 9–70 | 15 | 100
Vitamin D (mcg/d) | Calciferol | Males | ≥71 | 20 | 100
Vitamin D (mcg/d) | Calciferol | Females | 9–70 | 15 | 100
Vitamin D (mcg/d) | Calciferol | Females | ≥71 | 20 | 100
Vitamin E (mg/d) | alpha-tocopherol | Males | 9–13 | 11 | 600
Vitamin E (mg/d) | alpha-tocopherol | Males | 14–18 | 15 | 800
Vitamin E (mg/d) | alpha-tocopherol | Males | ≥19 | 15 | 1000
Vitamin E (mg/d) | alpha-tocopherol | Females | 9–13 | 11 | 600
Vitamin E (mg/d) | alpha-tocopherol | Females | 14–18 | 15 | 800
Vitamin E (mg/d) | alpha-tocopherol | Females | ≥19 | 15 | 1000
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Males | 9–13 | 1300 | 3000
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Males | 19–30 | 1000 | 2500
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Males | 51–70 | 1000 | 2000
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Males | ≥71 | 1200 | 2000
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Females | 9–13 | 1300 | 3000
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Females | 19–30 | 1000 | 2500
Calcium (mg/d) | Calcium carbonate, calcium glucnate, calcium citrate | Females | ≥51 | 1200 | 2000
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, pteroylmonoglutamic acid, folate | Males | 9–13 | 300 | 600
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, pteroylmonoglutamic acid, folate | Males | 14–18 | 400 | 800
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, pteroylmonoglutamic acid, folate | Males | ≥19 | 400 | 1000
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, pteroylmonoglutamic acid, folate | Females | 9–13 | 300 | 600
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, pteroylmonoglutamic acid, folate | Females | 14–18 | 400 | 800
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, pteroylmonoglutamic acid, folate | Females | ≥19 | 400 | 1000
Iron (mg/d) | None | Males | 9–13 | 8 | 40
Iron (mg/d) | None | Males | 14–18 | 11 | 45
Iron (mg/d) | None | Males | ≥19 | 8 | 45
Iron (mg/d) | None | Females | 9–13 | 8 | 40
Iron (mg/d) | None | Females | 14–18 | 15 | 45
Iron (mg/d) | None | Females | 19–30 | 18 | 45
Iron (mg/d) | None | Females | 31–50 | 15 | 45
Iron (mg/d) | None | Females | ≥51 | 8 | 45
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Males | 9–13 | 240 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Males | 14–18 | 410 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Males | 19–30 | 400 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Males | ≥31 | 420 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Females | 9–13 | 240 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Females | 14–18 | 360 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Females | 19–30 | 310 | 350
Magnesium (mg/d) | Magnesia, magnesia carbonica, magnesia muriatica, magnesium gluconate, milk of magnesia | Females | ≥31 | 320 | 350
Niacin (mg/d) | Vitamin B_3_, nicotinic acid, vitamin PP | Males | 9–13 | 12 | 20
Niacin (mg/d) | Vitamin B_3_, nicotinic acid, vitamin PP | Males | 14–18 | 16 | 30
Niacin (mg/d) | Vitamin B_3_, nicotinic acid, vitamin PP | Males | ≥19 | 16 | 35
Niacin (mg/d) | Vitamin B_3_, nicotinic acid, vitamin PP | Females | 9–13 | 12 | 20
Niacin (mg/d) | Vitamin B_3_, nicotinic acid, vitamin PP | Females | 14–18 | 14 | 30
Niacin (mg/d) | Vitamin B_3_, nicotinic acid, vitamin PP | Females | ≥19 | 14 | 35
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Males | 9–13 | 40 | 280
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Males | ≥14 | 55 | 400
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Females | 9–13 | 40 | 280
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Females | ≥14 | 55 | 400
Zinc (mg/d) | Zinc acetate | Males | 9–13 | 8 | 23
Zinc (mg/d) | Zinc acetate | Males | 14–18 | 11 | 34
Zinc (mg/d) | Zinc acetate | Males | ≥19 | 11 | 40
Zinc (mg/d) | Zinc acetate | Females | 9–13 | 8 | 23
Zinc (mg/d) | Zinc acetate | Females | 14–18 | 9 | 34
Zinc (mg/d) | Zinc acetate | Females | ≥19 | 8 | 40

* Data for children younger than age 9 years are available in original source documents.

Abbreviations: ND = not determinable; RDA = recommended dietary allowance; UL = upper intake level.

Note: Beta-carotene does not have a dietary reference intake.