# References

1 U.S. Preventive Services Task Force. Screening for dementia: recommendation and rationale. Ann Intern Med. 2003;138(11):925-6. [pmid: 12779303].
2 Boustani M, Peterson B, Harris R, et al. Screening for Dementia. Systematic Evidence Review No. 20. Rockville, MD. Agency for Healthcare Research and Quality. 2003. [pmid: 20722116].
3 American Psychiatric Association. Diagnostic and Statistic Manual of Mental Disorders. Washington, DC. American Psychiatric Association. 1994.
4 American Psychiatric Association. Recent Updates to Proposed Revisions for DSM-5. Washington, DC. American Psychiatric Association. 2012. Accessed at http://www.dsm5.org/Pages/RecentUpdates.aspx on 28 October 2013.
5 Plassman BL, Langa KM, Fisher GG, et al. Prevalence of dementia in the United States: the Aging, Demographics, and Memory Study. Neuroepidemiology. 2007;29(1-2):125-32. [pmid: 17975326].
6 Warner J, Butler R, Gupta S. Dementia. Clin Evid (Online). 2010;2010. [pii: 1001]. [pmid: 21726471].
7 Querfurth HW, LaFerla FM. Alzheimer's disease. N Engl J Med. 2010;362(4):329-44. [pmid: 20107219].
8 Savva GM, Wharton SB, Ince PG, et al. Age, neuropathology, and dementia. N Engl J Med. 2009;360(22):2302-9. [pmid: 19474427].
9 Sonnen JA, Larson EB, Crane PK, et al. Pathological correlates of dementia in a longitudinal, population-based sample of aging. Ann Neurol. 2007;62(4):406-13. [pmid: 17879383].
10 Halter JB, Ouslander JG, Tinetti ME, et al., editors. Hazzard's Geriatric Medicine and Gerontology. 6th ed. New York. McGraw-Hill. 2009.
11 Espino DV, Jules-Bradley AC, Johnston CL, et al. Diagnostic approach to the confused elderly patient. Am Fam Physician. 1998;57(6):1358-66. [pmid: 9531917].
12 Matthews FE, Stephan BC, Bond J, et al. Operationalisation of mild cognitive impairment: a graphical approach. PLoS Med. 2007;4(10):e304. [pmid: 17973571].
13 Winblad B, Palmer K, Kivipelto M, et al. Mild cognitive impairment—beyond controversies, towards a consensus: report of the International Working Group on Mild Cognitive Impairment. J Intern Med. 2004;256(3):240-6. [pmid: 15324367].
14 Petersen RC, Smith GE, Waring SC, et al. Mild cognitive impairment: clinical characterization and outcome. Arch Neurol. 1999;56(3):303-8. [pmid: 10190820].
15 Petersen RC, Roberts RO, Knopman DS, et al. Mild cognitive impairment: ten years later. Arch Neurol. 2009;66(12):1447-55. [pmid: 20008648].
16 Seshadri S, Beiser A, Au R, et al. Operationalizing diagnostic criteria for Alzheimer's disease and other age-related cognitive impairment—part 2. Alzheimers Dement. 2011;7(1):35-52. [pmid: 21255742].
17 Mitchell AJ, Shiri-Feshki M. Rate of progression of mild cognitive impairment to dementia—meta-analysis of 41 robust inception cohort studies. Acta Psychiatr Scand. 2009;119(4):252-65. [pmid: 19236314].
18 Stephan BC, Kurth T, Matthews FE, et al. Dementia risk prediction in the population: are screening models accurate?. Nat Rev Neurol. 2010;6(6):318-26. [pmid: 20498679].
19 Holsinger T, Deveau J, Boustani M, et al. Does this patient have dementia?. JAMA. 2007;297(21):2391-404. [pmid: 17551132].
20 Alzheimer's Association. 2012 Alzheimer's disease facts and figures. Alzheimers Dement. 2012;8(2):131-68. [pmid: 22404854].
21 Launer LJ. Counting dementia: there is no one “best” way. Alzheimers Dement. 2011;7(1):10-4. [pmid: 21255740].
22 Ferri CP, Prince M, Brayne C, et al. Global prevalence of dementia: a Delphi consensus study. Lancet. 2005;366(9503):2112-7. [pmid: 16360788].
23 Potter GG, Plassman BL, Burke JR, et al. Cognitive performance and informant reports in the diagnosis of cognitive impairment and dementia in African Americans and whites. Alzheimers Dement. 2009;5(6):445-53. [pmid: 19896583].
24 Daviglus ML, Bell CC, Berrettini W, et al. National Institutes of Health State-of-the-Science Conference statement: preventing Alzheimer disease and cognitive decline. Ann Intern Med. 2010;153(3):176-81. [pmid: 20547888].
25 Clarfield AM. The decreasing prevalence of reversible dementias: an updated meta-analysis. Arch Intern Med. 2003;163(18):2219-29. [pmid: 14557220].
26 Tang MX, Cross P, Andrews H, et al. Incidence of AD in African-Americans, Caribbean Hispanics, and Caucasians in northern Manhattan. Neurology. 2001;56(1):49-56. [pmid: 11148235].
27 Chin AL, Negash S, Hamilton R. Diversity and disparity in dementia: the impact of ethnoracial differences in Alzheimer disease. Alzheimer Dis Assoc Disord. 2011;25(3):187-95. [pmid: 21399486].
28 Gurland BJ, Wilder DE, Lantigua R, et al. Rates of dementia in three ethnoracial groups. Int J Geriatr Psychiatry. 1999;14(6):481-93. [pmid: 10398359].
29 Bischkopf J, Busse A, Angermeyer MC. Mild cognitive impairment—a review of prevalence, incidence and outcome according to current approaches. Acta Psychiatr Scand. 2002;106(6):403-14. [pmid: 12392483].
30 Ward A, Arrighi HM, Michels S, et al. Mild cognitive impairment: disparity of incidence and prevalence estimates. Alzheimers Dement. 2012;8:14-21. [pmid: 22265588].
31 Mioshi E, Hsieh S, Savage S, et al. Clinical staging and disease progression in frontotemporal dementia. Neurology. 2010;74(20):1591-7. [pmid: 20479357].
32 Sollberger M, Neuhaus J, Ketelle R, et al. Interpersonal traits change as a function of disease type and severity in degenerative brain diseases. J Neurol Neurosurg Psychiatry. 2010;82(7):732-9. [pmid: 21172858].
33 Xie J, Brayne C, Matthews FE. Survival times in people with dementia: analysis from population based cohort study with 14 year follow-up. BMJ. 2008;336(7638):258-62. [pmid: 18187696].
34 Rait G, Walters K, Bottomley C, et al. Survival of people with clinical diagnosis of dementia in primary care: cohort study. BMJ. 2010;341:c3584. [pmid: 20688840].
35 Brookmeyer R, Corrada MM, Curriero FC, et al. Survival following a diagnosis of Alzheimer disease. Arch Neurol. 2002;59(11):1764-7. [pmid: 12433264].
36 Roberson ED, Hesse JH, Rose KD, et al. Frontotemporal dementia progresses to death faster than Alzheimer disease. Neurology. 2005;65(5):719-25. [pmid: 16157905].
37 Hodges JR, Davies R, Xuereb J, et al. Survival in frontotemporal dementia. Neurology. 2003;61(3):349-54. [pmid: 12913196].
38 Boustani M, Peterson B, Hanson L, et al. Screening for dementia in primary care: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138(11):927-37. [pmid: 12779304].
39 Hanyu H, Sato T, Hirao K, et al. Differences in clinical course between dementia with Lewy bodies and Alzheimer's disease. Eur J Neurol. 2009;16(2):212-7. [pmid: 19146642].
40 Ballard C, O'Brien J, Morris CM, et al. The progression of cognitive impairment in dementia with Lewy bodies, vascular dementia and Alzheimer's disease. Int J Geriatr Psychiatry. 2001;16(5):499-503. [pmid: 11376466].
41 Mathias JL, Morphett K. Neurobehavioral differences between Alzheimer's disease and frontotemporal dementia: a meta-analysis. J Clin Exp Neuropsychol. 2010;32(7):682-98. [pmid: 20063255].
42 Engelborghs S, Maertens K, Nagels G, et al. Neuropsychiatric symptoms of dementia: cross-sectional analysis from a prospective, longitudinal Belgian study. Int J Geriatr Psychiatry. 2005;20(11):1028-37. [pmid: 16250064].
43 Rascovsky K, Hodges JR, Knopman D, et al. Sensitivity of revised diagnostic criteria for the behavioural variant of frontotemporal dementia. Brain. 2011;134(Pt 9):2456-77. [pmid: 21810890].
44 McKeith IG, Dickson DW, Lowe J, et al. Diagnosis and management of dementia with Lewy bodies: third report of the DLB Consortium. Neurology. 2005;65(12):1863-72. [pmid: 16237129].
45 Manly JJ, Tang MX, Schupf N, et al. Frequency and course of mild cognitive impairment in a multiethnic community. Ann Neurol. 2008;63(4):494-506. [pmid: 18300306].
46 Loewenstein DA, Acevedo A, Small BJ, et al. Stability of different subtypes of mild cognitive impairment among the elderly over a 2- to 3-year follow-up period. Dement Geriatr Cogn Disord. 2009;27(5):418-23. [pmid: 19365121].
47 Ganguli M. Outcomes of mild cognitive impairment by definition: a population study. Arch Neurol. 2011;68(6):761-7. [pmid: 21670400].
48 Farias ST, Mungas D, Reed BR, et al. Progression of mild cognitive impairment to dementia in clinic- vs community-based cohorts. Arch Neurol. 2009;66(9):1151-7. [pmid: 19752306].
49 Roberts RO, Geda YE, Knopman DS, et al. The incidence of MCI differs by subtype and is higher in men: the Mayo Clinic Study of Aging. Neurology. 2012;78(5):342-51. [pmid: 22282647].
50 Larrieu S, Letenneur L, Orgogozo JM, et al. Incidence and outcome of mild cognitive impairment in a population-based prospective cohort. Neurology. 2002;59(10):1594-9. [pmid: 12451203].
51 Petersen RC. Clinical practice: mild cognitive impairment. N Engl J Med. 2011;364(23):2227-34. [pmid: 21651394].
52 Palmer K, Wang HX, Backman L, et al. Differential evolution of cognitive impairment in nondemented older persons: results from the Kungsholmen Project. Am J Psychiatry. 2002;159(3):436-42. [pmid: 11870008].
53 Ingles JL, Fisk JD, Merry HR, et al. Five-year outcomes for dementia defined solely by neuropsychological test performance. Neuroepidemiology. 2003;22(3):172-8. [pmid: 12711849].
54 Guehne U, Luck T, Busse A, et al. Mortality in individuals with mild cognitive impairment. Results of the Leipzig Longitudinal Study of the Aged (LEILA75+). Neuroepidemiology. 2007;29(3-4):226-34. [pmid: 18073495].
55 Wilson RS, Aggarwal NT, Barnes LL, et al. Biracial population study of mortality in mild cognitive impairment and Alzheimer disease. Arch Neurol. 2009;66(6):767-72. [pmid: 19506138].
56 Johansson B, Zarit SH. Early cognitive markers of the incidence of dementia and mortality: a longitudinal population-based study of the oldest old. Int J Geriatr Psychiatry. 1997;12(1):53-9. [pmid: 9050424].
57 Fisk JD, Merry HR, Rockwood K. Variations in case definition affect prevalence but not outcomes of mild cognitive impairment. Neurology. 2003;61(9):1179-84. [pmid: 14610117].
58 Fisk JD, Rockwood K. Outcomes of incident mild cognitive impairment in relation to case definition. J Neurol Neurosurg Psychiatry. 2005;76(8):1175-7. [pmid: 16024904].
59 Plassman BL, Williams JW Jr, Burke JR, et al. Systematic review: factors associated with risk for and possible prevention of cognitive decline in later life. Ann Intern Med. 2010;153(3):182-93. [pmid: 20547887].
60 Goveas JS, Espeland MA, Hogan P, et al. Depressive symptoms, brain volumes and subclinical cerebrovascular disease in postmenopausal women: the Women's Health Initiative MRI study. J Affect Disord. 2011;132(1-2):275-84. [pmid: 21349587].
61 Boyle PA, Buchman AS, Wilson RS, et al. Physical frailty is associated with incident mild cognitive impairment in community-based older persons. J Am Geriatr Soc. 2010;58(2):248-55. [pmid: 20070417].
62 Ritchie K, Carriere I, Ritchie CW, et al. Designing prevention programmes to reduce incidence of dementia: prospective cohort study of modifiable risk factors. BMJ. 2010;341:c3885. [pmid: 20688841].
63 Scarmeas N, Luchsinger JA, Schupf N, et al. Physical activity, diet, and risk of Alzheimer disease. JAMA. 2009;302(6):627-37. [pmid: 19671904].
64 Etgen T, Sander D, Huntgeburth U, et al. Physical activity and incident cognitive impairment in elderly persons: the INVADE study. Arch Intern Med. 2010;170(2):186-93. [pmid: 20101014].
65 Mukamal KJ, Kuller LH, Fitzpatrick AL, et al. Prospective study of alcohol consumption and risk of dementia in older adults. JAMA. 2003;289(11):1405-13. [pmid: 12636463].
66 Ganguli M, Rodriguez E, Mulsant B, et al. Detection and management of cognitive impairment in primary care: the Steel Valley Seniors Survey. J Am Geriatr Soc. 2004;52(10):1668-75. [pmid: 15450043].
67 Valcour VG, Masaki KH, Curb JD, et al. The detection of dementia in the primary care setting. Arch Intern Med. 2000;160(19):2964-8. [pmid: 11041904].
68 Olafsdottir M, Skoog I, Marcusson J. Detection of dementia in primary care: the Linköping study. Dement Geriatr Cogn Disord. 2000;11(4):223-9. [pmid: 10867449].
69 Chodosh J, Petitti DB, Elliott M, et al. Physician recognition of cognitive impairment: evaluating the need for improvement. J Am Geriatr Soc. 2004;52(7):1051-9. [pmid: 15209641].
70 Mitchell AJ. The clinical significance of subjective memory complaints in the diagnosis of mild cognitive impairment and dementia: a meta-analysis. Int J Geriatr Psychiatry. 2008;23(11):1191-202. [pmid: 18500688].
71 Ashford JW, Borson S, O'Hara R, et al. Should older adults be screened for dementia? It is important to screen for evidence of dementia!. Alzheimers Dement. 2007;3(2):75-80. [pmid: 19595920].
72 Schubert CC, Boustani M, Callahan CM, et al. Comorbidity profile of dementia patients in primary care: are they sicker?. J Am Geriatr Soc. 2006;54(1):104-9. [pmid: 16420205].
73 American Geriatrics Society 2012 Beers Criteria Update Expert Panel. American Geriatrics Society updated Beers Criteria for potentially inappropriate medication use in older adults. J Am Geriatr Soc. 2012;60(4):616-31. [pmid: 22376048].
74 Leipzig RM, Whitlock EP, Wolff TA, et al. Reconsidering the approach to prevention recommendations for older adults. Ann Intern Med. 2010;153(12):809-14. [pmid: 21173415].
75 American Geriatrics Society Expert Panel on the Care of Older Adults with Multimorbidity. Patient-centered care for older adults with multiple chronic conditions: a stepwise approach from the American Geriatrics Society. J Am Geriatr Soc. 2012;60(10):1957-68. [pmid: 22994844].
76 Mitchell AJ. A meta-analysis of the accuracy of the Mini-Mental State Examination in the detection of dementia and mild cognitive impairment. J Psychiatr Res. 2009;43(4):411-31. [pmid: 18579155].
77 Mitchell AJ, Malladi S. Screening and case finding tools for the detection of dementia, I: evidence-based meta-analysis of multidomain tests. Am J Geriatr Psychiatry. 2010;18(9):759-82. [pmid: 20808118].
78 Mitchell AJ, Malladi S. Screening and case-finding tools for the detection of dementia, II: evidence-based meta-analysis of single-domain tests. Am J Geriatr Psychiatry. 2010;18(9):783-800. [pmid: 20808094].
79 Lonie JA, Tierney KM, Ebmeier KP. Screening for mild cognitive impairment: a systematic review. Int J Geriatr Psychiatry. 2009;24(9):902-15. [pmid: 19226524].
80 Cherbuin N, Anstey KJ, Lipnicki DM. Screening for dementia: a review of self- and informant-assessment instruments. Int Psychogeriatr. 2008;20(3):431-58. [pmid: 18289452].
81 Appels BA, Scherder E. The diagnostic accuracy of dementia-screening instruments with an administration time of 10 to 45 minutes for use in secondary care: a systematic review. Am J Alzheimers Dis Other Demen. 2010;25(4):301-16. [pmid: 20539025].
82 American Geriatrics Society. A Guide to Dementia Diagnosis and Treatment. New York. American Geriatrics Society. 2011. Accessed at http://dementia.americangeriatrics.org/documents/AGS_PC_Dementia_Sheet_2010v2.pdf on 28 October 2013.
83 Knopman DS, Dekosky ST, Cummings JL, et al. Practice parameter: diagnosis of dementia (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56(9):1143-53. [pmid: 11342678].
84 Sperling RA, Aisen PS, Beckett LA, et al. Toward defining the preclinical stages of Alzheimer's disease: recommendations from the National Institute on Aging-Alzheimer's Association workgroups on diagnostic guidelines for Alzheimer's disease. Alzheimers Dement. 2011;7(3):280-92. [pmid: 21514248].
85 Jack CR Jr, Albert MS, Knopman DS, et al. Introduction to the recommendations from the National Institute on Aging-Alzheimer's Association workgroups on diagnostic guidelines for Alzheimer's disease. Alzheimers Dement. 2011;7(3):257-62. [pmid: 21514247].
86 Sonnen JA, Montine KS, Quinn JF, et al. Cerebrospinal fluid biomarkers in mild cognitive impairment and dementia. J Alzheimers Dis. 2010;19(1):301-9. [pmid: 20061646].
87 Soares HD, Potter WZ, Pickering E, et al. Plasma biomarkers associated with the apolipoprotein E genotype and Alzheimer disease. Arch Neurol. 2012;69(10):1310-7. [pmid: 22801723].
88 Doecke JD, Laws SM, Faux NG, et al. Blood-based protein biomarkers for diagnosis of Alzheimer disease. Arch Neurol. 2012;69(10):1318-25. [pmid: 22801742].
89 Debette S, Markus HS. The clinical importance of white matter hyperintensities on brain magnetic resonance imaging: systematic review and meta-analysis. BMJ. 2010;341(7767):1-9.
90 Treglia G, Cason E. Diagnostic performance of myocardial innervation imaging using MIBG scintigraphy in differential diagnosis between dementia with Lewy bodies and other dementias: a systematic review and a meta-analysis. J Neuroimaging. 2012;22(2):111-7. [pmid: 21091814].
91 Sexton CE, Kalu UG, Filippini N, et al. A meta-analysis of diffusion tensor imaging in mild cognitive impairment and Alzheimer's disease. Neurobiol Aging. 2011;32(12):2322.e5-18. [pmid: 20619504].
92 Shi F, Liu B, Zhou Y, et al. Hippocampal volume and asymmetry in mild cognitive impairment and Alzheimer's disease: meta-analyses of MRI studies. Hippocampus. 2009;19(11):1055-64. [pmid: 19309039].
93 Daviglus ML, Bell CC, Berrettini W, et al. NIH State-of-the-Science Conference Statement: preventing Alzheimer's disease and cognitive decline. NIH Consens State Sci Statements. 2010;27(4):1-30. [pmid: 20445638].
94 Qaseem A, Snow V, Cross JT Jr, et al. Current pharmacologic treatment of dementia: a clinical practice guideline from the American College of Physicians and the American Academy of Family Physicians. Ann Intern Med. 2008;148(5):370-8. [pmid: 18316755].
95 Institute of Medicine. Retooling for an Aging America: Building the Health Care Workforce. Washington, DC. National Academies Press. 2008.
96 Schultz R, Martire LM. Family caregiving of persons with dementia: prevalence, health effects, and support strategies. Am J Geriatr Psychiatry. 2004;12(3):240-9. [pmid: 15126224].
97 Brodaty H, Green A, Koschera A. Meta-analysis of psychosocial interventions for caregivers of people with dementia. J Am Geriatr Soc. 2003;51(5):657-64. [pmid: 12752841].
98 Olazaran J, Reisberg B, Clare L, et al. Nonpharmacological therapies in Alzheimer's disease: a systematic review of efficacy. Dement Geriatr Cogn Disord. 2010;30(2):161-78. [pmid: 20838046].
99 Baker LD, Barsness SM, Borson S, et al. Effects of growth hormone–releasing hormone on cognitive function in adults with mild cognitive impairment and healthy older adults: results of a controlled trial. Arch Neurol. 2012;69(11):1420-9. [pmid: 22869065].
100 Winblad B, Andreasen N, Minthon L, et al. Safety, tolerability, and antibody response of active Aβ immunotherapy with CAD106 in patients with Alzheimer's disease: randomised, double-blind, placebo-controlled, first-in-human study. Lancet Neurol. 2012;11:597-604. [pmid: 22677258].
101 Relkin N, Bettger L, Tsakanikas D, et al. Three-year follow up on the IVIG for Alzheimer's Phase II Study. Paper presented at: Alzheimer's Association International Conference. July 14-19, 2012. Vancouver, Canada.
102 Bradford A, Kunik ME, Schulz P, et al. Missed and delayed diagnosis of dementia in primary care: prevalence and contributing factors. Alzheimer Dis Assoc Disord. 2009;23(4):306-14. [pmid: 19568149].
103 Hort J, O'Brien JT, Gainotti G, et al. EFNS guidelines for the diagnosis and management of Alzheimer's disease. Eur J Neurol. 2010;17(10):1236-48. [pmid: 20831773].
104 Patient Protection and Affordable Care Act. Pub. L. No. 111-148. §2702, 124 Stat. 119, 318-319. 2010.
105 Centers for Medicare & Medicaid Services. CMS Manual System: Medicare Benefit Policy. Pub 100-02, Transmittal 138. Washington, DC. Department of Health and Human Services. 2011.
106 Cordell CB, Borson S, Boustani M, et al. Alzheimer's Association recommendations for operationalizing the detection of cognitive impairment during the Medicare Annual Wellness Visit in a primary care setting. Alzheimers Dement. 2013;9(2):141-50. [pmid: 23265826].
107 Roberts JS, Karlawish JH, Uhlmann WR, et al. Mild cognitive impairment in clinical care: a survey of American Academy of Neurology members. Neurology. 2010;75(5):425-31. [pmid: 20679636].
108 McGuinness B, O'Hare J, Craig D, et al. Statins for the treatment of dementia. Cochrane Database Sys Rev. 2010;(8):CD007514. [pmid: 20687089].
109 Rands G, Orrell M, Spector AE. Aspirin for vascular dementia. Cochrane Database Sys Rev. 2000;(4):CD001296. [pmid: 11034710].
110 Raina P, Santaguida P, Ismaila A, et al. Effectiveness of cholinesterase inhibitors and memantine for treating dementia: evidence review for a clinical practice guideline. Ann Intern Med. 2008;148(5):379-97. [pmid: 18316756].
111 Malouf R, Grimley EJ. The effect of vitamin B6 on cognition. Cochrane Database Syst Rev. 2003;(4):CD004393. [pmid: 14584010].
112 Malouf R, Areosa SA. Vitamin B12 for cognition. Cochrane Database Syst Rev. 2003;(3):CD004326. [pmid: 12918012].
113 Malouf R, Grimley EJ. Folic acid with or without vitamin B12 for the prevention and treatment of healthy elderly and demented people. Cochrane Database Sys Rev. 2008;(4):CD004514. [pmid: 18843658].
114 Balk E, Chung M, Raman G, et al. B-vitamins and Berries and Age-Related Neurodegenerative Disorders. AHRQ Publication No. 06-E008. Rockville, MD. Agency for Healthcare Research and Quality. 2006.
115 Jia X, McNeill G, Avenell A. Does taking vitamin, mineral and fatty acid supplements prevent cognitive decline? A systematic review of randomized controlled trials. J Hum Nutr Diet. 2008;21(4):317-36. [pmid: 18721399].
116 Issa AM, Mojica WA, Morton SC, et al. The efficacy of omega-3 fatty acids on cognitive function in aging and dementia: a systematic review. Dement Geriatr Cogn Disord. 2006;21(2):88-96. [pmid: 16340205].
117 van Uffelen JG, Chin AP, Hopman-Rock M, et al. The effects of exercise on cognition in older adults with and without cognitive decline: a systematic review. Clin J Sport Med. 2008;18(6):486-500. [pmid: 19001882].
118 Forbes D, Forbes S, Morgan DG, et al. Physical activity programs for persons with dementia. Cochrane Database Sys Rev. 2008;(3):CD006489. [pmid: 18646158].
119 Santaguida PS, Raina P, Booker L, et al. Pharmacological treatment of dementia. Evid Rep Technol Assess (Summ). 2004;(97):1-16. [pmid: 15279402].
120 Flicker C, Ferris SH, Reisberg B. Mild cognitive impairment in the elderly: predictors of dementia. Neurology. 1991;41(7):1006-9. [pmid: 2067629].
121 United Nations Development Programme. Human Development Index: 2012 Rankings. New York. United Nations Development Programme. 2013. Accessed at http://hdr.undp.org/en/statistics/ on 29 October 2013.
122 Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299(17):926-30. [pmid: 692598].
123 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061-6. [pmid: 10493205].
124 Whiting P, Rutjes AW, Reitsma JB, et al. Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. 2004;140(3):189-202. [pmid: 14757617].
125 Rutjes AW, Reitsma JB, Di Nisio M, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174(4):469-76. [pmid: 16477057].
126 Leeflang MM, Bossuyt PM, Irwig L. Diagnostic test accuracy may vary with prevalence: implications for evidence-based diagnosis. J Clin Epidemiol. 2009;62(1):5-12. [pmid: 18778913].
127 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm on 29 October 2013.
128 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
129 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
130 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analyses. Ottawa. Ottawa Hospital Research Institute. 2013. Accessed at http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp on 29 October 2013.
131 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
132 de Groot JA, Bossuyt PM, Reitsma JB, et al. Verification problems in diagnostic accuracy studies: consequences and solutions. BMJ. 2011;343:d4770. [pmid: 21810869].
133 Lee JY, Dong WL, Cho SJ, et al. Brief screening for mild cognitive impairment in elderly outpatient clinic: validation of the Korean version of the Montreal Cognitive Assessment. J Geriatr Psychiatry Neurol. 2008;21(2):104-10. [pmid: 18474719].
134 Tariq SH, Tumosa N, Chibnall JT, et al. Comparison of the Saint Louis University mental status examination and the Mini-Mental State Examination for detecting dementia and mild neurocognitive disorder—a pilot study. Am J Geriatr Psychiatry. 2006;14(11):900-10. [pmid: 17068312].
135 Ayalon L. The IQCODE versus a single-item informant measure to discriminate between cognitively intact individuals and individuals with dementia or cognitive impairment. J Geriatr Psychiatry Neurol. 2011;24(3):168-73. [pmid: 21856971].
136 Bradburn MJ, Deeks JJ, Altman DG. Metan-a command for meta-analysis in Stata. Sterne JA, editor. Meta-Analysis in Stata: An Updated Collection From the Stata Journal. College Station, TX. Stata Press. 1998.
137 Orrell M, Woods B, Spector A. Should we use individual cognitive stimulation therapy to improve cognitive function in people with dementia?. BMJ. 2012;344:e633. [pmid: 22337752].
138 Rosen WG, Mohs RC, Davis KL. A new rating scale for Alzheimer's disease. Am J Psychiatry. 1984;141(11):1356-64. [pmid: 6496779].
139 Doraiswamy PM, Kaiser L, Bieber F, et al. The Alzheimer's Disease Assessment Scale: evaluation of psychometric properties and patterns of cognitive decline in multicenter clinical trials of mild to moderate Alzheimer's disease. Alzheimer Dis Assoc Disord. 2001;15(4):174-83. [pmid: 11723368].
140 Clark CM, Sheppard L, Fillenbaum GG, et al. Variability in annual Mini-Mental State Examination score in patients with probable Alzheimer disease: a clinical perspective of data from the Consortium to Establish a Registry for Alzheimer's Disease. Arch Neurol. 1999;56(7):857-62. [pmid: 10404988].
141 Schneider LS, Olin JT, Doody RS, et al. Validity and reliability of the Alzheimer's Disease Cooperative Study-Clinical Global Impression of Change. Alzheimer Dis Assoc Disord. 1997;11(Suppl 2):S22-S32. [pmid: 9236949].
142 Katz S, Downs TD, Cash HR, et al. Progress in development of the index of ADL. Gerontologist. 1970;10(1):20-30. [pmid: 5420677].
143 Lawton MP, Brody EM. Assessment of older people: self-maintaining and instrumental activities of daily living. Gerontologist. 1969;9(3):179-86. [pmid: 5349366].
144 Borenstein M, Hedges LV, Higgins JP, et al. Introduction to Meta-Analysis. West Sussex, England. Wiley & Sons. 2009.
145 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. 2005;45(6):802-11. [pmid: 16326662].
146 Hepburn KW, Lewis M, Narayan S, et al. Partners in caregiving: a psychoeducation program affecting dementia family caregivers' distress and caregiving outlook. Clin Gerontol. 2005;29(1):53-69.
147 Cohen J. Statistical Power Analysis for the Behavioral Sciences. Hillsdale, NJ. Lawrence Earlbaum Associates. 1988.
148 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
149 Sterne JA, Harbord RM. Funnel plots in meta-analysis. Sterne JA, editor. Meta-Analysis in Stata: An Updated Collection From the Stata Journal. College Station, TX. Stata Press. 2009.
150 Steichen TJ. Nonparametric trim and fill analysis of publication bias in meta-analysis. Sterne JA, editor. Meta-Analysis in Stata: An Updated Collection From the Stata Journal. College Station, TX. Stata Press. 2009.
151 Roman GC, Sachdev P, Royall DR, et al. Vascular cognitive disorder: a new diagnostic category updating vascular cognitive impairment and vascular dementia. J Neurol Sci. 2004;226(1-2):81-7. [pmid: 15537526].
152 Kaufer DI, Williams CS, Braaten AJ, et al. Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. 2008;9(8):586-93. [pmid: 19083293].
153 Scharre DW, Chang SI, Murden RA, et al. Self-Administered Gerocognitive Examination (SAGE): a brief cognitive assessment instrument for mild cognitive impairment (MCI) and early dementia. Alzheimer Dis Assoc Disord. 2010;24(1):64-71. [pmid: 20220323].
154 Brodaty H, Pond D, Kemp NM, et al. The GPCOG: a new screening test for dementia designed for general practice. J Am Geriatr Soc. 2002;50(3):530-4. [pmid: 11943052].
155 Erkinjuntti T, Sulkava R, Wikstrom J, et al. Short Portable Mental Status Questionnaire as a screening test for dementia and delirium among the elderly. J Am Geriatr Soc. 1987;35(5):412-6. [pmid: 3571790].
156 Juva K, Makela M, Erkinjuntti T, et al. Functional assessment scales in detecting dementia. Age Ageing. 1997;26(5):393-400. [pmid: 9351484].
157 Gagnon M, Letenneur L, Dartigues JF, et al. Validity of the Mini-Mental State Examination as a screening instrument for cognitive impairment and dementia in French elderly community residents. Neuroepidemiology. 1990;9(3):143-50. [pmid: 2402325].
158 Grut M, Fratiglioni L, Viitanen M, et al. Accuracy of the Mini-Mental Status Examination as a screening test for dementia in a Swedish elderly population. Acta Neurol Scand. 1993;87(4):312-7. [pmid: 8503262].
159 McDowell I, Kristjansson B, Hill GB, et al. Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini-Mental State Exam (3MS) compared. J Clin Epidemiol. 1997;50(4):377-83. [pmid: 9179095].
160 Cruz-Orduna I, Bellon JM, Torrero P, et al. Detecting MCI and dementia in primary care: efficiency of the MMS, the FAQ and the IQCODE. Fam Pract. 2012;29(4):401-6. [pmid: 22121012].
161 Fuchs A, Wiese B, Altiner A, et al. Cued recall and other cognitive tasks to facilitate dementia recognition in primary care. J Am Geriatr Soc. 2012;60(1):130-5. [pmid: 22150245].
162 Del Ser T, Sanchez-Sanchez F, Garcia de Yebenes MJ, et al. Validation of the seven-minute screen neurocognitive battery for the diagnosis of dementia in a Spanish population-based sample. Dement Geriatr Cogn Disord. 2006;22(5-6):454-64. [pmid: 16988506].
163 Jeong SK, Cho KH, Kim JM. The usefulness of the Korean version of modified Mini-Mental State Examination (K-mMMSE) for dementia screening in community dwelling elderly people. BMC Public Health. 2004;4:31. [pmid: 15283869].
164 Lam LC, Tam CW, Lui VW, et al. Screening of mild cognitive impairment in Chinese older adults—a multistage validation of the Chinese abbreviated mild cognitive impairment test. Neuroepidemiology. 2008;30(1):6-12. [pmid: 18204291].
165 Morales JM, Bermejo F, Romero M, et al. Screening of dementia in community-dwelling elderly through informant report. Int J Geriatr Psychiatry. 1997;12(8):808-16. [pmid: 9283925].
166 Hyman BT, Phelps CH, Beach TG, et al. National Institute on Aging-Alzheimer's Association guidelines for the neuropathologic assessment of Alzheimer's disease. Alzheimers Dement. 2012;8(1):1-13. [pmid: 22265587].
167 Ball LJ, Ogden A, Mandi D, et al. The validation of a mailed health survey for screening of dementia of the Alzheimer's type. J Am Geriatr Soc. 2001;49(6):798-802. [pmid: 11454121].
168 Grober E, Hall C, McGinn M, et al. Neuropsychological strategies for detecting early dementia. J Int Neuropsychol Soc. 2008;14(1):130-42. [pmid: 18078539].
169 Kirby M, Denihan A, Bruce I, et al. The clock drawing test in primary care: sensitivity in dementia detection and specificity against normal and depressed elderly. Int J Geriatr Psychiatry. 2001;16(10):935-40. [pmid: 11607936].
170 Lavery LL, Lu SY, Chang CC, et al. Cognitive assessment of older primary care patients with and without memory complaints. J Gen Intern Med. 2007;22(7):949-54. [pmid: 17453265].
171 Wolf-Klein GP, Silverstone FA, Levy AP, et al. Screening for Alzheimer's disease by clock drawing. J Am Geriatr Soc. 1989;37(8):730-4. [pmid: 2754158].
172 Borson S, Scanlan JM, Watanabe J, et al. Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. 2006;21(4):349-55. [pmid: 16534774].
173 Holsinger T, Plassman BL, Stechuchak KM, et al. Screening for cognitive impairment: comparing the performance of four instruments in primary care. J Am Geriatr Soc. 2012;60(6):1027-36. [pmid: 22646750].
174 Buschke H, Kuslansky G, Katz M, et al. Screening for dementia with the Memory Impairment Screen. Neurology. 1999;52(2):231-8. [pmid: 9932936].
175 Kuslansky G, Buschke H, Katz M, et al. Screening for Alzheimer's disease: the Memory Impairment Screen versus the conventional three-word memory test. J Am Geriatr Soc. 2002;50(6):1086-91. [pmid: 12110070].
176 Lipton RB, Katz MJ, Kuslansky G, et al. Screening for dementia by telephone using the Memory Impairment Screen. J Am Geriatr Soc. 2003;51(10):1382-90. [pmid: 14511157].
177 Fillenbaum G, Heyman A, Williams K, et al. Sensitivity and specificity of standardized screens of cognitive impairment and dementia among elderly black and white community residents. J Clin Epidemiol. 1990;43(7):651-60. [pmid: 2370572].
178 Hooijer C, Dinkgreve M, Jonker C, et al. Short screening tests for dementia in the elderly population, I: a comparison between AMTS, MMSE, MSQ and SPMSQ. Int J Geriatr Psychiatry. 1992;7(8):559-71.
179 Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. 1998;13(6):368-80. [pmid: 9658272].
180 Hodkinson HM. Evaluation of a mental test score for assessment of mental impairment in the elderly. Age Ageing. 1972;1(4):233-8. [pmid: 4669880].
181 Rait G, Morley M, Burns A, et al. Screening for cognitive impairment in older African-Caribbeans. Psychol Med. 2000;30(4):957-63. [pmid: 11037103].
182 Rait G, Burns A, Baldwin R, et al. Validating screening instruments for cognitive impairment in older South Asians in the United Kingdom. Int J Geriatr Psychiatry. 2000;15(1):54-62. [pmid: 10637405].
183 Solomon PR, Brush M, Calvo V, et al. Identifying dementia in the primary care practice. Int Psychogeriatr. 2000;12(4):483-93. [pmid: 11263715].
184 Manly JJ, Schupf N, Stern Y, et al. Telephone-based identification of mild cognitive impairment and dementia in a multicultural cohort. Arch Neurol. 2011;68(5):607-14. [pmid: 21555635].
185 Callahan CM, Unverzagt FW, Hui SL, et al. Six-item screener to identify cognitive impairment among potential subjects for clinical research. Med Care. 2002;40(9):771-81. [pmid: 12218768].
186 Cullen B, Fahy S, Cunningham CJ, et al. Screening for dementia in an Irish community sample using MMSE: a comparison of norm-adjusted versus fixed cut-points. Int J Geriatr Psychiatry. 2005;20(4):371-6. [pmid: 15799072].
187 Fong TG, Jones RN, Rudolph JL, et al. Development and validation of a brief cognitive assessment tool: the sweet 16. Arch Intern Med. 2011;171(5):432-7. [pmid: 21059967].
188 Jorm AF, Broe GA, Creasy H, et al. Further data on the validity of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE). Int J Geriatr Psychiatry. 1996;11(2):131-9.
189 Kahle-Wrobleski K, Corrada MM, Li B, et al. Sensitivity and specificity of the Mini-Mental State Examination for identifying dementia in the oldest-old: the 90+ study. J Am Geriatr Soc. 2007;55(2):284-9. [pmid: 17302668].
190 Kay DW, Henderson AS, Scott R, et al. Dementia and depression among the elderly living in the Hobart community: the effect of the diagnostic criteria on the prevalence rates. Psychol Med. 1985;15(4):771-88. [pmid: 4080881].
191 Reischies FM, Geiselmann B. Age-related cognitive decline and vision impairment affecting the detection of dementia syndrome in old age. Br J Psychiatry. 1997;171:449-51. [pmid: 9463604].
192 Waite LM, Broe GA, Casey B, et al. Screening for dementia using an informant interview. Aging Neuropsychol Cogn. 1998;5(3):194-202.
193 Mungas D, Marshall SC, Weldon M, et al. Age and education correction of Mini-Mental State Examination for English and Spanish-speaking elderly. Neurology. 1996;46(3):700-6. [pmid: 8618670].
194 Jorm AF. The Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE): a review. Int Psychogeriatr. 2004;16(3):275-93. [pmid: 15559753].
195 Tokuhara KG, Valcour VG, Masaki KH, et al. Utility of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) for dementia in a Japanese-American population. Hawaii Med J. 2006;65(3):72-5. [pmid: 16724448].
196 Ehreke L, Luck T, Luppa M, et al. Clock drawing test—screening utility for mild cognitive impairment according to different scoring systems: results of the Leipzig Longitudinal Study of the Aged (LEILA 75+). Int Psychogeriatr. 2011;23(10):1592-601. [pmid: 21813037].
197 Li M, Ng TP, Kua EH, et al. Brief informant screening test for mild cognitive impairment and early Alzheimer's disease. Dement Geriatr Cogn Disord. 2006;21(5-6):392-402. [pmid: 16645272].
198 Ehreke L, Luppa M, Luck T, et al. Is the clock drawing test appropriate for screening for mild cognitive impairment? Results of the German study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Dement Geriatr Cogn Disord. 2009;28(4):365-72. [pmid: 19887799].
199 Lee KS, Kim EA, Hong CH, et al. Clock drawing test in mild cognitive impairment: quantitative analysis of four scoring methods and qualitative analysis. Dement Geriatr Cogn Disord. 2008;26(6):483-9. [pmid: 18987468].
200 Saxton J, Morrow L, Eschman A, et al. Computer assessment of mild cognitive impairment. Postgrad Med. 2009;121(2):177-85. [pmid: 19332976].
201 Markwick A, Zamboni G, de Jager CA. Profiles of cognitive subtest impairment in the Montreal Cognitive Assessment (MoCA) in a research cohort with normal Mini-Mental State Examination (MMSE) scores. J Clin Exp Neuropsychol. 2012;34(7):750-7. [pmid: 22468719].
202 Donnelly K, Donnelly JP, Cory E. Primary care screening for cognitive impairment in elderly veterans. Am J Alzheimers Dis Other Demen. 2008;23(3):218-26. [pmid: 18375531].
203 Vercambre MN, Cuvelier H, Gayon YA, et al. Validation study of a French version of the modified Telephone Interview for Cognitive Status (F-TICS-m) in elderly women. Int J Geriatr Psychiatry. 2010;25(11):1142-9. [pmid: 20054838].
204 Cook SE, Marsiske M, McCoy KJ. The use of the Modified Telephone Interview for Cognitive Status (TICS-M) in the detection of amnestic mild cognitive impairment. J Geriatr Psychiatry Neurol. 2009;22(2):103-9. [pmid: 19417219].
205 Rideaux T, Beaudreau SA, Fernandez S, et al. Utility of the abbreviated Fuld Object Memory Evaluation and MMSE for detection of dementia and cognitive impairment not dementia in diverse ethnic groups. J Alzheimers Dis. 2012;31(2):371-86. [pmid: 22555374].
206 Boustani M, Callahan CM, Unverzagt FW, et al. Implementing a screening and diagnosis program for dementia in primary care. J Gen Intern Med. 2005;20(7):572-7. [pmid: 16050849].
207 Boustani M, Perkins AJ, Fox C, et al. Who refuses the diagnostic assessment for dementia in primary care?. Int J Geriatr Psychiatry. 2006;21(6):556-63. [pmid: 16783796].
208 Doody RS, Ferris SH, Salloway S, et al. Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. 2009;72(18):1555-61. [pmid: 19176895].
209 Koontz J, Baskys A. Effects of galantamine on working memory and global functioning in patients with mild cognitive impairment: a double-blind placebo-controlled study. Am J Alzheimers Dis Other Demen. 2005;20(5):295-302. [pmid: 16273995].
210 Petersen RC, Thomas RG, Grundman M, et al. Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. 2005;352(23):2379-88. [pmid: 15829527].
211 Salloway S, Ferris S, Kluger A, et al. Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. 2004;63(4):651-7. [pmid: 15326237].
212 Suzuki T, Shimada H, Makizako H, et al. Effects of multicomponent exercise on cognitive function in WMS-LM older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. 2012;12(1):128. [pmid: 23113898].
213 Lautenschlager NT, Cox KL, Flicker L, et al. Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial. JAMA. 2008;300(9):1027-37. [pmid: 18768414].
214 Mori E, Ikeda M, Kosaka K. Donepezil for dementia with Lewy bodies: a randomized, placebo-controlled trial. Ann Neurol. 2012;72(1):41-52. [pmid: 22829268].
215 Requena C, Lopez Ibor MI, Maestu F, et al. Effects of cholinergic drugs and cognitive training on dementia. Dement Geriatr Cogn Disord. 2004;18(1):50-4. [pmid: 15084794].
216 Auchus AP, Brashear HR, Salloway S, et al. Galantamine treatment of vascular dementia: a randomized trial. Neurology. 2007;69(5):448-58. [pmid: 17664404].
217 Rockwood K, Fay S, Song X, et al. Attainment of treatment goals by people with Alzheimer's disease receiving galantamine: a randomized controlled trial. CMAJ. 2006;174(8):1099-105. [pmid: 16554498].
218 Ballard C, Sauter M, Scheltens P, et al. Efficacy, safety and tolerability of rivastigmine capsules in patients with probable vascular dementia: the VantagE study. Curr Med Res Opin. 2008;24(9):2561-74. [pmid: 18674411].
219 Feldman HH, Lane R, Study 304 Group. Rivastigmine: a placebo controlled trial of twice daily and three times daily regimens in patients with Alzheimer's disease. J Neurol Neurosurg Psychiatry. 2007;78(10):1056-63. [pmid: 17353259].
220 Mok V, Wong A, Ho S, et al. Rivastigmine in Chinese patients with subcortical vascular dementia. Neuropsychiatr Dis Treat. 2007;3(6):943-8. [pmid: 19300631].
221 Winblad B, Cummings J, Andreasen N, et al. A six-month double-blind, randomized, placebo-controlled study of a transdermal patch in Alzheimer's disease—rivastigmine patch versus capsule. Int J Geriatr Psychiatry. 2007;22(5):456-67. [pmid: 17380489].
222 Saxton J, Hofbauer RK, Woodward M, et al. Memantine and functional communication in Alzheimer's disease: results of a 12-week, international, randomized clinical trial. J Alzheimers Dis. 2012;28(1):109-18. [pmid: 21955815].
223 Wilkinson D, Fox NC, Barkhof F, et al. Memantine and brain atrophy in Alzheimer's disease: a 1-year randomized controlled trial. J Alzheimers Dis. 2012;29(2):459-69. [pmid: 22269160].
224 Bakchine S, Loft H. Memantine treatment in patients with mild to moderate Alzheimer's disease: results of a randomised, double-blind, placebo-controlled 6-month study. J Alzheimers Dis. 2008;13(1):97-107. [pmid: 18334761].
225 Ferris S, Schneider L, Farmer M, et al. A double-blind, placebo-controlled trial of memantine in age-associated memory impairment (memantine in AAMI). Int J Geriatr Psychiatry. 2007;22(5):448-55. [pmid: 17117395].
226 Porsteinsson AP, Grossberg GT, Mintzer J, et al. Memantine treatment in patients with mild to moderate Alzheimer's disease already receiving a cholinesterase inhibitor: a randomized, double-blind, placebo-controlled trial. Curr Alzheimer Res. 2008;5(1):83-9. [pmid: 18288936].
227 Winblad B, Poritis N. Memantine in severe dementia: results of the 9M-Best Study (benefit and efficacy in Severely demented patients during treatment with memantine). Int J Geriatr Psychiatry. 1999;14(2):135-46. [pmid: 10885864].
228 Winblad B, Kilander L, Eriksson S, et al. Donepezil in patients with severe Alzheimer's disease: double-blind, parallel-group, placebo-controlled study. Lancet. 2006;367(9516):1057-65. [pmid: 16581404].
229 Emre M, Aarsland D, Albanese A, et al. Rivastigmine for dementia associated with Parkinson's disease. N Engl J Med. 2004;351(24):2509-18. [pmid: 15590953].
230 Leroi I, Brandt J, Reich SG, et al. Randomized placebo-controlled trial of donepezil in cognitive impairment in Parkinson's disease. Int J Geriatr Psychiatry. 2004;19(1):1-8. [pmid: 14716693].
231 Prasher VP, Huxley A, Haque MS, et al. A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Down syndrome and Alzheimer's disease—pilot study. Int J Geriatr Psychiatry. 2002;17(3):270-8. [pmid: 11921156].
232 Black S, Roman GC, Geldmacher DS, et al. Efficacy and tolerability of donepezil in vascular dementia: positive results of a 24-week, multicenter, international, randomized, placebo-controlled clinical trial. Stroke. 2003;34(10):2323-30. [pmid: 12970516].
233 Wilkinson D, Doody R, Helme R, et al. Donepezil in vascular dementia: a randomized, placebo-controlled study. Neurology. 2003;61(4):479-86. [pmid: 12939421].
234 Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease: results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10(3):237-44. [pmid: 10325453].
235 dos Santos Moraes W, Poyares DR, Guilleminault C, et al. The effect of donepezil on sleep and REM sleep EEG in patients with Alzheimer disease: a double-blind placebo-controlled study. Sleep. 2006;29(2):199-205. [pmid: 16494088].
236 Feldman H, Gauthier S, Hecker J, et al. A 24-week, randomized, double-blind study of donepezil in moderate to severe Alzheimer's disease. Neurology. 2001;57(4):613-20. [pmid: 11524468].
237 Holmes C, Wilkinson D, Dean C, et al. The efficacy of donepezil in the treatment of neuropsychiatric symptoms in Alzheimer disease. Neurology. 2004;63(2):214-9. [pmid: 15277611].
238 Kemp PM, Holmes C, Hoffmann S, et al. A randomised placebo controlled study to assess the effects of cholinergic treatment on muscarinic receptors in Alzheimer's disease. J Neurol Neurosurg Psychiatry. 2003;74(11):1567-70. [pmid: 14617718].
239 Krishnan KR, Charles HC, Doraiswamy PM, et al. Randomized, placebo-controlled trial of the effects of donepezil on neuronal markers and hippocampal volumes in Alzheimer's disease. Am J Psychiatry. 2003;160(11):2003-11. [pmid: 14594748].
240 Mazza M, Capuano A, Bria P, et al. Ginkgo biloba and donepezil: a comparison in the treatment of Alzheimer's dementia in a randomized placebo-controlled double-blind study. Eur J Neurol. 2006;13(9):981-5. [pmid: 16930364].
241 Rogers SL, Friedhoff LT. The efficacy and safety of donepezil in patients with Alzheimer's disease: results of a US multicentre, randomized, double-blind, placebo-controlled trial. Dementia. 1996;7(6):293-303. [pmid: 8915035].
242 Rogers SL, Doody RS, Mohs RC, et al. Donepezil improves cognition and global function in Alzheimer disease: a 15-week, double-blind, placebo-controlled study. Arch Intern Med. 1998;158(9):1021-31. [pmid: 9588436].
243 Rogers SL, Farlow MR, Doody RS, et al. A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Alzheimer's disease. Neurology. 1998;50(1):136-45. [pmid: 9443470].
244 Seltzer B, Zolnouni P, Nunez M, et al. Efficacy of donepezil in early-stage Alzheimer disease: a randomized placebo-controlled trial. Arch Neurol. 2004;61(12):1852-6. [pmid: 15596605].
245 Tariot PN, Cummings JL, Katz IR, et al. A randomized, double-blind, placebo-controlled study of the efficacy and safety of donepezil in patients with Alzheimer's disease in the nursing home setting. J Telemed Telecare. 2001;49(12):1590-9. [pmid: 11843990].
246 Thomas A, Iacono D, Bonanni L, et al. Donepezil, rivastigmine, and vitamin E in Alzheimer disease: a combined P300 event-related potentials/neuropsychologic evaluation over 6 months. Clin Neuropharmacol. 2001;24(1):31-42. [pmid: 11290880].
247 Tune L, Tiseo PJ, Ieni J, et al. Donepezil HCl (E2020) maintains functional brain activity in patients with Alzheimer disease: results of a 24-week, double-blind, placebo-controlled study. Am J Geriatr Psychiatry. 2003;11(2):169-77. [pmid: 12611746].
248 Mohs RC, Doody RS, Morris JC, et al. A 1-year, placebo-controlled preservation of function survival study of donepezil in AD patients. Neurology. 2001;57(3):481-8. [pmid: 11502917].
249 Winblad B, Engedal K, Soininen H, et al. A 1-year, randomized, placebo-controlled study of donepezil in patients with mild to moderate AD. Neurology. 2001;57(3):489-95. [pmid: 11502918].
250 Courtney C, Farrell D, Gray R, et al. Long-term donepezil treatment in 565 patients with Alzheimer's disease (AD2000): randomised double-blind trial. Lancet. 2004;363(9427):2105-15. [pmid: 15220031].
251 Bullock R, Bergman H, Touchon J, et al. Effect of age on response to rivastigmine or donepezil in patients with Alzheimer's disease. Curr Med Res Opin. 2006;22(3):483-94. [pmid: 16574032].
252 Wilcock GK, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer's disease: multicentre randomised controlled trial. BMJ. 2000;321(7274):1445-9. [pmid: 11110737].
253 Wilkinson D, Murray J. Galantamine: a randomized, double-blind, dose comparison in patients with Alzheimer's disease. Int J Geriatr Psychiatry. 2001;16(9):852-7. [pmid: 11571763].
254 Wilkinson DG, Howe I. Switching from donepezil to galantamine: a double-blind study of two wash-out periods. Int J Geriatr Psychiatry. 2005;20(5):489-91. [pmid: 15852437].
255 Brodaty H, Corey-Bloom J, Potocnik FC, et al. Galantamine prolonged-release formulation in the treatment of mild to moderate Alzheimer's disease. Dement Geriatr Cogn Disord. 2005;20(2-3):120-32. [pmid: 15990426].
256 Erkinjuntti T, Kurz A, Gauthier S, et al. Efficacy of galantamine in probable vascular dementia and Alzheimer's disease combined with cerebrovascular disease: a randomised trial. Lancet. 2002;359(9314):1283-90. [pmid: 11965273].
257 Raskind MA, Sadowsky CH, Sigmund WR, et al. Effect of tacrine on language, praxis, and noncognitive behavioral problems in Alzheimer disease. Arch Neurol. 1997;54(7):836-40. [pmid: 9236571].
258 Rockwood K, Mintzer J, Truyen L, et al. Effects of a flexible galantamine dose in Alzheimer's disease: a randomised, controlled trial. J Neurol Neurosurg Psychiatry. 2001;71(5):589-95. [pmid: 11606667].
259 Tariot PN, Solomon PR, Morris JC, et al. A 5-month, randomized, placebo-controlled trial of galantamine in AD. Neurology. 2000;54(12):2269-76. [pmid: 10881251].
260 Corey-Bloom J, Anand R, Veach J. A randomized trial evaluating the efficacy and safety of ENA 713 (rivastigmine tartrate), a new acetylcholinesterase inhibitor, in patients with mild to moderately severe Alzheimer's disease. Int J Geriatr Psychopharmacol. 1998;1(2):55-65.
261 Forette F, Anand R, Gharabawi G. A phase II study in patients with Alzheimer's disease to assess the preliminary efficacy and maximum tolerated dose of rivastigmine (Exelon). Eur J Neurol. 1999;6(4):423-9. [pmid: 10362894].
262 Karaman Y, Erdogan F, Koseoglu E, et al. A 12-month study of the efficacy of rivastigmine in patients with advanced moderate Alzheimer's disease. Dement Geriatr Cogn Disord. 2005;19(1):51-6. [pmid: 15383747].
263 Rosler M, Anand R, Cicin-Sain A, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease: international randomised controlled trial. BMJ. 1999;318(7184):633-8. [pmid: 10066203].
264 Potkin SG, Anand R, Fleming K, et al. Brain metabolic and clinical effects of rivastigmine in Alzheimer's disease. Int J Neuropsychopharmacol. 2001;4(3):223-30. [pmid: 11602028].
265 Knapp MJ, Knopman DS, Solomon PR, et al. A 30-week randomized controlled trial of high-dose tacrine in patients with Alzheimer's disease. JAMA. 1994;271(13):985-91. [pmid: 8139083].
266 Maltby N, Broe GA, Creasey H, et al. Efficacy of tacrine and lecithin in mild to moderate Alzheimer's disease: double blind trial. BMJ. 1994;308(6933):879-83. [pmid: 8173365].
267 Prentice N, Van Beck M, Dougall NJ, et al. A double-blind, placebo-controlled study of tacrine in patients with Alzheimer's disease using SPET. J Psychopharmacol. 1996;10(3):175-81. [pmid: 22302942].
268 Weinstein HC, Teunisse S, Van Gool WA. Tetrahydroaminoacridine and lecithin in the treatment of Alzheimer's disease: effect on cognition, functioning in daily life, behavioural disturbances and burden experienced by the carers. J Neurol. 1991;238(1):34-8. [pmid: 2030370].
269 Wong WJ, Liu HC, Fuh JL, et al. A double-blind, placebo-controlled study of tacrine in Chinese patients with Alzheimer's disease. Dement Geriatr Cogn Disord. 1999;10(4):289-94. [pmid: 10364647].
270 Wood PC, Castleden CM. A double-blind, placebo controlled, multicentre study of tacrine for Alzheimer's disease. Int J Geriatr Psychiatry. 1994;9(8):649-54.
271 Orgogozo JM, Rigaud AS, Stoffler A, et al. Efficacy and safety of memantine in patients with mild to moderate vascular dementia: a randomized, placebo-controlled trial (MMM 300). Stroke. 2002;33(7):1834-9. [pmid: 12105362].
272 Peskind ER, Potkin SG, Pomara N, et al. Memantine treatment in mild to moderate Alzheimer disease: a 24-week randomized, controlled trial. Am J Geriatr Psychiatry. 2006;14(8):704-15. [pmid: 16861375].
273 Reisberg B, Doody R, Stoffler A, et al. Memantine in moderate-to-severe Alzheimer's disease. N Engl J Med. 2003;348(14):1333-41. [pmid: 12672860].
274 Tariot PN, Farlow MR, Grossberg GT, et al. Memantine treatment in patients with moderate to severe Alzheimer disease already receiving donepezil: a randomized controlled trial. JAMA. 2004;291(3):317-24. [pmid: 14734594].
275 Wilcock G, Mobius HJ, Stoffler A. A double-blind, placebo-controlled multicentre study of memantine in mild to moderate vascular dementia (MMM500). Int Clin Psychopharmacol. 2002;17(6):297-305. [pmid: 12409683].
276 Lu PH, Edland SD, Teng E, et al. Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. 2009;72(24):2115-21. [pmid: 19528519].
277 Doody RS, Ferris S, Salloway S, et al. Safety and tolerability of donepezil in mild cognitive impairment: open-label extension study. Am J Alzheimers Dis Other Demen. 2010;25(2):155-9. [pmid: 19949165].
278 Burns A, Gauthier S, Perdomo C. Efficacy and safety of donepezil over 3 years: an open-label, multicentre study in patients with Alzheimer's disease. Int J Geriatr Psychiatry. 2007;22(8):806-12. [pmid: 17199235].
279 Wilkinson D, Roman G, Salloway S, et al. The long-term efficacy and tolerability of donepezil in patients with vascular dementia. Int J Geriatr Psychiatry. 2010;25(3):305-13. [pmid: 19623601].
280 Cummings JL, Farlow MR, Meng X, et al. Rivastigmine transdermal patch skin tolerability: results of a 1-year clinical trial in patients with mild-to-moderate Alzheimer's disease. Clin Drug Invest. 2010;30(1):41-9. [pmid: 19995097].
281 Ott BR, Blake LM, Kagan E, et al. Open label, multicenter, 28-week extension study of the safety and tolerability of memantine in patients with mild to moderate Alzheimer's disease. J Neurol. 2007;254(3):351-8. [pmid: 17345042].
282 Erkinjuntti T, Kurz A, Small GW, et al. An open-label extension trial of galantamine in patients with probable vascular dementia and mixed dementia. Clin Ther. 2003;25(6):1765-82. [pmid: 12860497].
283 Small G, Erkinjuntti T, Kurz A, et al. Galantamine in the treatment of cognitive decline in patients with vascular dementia or Alzheimer's disease with cerebrovascular disease. CNS Drugs. 2003;17(12):905-14. [pmid: 12962529].
284 Kurz AF, Erkinjuntti T, Small GW, et al. Long-term safety and cognitive effects of galantamine in the treatment of probable vascular dementia or Alzheimer's disease with cerebrovascular disease. Eur J Neurol. 2003;10(6):633-40. [pmid: 14641507].
285 Wimo A, Winblad B, Shah SN, et al. Impact of donepezil treatment for Alzheimer's disease on caregiver time. Curr Med Res Opin. 2004;20(8):1221-5. [pmid: 15324524].
286 Boada-Rovira M, Brodaty H, Cras P, et al. Efficacy and safety of donepezil in patients with Alzheimer's disease: results of a global, multinational, clinical experience study. Drugs Aging. 2004;21(1):43-53. [pmid: 14715043].
287 Relkin NR, Reichman WE, Orazem J, et al. A large, community-based, open-label trial of donepezil in the treatment of Alzheimer's disease. Dement Geriatr Cogn Disord. 2003;16(1):15-24. [pmid: 12714795].
288 Babai S, Auriche P, Le-Louet H. Comparison of adverse drug reactions with donepezil versus memantine: analysis of the French Pharmacovigilance Database. Therapie. 2010;65(3):255-9. [pmid: 20699079].
289 Dunn NR, Pearce GL, Shakir SA. Adverse effects associated with the use of donepezil in general practice in England. J Psychopharmacol (Oxf). 2000;14(4):406-8. [pmid: 11198060].
290 Hernandez RK, Farwell W, Cantor MD, et al. Cholinesterase inhibitors and incidence of bradycardia in patients with dementia in the Veterans Affairs New England Healthcare System. J Telemed Telecare. 2009;57(11):1997-2003. [pmid: 19793162].
291 Park-Wyllie LY, Mamdani MM, Li P, et al. Cholinesterase inhibitors and hospitalization for bradycardia: a population-based study. PLoS Med. 2009;6(9):e1000157. [pmid: 19787032].
292 Forstl H, Stamouli SS, Janetzky W, et al. Memantine in everyday clinical practice: a comparison of studies in Germany and Greece. Dement Geriatr Cogn Disord. 2011;32(4):267-72. [pmid: 22237255].
293 Vidal JS, Lacombe JM, Dartigues JF, et al. Memantine therapy for Alzheimer disease in real-world practice: an observational study in a large representative sample of French patients. Alzheimer Dis Assoc Disord. 2008;22(2):125-30. [pmid: 18525283].
294 Froelich L, Andreasen N, Tsolaki M, et al. Long-term treatment of patients with Alzheimer's disease in primary and secondary care: results from an international survey. Curr Med Res Opin. 2009;25(12):3059-68. [pmid: 19852697].
295 Raschetti R, Maggini M, Sorrentino GC, et al. A cohort study of effectiveness of acetylcholinesterase inhibitors in Alzheimer's disease. Eur J Clin Pharmacol. 2005;61(5-6):361-8. [pmid: 15912389].
296 Pariente A, Sanctussy DJ, Miremont-Salame G, et al. Factors associated with serious adverse reactions to cholinesterase inhibitors: a study of spontaneous reporting. CNS Drugs. 2010;24(1):55-63. [pmid: 20030419].
297 Stephenson A, Seitz DP, Fischer HD, et al. Cholinesterase inhibitors and adverse pulmonary events in older people with chronic obstructive pulmonary disease and concomitant dementia: a population-based, cohort study. Drugs Aging. 2012;29(3):213-23. [pmid: 22332932].
298 Gill SS, Anderson GM, Fischer HD, et al. Syncope and its consequences in patients with dementia receiving cholinesterase inhibitors: a population-based cohort study. Arch Intern Med. 2009;169(9):867-73. [pmid: 19433698].
299 Fosbol EL, Peterson ED, Holm E, et al. Comparative cardiovascular safety of dementia medications: a cross-national study. J Am Geriatr Soc. 2012;60(12):2283-9. [pmid: 23176182].
300 Clarke R, Harrison G, Richards S, et al. Effect of vitamins and aspirin on markers of platelet activation, oxidative stress and homocysteine in people at high risk of dementia. J Intern Med. 2003;254(1):67-75. [pmid: 12823643].
301 de Jager CA, Oulhaj A, Jacoby R, et al. Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. 2012;27(6):592-600. [pmid: 21780182].
302 Sinn N, Milte CM, Street SJ, et al. Effects of ω-3 fatty acids, EPA v. DHA, on depressive symptoms, quality of life, memory and executive function in older adults with mild cognitive impairment: a 6-month randomised controlled trial. Br J Nutr. 2012;107(11):1682-93. [pmid: 21929835].
303 van Uffelen JG, Chinapaw MJ, van Mechelen W, et al. Walking or vitamin B for cognition in older adults with mild cognitive impairment? A randomised controlled trial. Br J Sports Med. 2008;42(5):344-51. [pmid: 18308888].
304 Yurko-Mauro K, McCarthy D, Rom D, et al. Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimers Dement. 2010;6(6):456-64. [pmid: 20434961].
305 AD2000 Collaborative Group, Bentham P, Gray R, et al. Aspirin in Alzheimer's disease (AD2000): a randomised open-label trial. Lancet Neurology. 2008;7(1):41-9. [pmid: 18068522].
306 Feldman HH, Doody RS, Kivipelto M, et al. Randomized controlled trial of atorvastatin in mild to moderate Alzheimer disease: LEADe. Neurology. 2010;74(12):956-64. [pmid: 20200346].
307 Sano M, Bell KL, Galasko D, et al. A randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. 2011;77(6):556-63. [pmid: 21795660].
308 Simons M, Schwarzler F, Lutjohann D, et al. Treatment with simvastatin in normocholesterolemic patients with Alzheimer's disease: a 26-week randomized, placebo-controlled, double-blind trial. Ann Neurol. 2002;52(3):346-50. [pmid: 12205648].
309 Sparks DL, Sabbagh MN, Connor DJ, et al. Atorvastatin for the treatment of mild to moderate Alzheimer disease: preliminary results. Arch Neurol. 2005;62(5):753-7. [pmid: 15883262].
310 Pasqualetti P, Bonomini C, Dal Forno G, et al. A randomized controlled study on effects of ibuprofen on cognitive progression of Alzheimer's disease. Aging Clin Exp Res. 2009;21(2):102-10. [pmid: 19448381].
311 Aisen PS, Schafer KA, Grundman M, et al. Effects of rofecoxib or naproxen vs placebo on Alzheimer disease progression: a randomized controlled trial. JAMA. 2003;289(21):2819-26. [pmid: 12783912].
312 de Jong D, Jansen R, Hoefnagels W, et al. No effect of one-year treatment with indomethacin on Alzheimer's disease progression: a randomized controlled trial. PLoS One. 2008;3(1):e1475. [pmid: 18213383].
313 Soininen H, West C, Robbins J, et al. Long-term efficacy and safety of celecoxib in Alzheimer's disease. Dement Geriatr Cogn Dis. 2007;23(1):8-21. [pmid: 17068392].
314 Wang PN, Liao SQ, Liu RS, et al. Effects of estrogen on cognition, mood, and cerebral blood flow in AD: a controlled study. Neurology. 2000;54(11):2061-6. [pmid: 10851363].
315 Henderson VW, Paganini-Hill A, Miller BL, et al. Estrogen for Alzheimer's disease in women: randomized, double-blind, placebo-controlled trial. Neurology. 2000;54(2):295-301. [pmid: 10668686].
316 Mulnard RA, Cotman CW, Kawas C, et al. Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: a randomized controlled trial. JAMA. 2000;283(8):1007-15. [pmid: 10697060].
317 Valen-Sendstad A, Engedal K, Stray-Pedersen B, et al. Effects of hormone therapy on depressive symptoms and cognitive functions in women with Alzheimer disease: a 12 month randomized, double-blind, placebo-controlled study of low-dose estradiol and norethisterone. Am J Geriatr Psychiatry. 2010;18(1):11-20. [pmid: 20094015].
318 Lu PH, Masterman DA, Mulnard R, et al. Effects of testosterone on cognition and mood in male patients with mild Alzheimer disease and healthy elderly men. Arch Neurol. 2006;63(2):177-85. [pmid: 16344336].
319 Freund-Levi Y, Eriksdotter-Jonhagen M, Cederholm T, et al. Omega-3 fatty acid treatment in 174 patients with mild to moderate Alzheimer disease: OmegAD study—a randomized double-blind trial. Arch Neurol. 2006;63(10):1402-8. [pmid: 17030655].
320 Sano M, Ernesto C, Thomas RG, et al. A controlled trial of selegiline, alpha-tocopherol, or both as treatment for Alzheimer's disease. N Engl J Med. 1997;336(17):1216-22. [pmid: 9110909].
321 Aisen PS, Schneider LS, Sano M, et al. High-dose B vitamin supplementation and cognitive decline in Alzheimer disease: a randomized controlled trial. JAMA. 2008;300(15):1774-83. [pmid: 18854539].
322 Charlesworth G, Shepstone L, Wilson E, et al. Befriending carers of people with dementia: randomised controlled trial. BMJ. 2008;336(7656):1295-7. [pmid: 18505757].
323 Pillemer K, Jill SJ. Peer support for Alzheimer's caregivers: is it enough to make a difference?. Res Aging. 2002;24(2):171-92.
324 Winter L, Gitlin LN. Evaluation of a telephone-based support group intervention for female caregivers of community-dwelling individuals with dementia. Am J Alzheimers Dis Other Demen. 2006;21(6):391-7. [pmid: 17267370].
325 Gallagher-Thompson D, Coon DW, Solano N, et al. Change in indices of distress among Latino and Anglo female caregivers of elderly relatives with dementia: site-specific results from the REACH national collaborative study. Gerontologist. 2003;43(4):580-91. [pmid: 12937336].
326 Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: a randomized controlled trial. J Appl Gerontol. 2009;28(2):171-94. [pmid: 21709757].
327 Hirano A, Suzuki Y, Kuzuya M, et al. Influence of regular exercise on subjective sense of burden and physical symptoms in community-dwelling caregivers of dementia patients: a randomized controlled trial. Arch Gerontol Geriatr. 2011;53(2):e158-63. [pmid: 20850878].
328 King AC, Baumann K, O'Sullivan P, et al. Effects of moderate-intensity exercise on physiological, behavioral, and emotional responses to family caregiving. J Gerontol A Biol Sci Med Sci. 2002;57(1):M26-36. [pmid: 11773209].
329 LoGiudice D, Waltrowicz W, Brown K, et al. Do memory clinics improve the quality of life of carers? A randomized pilot trial. Int J Geriatr Psychiatry. 1999;14(8):626-32. [pmid: 10489653].
330 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. 2003;43(4):568-79. [pmid: 12937335].
331 Gitlin LN, Winter L, Corcoran M, et al. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH initiative. Gerontologist. 2003;43(4):532-46. [pmid: 12937332].
332 Gitlin LN, Belle SH, Burgio LD, et al. Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. 2003;18(3):361-74. [pmid: 14518800].
333 Mahoney DF, Tarlow BJ, Jones RN. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. 2003;43(4):556-67. [pmid: 12937334].
334 Joling KJ, van Marwijk HW, Smit F, et al. Does a family meetings intervention prevent depression and anxiety in family caregivers of dementia patients? A randomized trial. PLoS One. 2012;7(1):e30936. [pmid: 22303473].
335 Mittelman MS, Brodaty H, Wallen AS, et al. A three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: effects on caregiver depression. Am J Geriatr Psychiatry. 2008;16(11):893-904. [pmid: 18978250].
336 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial. Ann Intern Med. 2006;145(10):713-26. [pmid: 17116916].
337 Spijker A, Wollersheim H, Teerenstra S, et al. Systematic care for caregivers of patients with dementia: a multicenter, cluster-randomized, controlled trial. Am J Geriatr Psychiatry. 2011;19(6):521-31. [pmid: 21358385].
338 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res. 1995;44(3):166-72. [pmid: 7761293].
339 Finkel S, Czaja SJ, Schulz R, et al. E-care: a telecommunications technology intervention for family caregivers of dementia patients. Am J Geriatr Psychiatry. 2007;15(5):443-8. [pmid: 17463195].
340 Gitlin LN, Corcoran M, Winter L, et al. A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. 2001;41(1):4-14. [pmid: 11220813].
341 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. 2010;304(9):983-91. [pmid: 20810376].
342 Gitlin LN, Winter L, Dennis MP, et al. Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. 2010;58(8):1465-74. [pmid: 20662955].
343 Graff MJ, Vernooij-Dassen MJ, Thijssen M, et al. Community based occupational therapy for patients with dementia and their care givers: randomised controlled trial. BMJ. 2006;333(7580):1196. [pmid: 17114212].
344 Voigt-Radloff S, Graff M, Leonhart R, et al. A multicentre RCT on community occupational therapy in Alzheimer's disease: 10 sessions are not better than one consultation. BMJ Open. 2011;1(1):e000096. [pmid: 22021760].
345 Bass DM, Clark PA, Looman WJ, et al. The Cleveland Alzheimer's managed care demonstration: outcomes after 12 months of implementation. Gerontologist. 2003;43(1):73-85. [pmid: 12604748].
346 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. 2006;295(18):2148-57. [pmid: 16684985].
347 Chu P, Edwards J, Levin R, et al. The use of clinical case management for early state Alzheimer's patients and their families. Am J Alzheimers Dis Other Demen. 2000;15(5):284-90.
348 Eloniemi-Sulkava U, Notkola IL, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: a randomized trial. J Am Geriatr Soc. 2001;49(10):1282-7. [pmid: 11890485].
349 Fortinsky RH, Kulldorff M, Kleppinger A, et al. Dementia care consultation for family caregivers: collaborative model linking an Alzheimer's Association chapter with primary care physicians. Aging Ment Health. 2009;13(2):162-70. [pmid: 19347683].
350 Jansen AP, van Hout HP, Nijpels G, et al. Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: a randomized clinical trial. Int J Nurs Stud. 2011;48(8):933-43. [pmid: 21356537].
351 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. 2010;25(4):395-402. [pmid: 19606455].
352 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. Ann Intern Med. 2006;145(10):727-38. [pmid: 17116917].
353 Chu H, Yang CY, Liao YH, et al. The effects of a support group on dementia caregivers' burden and depression. J Aging Health. 2011;23(2):228-41. [pmid: 20847363].
354 Gitlin LN, Winter L, Burke J, et al. Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. 2008;16(3):229-39. [pmid: 18310553].
355 Martin-Carrasco M, Martin MF, Valero CP, et al. Effectiveness of a psychoeducational intervention program in the reduction of caregiver burden in Alzheimer's disease patients' caregivers. Int J Geriatr Psychiatry. 2009;24(5):489-99. [pmid: 18949763].
356 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen ML, et al. Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. 2009;57(12):2200-8. [pmid: 20121986].
357 Hinchliffe AC, Hyman IL, Blizard B, et al. Behavioural complications of dementia: can they be treated?. Int J Geriatr Psychiatry. 1995;10(10):839-47.
358 Kurz A, Wagenpfeil S, Hallauer J, et al. Evaluation of a brief educational program for dementia carers: the AENEAS study. Int J Geriatr Psychiatry. 2010;25(8):861-9. [pmid: 19946869].
359 Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. 2000;176:557-62. [pmid: 10974962].
360 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients: effects on patients and carers. Dement Geriatr Cogn Disord. 2007;24(6):469-75. [pmid: 17986818].
361 Brodaty H, Gresham M. Effect of a training programme to reduce stress in carers of patients with dementia. BMJ. 1989;299(6712):1375-9. [pmid: 2513967].
362 Hebert R, Leclerc G, Bravo G, et al. Efficacy of a support group programme for care-givers of demented patients in the community: a randomized controlled trial. Arch Gerontol Geriatr. 1994;18(1):1-14. [pmid: 15374309].
363 Hebert R, Levesque L, Vezina J, et al. Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. 2003;58(1):S58-67. [pmid: 12496309].
364 Roberts J, Browne G, Milne C, et al. Problem-solving counseling for caregivers of the cognitively impaired: effective for whom?. Nurs Res. 1999;48(3):162-72. [pmid: 10337847].
365 Ducharme FC, Levesque LL, Lachance LM, et al. “Learning to become a family caregiver”: efficacy of an intervention program for caregivers following diagnosis of dementia in a relative. Gerontologist. 2011;51(4):484-94. [pmid: 21383112].
366 Huang HL, Shyu YI, Chen MC, et al. A pilot study on a home-based caregiver training program for improving caregiver self-efficacy and decreasing the behavioral problems of elders with dementia in Taiwan. Int J Geriatr Psychiatry. 2003;18(4):337-45. [pmid: 12673611].
367 Gallagher-Thompson D, Gray HL, Dupart T, et al. Effectiveness of cognitive/behavioral small group intervention for reduction of depression and stress in non-Hispanic white and Hispanic/Latino women dementia family caregivers: outcomes and mediators of change. J Ration Emot Cogn Behav Ther. 2008;26(4):286-303.
368 Waldorff FB, Buss DV, Eckermann A, et al. Efficacy of psychosocial intervention in patients with mild Alzheimer's disease: the multicentre, rater blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ. 2012;345:e4693. [pmid: 22807076].
369 Zarit SH, Reever KE, Bach-Peterson J. Relatives of the impaired elderly: correlates of feelings of burden. Gerontologist. 1980;20(6):649-55. [pmid: 7203086].
370 Teri L, Truax P, Logsdon R, et al. Assessment of behavioral problems in dementia: the revised memory and behavior problems checklist. Psychol Aging. 1992;7(4):622-31. [pmid: 1466831].
371 Hepburn KW, Tornatore J, Center B, et al. Dementia family caregiver training: affecting beliefs about caregiving and caregiver outcomes. J Am Geriatr Soc. 2001;49(4):450-7. [pmid: 11347790].
372 Ostwald SK, Hepburn KW, Caron W, et al. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. 1999;39(3):299-309. [pmid: 10396888].
373 Radloff LS. The CES-D scale: a self-report depression scale for research in the general population. Appl Psychol Med. 1977;1:385-401.
374 Coon DW, Thompson L, Steffen A, et al. Anger and depression management: psychoeducational skill training interventions for women caregivers of a relative with dementia. Gerontologist. 2003;43(5):678-89. [pmid: 14570964].
375 Chang BL. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. 1999;48(3):173-82. [pmid: 10337848].
376 Schoenmakers B, Buntinx F, DeLepeleire J. Supporting family carers of community-dwelling elder with cognitive decline: a randomized controlled trial. Int J Family Med. 2010;2010:184152. [pmid: 22332005].
377 Losada A, Marquez-Gonzalez M, Romero-Moreno R. Mechanisms of action of a psychological intervention for dementia caregivers: effects of behavioral activation and modification of dysfunctional thoughts. Int J Geriatr Psychiatry. 2011;26(11):1119-27. [pmid: 21061414].
378 Williams VP, Bishop-Fitzpatrick L, Lane JD, et al. Video-based coping skills to reduce health risk and improve psychological and physical well-being in Alzheimer's disease family caregivers. Psychosom Med. 2010;72(9):897-904. [pmid: 20978227].
379 Martin-Cook K, Davis BA, Hynan LS, et al. A randomized, controlled study of an Alzheimer's caregiver skills training program. Am J Alzheimers Dis Other Demen. 2005;20(4):204-10. [pmid: 16136843].
380 Kinsella GJ, Mullaly E, Rand E, et al. Early intervention for mild cognitive impairment: a randomised controlled trial. J Neurol Neurosurg Psychiatry. 2009;80(7):730-6. [pmid: 19332424].
381 Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging Ment Health. 2002;6(1):5-11. [pmid: 11827617].
382 Troyer AK, Murphy KJ, Anderson ND, et al. Changing everyday memory behaviour in amnestic mild cognitive impairment: a randomised controlled trial. Neuropsychol Rehabil. 2008;18(1):65-88. [pmid: 17943615].
383 Greenaway MC, Duncan NL, Smith GE. The memory support system for mild cognitive impairment: randomized trial of a cognitive rehabilitation intervention. Int J Geriatr Psychiatry. 2013;28(4):402-9. [pmid: 22678947].
384 Buschert VC, Friese U, Teipel SJ, et al. Effects of a newly developed cognitive intervention in amnestic mild cognitive impairment and mild Alzheimer's disease: a pilot study. J Alzheimers Dis. 2011;25(4):679-94. [pmid: 21483095].
385 Olazaran J, Muniz R, Reisberg B, et al. Benefits of cognitive-motor intervention in MCI and mild to moderate Alzheimer disease. Neurology. 2004;63(12):2348-53. [pmid: 15623698].
386 Tsolaki M, Kounti F, Agogiatou C, et al. Effectiveness of nonpharmacological approaches in patients with mild cognitive impairment. Neurodegener Dis. 2011;8(3):138-45. [pmid: 21135531].
387 Burgener SC, Yang Y, Gilbert R, et al. The effects of a multimodal intervention on outcomes of persons with early-stage dementia. Am J Alzheimers Dis Other Demen. 2008;23(4):382-94. [pmid: 18453642].
388 Cahn-Weiner DA, Malloy PF, Rebok GW, et al. Results of a randomized placebo-controlled study of memory training for mildly impaired Alzheimer's disease patients. Appl Neuropsychol. 2003;10(4):215-23. [pmid: 14690802].
389 Clare L, Linden DE, Woods RT, et al. Goal-oriented cognitive rehabilitation for people with early-stage Alzheimer disease: a single-blind randomized controlled trial of clinical efficacy. Am J Geriatr Psychiatry. 2010;18(10):928-39. [pmid: 20808145].
390 Schwenk M, Zieschang T, Oster P, et al. Dual-task performances can be improved in patients with dementia: a randomized controlled trial. Neurology. 2010;74(24):1961-8. [pmid: 20445152].
391 Chapman SB, Weiner MF, Rackley A, et al. Effects of cognitive-communication stimulation for Alzheimer's disease patients treated with donepezil. J Speech Lang Hear Res. 2004;47(5):1149-63. [pmid: 15603468].
392 Quayhagen MP, Quayhagen M. Testing of a cognitive stimulation intervention for dementia caregiving dyads. Neuropsychol Rehabil. 2001;11(3-4):319-32.
393 Kurz A, Thone-Otto A, Cramer B, et al. CORDIAL: cognitive rehabilitation and cognitive-behavioral treatment for early dementia in Alzheimer disease—a multicenter, randomized, controlled trial. Alzheimer Dis Assoc Disord. 2012;26(3):246-53. [pmid: 21986341].
394 Lam LC, Chau RC, Wong BM, et al. Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. Int J Geriatr Psychiatry. 2011;26(7):733-40. [pmid: 21495078].
395 Tsai PF, Chang JY, Beck C, et al. A pilot cluster-randomized trial of a 20-week Tai Chi program in elders with cognitive impairment and osteoarthritic knee: effects on pain and other health outcomes. J Pain Symptom Manage. 2013;45(4):660-9. [pmid: 23017610].
396 Baker LD, Frank LL, Foster-Schubert K, et al. Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. 2010;67(1):71-9. [pmid: 20065132].
397 Nagamatsu LS, Handy TC, Hsu CL, et al. Resistance training promotes cognitive and functional brain plasticity in seniors with probable mild cognitive impairment. Arch Intern Med. 2012;172(8):666-8. [pmid: 22529236].
398 Steinberg M, Leoutsakos JM, Podewils LJ, et al. Evaluation of a home-based exercise program in the treatment of Alzheimer's disease: the Maximizing Independence in Dementia (MIND) study. Int J Geriatr Psychiatry. 2009;24(7):680-5. [pmid: 19089875].
399 Vreugdenhil A, Cannell J, Davies A, et al. A community-based exercise programme to improve functional ability in people with Alzheimer's disease: a randomized controlled trial. Scand J Caring Sci. 2012;26(1):12-9. [pmid: 21564154].
400 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. 2003;290(15):2015-22. [pmid: 14559955].
401 Venturelli M, Lanza M, Muti E, et al. Positive effects of physical training in activity of daily living-dependent older adults. Exp Aging Res. 2010;36(2):190-205. [pmid: 20209421].
402 Bellantonio S, Kenny AM, Fortinsky RH, et al. Efficacy of a geriatrics team intervention for residents in dementia-specific assisted living facilities: effect on unanticipated transitions. J Am Geriatr Soc. 2008;56(3):523-8. [pmid: 18179497].
403 Richard E, Van den Heuvel E, Moll van Charante EP, et al. Prevention of Dementia by Intensive Vascular Care (PreDIVA): a cluster-randomized trial in progress. Alzheimer Dis Assoc Disord. 2009;23(3):198-204. [pmid: 19812459].
404 Nourhashemi F, Andrieu S, Gillette-Guyonnet S, et al. Effectiveness of a specific care plan in patients with Alzheimer's disease: cluster randomised trial (PLASA study). BMJ. 2010;340:c2466. [pmid: 20522656].
405 Meeuwsen EJ, Melis RJ, Van Der Aa GC, et al. Effectiveness of dementia follow-up care by memory clinics or general practitioners: randomised controlled trial. BMJ. 2012;344:e3086. [pmid: 22589500].
406 Wolfs CA, Kessels A, Dirksen CD, et al. Integrated multidisciplinary diagnostic approach for dementia care: randomised controlled trial. Br J Psychiatry. 2008;192(4):300-5. [pmid: 18378994].
407 Beer C, Horner B, Flicker L, et al. A cluster-randomised trial of staff education to improve the quality of life of people with dementia living in residential care: the DIRECT study. PLoS One. 2011;6(11):e28155. [pmid: 22140531].
408 Menn P, Holle R, Kunz S, et al. Dementia care in the general practice setting: a cluster randomized trial on the effectiveness and cost impact of three management strategies. Value Health. 2012;15(6):851-9. [pmid: 22999135].
409 Brodaty H, Low LF, Gibson L, et al. What is the best dementia screening instrument for general practitioners to use?. Am J Geriatr Psychiatry. 2006;14(5):391-400. [pmid: 16670243].
410 Jha A, Tabet N, Orrell M. To tell or not to tell: comparison of older patients' reaction to their diagnosis of dementia and depression. Int J Geriatr Psychiatry. 2001;16(9):879-85. [pmid: 11571768].
411 Fowler NR, Boustani MA, Frame A, et al. Effect of patient perceptions on dementia screening in primary care. J Am Geriatr Soc. 2012;60(6):1037-43. [pmid: 22690979].
412 National Institute for Health and Clinical Excellence. Donepezil, Galantamine, Rivastigmine and Memantine for the Treatment of Alzheimer's Disease. NICE Technology Appraisal Guidance No. 217. London. National Institute for Health and Clinical Excellence. 2011.
413 Russ TC, Morling JR. Cholinesterase inhibitors for mild cognitive impairment. Cochrane Database Syst Rev. 2012;(9):CD009132. [pmid: 22972133].
414 UpToDate. Galantamine: Drug Information. Philadelphia. Wolters Kluwer Health. 2013.
415 UpToDate. Rivastigmine: Drug Information. Philadelphia. Wolters Kluwer Health. 2013.
416 UpToDate. Donepezil: Drug Information. Philadelphia. Wolters Kluwer Health. 2013.
417 UpToDate. Memantine: Drug Information. Philadelphia. Wolters Kluwer Health. 2013.
418 Hansen RA, Gartlehner G, Kaufer DJ, et al. Drug Class Review on Alzheimer's Drugs: Final Report. Portland, OR. Oregon Health & Science University. 2006. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK10310/ on 30 October 2013.
419 McGuinness B, O'Hare J, Craig D, et al. Cochrane review on ‘statins for the treatment of dementia’. Int J Geriatr Psychiatry. 2013;28(2):119-26. [pmid: 22473869].
420 McGuinness B, O'Hare J, Craig D, et al. Statins for the treatment of dementia. Cochrane Database Sys Rev. 2010;(8):CD007514. [pmid: 20687089].
421 Jaturapatporn D, Isaac MG, McCleery J, et al. Aspirin, steroidal and non-steroidal anti-inflammatory drugs for the treatment of Alzheimer's disease. Cochrane Database Sys Rev. 2012;(2):CD006378.
422 Hogervorst E, Yaffe K, Richards M, et al. Hormone replacement therapy to maintain cognitive function in women with dementia. Cochrane Database Sys Rev. 2009;(1):CD003799. [pmid: 19160224].
423 Moore E, Mander A, Ames D, et al. Cognitive impairment and vitamin B12: a review. Int Psychogeriatr. 2012;24(4):541-56. [pmid: 22221769].
424 Ford AH, Almeida OP. Effect of homocysteine lowering treatment on cognitive function: a systematic review and meta-analysis of randomized controlled trials. J Alzheimers Dis. 2012;29(1):133-49. [pmid: 22232016].
425 Farina N, Isaac MG, Clark AR, et al. Vitamin E for Alzheimer's dementia and mild cognitive impairment. Cochrane Database Sys Rev. 2012;(11):CD002854. [pmid: 23152215].
426 Vernooij-Dassen M, Draskovic I, McCleery J, et al. Cognitive reframing for carers of people with dementia. Cochrane Database Sys Rev. 2011;(11):CD005318. [pmid: 22071821].
427 Goy E, Kansagara D, Freeman M. A Systematic Evidence Review of Interventions for Non-Professional Caregivers of Individuals With Dementia. Washington, DC. U.S. Department of Veterans Affairs. 2010. Accessed at http://www.ncbi.nlm.nih.gov/pubmed/?term=NBK49194 on 30 October 2013.
428 Chien LY, Chu H, Guo JL, et al. Caregiver support groups in patients with dementia: a meta-analysis. Int J Geriatr Psychiatry. 2011;26:1089-98. [pmid: 21308785].
429 Tam-Tham H, Cepoiu-Martin M, Ronksley PE, et al. Dementia case management and risk of long-term care placement: a systematic review and meta-analysis. Int J Geriatr Psychiatry. 2013;28(9):889-902. [pmid: 23188735].
430 Woods B, Aguirre E, Spector AE, et al. Cognitive stimulation to improve cognitive functioning in people with dementia. Cochrane Database Syst Rev. 2012;(2):CD005562. [pmid: 22336813].
431 Reijnders J, van Heugten C, van Boxtel M. Cognitive interventions in healthy older adults and people with mild cognitive impairment: a systematic review. Ageing Res Rev. 2012;12(1):263-75. [pmid: 22841936].
432 Kurz AF, Leucht S, Lautenschlager NT. The clinical significance of cognition-focused interventions for cognitively impaired older adults: a systematic review of randomized controlled trials. Int Psychogeriatr. 2011;23(9):1364-75. [pmid: 21740614].
433 Pitkala K, Savikko N, Poysti M, et al. Efficacy of physical exercise intervention on mobility and physical functioning in older people with dementia: a systematic review. Exp Gerontol. 2013;48(1):85-93. [pmid: 22960590].
434 Cordell CB, Borson S, Boustani M, et al. Alzheimer's Association recommendations for operationalizing the detection of cognitive impairment during the Medicare Annual Wellness Visit in a primary care setting. Alzheimers Dement. 2013;9(2):141-50. [pmid: 23265826].
435 Corrada MM, Brookmeyer R, Paganini-Hill A, et al. Dementia incidence continues to increase with age in the oldest old: the 90+ study. Ann Neurol. 2010;67(1):114-21. [pmid: 20186856].
436 Ziegler-Graham K, Brookmeyer R, Johnson E, et al. Worldwide variation in the doubling time of Alzheimer's disease incidence rates. Alzheimers Dement. 2008;4(5):316-23. [pmid: 18790458].
437 Fitzpatrick AL, Kuller LH, Ives DG, et al. Incidence and prevalence of dementia in the Cardiovascular Health Study. J Telemed Telecare. 2004;52(2):195-204.
438 Corrada MM, Brookmeyer R, Paganini-Hill A, et al. Dementia incidence continues to increase with age in the oldest old: the 90+ study. Ann Neurol. 2010;67(1):114-21. [pmid: 20186856].
439 Prince M, Bryce R, Ferri C. World Alzheimer Report 2011: The Benefits of Early Diagnosis and Intervention. London. Alzheimer's Disease International. 2011.
440 Requena C, Maestu F, Campo P, et al. Effects of cholinergic drugs and cognitive training on dementia: 2-year follow-up. Dement Geriatr Cogn Disord. 2006;22(4):339-45. [pmid: 16954689].
441 Rockwood K, Fay S, Jarrett P, et al. Effect of galantamine on verbal repetition in AD: a secondary analysis of the VISTA trial. Neurology. 2007;68(14):1116-21. [pmid: 17404193].
442 Rockwood K, Fay S, Gorman M. The ADAS-cog and clinically meaningful change in the VISTA clinical trial of galantamine for Alzheimer's disease. Int J Geriatr Psychiatry. 2010;25(2):191-201. [pmid: 19548273].
443 Wong VS. Effect of galantamine on verbal repetition in AD: a secondary analysis of the VISTA trial. Neurology. 2007;69(8):809-10. [pmid: 17709718].
444 Winblad B, Grossberg G, Frolich L, et al. IDEAL: a 6-month, double-blind, placebo-controlled study of the first skin patch for Alzheimer disease. Neurology. 2007;69(4 Suppl 1):S14-22. [pmid: 17646619].
445 Grossberg G, Meng X, Olin JT. Impact of rivastigmine patch and capsules on activities of daily living in Alzheimer's disease. Am J Alzheimers Dis Other Demen. 2011;26(1):65-71. [pmid: 21282280].
446 Grossberg GT, Schmitt FA, Meng X, et al. Reviews: effects of transdermal rivastigmine on ADAS-cog items in mild-to-moderate Alzheimer's disease. Am J Alzheimers Dis Other Demen. 2010;25(8):627-33. [pmid: 21131668].
447 Cummings JL, Ferris SH, Farlow MR, et al. Effects of rivastigmine transdermal patch and capsule on aspects of clinical global impression of change in Alzheimer's disease: a retrospective analysis. Dement Geriatr Cogn Disord. 2010;29(5):406-12. [pmid: 20502014].
448 Lee JH, Sevigny J. Effects of body weight on tolerability of rivastigmine transdermal patch: a post-hoc analysis of a double-blind trial in patients with Alzheimer disease. Alzheimers Dis Assoc Disord. 2011;25(1):58-62. [pmid: 20975519].
449 Grossberg G, Sadowsky C, Frostl H, et al. Safety and tolerability of the rivastigmine patch: results of a 28-week open-label extension. Alzheimer Dis Assoc Disord. 2009;23(2):158-64. [pmid: 19484917].
450 Munoz DG, Feldman H. Causes of Alzheimer's disease. CMAJ. 2000;162(1):65-72. [pmid: 11216203].
451 Aronson S, Van Baelen B, Kavanagh S, et al. Optimal dosing of galantamine in patients with mild or moderate Alzheimer's disease: post hoc analysis of a randomized, double-blind, placebo-controlled trial. Drugs Aging. 2009;26(3):231-9. [pmid: 19358618].
452 Kadir A, Darreh-Shori T, Almkvist O, et al. PET imaging of the in vivo brain acetylcholinesterase activity and nicotine binding in galantamine-treated patients with AD. Neurobiol Aging. 2008;29(8):1204-17. [pmid: 17379359].
453 Jones RW, Kivipelto M, Feldman H, et al. The Atorvastatin/Donepezil in Alzheimer's Disease Study (LEADe): design and baseline characteristics. Alzheimers Dement. 2008;4(2):145-53. [pmid: 18631958].
454 Sparks DL, Connor DJ, Sabbagh MN, et al. Circulating cholesterol levels, apolipoprotein E genotype and dementia severity influence the benefit of atorvastatin treatment in Alzheimer's disease: results of the Alzheimer's Disease Cholesterol-Lowering Treatment (ADCLT) trial. Acta Neurol Scand. 2006;114(Suppl 185):3-7. [pmid: 16866904].
455 Sparks DL, Sabbagh M, Connor D, et al. Statin therapy in Alzheimer's disease. Acta Neurol Scand. 2006;114(Suppl 185):78-86. [pmid: 16866915].
456 Connelly PJ, Prentice NP, Cousland G, et al. A randomised double-blind placebo-controlled trial of folic acid supplementation of cholinesterase inhibitors in Alzheimer's disease. Int J Geriatr Psychiatry. 2008;23(2):155-60. [pmid: 17600848].
457 Freund-Levi Y, Basun H, Cederholm T, et al. Omega-3 supplementation in mild to moderate Alzheimer's disease: effects on neuropsychiatric symptoms. Int J Geriatr Psychiatry. 2008;23(2):161-9. [pmid: 17582225].
458 Kwok T, Lee J, Law CB, et al. A randomized placebo controlled trial of homocysteine lowering to reduce cognitive decline in older demented people. Clin Nutr. 2011;30(3):297-302. [pmid: 21216507].
459 Quinn JF, Raman R, Thomas RG, et al. Docosahexaenoic acid supplementation and cognitive decline in Alzheimer disease: a randomized trial. JAMA. 2010;304(17):1903-11. [pmid: 21045096].
460 Sun Y, Lu CJ, Chien KL, et al. Efficacy of multivitamin supplementation containing vitamins B6 and B12 and folic acid as adjunctive treatment with a cholinesterase inhibitor in Alzheimer's disease: a 26-week, randomized, double-blind, placebo-controlled study in Taiwanese patients. Clin Ther. 2007;29(10):2204-14. [pmid: 18042476].
461 van Uffelen JG, Chin AP, Hopman-Rock M, et al. The effect of walking and vitamin B supplementation on quality of life in community-dwelling adults with mild cognitive impairment: a randomized, controlled trial. Qual Life Res. 2007;16(7):1137-46. [pmid: 17616840].
462 van Uffelen JG, Hopman-Rock M, Chin AP, et al. Protocol for Project FACT: a randomised controlled trial on the effect of a walking program and vitamin B supplementation on the rate of cognitive decline and psychosocial wellbeing in older adults with mild cognitive impairment [ISRCTN19227688]. BMC Geriatrics. 2005;5:18. [pmid: 16375760].
463 De Rotrou J, Cantegreil I, Faucounau V, et al. Do patients diagnosed with Alzheimer's disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. 2011;26(8):833-42. [pmid: 20922772].
464 Wright LK, Litaker M, Laraia MT, et al. Continuum of care for Alzheimer's disease: a nurse education and counseling program. Issues Ment Health Nurs. 2001;22(3):231-52. [pmid: 11885210].
465 Joling KJ, van Marwijk HW, van der Horst HE, et al. Effectiveness of family meetings for family caregivers on delaying time to nursing home placement of dementia patients: a randomized trial. PLoS One. 2012;7(8):e42145. [pmid: 22876304].
466 Quayhagen MP, Quayhagen M, Corbeil RR, et al. A dyadic remediation program for care recipients with dementia. Nurs Res. 1995;44(3):153-9. [pmid: 7761291].
467 Beer CD, Horner B, Almeida OP, et al. Dementia in residential care: education intervention trial (DIRECT): protocol for a randomised controlled trial. Trials. 2010;11:63. [pmid: 20500891].