# Discussion

## Summary of Findings

### Overall

We did not identify any direct trial evidence demonstrating that screening for cognitive impairment improves health outcomes or important patient, family, or clinician decisionmaking outcomes. As such, our review primarily addressed two broad questions: 1) How well does screening detect dementia or MCI in primary care? and 2) How effective are interventions to improve patient or caregiver outcomes in people with screen-detected cognitive impairment (i.e., those with mild to moderate dementia or MCI)? Our review identified a very large body of well-conducted diagnostic accuracy studies that evaluated brief screening instruments in unselected older adults outside of specialty care (i.e., memory or neurology clinics). Despite this large number of studies, however, only a handful of instruments have been studied in more than one trial applicable to primary care (Table 16). Nonetheless, it is clear that several brief instruments can have sensitivity and specificity greater than 80 percent to detect dementia, regardless of etiology (e.g., AD vs. VaD). The MMSE (k=25) is the best-studied instrument; however, it has the longest administration time (up to 10 minutes) and is not available for public use (without cost). Other instruments with more limited evidence include the CDT (k=7), Mini-Cog (k=4), MIS (k=5), AMT (k=4), SPMSQ (k=4), FCSRT (k=2), 7MS (k=2), TICS (k=2; also not available for public use), and IQCODE (k=5). However, the AMT, SPMSQ, FCSRT, 7MS, and TICS have very limited evidence (only one study each) in English. Each of these instruments can have reasonable test performance; however, estimates of sensitivity and specificity vary, and the optimal diagnostic threshold/cut-point for many of these instruments is unclear. While other instruments appear promising, such as the 6-Item Screener, VAT, GPCOG, ADLs/IADLs, Benton's Orientation Test, Delayed Recall Test, and Short Concord Informant Dementia scale, they have only been studied once in primary care–relevant populations. No studies directly address the adverse psychological effects of screening or adverse effects from false-positive or false-negative testing. One fair-quality study found that approximately half the older adults who screened positive for cognitive impairment refused to complete a formal diagnostic workup.

Table 16 Summary of Evidence

KQ, by Instrument or Treatment | Number, Design | Quality | Applicability | Consistency | Diagnostic Accuracy or Magnitude of Effect (Including Precision)
KQ 1 | None | NA | NA | NA | NA
KQ 2 (dementia) | 46 Dx accuracy | Fair to good | Wide range of instruments, broad inclusion of older adult populations with a wide range of underlying dementia | Some inconsistencies in estimates of diagnostic performance, unclear if due to differences in study quality, populations, or scoring of instrument | The best-studied instrument is the MMSE, but administration time can be 10 minutes. Other instruments with more limited evidence include the CDT, Mini-Cog, MIS, AMT, SPMSQ, FCSRT, 7MS, TICS, and IQCODE. Each of these tests can have reasonable test performance, but estimates of sensitivity and specificity vary. The AMT, SPMSQ, FCSRT, 7MS, and TICS have very limited evidence in English. Other instruments such as the 6-item screener, VAT, GPCOG, ADL/IADL, Benton's Orientation Test, and Delayed Recall Test, and the Short Concord Informant Dementia Scale for dementia, appear promising, but their test performances have not been reproduced in other primary care–relevant populations.
-CDT | 7 Dx accuracy | Fair to good | Wide range of prevalence, unclear optimal scoring/cut-point | Unclear if inconsistency due to difference in population (e.g., education) or scoring methods/cut-points | 6 studies (n=2170) Sn, 67-97.9 (95% CI, 39 to 100) Sp, 69-94.2 (95% CI, 54 to 97.1)
-Mini-Cog | 4 Dx accuracy | Fair to good | Wide range of prevalence, unclear optimal cut-point | Unclear if inconsistency due to difference in population (e.g., education) or scoring methods/cut-points for CDT | 4 studies (n=1208) Sn, 76-100 (95% CI, 54 to 100) Sp, 54-85.2 (95% CI, 43 to 88.4)
-MIS(-T) | 5 Dx accuracy | Fair to good | Wide range of prevalence | Two best-quality studies with low sensitivity | 5 studies (n=1971) Sn, 43-86 (95% CI, 24 to 96) Sp, 93-97 (95% CI, 56 to 100)
-MSQ or SPMSQ | 4 Dx accuracy | Fair | Wide range of prevalence, only one study in English, unclear optimal cut-point | SPMSQ and MSQ performed similarly in 2 studies evaluating both, unclear if inconsistency due to cut-points | 4 studies (n=940) Sn, 92.3-100 (95% CI, 29 to 100) Sp, 83.5-100 (95% CI, 76 to 100)
-Verbal fluency | 6 Dx accuracy | Fair to good (mostly fair) | Wide range of prevalence | Test performance overlapped regardless of cut-point | For a cut-point of 12 or 13: 3 studies (n=1041) Sn, 37-89.5 (95% CI, 19 to 100) Sp, 62-97 (95% CI, 48 to 99) For a cut-point of 14: 3 studies (n=905) Sn, 57-88 (95% CI, 35 to 100) Sp, 43-94 (95% CI, 33 to 97)
-AMT | 4 Dx accuracy | Fair | Wide range of prevalence, only one study in English, and none of the studies conducted in the U.S. | Unclear if inconsistency due to difference in population (language, culture, underlying prevalence) | 4 studies (n=863) Sn, 42-100 (95% CI, 16 to 100) Sp, 83-95.4 (95% CI, 76 to 99)
-FCRST | 2 Dx accuracy | Fair to good | High prevalence of dementia, only one study in English, unclear optimal cut-point | Only 2 studies, different populations and cut-points | 2 studies (n=734) Sn, 86-100 (95% CI, 41 to 100) Sp, 73-87.2 (95% CI, 56 to 96)
-7MS | 2 Dx accuracy | Fair | Intermediate prevalence of dementia, only one study in English, unclear optimal cut-point | Only 2 studies, different populations and cut-points | 2 studies (n=553) Sn, 100 (95% CI, 71.5 to 100) Sp, 95.1-100 (95% CI, 86.8 to 100)
-TICS | 2 Dx accuracy | Fair | Intermediate prevalence of dementia, only one study in English, unclear optimal cut-point | Only 2 studies, different populations and cut-points | 2 studies (n=677) Sn, 74-88 (95% CI, 54 to 96) Sp, 86-87 (95% CI, 81 to 91)
-MMSE | 25 Dx accuracy | Fair | Wide range of prevalence, wide range of languages | Test performance overlapped regardless of cut-point of 23/24 or 24/25, optimal cut-point for low education is lower | For a cut-point of 23/24, 24/25: 14 studies (n=10,185) Sn, 88.3 (95% CI, 81.3 to 92.9) Sp, 86.2 (95% CI, 81.8 to 89.7)
-IQCODE | 5 Dx accuracy | Fair to good (mostly fair) | Intermediate prevalence of dementia, unclear optimal cut-point, cut-point recommended by test developers not supported in evidence | Test performance overlapped for short and full versions, and overlapped for different cut-points | 5 studies (n=1108) Sn, 75-87.6 (95% CI, 41 to 100) Sp, 65-91.1 (95% CI, 59 to 100)
-Other instruments | 1 Dx accuracy study for each instrument | Fair to good | Cannot comment on applicability because instruments only evaluated in one study, lack of reproducibility in primary care–relevant population | Cannot comment on consistency of findings because instruments only evaluated in one study | 6-item screener, VAT, GPCOG, ADL/IADL, Short Concord Informant Dementia Scale, Benton's Orientation Test, and Delayed Recall Test have Sn/Sp >80%
KQ 2 (MCI ± dementia) | 27 Dx accuracy | Fair to good | Wide range of instruments, broad inclusion of older adult populations with a wide range of underlying dementia | Inconsistencies in estimates of diagnostic performance; unclear if due to differences in study quality, definitions, diagnostic criteria for MCI, populations, or scoring of instrument | Overall, screening instruments have less evidence to support their use to detect MCI and have much lower sensitivity to detect MCI than dementia. The MoCA, specifically designed to detect MCI, has limited evidence in English. Several instruments, including AD8, SLUMS, FOME, and CAMCI for MCI, appear promising, but their test performance has not been reproduced in other primary care–relevant populations.
-CDT | 4 Dx accuracy | Fair | Unclear optimal definition of MCI, and unclear optimal scoring/cut-point | Unclear if inconsistency due to difference in definition of MCI, prevalence of underlying MCI, education level, or scoring/cut-points | 4 studies (n=4191) to detect MCI Sn, 40-85 (95% CI, 34.1 to 97) Sp, 44-83 (95% CI, 33 to 87.5)
-Mini-Cog | 3 Dx accuracy | Fair to good | Unclear optimal definition of MCI, and unclear optimal scoring of CDT | Unclear if inconsistency due to difference in definition of MCI, prevalence of underlying MCI, or scoring of CDT | 1 study (n=91) to detect MCI Sn, 50 (95% CI, 38 to 62) Sp, 73 (95% CI, 42 to 92) 2 studies (n=1001) to detect MCI + dementia Sn, 39-84 (95% CI, 34 to 88.5) Sp, 78-87.9 (95% CI, 73 to 92.8)
-TICS(-M) | 3 Dx accuracy | Fair | Unclear optimal definition of MCI, and unclear optimal cut-point | Each study found a different optimal cut-point; unclear if inconsistency due to difference in definition of MCI or differences in population (prevalence, education, language) | For cut-point of 26 or 27: 1 study (n=71) to detect MCI Sn, 17.6 (95% CI, 3.8 to 43.4) Sp, 100 (95% CI, 93.4 to 100) 2 studies (n=497) to detect MCI + dementia Sn, 73-99 (95% CI, 64 to 100) Sp, 46-77 (95% CI, 35 to 82)
-MMSE | 15 Dx accuracy | Fair to good | Unclear optimal definition of MCI, and unclear optimal cut-point | Unclear if inconsistency due to difference in definition of MCI, population (prevalence, education, language), or cut-points | For a cut-point of 23 or 24: 3 studies (n=1544) to detect MCI Sn, 72-77 (95% CI, 62.5 to 85) Sp, 70-89 (95% CI, 58 to 98.6) For a cut-point of 27 or 28: 3 studies (n=1235) to detect MCI Sn, 45-60 (95% CI, 36 to 74) Sp, 65-90 (95% CI, 56 to 99) 1 study (n=63) to detect MCI + dementia Sn, 71 (95% CI, 48 to 89) Sp, 90 (95% CI, 77 to 97)
-IQCODE | 4 Dx accuracy | Fair | Unclear optimal definition of MCI, and unclear optimal cut-point | Unclear if inconsistency due to difference in definition of MCI, underlying prevalence, or cut-points | 1 study (n=441) to detect MCI Sn, 74.8 (95% CI, 67.7 to 80.7) Sp, 69.0 (95% CI, 63.1 to 74.7) 2 studies (n=390) to detect MCI + dementia Sn, 71.1-82.6 (95% CI, 60.6 to NR) Sp, 74.3-83.0 (95% CI, 62.4 to 84.0)
-MoCA | 2 Dx accuracy | Fair to good | Unclear optimal cut-point | Unclear if inconsistency due to difference in underlying population characteristics | For cut-point of 25/26: 2 studies (n=554) to detect MCI Sn, 80-100 (95% CI, 56.3 to 100) Sp, 50-76 (95% CI, 41 to 84.9)
-Other instruments | 1 Dx accuracy study for each instrument | Fair to good | Cannot comment on applicability because instruments only evaluated in one study, lack of reproducibility in primary care–relevant population | Cannot comment on consistency of findings because instruments only evaluated in one study | AD8, FOME, SLUMS, CAMCI have Sn/Sp >80%
KQ 3 | 1 Dx accuracy | Fair | Unclear applicability given single study in urban low-income area in mostly black women | Cannot comment on consistency of findings because only one study | No studies directly reported adverse effects from screening, subsequent diagnostic testing, or missed/delayed diagnosis. One study (n=434) reported 48% of older adults who screened positive for cognitive impairment refused to complete a diagnostic workup for dementia.
KQ 4 (dementia and MCI) | 1 SER and 130 RCTs | Fair to good | Older adults with mild to moderate dementia (mainly AD) or MCI, underrepresentation of nonwhite populations, some complex interventions not widely available | Within specific types of interventions, generally consistent findings by outcome. Inconsistent reporting of certain important outcomes. | For dementia, AChEIs and memantine can improve global cognitive function in the short-term; on average, these effects are likely not clinically signficant but may be for targeted individuals who we cannot evaluate. Complex interventions aimed at caregivers or dyads can result in small improvement in caregiver burden and depression, but the clinical significance of these small changes is not clear. Evidence of benefits for medications and caregiver interventions are mainly in persons with moderate (as opposed to mild) dementia. Cognitive stimulation ± training can improve global cognitive function, but this is based on a much more limited body of evidence and the very large imprecision around benefit limits meaningful interpretation. For MCI, the body of evidence is much smaller, without substantial reproducibility or consistency of findings of benefit for AChEIs, memantine, or cognitive stimulation.
Pharmacologic interventions | FDA-approved medications: 1 SER (50 RCTs) and 14 RCTs Other medications: 26 RCTs | Fair to good | Older adults with mild to moderate dementia (mainly AD), underrepresentation of nonwhite populations, doses of medications or supplements applicable to common use | Inconsistent by class of medication, but within classes of medications/supplements, findings are consistent for major outcomes. Cannot evaluate inconsistency of other outcomes given sparse reporting. | For dementia, AChEIs and memantine can improve global cognitive function in the short-term, but the clinical significance is unclear; using accepted thresholds of clinical benefit, the average benefit across patients is clinically insignificant. AChEIs can improve scores on a clinically meaningful measure of global function in the short-term. Evidence in people with MCI is sparse, with no benefit on global cognitive function. Other medications evaluated had no benefit on global cognitive or physical function in people with dementia or MCI.
AChEIs | 1 SER (45 RCTs) and 9 RCTs | Fair to good | Older adults with mild to moderate dementia (few trials in MCI), mostly AD (few trials in VaD); populations primarily from North America and western Europe; doses of medications applicable to common use | Consistent findings in global cognitive function. Generally consistent findings of benefit in global function outcomes. Inconsistent findings of benefit in physical function; cannot evaluate inconsistency given sparse reporting. | Donepezil (k=24; n=7553), galantamine (k=12; n=6008), and rivastigmine (k=12; n=4829) have statistically significant benefits on global cognitive function in the short-term (approximately 1 to 3 points change on the ADAS-cog). In a small subset of trials, donepezil, galantamine, and rivastigmine have a small benefit on global function, using a clinically meaningful scale, in the short-term. Physical function was only reported in half the trials and showed mixed results. Only 4 trials (3 for donepezil, 1 for galantamine) in MCI. While small statistically significant benefits were demonstrated for donepezil, 2 trials of donepezil showed no difference in progression of MCI to dementia at 3 years.
Memantine | 1 SER (5 RCTs) and 5 RCTs | Fair to good | Older adults with mild to moderate dementia, mostly AD (2 trials in VaD); populations from North America and western Europe; doses of medications applicable to common use | Consistent findings in global cognitive function. Inconsistent findings of benefit in global and physical function; cannot determine if differences in population or study characteristics explain inconsistencies | Statistically significant but clinically marginal benefits in cognitive function in the short-term (k=9; n=3323). Mixed benefit in global function (k=7; n=1880) and physical function (k=5; n=1962). Benefits appear to be limited to persons with moderate AD.
Aspirin | 2 RCTs | Fair | Older adults with mild to moderate dementia or MCI, mainly AD; populations from U.S. and western Europe; low-dose aspirin | Consistent finding of no benefit | No benefit in global cognitive or physical function for low-dose ASA (n=459)
Statins | 4 RCTs | Fair | Older adults with mild to moderate dementia, mainly AD; populations from U.S. and western Europe; doses of medications applicable to common use | Consistent finding of no benefit | No benefit in global cognitive function, physical function, or neuropsychiatric symptoms for simvastatin or atorvastatin (n=1153)
NSAIDs | 4 RCTs | Fair | Older adults with mild to moderate dementia, populations from U.S. and western Europe; doses of medications applicable to common use | Consistent finding of no benefit despite type of NSAID | No benefit in global cognitive or physical function for ibuprofen, naproxen, indomethacin, or celecoxib (n=959). Other outcomes sparsely reported.
Gonadal steroids | 5 RCTs | Fair; short duration of followup | Older adults with mild to moderate dementia (AD only); populations from U.S., Europe, and Asia; doses of medications applicable to common use | Consistent finding of no benefit despite type of hormone | No benefit in global cognitive or physical function for estrogen ± progesterone (k=4; n=277); no benefit in global cognitive function for testosterone (k=1; n=18). Other outcomes sparsely reported.
Dietary supplements | 12 RCTs | Fair to good | Broad range of older adults with mild to moderate dementia or MCI, mainly in people with AD; populations from U.S., northern Europe, and Asia | Consistent finding of no benefit despite type of dietary supplement | No benefit in global cognitive or physical function for dietary supplements, including multivitamins (k=1; n=89), B vitamins (k=7; n=1294), vitamins E ± C (k=3; n=522), or omega-3 fatty acids (k=4; n=1145). Other outcomes sparsely reported.
Nonpharmacologic interventions | 93 RCTs | Fair to good (mostly fair) | Broad range of older adults with mild to moderate dementia or MCI; underrepresentation of nonwhite populations; many complex interventions may not be widely available in the U.S. | Inconsistencies by type of intervention. Inconsistencies within type of intervention may be due to differences in populations, details of intervention, and outcome measurement. Cannot evaluate inconsistency of other outcomes given sparse reporting. | For dementia, it appears that complex interventions aimed at caregivers or dyads of patients with moderate (as opposed to mild) dementia can result in small improvement in caregiver burden and depression, but the clinical significance of these small changes is not clear. For MCI or mild to moderate dementia, cognitive stimulation ± training can result in improvement in global cognitive function; however, the clinical significance of these changes is not clear given the sizeable imprecision around this benefit.
Caregiver (or dyad) interventions | 59 RCTs | Fair to good | Broad range of older adults with mild to moderate dementia; populations from North America, Europe, Australia, and Asia; very wide range of types and intensity of interventions | Generally consistent for caregiver burden and depression outcomes; however, large clinical and statistical heterogeneity in types and components, intensity, and duration of interventions limits interpretation of point estimate(s) from pooled analyses. Cannot evaluate inconsistency of other outcomes given sparse reporting. | Most trials (k=52; n=8932) evaluated caregiver interventions with a psychoeducational component. Small to very small benefit in caregiver burden and depression for broad range of caregiver interventions with a psychoeducational component in the short-term (generally 3-12 months). Pooled analyses for both caregiver burden (k=24; n=2679) and depression (k=30; n=3537) outcomes showed a small benefit (SMD, -0.23 [95% CI, -0.35 to -0.12]; I^2^=52.7; and for SMD, -0.21 [95% CI, -0.30 to -0.13]; I^2^=34.1, respectively).
Cognitive training, rehabilitation, or stimulation ± motor training | 15 RCTs | Fair | Broad range of older adults with mild to moderate dementia and MCI; populations in North American, Europe, and Australia | Unclear if inconsistency in findings for cognitive function were due to differences in study quality, populations, intervention type or intensity, or outcomes measured. Cannot evaluate inconsistency of other outcomes given sparse reporting. | Cognitive interventions (k=15; n=1128) had inconsistent findings of benefit. Cognitive stimulation ± cognitive training can improve cognitive function in people with MCI or mild dementia. Pooled analyses for global cognitive outcomes (k=6; n=513) showed a moderate benefit at 6 to 12 months (SMD, -0.59 [95% CI, -0.93 to -0.25]; I^2^=52.7%). Confidence intervals were quite wide; therefore, the effect on global cognitive function can range from very small to moderate.
Exercise interventions | 10 RCTs | Fair to good (mostly fair) | Broad range of older adults with mild to moderate dementia and MCI; populations in North America, Australia, and Hong Kong | Inconsistent; unclear if due to differences in study quality, population, intervention, or outcomes measured. Cannot evaluate other outcomes given sparse reporting. | Exercise interventions (k=10; n=1033) had inconsistent findings of benefit. However, selected, well-conducted studies suggest a small benefit in cognitive function in people with MCI (k=2; n=220) and physical function and HRQL in people with dementia (k=1; n=153).
Multidisciplinary interventions | 5 RCTs | Fair | Older adults with either mild to moderate dementia or MCI; only one trial in the U.S., which was conducted in an assisted living facility, remaining trials conducted in Europe | Consistent finding of no benefit. | Multidisciplinary care interventions involving assessment and care coordination (k=5; n=1766) showed no benefit in global cognitive function, physical function, institutionalization, or HRQL.
Education only | 2 RCTs | Fair | Older adults with mild to moderate dementia living in residential care facility in Australia or GP practices in Germany | Consistent finding of no benefit. | Two trials (n=741) aimed at educating residential care staff and/or GPs caring for people with dementia found no benefit in HRQL, neuropsychiatric disturbances, hospitalization, or institutionalization.
KQ 5 | 1 SER (50 RCTs), 40 RCTs, 6 OLEs, and 13 observational studies | Fair to good (mostly fair) | Broad range of older adults with both dementia and MCI; majority of studies from trial populations; poor representation of nonwhite populations | Generally consistent findings for FDA-approved medications for AD; however, cannot evaluate for other interventions given sparse reporting of adverse effects. | Adverse effects are not commonly reported in intervention trials and not described in the observational literature, with the exception of harms of AChEIs. AChEIs commonly have side effects that lead to discontinuation of medication.
FDA-approved medications for AD | 1 SER (50 RCTs), 16 RCTs, 6 OLEs, and 13 cross-sectional, case-control, or cohort studies | Fair to good | Broad range of older adults with mild to moderate dementia and MCI; populations from North America, Europe, Australia, and Asia | Generally consistent findings by class effect (AChEI vs. NMDA receptor antagonist), estimation of frequency of adverse events may be higher in observational studies due to population selection (more restrictive for trials). | Discontinuation from AChEIs (k=45) but not memantine (k=9) is more common than placebo. Across trials, there does not appear to be a difference in total serious adverse events for any of these medications; however, tacrine trials did not report serious adverse events. Observational studies examining AChEIs (k=12; n=188,912) suggest that the most common serious adverse events are CNS, heart rate/rhythm, and GI disorders, and that bradycardia and adverse events related to bradycardia (e.g., fall, syncope) are increased due to their use.
Other medications | 20 RCTs | Fair | Broad range of older adults with mild to moderate dementia and MCI; populations restricted to people enrolled in trials; populations from U.S., Europe, and Asia | Some minor inconsistencies by differences in type and dose of medication, population, and type of adverse effect reported. | Inconsistently reported in trials. No statistically significant differences in total adverse effects, serious adverse effects, or discontinuation of medication due to adverse effects, except for increased total adverse events and serious bleeding in persons taking ASA (k=1; n=310), increased withdrawal due to adverse events in people taking high-dose atorvastatin (k=1; n=640), increased syncope in residents of ALF receiving high-dose vitamin E (k=1; n=169), and increased vaginal bleeding in people taking estrogen replacement (k=1; n=50).
Nonpharmacologic interventions | 4 RCTs | Fair | Broad range of older adults with mild to moderate dementia and MCI; populations restricted to trial populations | Few hypothesized harms; however, unclear consistency given adverse effects were rarely reported. | Harms were not reported for caregiver interventions, cognitive training or stimulation, or multidisciplinary care interventions. There was no evidence of increased total or serious adverse effects due to exercise interventions (k=4; n=439).

Abbreviations: AChEI = acetylcholinesterase inhibitor; AD8 = Ascertain Dementia 8; ADL = activities of daily living; AMT = Abbreviated Mental Test; CAMCI = Computer Assessment of Mild Cognitive Impairment; CDT = clock drawing test; CI = confidence interval; DX = diagnostic; FCRST = Free and Cued Selective Reminding Test; GPCOG = General Practitioner Assessment of Cognition; IADL = instrumental activities of daily living; IQCODE = informant Questionnaire on Cognitive Decline in the Elderly; KQ = key question; MCI = mild cognitive impairment; MIS(T) = Memory Impairment Screen by Telephone; MMSE = Mini-Mental State Examination; MoCA = Montreal Cognitive Assessment; MSQ = Mental Status Questionnaire; NA = not applicable; NR = not reported; NSAID = nonsteroidal anti-inflammatory drug; RCT = randomized, controlled trial; SER = systematic evidence review; Sn = sensitivity; Sp = specificity; SLUMS = St. Louis University Mental Status; SPMSQ = Short Portable Mental Status Questionnaire; TICS = Telephone Interview for Cognitive Status; TICS(M) = Telephone Interview for Cognitive Status Modified; VAT = Visual Association Test; 7MS = 7-Minute Screen.

Our review identified a very large body of well-conducted trials examining the efficacy and effectiveness of a broad range of interventions aimed at either the patient or the caregiver. However, none of these trials examined the ability of interventions to change decisionmaking of the patient, caregiver/family, or clinician. Currently, the two most developed bodies of intervention literature address FDA-approved medications to treat AD and psychoeducational caregiver interventions. These types of interventions appear to have benefit in people with moderate dementia; however, the clinical importance of this benefit and the degree to which it might apply to older adults with screen-detected cognitive impairment is uncertain. AChEIs and memantine can improve global cognitive function and AChEIs can improve global function in the short-term for people with moderate AD. Much more limited evidence exists for people with mild AD or other types of dementia. The average effects of changes in cognitive functioning observed in trials, however, are small and the clinical importance is likely negligible when using commonly accepted thresholds to interpret this change. While clinically important benefits may exist for targeted individuals, trials included in our review did not distinguish which individuals would most likely benefit. Likewise, complex interventions aimed at caregivers and patient-caregiver dyads (including case management, caregiver support interventions) can improve caregiver burden and depression, but the average effects of benefit in these trials are small and the clinical importance of these small changes on outcome measures remains unclear. Based on more limited evidence, cognitive stimulation can also improve (or prevent decline of) global cognitive function. A very wide 95 percent CI, however, limits our ability to determine the magnitude of benefit. Inconsistent reporting also limits our ability to interpret the effect of these pharmacologic and nonpharmacologic interventions on other important patient outcomes (e.g., HRQL). Discontinuation of AChEIs is common, and serious harms of AChEIs can include central nervous system, cardiovascular, and gastrointestinal signs and symptoms. Harms were not reported for caregiver interventions or cognitive stimulation, but are assumed to be minimal.

A much smaller, and newer, body of literature examines the test performance of various screening instruments and the effectiveness of various interventions for MCI (Table 16). These studies generally used different diagnostic criteria to identify MCI, and none of the studies used the most recent criteria as defined by the National Institute on Aging-Alzheimer's Association. The diagnostic accuracy of these instruments (i.e., CDT, Mini-Cog, TICS, MMSE, MoCA, and IQCODE) in primary care–relevant populations suggest they have much lower sensitivity to detect MCI than dementia, despite adjustment of diagnostic thresholds/cut-points. The AD8, FOME, SLUMS, and CAMCI are all promising instruments, although their test performances have not yet been reproduced in unselected populations. Currently, the benefit of AChEIs, memantine, and cognitive stimulation on global cognitive function and other important outcomes remains uncertain for people with MCI due to the small evidence base with mixed findings.

### Screening

Our review identified a number of brief instruments that primary care providers can use to screen for cognitive impairment (Table 16). The MMSE is the best studied of these instruments; pooled estimates across 14 studies (n=10,185) resulted in 88.3 percent sensitivity (95% CI, 81.3% to 92.9%) and 86.2 percent specificity (95% CI, 81.8% to 89.7%) for a cut-point of 23/24 or 24/25. Using higher cut-points (k=3; n=1,544) did not improve sensitivity to detect MCI. Researchers have also studied other instruments, including the CDT, Mini-Cog, MIS, AMT, SPMSQ, FCSRT, 7MS, TICS, and IQCODE, although this research is less extensive. Based on these studies, the CDT (k=7; n=2,509) had a much wider range of sensitivity and specificity (67% to 97.9% and 69% to 94.2%, respectively), and the optimal cut-point was unclear in the body of literature we examined. The Mini-Cog (k=4; n=1,570) likely has better sensitivity than the CDT alone (76% to 100%), but with a possible tradeoff of lower specificity (54% to 85.2%). For MCI, the CDT (k=4; n= 4,191) and Mini-Cog (k=3; n=1,092) clearly have much lower sensitivity. Although the MIS (k=5; n=1,971) and AMT (k=4; n=824) can have relatively good test performance to screen for dementia, sensitivity in the best-quality studies was very low (∼40%). The SPMSQ (k=4; n=1,057), FCSRT (k=2; n=734), TICS (k=2; n=677), and 7MS (k=2; n=553) also have reasonable test performance to detect dementia, although this is based on a very limited number of studies and unknown optimal cut-points for each instrument. If an informant-based screening tool is desired, the IQCODE may be a reasonable option to screen for dementia (k=5; n=1,251), although the optimal cut-point is unclear. There is less evidence to support its use to detect MCI (k=4; n=975). The majority of the diagnostic accuracy studies did not specify what types of dementia were identified, although the majority of cases were presumed to be AD. Only five studies addressed screening for specific types of dementia and none of them reported the test performance separately for each type of dementia.171,172,174,175,197 One included study by Borson and colleagues found that the percent of cases correctly identified by the Mini-Cog was 99 percent of AD cases, 100 percent of VaD cases, and 82 percent of other dementia cases.172

Our review findings for the diagnostic accuracy of screening for dementia are generally consistent with other recent existing reviews.2,19,186,409 Our review includes twice the number of studies as the most comprehensive existing reviews.19,409 Our review, however, excludes many studies that were included in these prior reviews because we were more stringent on the internal validity (i.e., we excluded studies without a true reference standard or with significant verification bias, case-control studies, or generally poor-quality studies) and external validity (i.e., we excluded studies evaluating lengthy instruments not feasible in primary care, or studies conducted in memory clinics or other specialty care or referred populations). The previous systematic review conducted for the USPSTF included a more limited body of evidence and somewhat more selective literature, which was less applicable to populations in primary care.2 This review found the most robust evidence for the MMSE, and that depending on the cut-point, sensitivity and specificity was approximately 91 to 92 percent and 56 to 96 percent, respectively. This review acknowledged the well-recognized differences in test norms based on age and education, although there is no commonly accepted (standardized) cut-point adjustment by age and education. A subsequent review by Holsinger and colleagues for the Rational Clinical Exam series updated the USPSTF review to 2006.^19^ This review had similar findings for the MMSE and found that a few other instruments had reasonable test performance, including the MIS, AMT, CDT, 7MS, and GPCOG; however, all findings were based on very limited studies.19 It found that the MIS had the best test performance (likelihood ratio), but was evaluated in only one study.19 Another recent review by Brodaty and colleagues, through January 2004, found similar commonly evaluated instruments, including the CDT, Mini-Cog, MIS, AMT, MMSE, and IQCODE.409

This review found that the GPCOG, Mini-Cog, and MIS performed better than the MMSE; however, this is based on only one study evaluating each instrument.409 One review, focused exclusively on the MMSE, estimated sensitivity and specificity at 78.4 and 87.8 percent (CIs not reported), respectively.76 While these estimates fall within our range of estimates, we caution overemphasizing the pooled estimates given the clinical heterogeneity across studies (i.e., differences in populations and cut-points).76 One review specifically addressed the differential ability of the various cognitive screening instruments to detect the different types of dementia.186 Because many of the instruments focus preferentially on memory dysfunction (as opposed to other domains of cognitive function), which is the hallmark of AD, but is not necessarily impaired at an early stage with other types of dementia, it is thought that some instruments may perform better (or more consistently) across different types of dementia. This review found that the instruments that rated the “highest” with regard to validation methods, reliability, test performance, and coverage of key cognitive domains included the MMSE and instruments that expand on the content of the MMSE (from which an MMSE score can be derived). The authors concluded that despite an understandable drive toward ultra-brief tests which can be used in a typically time-constrained general practitioner consultation, an administration time of more than 10 minutes appears to be an unavoidable cost of achieving sufficiently robust statistical performance while covering key domains.186

Screening for cognitive impairment may have direct or indirect harms from the diagnostic inaccuracy of screening (false-positives and false-negatives). However, we found no studies to substantiate or refute the concern about harms of screening. We included only one small fair-quality study that addressed harms, which found that the refusal rate for subsequent diagnostic assessment can be very high, suggesting patient issues with subsequent testing or diagnostic confirmation of screening results; however, this study did not directly assess psychological harms.206,207 Studies not included in our review suggest that patients with dementia, even if upset with their diagnosis, wanted to know their diagnosis,410 and that willingness to participate in screening is directly associated with perceptions about the benefits of screening.411 Although screening itself, and the subsequent diagnostic workup for abnormal results, is generally noninvasive, there may still be significant harm from false-positives if patients or clinicians do not follow through with subsequent diagnostic testing. Thus, if false-positives are a concern, instruments (or cut-points) with very high specificity should be given preference. Potential harms from false-negatives, if they are of concern, can be minimized with repeated screening.

### Treatment

Our review was not a comprehensive analysis of all treatment and management options for people with cognitive impairment; instead, we focused on selected interventions aimed at people with mild to moderate dementia and/or MCI (i.e., those populations more representative of screen-detected older adults with cognitive impairment). We reviewed currently available pharmacologic interventions in the United States, including: 1) FDA-approved medications for use in AD, namely AChEIs and memantine (although memantine is currently approved for use in patients with moderate to severe AD, we included only those trials evaluating this medication in our population of interest); 2) potentially disease-modifying medications (i.e., antiplatelet therapy, antihypertension therapy, HMG Co-A reductase inhibitors, NSAIDs, gonadal steroids); and 3) potentially disease-modifying vitamins or supplements, not including herbal supplements (e.g., gingko biloba). Nonpharmacologic interventions covered in this review include: 1) focused and complex interventions aimed primarily at the caregiver or patient-caregiver dyad; and 2) focused and complex interventions aimed primarily at the patient (i.e., interventions to support or enhance cognitive function and/or physical function, education, and multidisciplinary care interventions involving assessment and care coordination).

Overall, based on a large body of evidence, including one systematic review of 50 RCTs and 14 subsequently published RCTs, AChEIs and memantine can improve global cognitive function in the short-term (average effects of 1- to 3-point change on the ADAS-cog) (Table 16). The vast majority of evidence is from trials in people with AD and with followup limited to 6 months. Using commonly accepted values to interpret the clinical importance of these changes (i.e., 4-point change in ADAS-cog over 6 months), it appears that the average effect of these changes may not be clinically important. The prediction interval for the pooled analyses on ADAS-cog outcomes usually crossed into statistical nonsignificance for each of these medications, indicating the statistical significance of the pooled effect may not be robust to the addition of new trials (data not shown). The prediction interval gives the upper and lower bounds of the true effect in 95 percent of cases of a new (yet unpublished/not conducted) study, assuming the same level of statistical heterogeneity. Measures of global functioning (e.g., CIBIC-plus) were less commonly reported, but were still reported in the majority of trials. AChEIs appear to consistently improve measures of global functioning in people with AD in the short-term, but memantine does not. Although the CIBIC-plus is inherently a clinically relevant measure of function, and as a result any change in score is generally considered clinically important, improvement in trials were less than 1-point change (a fraction of a point on a 7-point scale). Only seven trials and eight OLEs of included trials had longer-term followup that demonstrated similar effects of benefits for AChEIs but not memantine compared with 6-month followup from trials. Two trials of donepezil in people with MCI showed no difference in progression to AD at about 3 years. Outcome measures of overall physical function were not commonly reported, and these measures showed mixed results when they were reported. Therefore, it is unclear what impact these medications have on global physical functioning given the inconsistent reporting and findings.

Our review findings update the large body of evidence summarized by Raina and colleagues.110 Findings from published trials since this review are entirely consistent with Raina's findings for AChEIs and memantine, with the largest addition of evidence for rivastigmine. Findings from trials of memantine published after this review are less consistent, as findings from three additional trials in people with mild to moderate dementia did not show a benefit in global functioning,224-226 in contrast to the small benefit in global functioning observed in the five trials included in the review by Raina and colleagues. Our review's findings on the benefit and magnitude of benefit are also consistent with evidence that supports the March 2011 NICE guidelines on the use of donepezil, galantamine, rivastigmine, and memantine for the treatment of AD. This evidence also included a wider range of studies, including comparative effectiveness trials, open-label studies, observational studies of effectiveness, and unpublished data submitted by pharmaceutical companies.412 In addition to our review findings, the NICE guideline included evidence to suggest that: 1) based on observational studies, cognitive benefits from donepezil can be maintained for up to 3 years; 2) based on a single RCT, rivastigmine had a significant difference in improvement of global outcomes but not cognitive function compared with donepezil; and 3) based on mixed treatment comparison using Bayeseian Markov chain Monte Carlo sampling, AChEIs provided benefits for cognitive function, as well as physical function (as measured by ADLs). Finally, evidence for these medications in people with MCI is much more limited (k=5). While these trials show a small statistically significant benefit for donepezil and galantamine (but not memantine) on global cognitive function, the magnitude of this effect is likely not clinically meaningful. Our review's findings are consistent with a recent Cochrane review of AChEIs for MCI, which found no difference from placebo for progression to MCI at 1 and 3 years.413

Based on 66 RCTs, six OLEs of included RCTs, and 13 other observational studies, it is clear that AChEIs and memantine have adverse effects (Table 16). Discontinuation due to adverse effects from AChEIs was higher in treatment groups compared with placebo groups, but this trend was not apparent for memantine. While there did not appear to be an increase in serious adverse events (excluding tacrine) in trials with selected populations and limited duration of followup, the estimates of total serious adverse events for AChEIs in one observational study were higher than proportions of serious adverse events observed in trials. From observational studies, AChEIs increase the risk for bradycardia and falls, syncope, and pacemaker placement due to bradycardia. Due to resource limitations, our review did not report the proportion of specific types of adverse events or side effects and did not search the FDA databases for additional harms not reported in published studies. Types and relative frequencies of specific adverse effects are well described in narrative reviews and pharmacologic references. The most common adverse reactions for AChEIs include gastrointestinal symptoms (i.e., nausea, vomiting, diarrhea, anorexia, and abdominal discomfort), central nervous system symptoms (i.e., dizziness, headaches, sleep disturbance, somnolence, confusion, fatigue, depression, and other mood or neuropsychiatric disturbances), and cardiovascular signs/symptoms (i.e., bradycardia, hypertension, syncope, and chest pain).414-416 The most common adverse reactions for memantine include gastrointestinal symptoms (i.e., constipation, vomiting), central nervous system symptoms (i.e., dizziness, headaches, somnolence, confusion, fatigue), and cardiovascular signs (i.e., hypertension).417 An older review from 2006 by Hansen and colleagues was conducted as part of the Drug Effectiveness Review Project.418 This review, designed to evaluate the effectiveness and comparative effectiveness of these medications, included a hand search of the Center for Drug Evaluation and Research database to identify unpublished research submitted to the FDA and dossiers submitted by pharmaceutical companies. Neither of these sources contributed any unpublished evidence on harms for currently used medications (excluding tacrine).418

We found 26 RCTs that evaluated other medications or supplements, including low-dose aspirin, HMG-CoA reductase inhibitors (simvastatin and atorvastatin), NSAIDs (ibuprofen, naproxen, indomethacin, and celecoxib), gonadal steroids (estrogen plus or minus progesterone and testosterone), and dietary supplements (multivitamins, B vitamins, vitamin E plus or minus vitamin C, and omega-3 fatty acids). However, we found no trials evaluating antihypertension therapies that met our inclusion criteria. We found no benefit on global cognitive or physical function in people with mild to moderate dementia or MCI for any of these medications or supplements (Table 16). Our review's findings for these medications are consistent with other existing reviews for HMG-CoA reductase inhibitors,419,420 aspirin and NSAIDs,421 gonadal steroids,422 B vitamins,111-115,423,424 vitamin E,425 and omega-3 fatty acids.115,116

We found that complex psychoeducational interventions aimed at caregivers or dyads (k=52) have a small benefit on caregiver burden and depression outcomes based on a large body of literature that evaluated nonpharmacologic interventions. While there were substantial clinical differences (and statistical heterogeneity) among interventions, these interventions generally provided education about dementia and/or caregiving, caregiver skills training, and formal mechanisms of support. Interpretation of the standardized effect sizes and their 95 percent CIs range from very small (about 0.1) to small (about 0.3), which represented a 0- to 5-point change on the Zarit CBI (88-point scale) or 2- to 5-point change on the CES-D (60-point scale). Furthermore, prediction intervals for the pooled analyses on caregiver burden and depression outcomes indicate the statistical significance may not be robust to the addition of new trials (data not shown). Unfortunately, inconsistent reporting of other self-reported outcomes (e.g., global stress or distress, anxiety, HRQL, self-reported health status) and institutionalization limits our ability to interpret the clinical importance and consistency of findings for these outcomes. None of the included trials reported harms. We did not identify any additional studies that explicitly evaluated harms of caregiver interventions.

Our review is generally, but not entirely, consistent with existing systematic reviews on caregiver interventions, including case management interventions. Existing systematic reviews varied in the trials they included, with slight differences in focus and inclusion criteria. Nonetheless, existing reviews generally found that caregiver or dyad interventions (including caregiver support and case management) could improve caregiver burden (or well-being) and depression. These reviews lacked evidence for delaying institutionalization.98,426-429 Magnitude of effect on caregiver outcomes varied slightly due to differences in included trials and definitions of outcomes; however, effect sizes were generally small to moderate, with 95 percent CIs inclusive (consistent) with our review findings. Differences in findings of benefit on institutionalization are due to differences in included trials, based on our review's exclusion criteria (exclusion of people with moderately severe to severe dementia, respite care interventions, and trials without a true control or usual care group). Our review included a larger number of trials than other reviews, with 21 interventions aimed at the caregiver or dyad reporting institutionalization, only one of which showed statistically significant differences in institutionalization between trial arms.361

Based on a subset of trials (k=6; n=513) evaluating cognitive interventions, cognitive stimulation with or without cognitive training can improve global cognitive function in persons with MCI or dementia at 6 to 12 months. However, the statistical heterogeneity among trials and imprecision of the estimate (very wide 95% CI) was large. Given the relatively small sample size and high statistical heterogeneity, the prediction interval for the pooled analyses on global cognitive outcomes was not statistically significant (data not shown). Therefore, although promising, the certainty and magnitude of effect of cognitive stimulation in people with mild to moderate dementia or MCI is still unclear based on our review's findings. Findings from existing systematic reviews evaluating cognitive interventions were generally consistent with our review findings, although our conclusions based on these findings are a bit more understated.430-432 A recent Cochrane review by Woods and colleagues found these interventions (k=15; n=718) consistently improved global cognitive function (SMD, 0.41 [95% CI, 0.25 to 0.57]; I^2^=0%). This review differed from our review in its focus on persons with mild to moderate dementia, exclusion of institutionalized individuals, and differences in outcome analyses.430

Although there was no consistent benefit observed for exercise interventions (k=10; n=1,033), three of the better-conducted trials suggest a benefit in global cognitive function in people with MCI or physical functioning and HRQL in persons with dementia at 12 to 18 months. Overall, the clinical impact of exercise in people with impaired cognitive function is unclear, due to the limited number of trials and variation in populations, interventions, and reported outcomes. Our review's sparse and mixed findings were consistent with another existing systematic review's findings in noninstitutionalized older adults with dementia.433

## Applicability of Findings to Practice

### Implementation of Screening

Our review included brief screening instruments that could be reasonably administered in primary care (i.e., before, during, or after visits) by a clinician or primary care staff with minimal training or self-administered by the patient or a close informant. While most of the included instruments are available in the public domain, the MMSE (which remains the best-studied instrument) and the TICS (an instrument designed to be delivered by telephone) are two notable exceptions. The cost of the instrument is likely a significant barrier to its implementation given other, albeit less well-studied, alternatives. The opportunity cost of screening can be minimized by choosing very brief instruments or those that can be self-administered. However, we acknowledge that there are implications for the subsequent workup of people with screen-detected impaired cognitive function, including issues around guidance on best practices for satisfactory diagnostic workup, resources and capacity for neuropsychological testing or referral to neurology, psychiatry, or geriatric specialty services (if needed), and the potential for refusal of diagnostic workup and issues around acceptability of further testing and the diagnosis itself.

The Patient Protection and Affordable Care Act of 2010 introduced an Annual Wellness Visit, as part of Medicare, which requires an assessment to detect cognitive impairment. Currently, while CMS does not prescribe any standardized cognitive assessment instrument, it is currently working with others (i.e., National Institute on Aging) on potential recommendations for use of specific instruments.434 In addition, the Alzheimer's Association convened a workgroup to develop recommendations on how to operationalize the Annual Wellness Visit cognitive impairment assessment. This group recently outlined a stepwise approach and recommends the use of specific instruments (GPCOG, Mini-Cog, MIS, AD8, or short IQCODE; alternate tools, including the MMSE, SLUMS, or MoCA, at discretion of the clinician) in people at high risk for or those who have suspected cognitive impairment based on clinician observation, self- (or informant) reported concerns, and review of a Health Risk Assessment that includes questions on subjective cognitive complaints, ADLs, and IADLs. This approach is essentially a two-step screening process: screening with an assessment of ADLs/IADLs and a question on cognitive complaints, followed by a brief instrument designed to assess cognitive impairment. We found no evidence to support or refute this proposed method. Specifically, we found no diagnostic accuracy studies examining a two-step screening approach as described. Furthermore, our review focuses on screening, and therefore did not address the implementation of brief cognitive instruments in people with observed deficits or self-reported concerns (i.e., case-finding). Therefore, this review does not address implementation of testing in people with self-reported subjective memory complaints or known impaired ADLs or IADLs, although these instruments were included as cognitive screening instruments. Expert guidelines, including those of the USPSTF, have consistently recommended that all these people be assessed for cognitive impairment.1,82,83,103,434 It makes clinical sense to identify risk factors or risk assessments to identify people at high risk for cognitive impairment. Other groups (i.e., Centers for Disease Control and Prevention, National Institute on Aging), in addition to the Alzheimer's Association Medicare Detection of Cognitive Impairment Workgroup, are working to determine how best to identify these populations for targeted screening (M. Wagster, oral communication, May 2012). This was beyond the scope of our report.

### Age at Which to Start (and Stop) Screening

(Table 17)

Table 17 Positive and Negative Predictive Values for Various Sensitivity, Specificity, and Prevalence Percentages

Age (y) | Prevalence of Dementia | PPV 70/80^*^ | PPV 70/90^*^ | PPV 80/80^*^ | PPV 90/80^*^ | PPV 90/70^*^ | NPV 70/80^*^ | NPV 70/90^*^ | NPV 80/80^*^ | NPV 90/80^*^ | NPV 90/70^*^
65-69 | 1 | 3.41 | 6.60 | 3.88 | 4.35 | 2.94 | 99.6 | 99.7 | 99.7 | 99.9 | 99.9
70-79 | 5 | 15.6 | 26.9 | 17.4 | 19.1 | 13.6 | 98.1 | 98.3 | 98.7 | 99.3 | 99.3
70-79 | 10 | 28.0 | 43.8 | 30.8 | 33.3 | 25.0 | 96.0 | 96.4 | 97.3 | 98.6 | 98.4
80-84 | 15 | 38.2 | 55.3 | 41.3 | 44.3 | 34.6 | 93.8 | 94.4 | 95.8 | 97.8 | 97.5
80-84 | 20 | 46.7 | 63.6 | 50.0 | 52.9 | 42.9 | 91.4 | 92.3 | 94.1 | 97.0 | 96.6
85+ | 25 | 53.8 | 70.0 | 57.1 | 60.0 | 50.0 | 88.9 | 90.0 | 92.3 | 96.0 | 95.5
85+ | 30 | 60.0 | 75.0 | 63.2 | 65.9 | 56.3 | 86.2 | 87.5 | 90.3 | 94.9 | 94.2
85+ | 40 | 70.0 | 82.4 | 72.7 | 75.0 | 66.7 | 80.0 | 81.8 | 85.7 | 92.3 | 91.3

* Sensitivity/Specificity.

Note: All prevalence, PPV, NPV, sensitivity, and specificity values are percentages.

Abbreviations: PPV = positive predictive value; NPV = negative predictive value.

Age is the biggest risk factor for cognitive impairment. Therefore, if screening is advisable, then using age to target cognitive screening is a reasonable strategy. While population estimates vary, the best estimates for dementia prevalence in North America are generally low (<5%) before ages 70 to 75 years.5,22 Prevalence of dementia increases with each decade of life. Between ages 70 to 75 years and 80 to 85 years, dementia prevalence ranges from about 5 to 20 percent. Dementia prevalence is quite high at age 80 or 85 years and older (>20%).5,22

The prevalence of dementia greatly affects the positive predictive value (PPV) of testing and therefore can be used to infer reasonable ages at which to start screening for cognitive impairment or possibly target subpopulations in which it could be reasonable to start earlier screening, if advisable (Table 17). Looking across a range of sensitivities and specificities representative of currently available brief cognitive screening instruments (based on our review), it appears that the PPV is greater than 50 percent if the prevalence of underlying dementia approximates 15 to 20 percent. The general prevalence is much lower in populations younger than age 75 years, as are the PPVs across a range of sensitivities and specificities. If screening is advisable, there is no compelling rationale to stop screening based on increasing prevalence with age. Therefore, the rationale for stopping screening should be based on evidence that intervening in the oldest old (age 85 years and older) does not improve important outcomes or the harms of intervening outweigh the potential benefit. Our review does not support or refute this idea. Arguably, cognitive screening in the oldest old may be considered case-finding as opposed to true screening, as the prevalence of memory complaints is extremely high in this group.5

### Screening Interval

At a population level, the timing and frequency of rescreening is partly dependent on the incidence of dementia and the test performance of the cognitive screening instrument (i.e., rescreening can improve the sensitivity to detect dementia). Overall, there is a wide range of incidence rates. The incidence rate of AD grows exponentially with age, and the estimated doubling time of AD incidence in North America is 6 years.435,436 Incidence rates from one U.S.-based longitudinal cohort study demonstrate that rates increase with age, from 11.7 cases per 1,000 person-years at ages younger than 75 years to 32.0 cases per 1,000 person-years at ages 75 to 79 years, 57.5 cases per 1,000 person-years at ages 80 to 84 years, and 95.9 cases per 1,000 person-years at age 85 years or older.437 The incidence of dementia continues to increase with age even in the oldest old. A population-based longitudinal study of individuals age 90 years and older who did not have dementia at baseline found an overall incidence rate of dementia of 18.2 percent per year, for both men and women.438

If screening is advisable, based on incidence alone, it is reasonable to offer repeated screening, such as annually, and it may be reasonable to increase the frequency of repeated screening with increasing age (or other risk factors), such as more frequent screening in the oldest old (age ≥85 years), based on the very high incidence of dementia in this group. Repeated screening will also improve the cumulative sensitivity to detect dementia. Therefore, it may be reasonable to choose an instrument or scoring/cut-point for a particular instrument with very high specificity (e.g., >90%) at the expense of a slightly lower sensitivity, knowing that with repeated screening over time, the cumulative sensitivity will be much higher. Thresholds for acceptable levels of sensitivity and specificity, and therefore choice of instrument and cut-points, may vary depending on the stakeholder's resources and preferences.

### Impact of (Early) Diagnosis on Decisionmaking

We found no direct trial evidence to address if screening altered patient or clinical decisionmaking. We searched for existing systematic and narrative reviews on this topic to understand the impact of earlier diagnosis (through screening) of dementia, as we were unable to find trial evidence. We found one comprehensive and relevant review in the 2011 World Alzheimer's Report.439 Prince and colleagues attempted to answer if early diagnosis of cognitive impairment benefits people with dementia or their caregivers. Despite an extensive search, the authors found only three observational studies and five consensus statements or practice guidelines that addressed the impact of timing of diagnosis on subsequent disease course and outcomes for people with dementia and their caregivers. One large, observational study suggested that shorter time between first symptoms and first visit to a memory clinic was associated with longer patient survival. This study, however, had numerous limitations: 1) the onset of symptoms was assessed by retrospective recall by patients or relatives at the first visit to the clinic, 2) it is unclear if all important confounding variables were considered and controlled for, and 3) the representativeness of patients in this cohort is unclear, as they were all referred to a tertiary care center. Two additional observational studies attempted to determine the impact of early diagnosis on the subsequent rate of cognitive decline; both studies were relatively small, conducted in referral populations, and had methodological limitations. Despite a lack of empirical evidence, expert consensus statements and guidelines clearly believe that early diagnosis positively impacts important decisionmaking that ultimately will lead to improved patient outcomes and reduced future costs.439 Expert opinions and narrative reviews state that early detection of cognitive decline may be beneficial because it can positively affect one or more of the following: 1) optimizing current medical management (e.g., ability to search for potentially treatable or reversible disorders, factor in patient comprehension and compliance of treatment plans and other conditions, avoid medications with anticholinergic effects, and better manage related symptoms, such as depression and irritability); 2) relief gained from better understanding of symptoms (e.g., greater patient and family understanding and awareness of, and therefore ability to adapt to, diagnosis of dementia); 3) maximizing decisionmaking autonomy and planning for the future (e.g., facilitates involvement of patient and caregivers in planning medical, educational, and psychosocial interventions to suit their needs; identifies a time when the patient can still participate in medical, legal, and financial decisions; and make proxy plans); 4) appropriate access to services (e.g., patients and families can take advantage of appropriate programs and services, including community-based resources); and 5) risk reduction (e.g., greater attention to detail to prevent delirium, motor vehicle accidents, medication errors, and financial difficulties).

### Clinical Importance of Changes in Outcome Measures

The inconsistent reporting of a constellation of important patient (and caregiver) outcomes limits the clinical interpretation of the changes in individual outcomes on the overall patient (and caregiver) health and well-being. For example, small improvement in global cognitive function in the absence of improvement in physical functioning (e.g., ADLs) and HRQL is less convincing of true benefit compared with small improvement in cognitive function accompanied by improvements in ADLs or HRQL, and certainly delay in institutionalization. FDA-approved medications for AD, including donepezil, galantamine, rivastigmine, and memantine, clearly can improve measures of global cognitive outcomes in people with mild to moderate dementia in the short-term (mainly 6 months). In addition, donepezil, galantamine, and rivastigmine can improve measures of global functioning. The average effects range from 1- to 3-point change on the ADAS-cog and a fraction of a point on the CIBIC-plus. The clinical interpretation of these changes is subjective, and not widely agreed upon. We framed our results based on the precedent used by ACP and AAFP, however, such that a change of 4 points or more on the ADAS-cog over 6 months or any change on the CIBIC-plus is clinically meaningful.94 Based on these thresholds, we interpret our review findings to show small but likely clinically unimportant differences in cognitive outcomes, and small but unclear benefit in global functioning (because this outcome was less consistently reported, and the magnitude of change was <1 point). An analogous example is the interpretation of change on a better known clinically relevant scale, such as instruments measuring ADLs. Although any change in ADLs is clinically significant, the clinical meaning of a fraction of a point or a portion of an ADL is less clear. Because these changes in scores represent an average effect across a population, one could argue that a clinically more intuitive way of understanding the benefit is the reporting of dichotomous outcomes, such as the proportion of people with a clinically significant change on the ADAS-cog in the treatment group versus the placebo group. For example, it would be helpful to know if the average effect of a 2-point change on the ADAS-cog represents 50 percent of participants with a 4-point improvement (i.e., 50% “responders”) or 100 percent of participants with a 2-point improvement (i.e., 100% “nonresponders”). These dichotomous outcomes were rarely reported.

Complex caregiver interventions resulted in improvement in caregiver burden and depression outcomes. We found no guidance on the interpretation of clinically meaningful changes on caregiver burden and depression outcome measures. In general, absolute changes ranged from 0 to 5 points on multiple-item instruments (88-point Zarit CBI, 96-point RMBPC subscale, and 60-point CES-D). For depression outcomes, control groups typically showed small increases in depressed mood and intervention groups showed small improvements; however, baseline depression was typically in the minimal or mild range (e.g., average score of 12–15 on the CES-D, in which a score of 16 indicates possible depression). Using accepted thresholds to interpret standardized effect sizes, the effects on caregiver burden and depression outcomes ranged from very small (0.1) to small (0.4).

The clinical meaning of the changes is further complicated by the inconsistent reporting of other important and related outcome measures, such as HRQL or institutionalization. Many trials, because of their relatively short duration, were not designed to evaluate the impact of interventions on institutionalization. Institutionalization was rarely reported, and when reported, showed no statistically significant difference between treatment and control groups. Delay of institutionalization is clearly a clinically important outcome, as well as one of the main factors in cost of care and cost-effectiveness of interventions.

### Availability of Nonpharmacologic Interventions

The most promising nonpharmacologic interventions for people with mild to moderate dementia are complex caregiver interventions, which often involve multiple components (e.g., individual support, case management), as well as cognitive stimulation. Neither type of intervention is widely available in the United States. In fact, many trials evaluating complex caregiver interventions used widely available resources, such as support groups provided by (or modeled after) the Alzheimer's Association, as the control arm. From our review, the optimal intervention components for effective interventions (caregiver interventions) and the optimal format or intensity (dose/duration) are unclear, but as a whole, both caregiver and cognitive stimulation interventions can be quite resource-intensive, requiring specialist staff with training and multiple sessions over several months.

## Review Limitations

Our review has several important limitations given our primary aim and targeted audience—the USPSTF. Our review is not meant to be a comprehensive review of all cognitive screening instruments, nor a comprehensive review of all dementia treatments/interventions. We focused on the best-quality evidence of estimates of diagnostic accuracy of cognitive screening instruments in unselected community-dwelling older adults relevant to primary care in the United States. We therefore excluded case-control studies, studies without a true reference standard, studies only evaluating the correlation between screening instruments, instruments with lengthy administration time, institutionalized older adults, and populations selected for cognitive impairment or referred for subjective memory complaints, including populations exclusively from memory, neurology, and geriatric psychiatry clinics, and Alzheimer's Disease Research Centers. Due to these restrictions in scope, our review does not address several important aspects of screening test performance, including: the psychometric properties of testing, validation of screening instruments in different languages, optimal cut-points in scoring the included instruments, differential ability of instruments to detect different types of dementia, comparative performance of screening instruments, or ability to improve diagnostic performance by combining screening instruments (unless the instrument itself is a combination of instruments, such as the Mini-Cog is a combination of the CDT plus three-item recall).

Likewise, our review focuses on the best-quality evidence for specific currently used interventions aimed at community-dwelling older adults with screen-detected cognitive impairment, specifically people with mild to moderate dementia or MCI. Therefore, we excluded experimental interventions, interventions aimed at later stages of dementia, interventions aimed primarily at symptom management, institutionalized populations, and populations with moderately severe to severe dementia. We also excluded primary prevention trials; that is, trials in healthy older adults evaluating interventions to prevent, delay, or slow cognitive decline. Despite our best efforts, there may have been some inconsistency in operationalizing these inclusion criteria due to reporting in individual studies, studies with mixed populations, and different definitions of care settings in different countries (i.e., we included people in assisted living facilities, older adult homes, and residential care facilities, but excluded people in skilled nursing homes). For evidence of effectiveness, we limited our included studies to trial designs with a true or usual care control. Again, due to limited reporting of usual care and control groups in individual trials, there may have been some inconsistency in the operationalization of usual care or minimally active control group. Due to these limitations, our review does not address: the overall effectiveness (or harms) of each type of intervention, only the effectiveness (or harms) in a subset of people with mild to moderate dementia or MCI, the comparative effectiveness of different types of interventions (what works better or what dose works better), or the minimal/necessary components (including intensity/duration) needed for the effectiveness of complex interventions.

Due to resource limitations, we did not search FDA databases or contact industry for data on pharmacologic interventions. However, an older review from 2006 by Hansen and colleagues designed to evaluate the effectiveness and comparative effectiveness of AChEIs and memantine included a hand search for unpublished research submitted to the FDA and dossiers submitted by pharmaceutical companies, which did not contribute any unpublished evidence on harms for currently used medications (excluding tacrine).418 Due to resource limitations, we focused our synthesis of adverse effects on those interventions with a benefit, serious harms, larger observational studies (n>1,000), or those observational studies with longer-term followup (>1 year).

## Study Limitations and Future Research Needs

Despite such a large and rapidly growing body of research around screening for cognitive impairment, as well as treatment and management of people with dementia and MCI (Appendix G Table 1), there are several important research gaps. First is the lack of evidence around decisionmaking outcomes. Experts in the field argue that early diagnosis is important because it impacts clinical and patient decisionmaking. While this is a logical argument, there is currently little to no empirical evidence to support it. Older adults with dementia generally have multiple comorbid conditions in addition to their cognitive impairment. Researchers should conduct screening trials or observational studies to demonstrate changes in decisionmaking (at a minimum) and patient or caregiver outcomes (as an ideal). Studies examining how (and if) earlier identification of cognitive impairment or earlier management of patients with dementia and their caregivers impact clinician decisionmaking (e.g., medical management of comorbid conditions) and patient and family decisionmaking (e.g., advanced planning) are extremely important aspects to understand in order to better manage this rapidly growing health care problem.

Second, and perhaps equally as important, is how best to identify persons with cognitive impairment. Dementia is underdiagnosed in primary care. Researchers should conduct studies to understand how best to (systematically) identify persons with cognitive impairment. Based on empiric evidence, it is still unclear how best to apply brief cognitive assessment tools to aid in the identification of dementia. These brief instruments can be applied broadly to all older adults, (i.e., population-based screening) or in more targeted approaches, as suggested by the Annual Wellness Visit. To assist operationalizing the Annual Wellness Visit's mandate to assess for cognitive impairment, experts have suggested a step-wise approach to identify persons in whom a brief cognitive instrument should be applied. Research comparing what criteria (e.g., age, comorbid condition, functional status) should lead primary care clinicians to conduct cognitive assessment is needed.

Third, the harms of screening are very poorly studied. Some have argued that the harms of screening, other than the opportunity cost, are minimal given the noninvasive nature of screening and subsequent diagnostic workup. Other experts have argued that the harms of screening and mislabeling persons with dementia are quite real given the variation in practice of diagnostic confirmation of disease. If a broader adoption of screening for cognitive impairment is implemented in primary care, we need a better understanding of what, or if, harmful tradeoffs exist.

Fourth, while there are many well-designed diagnostic accuracy studies, there is still very little reproducibility of test performance of brief instruments that could be used in primary care among these studies. In some cases in which there are multiple studies, there appears to be important variation in test performance, which may be due to differences in populations or administration and scoring (choice of cut-point) of the instrument itself. Additional evaluation of these screening instruments in more representative populations is needed after studies have been validated in higher-risk populations (e.g., memory clinics) and/or with initial validation studies (e.g., case-control studies). Well-conducted diagnostic accuracy studies for the most promising instruments need to be reproduced in relevant populations. These diagnostic accuracy studies should report adequate baseline population characteristics, including age and education (any characteristic known to affect normative values of the instrument). These studies should report multiple cut-points if applicable, and be explicit about scoring methods or choice of cut-points (if multiple options exist).

Fifth, the clinical areas of defining, diagnosing, and treating cognitive impairment earlier (before loss of IADLs) are rapidly evolving. Experts in this field are actively working to refine diagnostic criteria and to standardize the identification of people with MCI or “mild neurocognitive disorder,” as called in the DSM-V. Ongoing research studies are evaluating different variants and operational definitions of the current MCI criteria. Future research should focus on improved criteria and subtypes of MCI with demonstrated prognostic and predictive value. The outcome (i.e., progression, regression, stability) of MCI reflects: 1) its underlying etiology, and thus subtypes should map to the underlying disease (e.g., amnestic MCI is more likely to represent underlying AD and therefore more likely to progress to dementia than nonamnestic MCI); 2) the individual patient's characteristics (i.e., age and comorbid conditions); and 3) how the population being studied is selected (e.g., clinic, research setting, community setting). These considerations should be incorporated into future research to understand the natural history of MCI, develop or improve MCI diagnostic criteria, identify subtypes, and standardize criteria. Criteria with established predictive value should then be operationalized in a standardized fashion in research studies, both in specialized settings (e.g., Alzheimer's Disease Research Center, memory clinics) and less selected populations (e.g., primary care or community-based settings).

Sixth, similar to diagnostic accuracy studies for detecting dementia, diagnostic accuracy studies for MCI should also report adequate baseline population characteristics and be explicit about scoring/cut-points (thresholds) used, reporting test performance for multiple cut-points if applicable (e.g., for different levels of age and education).

Seventh, while our report did not evaluate the role of biomarkers (i.e., plasma, urine, CSF) or imaging in screening for diseases affecting cognition, such as AD (as this field is still developmental), it is an active field of research. Ongoing research focuses on using these tests for early (even preclinical) detection of disease. If these types of tests prove useful in the diagnosis of types of dementia or MCI, they may provide an additional “gold standard” for diagnostic accuracy and calibration. They may also be useful for case-finding or screening purposes, should the eventual discovery of reliable, valid, sensitive, specific, and affordable tests manifest.

Eighth, the body of evidence around mild to moderate dementia treatment and MCI is very large and rapidly evolving (Appendix G Table 1). The overwhelming majority of evidence is in people with AD, and additional research is needed for the effectiveness of various interventions in other types of dementia, including VaD, FTD, and DLB.

Ninth, the average treatment effects reported for FDA-approved medications for AD and intensive interventions are disappointingly small. Consequently, it is difficult to interpret the clinical importance of such small changes. It is also possible that outcome measures themselves may have limited responsiveness (sensitivity to detect change) in patients with less pronounced cognitive impairment. For example, the ADAS-cog and MMSE may have ceiling effects and are therefore unable to show benefit in people with MCI or even mild dementia. Other important outcomes, such as global functioning, HRQL, global physical functioning, emergent or unexpected health care utilization, and institutionalization, are inconsistently reported (with the exception of CIBIC-plus as reported in drug trial literature). Inconsistent reporting could be symptomatic of selective reporting or inconsistent use of these outcome measures. Whatever the reason, this limits our ability to interpret effects on these outcomes as a body of literature. Given these challenges in interpreting the clinical significance of benefit (or even lack of benefit) in treatment trials, we suggest that trials should consistently report a constellation of important self-reported and objective outcomes (e.g., emergency visits and institutionalization). This might be difficult given that trials are costly to conduct and have very limited duration of followup, in most cases, generally less than 12 months (many drug trials have only 6 months followup). Longer duration of trials is also important to understanding the clinical significance of small changes on outcome measures, especially during earlier stages of dementia (i.e., may need longer duration of followup to observe benefit). For outcome measures with accepted thresholds of clinical significance, consistent and standardized (using same thresholds) reporting of results that is dichotomized into “responders” and “nonresponders” will also be helpful in interpreting the small average effects on continuous outcome measures.

Finally, while our report did not evaluate the effectiveness of experimental therapies targeted to alter the disease process, disease-modifying therapies (e.g., immunotherapy) to slow cognitive decline is an extremely active area of research.

## Conclusions

Currently, there is no trial evidence that addresses whether screening for cognitive impairment or early diagnosis of cognitive impairment improves patient, caregiver/family, or clinician decisionmaking or improves important patient, caregiver, or societal outcomes. Several brief screening instruments can adequately detect dementia, especially in populations with a higher prevalence of underlying dementia. Harms of screening for cognitive impairment, however, are not well studied. AChEIs, memantine, complex caregiver interventions, and cognitive stimulation all have evidence to support their use in mild to moderate dementia. However, the average effects of benefits observed in trials for these medications and caregiver interventions are generally small and in people with moderate (as opposed to mild) dementia. Therefore, the clinical importance and applicability of these interventions to screen-detected people with cognitive impairment is not clear. This benefit is also limited by commonly experienced side effects of AChEIs and limited availability of complex caregiver interventions. Cognitive stimulation appears promising in people with MCI and mild dementia, but the evidence base is small and the imprecision around the estimates of benefit limit the clinical interpretation of the benefit on cognitive functioning. Current evidence on screening for MCI includes studies that use different criteria to define this entity, sensitivity of the few instruments evaluated to detect MCI are lower (than sensitivity to detect dementia), despite choice of diagnostic cut-point, and there is little evidence for any pharmacologic or nonpharmacologic interventions to improve or preserve patient functioning in people with MCI.