# Results

## Key Questions 1–3 Overall Summary of Results for Screening for Cognitive Impairment

No trials examined the direct effect of screening for cognitive impairment on important patient outcomes, including decisionmaking outcomes. We identified 55 studies that address the diagnostic accuracy of brief screening instruments. The majority of these studies were not included in the prior USPSTF review. In order to be included in our review, the study had to assess the performance of an instrument that could be administered in less than 10 minutes or self-administered in less than 20 minutes. To facilitate discussion of results, we categorized these instruments as very brief (administered in ≤5 minutes), brief (within 6 to 10 minutes), or self-administered. We included 29 very brief instruments, 19 brief instruments, and 5 self-administered instruments (Table 1). All of these instruments can be administered and scored with minimal training.

Table 1 Summary of Included Screening Instruments (Alphabetical Order) (Key Question 2)

Instrument | Time to Administer (min) | Informant | Patient | Languages | # of Items | General Description | Memory | Executive Functioning | Aphasia | Apraxia | Agnosia | Total # of Studies | # of Dementia Studies | # of MCI^*^ Studies
3-Word Memory Test | 3 | | × | English | 3 | 3-item recall | × | | | | | 1 | 1 | 0
6-item screener | 1-2 | | × | English | 6 | 3-item recall plus 3 orientation questions | × | | | | | 1 | 1 | 1
7-Minute Screen (7MS) | 7 | | × | English, Spanish | 11 | Orientation, name objects, recall objects from categories, clock, vegetables | × | × | × | × | × | 2 | 2 | 0
Abbreviated Mental Test (AMT) | 5-7 | | × | English, Dutch, Bangladeshi, Gujarati, Hindi, Punjabi, Urdu | 10 | Orientation, memory, name objects, attention tests | × | | | | × | 4 | 4 | 0
Ascertain Dementia 8 (AD8) | <3 | × | | English | 8 | Asks informant about judgment, less interest in hobbies, repeats things, trouble using tools, forgets month or year, finances, trouble remembering appointments or daily things | × | × | | × | × | 1 | 0 | 1
Benton's Orientation Test | <7^**^ | | × | Spanish | 5 | Identify month, date, year, day of the week, and time of day | × | | | | | 1 | 1 | 0
Brief IADL (4IADL) | <5^**^ | | × | Chinese or English | 4 | Independent activities of daily living | | × | | | | 1 | 0 | 1
Clock Drawing Test (CDT) | 1-3 | | × | English, Spanish, German, Korean | 1 | Clock draw Note: different scoring systems used | | × | | × | | 10 | 7 | 3
Cognitive Assessment Screening Test (CAST) | 15 | | × | English | 28 | Memory, orientation, naming, copy a sentence, copy a figure, addition, fill out a check, clock draw, plus multiple questions about memory complaints, changes in behavior | × | × | × | × | × | 1 | 1 | 0
Computer Assessment of Mild Cognitive Impairment (CAMCI) | NR | | × | English | 8 | Orientation, figure identification, picture recall, word recall, attention, “virtual environment” (follow directions while driving) | × | × | | × | | 1 | 0 | 1
Free and Cued Selective Reminding Test (FCSRT) | <7^**^ | | × | English, Spanish | 16 | Controlled learning of a card with 4 pictures; each with a semantic cue; the patient counts backwards by threes for 20 seconds (as interference for working memory) and then has 3 recall trials without then with the semantic cues | × | | | | | 1 | 1 | 0
Fuld Object Memory Evaluation, abbreviated | 9 | | × | English, Spanish | 10 | Participants attempt to identify 10 common items concealed in a bag and are asked to recall the 10 items 3 different times. Each time after identifying the items, participants receive a semantic fluency distractor task for 60, 30, and 30 seconds, respectively | × | | | | | 1 | 0 | 1
Functional Activities Questionnaire (FAQ) | 5 | × | | Spanish | 10 | Activities and independent activities of daily living, ability to remember appointments, ability to keep track of current events, understanding books | × | × | | × | | 1 | 1 | 1
General Practitioner Assessment of Cognition (GPCOG) | 4-5 | × | × | English | 15 | Recall, orientation, recent news recall. Patient questionnaire is paired with an informant questionnaire that asks about memory, finances, wordfinding, ADLs | × | × | × | | | 1 | 1 | 0
Hopkins Verbal Learning Test (HVLT) | <5^**^ | | × | English | 12 | Immediate recall of objects^†^ | × | | | | | 2 | 1 | 1
Immediate recall | <10^**^ | | × | German | 10 | 10 words are given and patient is asked to recall as many as possible; repeated 3 times with the same words but given in different order | × | | | | | 1 | 1 | 0
Immediate Recall (Logical Memory I) | <7^**^ | | × | Chinese or English | 25 | Evaluator reads a story, then asks patient to remember as many things from story as possible | × | | | | | 1 | 0 | 1
Informant Report of Memory Problems (IRMP) | 1-2 | × | | Chinese or English | 1 | Informant report of memory problems | × | | | | | 1 | 0 | 1
Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE), Short | NR^‡^ | × | | English | 16 | Same as full IQCODE, except has 16 rather than 26 questions | × | × | | × | × | 3 | 2 | 2
IQCODE, Full | NR^‡^ | × | | Spanish, English | 26 | Informant asked to compare patient's current ability with what they remember of patient's ability 10 years ago, such as recognizing faces of family and friends | × | × | × | × | × | 4 | 4 | 3
Katz ADL | ≤5^**^ | | × | Finnish | 6 | Activities of daily living | | × | | × | × | 1 | 1 | 0
Kendrick Cognitive tests | <7^**^ | | × | English | | Recall of outline pictures of common items and speed of copying 10 rows of 10 digits each. Scoring guidelines permit 2 determinations: distinction between dementia and normal and distinction between dementia, depression, and normal | × | | | | | 1 | 1 | 0
Labyrinth Test | <7^**^ | | × | German | 1 | Patient is asked to draw a line that successfully navigates through a maze | | | | × | | 1 | 1 | 0
Lawton IADL | ≤5^**^ | | × | Finnish | 8 | Independent activities of daily living | | × | | × | × | 1 | 1 | 0
Memory Function 2 (MF-2) | 1.5 | × | × | English | 2 | Subjective memory complaints and trouble with executive function Note: This test can be completed by the informant or the patient | × | × | | | | 1 | 1 | 1
Memory Impairment Screen (MIS) | 4 | | × | English | 4 | 4-item recall, either spontaneous or cued recall | × | | | | | 4 | 4 | 1
Memory Impairment Screen by Telephone (MIS-T) | 4 | | × | English | 4 | 4-item recall, either spontaneous or cued recall | × | | | | | 1 | 1 | 0
Mental Status Questionnaire (MSQ) | 4 | | × | English, Dutch | 10 | Memory, orientation, naming, attention | × | | | | × | 2 | 2 | 0
Mini-Cog | 3-4 | | × | English, German | 4 | 3-item recall plus clock draw | × | × | | × | | 4 | 4 | 3
Mini-Mental State Examination (MMSE) | 7-10 | | × | English, Spanish, French, Swedish, German, Dutch, Korean, Chinese- Cantonese, Bangladeshi, Gujarati, Hindi, Punjabi, Urdu, Chinese or English, French or English | 30 | Orientation, recall, naming, draw figure, repetition, attention, reading, writing | × | | × | × | × | 31 | 25 | 14
Minimum Data Set Cognition Scale (MDS-Cog) | <10^**^ | | × | English | 8 | Asks about memory awareness of surroundings; decision-making and understanding; and dressing performance in the previous 7 days | × | × | | | × | 1 | 1 | 0
MMblind | 7-10 | | × | German | 25 | Excludes items from MMSE requiring vision: naming, reading, comprehension, copying, writing, and instructions to handle a sheet of paper, resulting in a maximum score of 22 | × | | × | | | 1 | 1 | 0
Montreal Cognitive Assessment (MOCA) | 10 | | × | Korean | 30 | Trails B, copy figure, clock, naming, verbal fluency, 5-word recall, similarities, orientation, attention | × | × | × | × | × | 1 | 0 | 1
Oral Trails | 4-6^**^ | | × | English | 2 | Asks patient to count out loud from 1 to 25, then alternate between numbers and letters (e.g., 1-A-2-B) | | × | | | | 1 | 1 | 0
Orientation-Memory Concentration (OMC) | 5 | | × | English | 6 | Memory, orientation, concentration | × | | | | | 1 | 1 | 0
Rey figure copy | <7^**^ | | × | English | 1 | Copy a complex figure first with the drawing then by memory | × | × | | × | | 1 | 1 | 0
Self-Administered Gerocognitive Examination (SAGE) | 10-15 | | × | English | 14 | Memory, orientation, copy figure, change figure, naming, math, similarities, clock draw, animals, trails | × | × | × | × | × | 1 | 1 | 1
Short Blessed Test (SBT) | 2 | | × | English | 6 | Memory, orientation, concentration (same as the OMC test) | × | | | | | 1 | 1 | 0
Short Concord Informant Dementia Scale | 6-11 | × | | English | 12 | Questions for informant about perceived changes in memory and ability to find their way around | × | | | | × | 1 | 1 | 0
Short Portable Mental Status Questionnaire (SPMSQ) | 3-4 | | × | English, Spanish, Finnish, Dutch | 10 | Orientation, memory, attention | × | | | | | 4 | 4 | 0
Single-item informant report | 1-2 | × | | English | 1 | Asks about patient memory | × | | | | | 1 | 0 | 1
St. Louis University Mental Status Examination (SLUMS) | 7 | | × | English | 30 | Orientation, 5-item recall, math, animals, attention, clock, figures, story | × | × | × | × | × | 1 | 0 | 1
Storandt Battery | 10 | | × | English | 2 | Word fluency and trailmaking | | × | × | | | 1 | 1 | 0
Subjective memory impairment | 1-2 | | × | German | 1 | Yes/No question: Do you feel like your memory is getting worse? | × | | | | | 1 | 1 | 0
Sweet 16 | 1-3 | | × | English | 16 | Orientation (identification of person, place, time, and situation), registration, digit spans (tests of verbal memory), and recall | × | | | | | 1 | 1 | 0
Telephone for Cognitive Status (TICS) | 7-9 | | × | English, Spanish, French | 11 | Orientation, repetition, naming, and calculations are some of the items covered | × | × | | | | 3 | 2 | 1
Telephone Iinterview for Cognitive Impairment Modified (TICS-M) | 7-9 | | × | English, French, English or Spanish | 13 | Similar to TICS | × | × | | | | 3 | 0 | 3
Trailmaking A and B | 1-2 (A), 2-4 (B) | | × | German | | Different versions have patients go to different numbers/letters | | × | | | | 3 | 2 | 1
Verbal fluency | 1-3 | | × | English, Spanish, German | 1 | Name as many animals, first names, or similar objects as possible in 1 minute | | | × | | | 6 | 6 | 0
Visual Association (VAT) | 4-6 | | × | German | 12 | Visual association and recall | × | | | × | | 1 | 1 | 0
Word List Learning | <7^**^ | | × | German | 8 | Immediate and delayed recall and recognition tasks (delay 20 min). Recognition task is composed of 8 targets and 8 distractors | × | | | | | 1 | 1 | 0

* Includes studies that screened for MCI only as well as studies that screened for MCI or dementia (MCI and dementia results not separated).

** Assumed.

† This test typically includes a delayed recall component as well as an immediate recall. Only the immediate recall was included due to time.

‡ Reported administration times varied, but the IQCODE can be self-administered in less than 20 minutes, so was included.

Abbreviations: ADL = activities of daily living; IADL = instrumental activities of daily living; MCI = mild cognitive impairment; NR = not reported.

Despite a very large body of evidence examining cognitive screening instruments, most instruments have only been studied in a handful of well-designed diagnostic accuracy studies in primary care–relevant populations (Tables 2–10). The best-studied instrument remains the MMSE, which has a relatively long administration time compared with other screening instruments included in this review. For the MMSE, the most commonly reported cut-points were 23/24 and 24/25, although higher and lower cut-points were evaluated in various studies. Pooled estimates across 14 studies (n=10,185) resulted in 88.3 percent sensitivity (95% CI, 81.3% to 92.9%) and 86.2 percent specificity (95% CI, 81.8% to 89.7%) for a cut-point of 23/24 or 24/25. Studies in populations with low levels of education (majority with primary school education or less) used lower cut-points. Test performance to detect MCI was based on a much smaller body of literature (k=15; n=5,758). Studies using higher cut-points to detect MCI did not have better sensitivity or specificity. Other instruments with more limited evidence include the CDT, Mini-Cog, MIS, AMT, SPMSQ, Free and Cued Selective Reminding Test (FCSRT), 7-Minute Screen, Telephone Interview for Cognitive Status (TICS), and IQCODE. The CDT also has several studies to support its use (k=7; n=2,509); however, it has a much wider range of sensitivity and specificity (67% to 97.9% and 69% to 94.2%, respectively) and the optimal cut-point is unclear from the body of literature we examined. The Mini-Cog, based on a smaller body of literature (k=4; n=1,570), likely has better sensitivity than the CDT alone (76% to 100%), but with a possible tradeoff of lower specificity (54% to 85.2%). For MCI, the CDT (k=4; n= 4,191) and Mini-Cog (k=3; n=1,092) have much lower sensitivity. Although the MIS (k=5; n=1,971) can have relatively good test performance to screen for dementia (sensitivity, 43% to 86%; specificity, 93% to 97%), the two best-quality studies (n=948) showed very low sensitivity (∼40%). Likewise, the AMT (k=4; n=824) can have relatively good test performance to screen for dementia (sensitivity, 42% to 100%; specificity, 83% to 95.4%), but one fair-quality study (n=289) had very low sensitivity (42%) and no studies were conducted in the United States. The SPMSQ (k=4; n=1,057), FCSRT (k=2; n=734), 7MS (k=2; n=553), and TICS (k=2; n=677) also have reasonable test performance, but based on a very limited number of studies. If a self-administered or informant-based screening tool is desired, the IQCODE may be a reasonable option to screen for either dementia (k=5; n=1,108; sensitivity, 75% to 87.6%; specificity, 65% to 91.1%) or MCI (k=4; n=975; sensitivity, 71.1% to 82.6%; specificity, 69.0% to 83.0%). However, for all these other instruments, there is much more limited evidence to support their use, with limited reproducibility in primary care–relevant populations and unknown optimal cut-points for each instrument. The AMT, SPMSQ, FCSRT, 7-Minute Screen, and TICS have very limited evidence in English. The AMT, MIS, SPMSQ, and TICS have no writing or drawing component and therefore can be administered to visually impaired individuals. Other instruments (i.e., 6-Item Screener, Visual Association Test [VAT], GPCOG, ADLs/IADLs, Benton's Orientation Test, Delayed Recall Test, and Short Concord Informant Dementia Scale for dementia; AD8, SLUMS, and Computer Assessment of Mild Cognitive Impairment [CAMCI] for MCI) appear promising (>80% sensitivity and specificity), but their test performance has not been reproduced in other primary care–relevant populations. No studies directly address the adverse psychological effects of screening or adverse effects from false-positive or false-negative testing. One fair-quality study found that approximately half of the older adults who screened positive for cognitive impairment refused to complete a formal diagnostic workup.

Table 2 Summary Table: Screening for Dementia (Dementia vs. MCI/Normal), Very Brief Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia | Cut-point | Outcomes
CDT | Fuchs, 2011^161^ | Fair | DE | 423 423 | 75-89 y PC | 82.4 | 68.4 | 62.2% “low” level | 5.0 | NR | Se, Sp, PPV, NPV, AUC
CDT | Kirby, 2001^169^ | Fair | IE | 648 648 | ≥65 y PC | 75.0 | NR | 10.8 | 6.3 | <6 | Se, Sp, PPV, NPV
CDT^*^ | Ball, 2001^167^ | Fair | US | 170 53 | ≥65 y Female Community | 76.3 | 100 | 13.6 | 9 | NR | Se, Sp
CDT | Del Ser, 2006^162^ | Fair | ES | 527 416 | ≥65 y Community | 79 | 51.7 | 63% <primary school | 11.5 | NR | Se, Sp, PPV, NPV, AUC
CDT | Grober, 2008^168^ | Good | US | 318 318 | ≥65 y NonHispanic white or black PC | 78.7 | 83 | 12.6 | 17.6 | 13 | Se, Sp, PPV, NPV
CDT | Wolf-Klein, 1989^171^ | Good | US | 325 312 | Geriatric health center | 76.8 | 70.5 | NR | 47.1 | NR | Se, Sp, PPV, NPV
Mini-Cog | Holsinger, 2012^173^ | Good | US | 639 630 | ≥65 y PC | 74.8 | 7.1 | 13.0 | 3.3 | 2/3 | Se, Sp, PPV, NPV
Mini-Cog | Fuchs, 2011^161^ | Fair | DE | 423 423 | 75-89 y PC | 82.4 | 68.4 | 62.2% “low” level | 5.0 | NR | Se, Sp, PPV, NPV, AUC
Mini-Cog | Kaufer, 2008^152^ | Fair | US | 146 146 | ≥65 y Residential care/assisted living | 83.4 | 79 | Majority ≥high school | 38 | 0 | Se, Sp, PPV, NPV
Mini-Cog | Borson, 2006^172^ | Fair | US^**^ | 371 371 | Community | NR | NR | NR | 40.2 | 2/3 | Se, Sp, PPV, NPV
MIS | Holsinger, 2012^173^ | Good | US | 639 630 | ≥65 y PC | 74.8 | 7.1 | 13.0 | 3.3 | 4/5 | Se, Sp, PPV, NPV
MIS-T | Lipton, 2003^176^ | Fair | US | 300 300 | ≥65 y PC | 79.3 | 66.0 | 12.8 | 9 | 4 | Se, Sp, PPV, NPV, AUC
MIS | Buschke, 1999^174^ | Fair | US | 483 483 | ≥65 y Senior centers; PC | 79.5 | 64 | 12.1 | 10.4 | 4 | Se, Sp, PPV, NPV, AUC
MIS | Kuslansky, 2002^175^ | Fair | US | 240 240 | ≥70 y PC | 78.7 | 64.1 | 12.5 | 11.7 | 4 | Se, Sp, PPV, NPV, AUC
MIS | Grober, 2008^168^ | Good | US | 318 318 | ≥65 y NonHispanic white or black PC | 78.7 | 83 | 12.6 | 17.6 | 4 | Se, Sp, PPV, NPV
SPMSQ | Erkinjuntti, 1987^155^ | Fair | FI | 119 119 | ≥65 y Community | 73 | 65 | 85% ≤grade school | 2.5 | 7/8 | Se, Sp, PPV, NPV
SPMSQ | Hooijer, 1992^178^ | Fair | NL | 358 358 | Older adults PC | NR | NR | NR | 3.6 | 7/8 | Se, Sp, PPV, NPV
MSQ | Hooijer, 1992^178^ | Fair | NL | 358 358 | Older adults PC | NR | NR | NR | 3.6 | 7/8 | Se, Sp, PPV, NPV
SPMSQ | Del Ser, 2006^162^ | Fair | ES | 527 416 | ≥65 y Community | 79 | 51.7 | 63% <primary school | 11.5 | NR | Se, Sp, PPV, NPV, AUC
SPMSQ | Fillenbaum, 1990^177^ | Fair | US | 164 164 | ≥65 y Community | NR | 57.9 | NR | 16.4 | NR | Se, Sp, PPV, NPV
MSQ | Fillenbaum, 1990^177^ | Fair | US | 164 164 | ≥65 y Community | NR | 57.9 | NR | 16.4 | 7/8 | Se, Sp, PPV, NPV
Verbal fluency–animals | Fuchs, 2011^161^ | Fair | DE | 423 423 | 75-89 y PC | 82.4 | 68.4 | 62.2% “low” level | 5.0 | ≤12 | Se, Sp, PPV, NPV, AUC
Category Fluency Telephone–animals and fruits | Lipton, 2003^176^ | Fair | US | 300 300 | ≥65 y PC | 79.3 | 66.0 | 12.8 | 9 | 13, 15, 19 | Se, Sp, PPV, NPV, AUC
Verbal fluency–category | Del Ser, 2006^162^ | Fair | ES | 527 416 | ≥65 y Community | 79 | 51.7 | 63% <primary school | 11.5 | NR | Se, Sp, PPV, NPV, AUC
Verbal fluency–animals | Heun, 1998^179^ | Fair | DE | 291 287 | 60-100 y Community | 76.6 | 59.9 | 9.5 | 12.9 | ≤14 | Se, Sp, PPV, NPV, AUC
Verbal fluency–first names | Heun, 1998^179^ | Fair | DE | 291 287 | 60-100 y Community | 76.6 | 59.9 | 9.5 | 12.9 | ≤14 | Se, Sp, PPV, NPV, AUC
Verbal fluency–animals | Grober, 2008^168^ | Good | US | 318 318 | ≥65 y NonHispanic white or black PC | 78.7 | 83 | 12.6 | 17.6 | 12 14 | Se, Sp, PPV, NPV

* Authors called their test the Clock Completion Test.

** Administered in the primary language of the participant.

Abbreviations: AUC = area under the curve; CDT = Clock Drawing Test; DE = Germany; ES = Spain; FI = Finland; IE = Ireland; MCI = mild cognitive impairment; MIS = Memory Impairment Screen; MIS-T = Memory Impairment Screen by Telephone; MSQ = Mental Status Questionnaire; NL = Netherlands; NPV = negative predictive value; NR = not reported; PC = primary care; PPV = positive predictive value; Se = standard error; Sp = specificity; SPMSQ = Short Portable Mental Status Questionnaire.

Table 3 Summary Table: Screening for Dementia (Dementia vs. MCI/Normal), Brief Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia | Cut-point | Outcomes
AMT | Brodaty, 2002^154^ | Fair | AU | 283 269 | 50-74 y (w/memory problem) or ≥75 y PC | 79.6 | 59.4 | 55.8% >8 y | 29 | 7/8 | Se, Sp, PPV, NPV, AUC
AMT | Hooijer, 1992^178^ | Fair | NL | 358 358 | Older adults PC | NR | NR | NR | 3.6 | 7/8 | Se, Sp, PPV, NPV
AMT | Rait, 2000^181^ | Fair | UK | 130 96 | ≥60 y Jamaican PC | 69 | 50 | 9 | 6 | ≥8 | Se, Sp, PPV, NPV
AMT | Rait, 2000^182^ | Fair | UK (Bangladeshi, Gujarati, Hindi, Punjabi, Urdu) | 120 101 | ≥60 y Gujarati or Pakistani PC | 69.2 | 52.5 | NR | 11 | 6 Gujarati 7 Pakistani | Se, Sp
FCSRT | Grober, 2008^168^ | Good | US | 318 318 | ≥65 y NonHispanic white or black PC | 78.7 | 83 | 12.6 | 17.6 | 25 | Se, Sp, PPV, NPV
FCR | Del Ser, 2006^162^ | Fair | ES | 527 416 | ≥65 y Community | 79 | 51.7 | 63% <primary school | 11.5 | NR | Se, Sp, PPV, NPV, AUC
7MS | Del Ser, 2006^162^ | Fair | ES | 527 416 | ≥65 y Community | 79 | 51.7 | 63% <primary school | 11.5 | NR | Se, Sp, PPV, NPV, AUC
7MS | Solomon, 2000^183^ | Fair− | US | 137 137 | ≥60 y PC | 77.0 | 67.2 | 11.8 | 8.0 | 0.3/0.7 (no patients scored between 0.3 & 0.7) | Se, Sp, PPV, NPV
TICS | Manly, 2011^184^ | Fair | US (English or Spanish) | 377 377 | ≥65 y PC | 81.4 | 68.2 | 10.4 | 14.1 | ≤22 | Se, Sp, PPV, NPV, AUC
TICS | Lipton, 2003^176^ | Fair+ | US | 300 300 | ≥65 y PC | 79.3 | 66.0 | 12.8 | 9 | 28 | Se, Sp, PPV, NPV, AUC
MMSE | Brodaty, 2002^154^ | Fair | AU | 283 283 | 50-74 y (w/memory problem) or ≥75 y PC | 79.6 | 59.4 | 55.8% >8 y | 29 | 24/25 (23/24 reported in text) | Se, Sp, PPV, NPV, AUC
MMSE | Callahan, 2002^185^ | Fair− | US | 2212 269 | ≥65 y Black Community | 74.4 | 59.4 | 10.4 | 4.3 | ≤24 | Se, Sp, PPV, NPV, AUC
MMSE | Cruz-Orduna, 2011^160^ | Fair | ES | 160 160 | Cognition-related complaint PC | 72.4 | 70 | 88.8% ≤primary school | 9.4 | 18/19 | Se, Sp, PPV, NPV, AUC
MMSE | Cullen, 2005^186^ | Fair− | IE | 1142 1115 | ≥65 y PC | 74.8 | 68 | 9.9 | 3.9 | <24 | Se, Sp, PPV, NPV
MMSE | Fillenbaum, 1990^177^ | Fair− | US | 164 164 | ≥65 y Community | NR | 57.9 | NR | 16.4 | NR | Se, Sp, PPV, NPV
MMSE | Fong, 2011^187^ | Fair | US | 709 709 | ≥70 y Community | 78.8 | 60 | NR | 1.2 | <24 | Se, Sp, PPV, NPV, AUC
MMSE | Gagnon, 1990^157^ | Fair− | FR | 2730 2730 | ≥65 y Community | 74.6 | 59.4 | 66% ≤primary school | 3.7 | 24 | Se, Sp, PPV, NPV
MMSE | Grut, 1993^158^ | Fair− | SE | 1810 668 | >74 y Community | NR | 76.1 | 46.1% ≥high school | 14.1 | 24/25 | Se, Sp, PPV
MMSE | Heun, 1998^179^ | Fair+ | DE | 291 287 | 60-100 y Community | 76.6 | 59.9 | 9.5 | 12.9 | ≤24 | Se, Sp, PPV, NPV, AUC
MMSE | Hooijer, 1992^178^ | Fair | NL | 358 358 | Older adults PC | NR | NR | NR | 3.6 | 23/24 | Se, Sp, PPV, NPV
MMSE | Jeong, 2004^163^ | Good | KR | 235 235 | ≥65 y Community | 73.5 | 66.4 | 1 (median) | 19.6 | 18/19 | Se, Sp, PPV, NPV, AUC
MMSE | Jorm, 1996^188^ | Fair | AU | 144 143 | POW/veteran | 72.9 | 0 | NR | NR | 26/27 | Se, Sp, AUC
MMSE | Kahle-Wrobleski, 2007^189^ | Fair− | US | 435 435 | ≥90 y Retirement community | 95 | 74 | 73% >12 y | 36 | 24 | Se, Sp, PPV, NPV, AUC
MMSE | Kaufer, 2008^152^ | Fair | US | 146 146 | ≥65 y Residential care/assisted living | 83.4 | 79 | majority with ≥high school | 38 | <27 | Se, Sp, PPV, NPV, AUC
MMSE | Kay, 1985^190^ | Fair | AU | 274 274 | ≥70 y Community | NR (158 were 70-79, 116 were 80+) | 63.5 | | 14.2 | 24/25 | Se, Sp, PPV, NPV
MMSE | Kirby, 2001^169^ | Fair | IE | 648 648 | ≥65 y PC | 75.0 | NR | 10.8 | 6.3 | <24 | Se, Sp, PPV, NPV
MMSE | Lavery, 2007^170^ | Fair | US | 1107 339 | ≥65 y PC | 77.5 | 68.7 | 66.8% ≥12 y | 9.7 | ≥22 | Se, Sp, PPV, NPV, AUC
MMSE | McDowell, 1997^159^ | Fair | CA (English or French) | 1600 1600 | ≥65 y | 80.0 | 59 | 8.6 | 23 | 24 | Se, Sp, PPV, NPV, AUC
MMSE | Morales, 1997^165^ | Fair | ES | 257 (97 urban, 160 rural) 257 | ≥65 y (urban); ≥60 y (rural) Community | 74.1 | 61.9 | 4.9 | 13.2 | 21 (urban) 20 (rural) | Se, Sp, PPV, NPV
MMSE | Rait, 2000^181^ | Fair | UK | 130 96 | ≥60 y Jamaican PC | 69 | 50 | 9 | 6 | ≥27 | Se, Sp, PPV, NPV
MMSE | Rait, 2000^182^ | Fair | UK (Bangladeshi, Gujarati, Hindi, Punjabi, Urdu) | 120 101 | ≥60 y Gujarati or Pakistani PC | 69.2 | 52.5 | NR | 11 | 24 Gujarati 27 Pakistani | Se, Sp
MMSE | Reischies, 1997^191^ | Fair− | DE | 516 449 | ≥70 y Community | NR | NR | NR | 19.4 | 24/25 | Se, Sp, PPV, NPV
MMSE | Scharre, 2010^153^ | Fair− | US | 254 63 | >59 y Geriatric outpatient; community; independent and assisted living facilities; senior centers; memory clinic | 78 | 66.7 | 93.7% ≥high school | 33 | ≤26 | Se, Sp, PPV, NPV, AUC
MMSE | Waite, 1998^192^ | Fair | AU | 630 360 | ≥75 y Community; veterans | 83.9 | 54.8 | 10 | 27.5 | 23/24 | Se, Sp, PPV, NPV, AUC

Abbreviations: AMT = Abbreviated Mental Test; AU = Australia; AUC = area under the curve; CA = Canada; DE = Germany; ES = Spain; FCR = Free and Cued Recall; FCSRT = Free and Cued Selective Reminding Test; FR = France; IE = Ireland; KR = South Korea; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; NL = Netherlands; NPV = negative predictive value; NR = not reported; PC = primary care; POW = prisoner of war; PPV = positive predictive value; SE = Sweden; Se = standard error; Sp = specificity; TICS = Telephone Interview for Cognitive Status; UK = United Kingdom; 7MS = 7-Minute Screen.

Table 4 Summary Table: Screening for Dementia (Dementia vs. MCI/Normal), Self-Administered Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia | Cut-point | Outcomes
Short IQCODE | Grober, 2008^168^ | Good | US | 318 318 | ≥65 y NonHispanic white or Black PC | 78.7 | 83 | 12.6 | 17.6 | 3.3 | Se, Sp, PPV, NPV
Short IQCODE | Jorm, 1996^188^ | Fair | AU | 144 143 | POW/veterans | 72.9 | 0 | NR | NR | 3.31/3.38 | Se, Sp, AUC
Full IQCODE | Cruz-Orduna, 2011^160^ | Fair | ES | 160 160 | Cognition-related complaint PC | 72.4 | 70 | 88.8% ≤primary school | 9.4 | 3.65/3.69 | Se, Sp, PPV, NPV, AUC
Full IQCODE | Morales, 1997^165^ | Fair | ES | 257 (97 urban, 160 rural) 257 | ≥65 y (urban); ≥60 y (rural) Community | 74.1 | 61.9 | 4.9 | 13.2 | 3.27 (urban) 3.31 (rural) | Se, Sp, PPV, NPV
Full IQCODE | Jorm, 1996^188^ | Fair | AU | 144 143 | POW/veterans | 72.9 | 0 | NR | NR | 3.27/3.30 | Se, Sp, AUC
Full IQCODE | Tokuhara, 2006^195^ | Fair+ | US | 299 230 (N analyzed unclear) | ≥65 y Japanese/Okinawan PC | 74.2 | 66 | 12.2 | 7 | 3.5 | Se, Sp, PPV, NPV
SAGE | Scharre, 2010^153^ | Fair− | US | 254 63 | >59 y Geriatric outpatient; community; independent and assisted living facilities; senior centers; memory clinic | 78 | 66.7 | 93.7% ≥high school | 33 | ≤14 | Se, Sp, PPV, NPV, AUC

Abbreviations: AU = Australia; AUC = area under the curve; ES = Spain; IQCODE = Informant Questionnaire on Cognitive Decline in the Elderly; MCI = mild cognitive impairment; NPV = negative predictive value; PC = primary care; PPV = positive predictive value; SAGE = Self-Administered Gerocognitive Examination; Se = standard error; Sp = specificity.

Table 5 Summary Table: Screening for Mild Cognitive Impairment (MCI vs. Normal, Dementia Not Included), Very Brief Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia, % MCI | Cut-point | Outcomes
CDT | Donnelly, 2008^202^ | Fair | US | 100 100 | ≥65 y PC | 77.9 | 1 | 12.9 | NA 20 | 1 SD | Se, Sp, PPV, NPV, AUC
CDT | Ehreke, 2009^198^ | Fair | DE | 3198 3198 | ≥75 y PC | 80.1 | 65.4 | 61.8% “low” level | NA 15.0 (original) 24.6 (modified) | 9 | Se, Sp, PPV, NPV, AUC
CDT | Ehreke, 2011^196^ | Fair | DE | 428 428 | ≥75 y Community and institutions | 83 | 73 | 63.5% “low” education | NA 13.6 | ≥2 (Shulman) ≤9 (Ihl and Sunderland) ≤7 (Rouleau) ≤15 (Babins) ≤18 (Mendez) ≤2 (Lin) | Se, Sp, PPV, NPV
CDT | Lee, 2008^199^ | Fair | KP | 465 465 | ≥60 y Hospital outpatients; community | 71.0 | 63.4 | 53.1% <primary school | NA 48.2 | 9/10 (Freedman) 6/6.5 (Todd) 7/8 (Rouleau) 1/2 (CERAD} | Se, Sp, PPV, NPV, AUC
Mini-Cog | Kaufer, 2008^152^ | Fair | US | 146 91 | ≥65 y Residential care/assisted living facilities | 83.4 | 79 | Majority >high school | NA 83.5 | 0 | Se, Sp, PPV, NPV, AUC
Mini-Cog | Borson, 2006^172^ | Fair | US (primary language spoken) | 371 371 | Community | NR | NR | NR | 40.2 12.1 | 2/3 | Se, Sp, PPV, NPV
Mini-Cog | Holsinger, 2012^173^ | Good | US | 639 630 | ≥65 y PC | 74.8 | 7.1 | NR | 3.3 39.2 | 2/3 | Se, Sp, PPV, NPV

Abbreviations: AUC = area under the curve; CDT = Clock Drawing Test; CERAD = Consortium to Establish a Registry for Alzheimer's Disease; DE = Germany; MCI = mild cognitive impairment; KP = South Korea; NA = not applicable; NPV = negative predictive value; NR = not reported; PC = primary care; PPV = positive predictive value; SD = standard deviation; Se = standard error; Sp = specificity.

Table 6 Summary Table: Screening for Mild Cognitive Impairment (MCI vs. Normal, Dementia Not Included), Brief Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia, % MCI | Cut-point | Outcomes
TICS-M | Cook, 2009^204^ | Fair | US | 71 71 | ≥65 y Community | 74.9 | 56.3 | 16.1 | NA 23.9 | 26 31 34 | Se, Sp, PPV, NPV, AUC
TICS-M | Manly, 2011^184^ | Fair | US (English or Spanish) | 377 377 | ≥65 y PC | 81.4 | 68.2 | 10.4 | 14.1 18.0 | ≤26 | Se, Sp, PPV, NPV, AUC
TICS-M | Vercambre, 2010^203^ | Fair | FR | 120 120 | Born between 1925 and 1930 Women National Education System | 78.8 | 100 | NR | 8.3 (probable and possible) 15 | 27 31 34 | Se, Sp, PPV, NPV, AUC
MMSE | Donnelly, 2008^202^ | Fair | US | 100 100 | ≥65 y PC | 77.9 | 1 | 12.9 | NA 20 | 1 SD | Se, Sp, PPV, NPV, AUC
MMSE | Kaufer, 2008^152^ | Fair | US | 146 91 | ≥65 y Residential care/assisted living facilities | 83.4 | 79 | Majority >high school | NA 83.5 | <28 | Se, Sp, PPV, NPV, AUC
MMSE | Rideaux, 2012^205^ | Fair | US | 701 522 | ≥70 y Community | 81 | 55 | 10.3 | 25.5 31.7 | <26 (white) <23 (black) <25 (Latino) | Se, Sp, PPV, NPV
MMSE | Saxton, 2009^200^ | Good | US | 524 524 | ≥60 y PC; Senior community centers | 73.3 | 65.1 | 13.46 | NA 43.5 | 28 | Se, Sp, PPV, NPV
MMSE | Scharre, 2010^153^ | Fair | US | 254 42 | >59 y Geriatric outpatient; community; independent & assisted living facilities; senior centers; memory clinic | 78 | 66.7 | 93.7% ≥high school | NA 50 | NR | Se, Sp, PPV, NPV, AUC
MMSE | Tariq, 2006^134^ | Fair | US | 702 620 | ≥60 y VA | 75.3 | NR | 69.4% ≥high school | NA 29.0 | 28.5 (<high school education) 29.5 (≥high school education) | Se, Sp, PPV, NPV, AUC
MoCA | Lee, 2008^133^ | Fair | KP | 196 152 | ≥65 y Community and hospital outpatients | 70 | 65 | 9.7% >12 yy | 22.4 18.9 | 25/26 | Se, Sp, PPV, NPV, AUC
MoCA | Markwick, 2012^201^ | Good | UK | 107 99 | NR | 76 | 54 | 76.6% >12 y | 7.5 18.7 | <26 | Se, Sp, PPV, NPV

Abbreviations: AUC = area under the curve; FR = France; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; NA = not applicable; NPV = negative predictive value; NR = not reported; PC = primary care; PPV = positive predictive value; SD = standard deviation; Se = standard error; Sp = specificity; TICS-M = Telephone Interview for Cognitive Impairment, Modified; VA = Veterans Affairs.

Table 7 Summary Table: Screening for Mild Cognitive Impairment (MCI vs. Normal, Dementia Not Included), Self-Administered Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia, % MCI | Cut-point | Outcomes
Short IQCODE | Ayalon, 2011^135^ | Fair− | US | 856 441 | ≥70 y PC | 80.3 | 55.6 | 11.2 | NA 42.0 | >3 | Se, Sp, PPV, NPV, AUC
Full IQCODE | Cruz-Orduna, 2011^160^ | Fair | ES | 160 160 | Cognition-related complaint PC | 72.4 | 70 | 88.8% <primary school | 9.4 46.9 | 3.31/3.35 | Se, Sp, PPV, NPV, AUC
Full IQCODE | Tokuhara, 2006^195^ | Fair | US | 299 230 | ≥65 y Japanese/Okinawan PC | 74.2 | 66 | 12.2 | 7 10 | 3.3 | Se, Sp, AUC

Abbreviations: AUC = area under the curve; ES = Spain; IQCODE = Informant Questionnaire on Cognitive Decline in the Elderly; MCI = mild cognitive impairment; NA = not applicable; NPV = negative predictive value; PC = primary care; PPV = positive predictive value; Se = standard error; Sp = specificity.

Table 8 Summary Table: Screening for Cognitive Impairment (MCI/Dementia vs. Normal), Very Brief Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia, % MCI | Cut-point | Outcomes
Mini-Cog (primary language spoken) | Borson, 2006^172^ | Fair | US | 371 371 | Community | NR | NR | NR | 40.2 12.1 | 2/3 | Se, Sp, PPV, NPV
Mini-cog | Holsinger, 2012^173^ | Good | US | 639 630 | ≥65 y PC | 74.8 | 7.1 | NR | 3.3 39.2 | 2/3 | Se, Sp, PPV, NPV
MIS | Holsinger, 2012^173^ | Good | US | 639 630 | ≥65 y PC | 74.8 | 7.1 | NR | 3.3 39.2 | 2/3 | Se, Sp, PPV, NPV

Abbreviations: MIS = Memory Impairment Screen; NPV = negative predictive value; NR = not reported; PPV = positive predictive value; PC = primary care; Se = sensitivity; Sp = specificity.

Table 9 Summary Table: Screening for Cognitive Impairment (MCI/Dementia vs. Normal), Brief Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection Criteria | Age (y) | % Female | Education (y) | % Dementia, % MCI | Cut-point | Outcomes
TICS (French) | Vercambre, 2010^203^ | Fair | FR | 120 120 | Born between 1925 and 1930 Women National Education System | 78.8 | 100 | NR | 8.3 (probable and possible) 15 | NR | AUC
TICS-M (English or Spanish) | Manly, 2011^184^ | Fair | US | 377 377 | ≥65 y PC | 81.4 | 68.2 | 10.4 | 14.1 18.0 | ≤26 | Se, Sp, PPV, NPV, AUC
TICS-M (French) | Vercambre, 2010^203^ | Fair | FR | 120 120 | Born between 1925 and 1930 Women National Education System | 78.8 | 100 | NR | 8.3 (probable and possible) 15 | 27 31 34 | Se, Sp, PPV, NPV, AUC
MMSE | Callahan, 2002^185^ | Fair | US | 2212 269 | ≥65 y Black Community | 74.4 | 59.4 | 12.1 | 4.3 26.4 | 23/24 24/25 | Se, Sp, PPV, NPV, AUC
MMSE (Spanish) | Cruz-Orduna, 2011^160^ | Fair | ES | 160 160 | Cognition-related complaint PC | 72.4 | 70 | % None/Incomplete: 44.4 % Primary: 44.4 % Superior: 5.6 | 9.4 46.9 | 23/24 | Se, Sp, PPV, NPV, AUC
MMSE | Cullen, 2005^186^ | Fair | IE | 1142 1115 | ≥65 y PC | 74.8 | 68 | 9.9 | 3.9 4.8 | 23/24 | Se, Sp, PPV, NPV
MMSE (Korean) | Jeong, 2004^163^ | Good | KP | 235 235 | ≥65 y Community | 73.5 | 66.4 | 1 (median) | 19.6 23.0 | 20/21 | Se, Sp, PPV, NPV, AUC
MMSE | Jorm, 1996^188^ | Fair | AU | 144 NR | POW/veteran | 72.9 | 0 | NR | NR NR | NR | AUC
MMSE (Chinese) | Lam, 2008^164^ | Fair | HK | 459 459 | Community | 71.2 | 54.5 | 4.8 | 9.6 35.3 | NR | AUC
MMSE (Chinese or English) | Li, 2006^197^ | Fair | SI | 144 NR | 65-90 y Community; neuroscience clinic | 72.7 | 50.7 | 4.7 | 13.2 25.7 | NR | AUC
MMSE (English or French) | McDowell, 1997^159^ | Fair | CA | 1600 1600 | ≥65 y Community | 80.0 | 59 | 8.6 | 23 30 | NR | AUC
MMSE | Scharre, 2010^153^ | Fair | US | 254 63 | >59 y Geriatric outpatient; community; independent and assisted living facilities; senior centers; memory clinic | 78 | 66.7 | 93.7% ≥high school | 33 33 | ≤27 | Se, Sp, PPV, NPV, AUC
MMSE (French) | Vercambre, 2010^203^ | Fair | FR | 120 120 | Born between 1925 and 1930 Women National Education System | 78.8 | 100 | NR | 8.3 15 | NR | AUC

Abbreviations: AU = Australia; AUC = area under the curve; CA = Canada; ES = Spain; FR = France; HK = Hong Kong; IE = Ireland; KP = South Korea; MMSE = Mini-Mental State Examination; NPV = negative predictive value; NR = not reported; POW = prisoner of war; PPV = positive predictive value; Se = sensitivity; SI = Singapore; Sp = specificity; TICS = Telephone Interview for Cognitive Impairment; TICS-M = Telephone Interview for Cognitive Impairment, Modified.

Table 10 Summary Table: Screening for Cognitive Impairment (MCI/Dementia vs. Normal), Self-Administered Instruments (Key Question 2)

Instrument | Study | Quality | Country | N Screened, N Analyzed | Selection criteria | Age (y) | % Female | Education (y) | % Dementia, % MCI | Cut-point | Outcomes
Short IQCODE | Jorm, 1996^188^ | Fair | AU | 144 NR | POW/veteran | 72.9 | 0 | NR | NR NR | NR | AUC
Full IQCODE | Jorm, 1996^188^ | Fair | AU | 144 NR | POW/veteran | 72.9 | 0 | NR | NR NR | NR | AUC
Full IQCODE (Spanish) | Cruz-Orduna, 2011^160^ | Fair | ES | 160 160 | Cognition-related complaint PC | 72.4 | 70 | 88.8% ≤primary school | 9.4 46.9 | 3.31/3.35 | Se, Sp, PPV, NPV, AUC
Full IQCODE | Tokuhara, 2006^195^ | Fair | US | 299 230 | ≥65 y Japanese/Okinawan PC | 74.2 | 66 | 12.2 | 7 10 | 3.3 | Se, Sp, PPV, NPV, AUC

Abbreviations: AU = Australia; AUC = area under the curve; ES = Spain; IQCODE = Informant Questionnaire on Cognitive Decline in the Elderly; NPV = negative predictive value; NR = not reported; PPV = positive predictive value; Se = sensitivity; Sp = specificity.

## Key Question 1 Does Screening for Cognitive Impairment in Community-Dwelling Older Adults in Primary Care–Relevant Settings Improve Decisionmaking, Patient, Family/Caregiver, or Societal Outcomes?

We found no trials that directly assessed whether screening for cognitive impairment in primary care could affect decisionmaking, health (patient or caregiver), or societal outcomes. No trials have been designed to assess whether screening for cognitive impairment changes patient or clinical decisionmaking or if screening improves patient, caregiver, or societal outcomes in addition to the standard of care, which is primarily testing for cognitive impairment based on clinical observation or other mechanisms of case-finding.

## Key Question 2 What Is the Test Performance of Screening Instruments to Detect Cognitive Impairment in Community-Dwelling Older Adult Primary Care Patients?

### Screening for Dementia

We found 41 studies that addressed the diagnostic accuracy of very brief and brief screening instruments that could be administered in primary care (Appendix D Tables 1 and 2) and seven studies that addressed instruments that could be self-administered (Appendix D Table 3).

Our included studies considered a broad range of participants relevant to older adult primary care populations and a wide variety of different screening instruments (Tables 2–10). Overall, study participants were community-dwelling older adults selected from the community or primary care practices. Two studies explicitly included people in assisted living or residential care facilities.152,153 Almost all studies had a majority of women participants, but studies varied in the mean age (range of means, 69 to 95 years) and prevalence of dementia (range of prevalence, 1.2% to 47.1%). Education was not always reported. If education was reported, it was often reported differently across studies. In general, however, most study participants had at least some high school education. In 12 studies (none of which were conducted in the United States), most of the participants had less than a high school education.154-165 The study population in six of these studies had very low levels of education (i.e., no formal education or only primary school).160,160,162-165 The most commonly evaluated screening instruments included (most to least common, instruments only evaluated once are not listed here): MMSE (k=25; n=12,348), CDT (k=7; n=2,509), verbal/category fluency tests (k=6; n=2,083), short or full IQCODE (k=5; n=1,108), MIS (k=4; n=1,671; k=1 for MIS-T; n=300), Mini-Cog (k=4; n=1,570), AMT (k=4; n=824), SPMSQ (k=4; n=1,057), Mental Status Questionnaire (MSQ) (k=2; n=522), FCSRT (k=2; n=734), 7-Minute Screen (k=2; n=553), and TICS (k=2; n=677).

For inclusion in this review, diagnostic accuracy studies were required to minimize selection bias (i.e., distorted selection of participants with case-control study design) and evaluate index tests against a true diagnostic reference standard, rather than other screening instruments. Only four studies were good quality; most were fair quality, with a range in risk of biases, the most common being partial verification (only a subset of participants whose screening test was negative received reference standard), unclear or lack of independence of application or interpretation of index test (screening) and reference standard, selection bias with stratified sampling or sampling of volunteers only, and unclear spectrum of patients due to poor reporting of how study population was derived or percent of/reasons for attrition. All studies had to apply a diagnostic reference standard. For dementia, the most common reference standard was DSM-III or DSM-IV or National Institute of Neurological and Communicative Disorders and Stroke and the Alzheimer's Disease and Related Disorders Association (NINCDS-ADRDA) criteria, although others used AGECAT or Cambridge Mental Disorders of the Elderly Examination (CAMDEX). Many studies did not explicitly mention the specific criteria they used to diagnose dementia. No studies used the most recent National Institute on Aging-Alzheimer's Association criteria.166 Studies generally did not specify the type or etiology of dementia. Most included studies used a combination of history, examination, neuropsychological testing, and/or expert consensus to determine the formal diagnosis.

#### Very Brief Instruments

(Table 2, Figure 2)

Figure 2 Diagnostic Accuracy of Very Brief Screening Instruments for Dementia (Key Question 2)

^*^ Calculated from 2×2 table

^††^ Confidence intervals could not be calculated

^**^ Calculated using the sensitivity, specificity, and prevalence of cognitive impairment

Abbreviations: CDT – Clock Drawing Test, CI – Confidence interval; M – MSQ, MIS – Memory Impairment Screen, MIS-T – Memory Impairment Screen by Telephone, MSQ – Mental Status Questionnaire, NR – Not reported; S – SPMSQ; SPMSQ – Short Portable Mental Status Questionnaire; T – MIS-T

Figure 2 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study for very brief screening instruments for dementia. This figure refers to KQ2. In addition to the diagnostic accuracy information, the number, prevalence of dementia, and scoring cut-off is presented. Included instruments in this plot are the CDT, mini-cog, MIS/MIS-T, SPMSQ/MSQ, and verbal fluency. This same information is presented in Appendix D, Table 1.

CDT. Two good-quality and five fair-quality studies evaluated the performance of the CDT.161, 162,167-171 While mean age and percent women in each study did not vary widely, there was large variation in prevalence of dementia. In the fair-quality studies, the proportion of people with dementia ranged from 5 to 11.5 percent. The proportions, however, were much higher in the good-quality studies (17.6% and 47.1%). In general, the range of sensitivity and specificity for the CDT across six studies (n=2,170) that reported this information was 67 to 97.9 percent (range 95% CI, 39 to 100) sensitivity and 69 to 94.2 percent (range 95% CI, 54 to 97.1) specificity.161,162,167-169,171 The highest estimate (94.2%) for specificity comes from the good-quality study, conducted much earlier than the other studies, with an unusually high prevalence of dementia in this sample.171 Two studies with the highest sensitivity estimates (89.5% and 97.9%) were both conducted in populations with on average low levels of education.161,162 It is unclear if the education level or another study characteristic particular to these two studies affected the instrument's sensitivity. The lack of reporting on how each CDT was scored, however, presents a major limitation for comparing estimates across studies. There are also multiple scoring methods for interpreting the CDT (each with varying degrees of complexity). Currently, there is no consensus on the best method, and only two of these six studies report the cut-points used (and used different cut-points).168,169 In general, while the CDT can have reasonable sensitivity and specificity, the 95% CI across studies varies widely and the diagnostic accuracy will vary with choice of scoring method and cut-points.

Mini-Cog. The Mini-Cog instrument includes the CDT plus a three-item word recall test. One good-quality and three fair-quality studies evaluated the Mini-Cog,152,161,172,173 one of which was administered in German.161 While the patients' mean age was about 79 years, the prevalence of dementia varied greatly across the four studies (range, 3.3% to 40.2%), which suggests important population differences. Across the four studies (n=1,570), sensitivity ranged from 76 to 100 percent (range 95% CI, 54 to 100) and specificity ranged from 54 to 85.2 percent (range 95% CI, 43 to 88.4).152,161,172,173 The best test performance was found in a study conducted in a population with a fairly low level of education.161 One study with a particularly low specificity was conducted in a residential care facility in a population with a very high proportion of people with dementia.152 It is unclear, however, if the differences in test performance are due to education, setting, or underlying prevalence of dementia, or if these differences are due to some other study-specific characteristic. Again, while lack of reporting and differences in cut-points limits the interpretation of results, it appears that the Mini-Cog has a better sensitivity than the CDT alone, although this increased sensitivity comes with a tradeoff of decreased specificity. However, it is difficult to assess whether adding the three-item word recall test improves sensitivity and specificity because of differences across studies in ages and proportion of people with dementia in the populations evaluated, and not knowing the differences in how the CDT was scored.

MIS. The MIS is a brief four-item delayed free and cued recall memory impairment test. Although related, it is different than the FCSRT (see the Brief Instruments section). Two good- and three fair-quality studies evaluate the MIS,168,173-176 one of which evaluates the MIS by telephone (MIS-T).176 All these studies had a similar mean age, 78 to 79 years, and levels of education; however, the proportion of people with dementia ranged from 3.3 to 17.6 percent. One good-quality study had a majority of men (92.9%), which is quite different than most other studies included in this review. Across the five studies (n=1,971), sensitivity ranged from 43 to 86 percent (range 95% CI, 24 to 96) and specificity ranged from 93 to 97 percent (range 95% CI, 56 to 100) at a cut-point of 4. One of these studies (n=300), which evaluated the MIS-T, had a similar test performance to the MIS evaluated in the other studies. Overall, sensitivity for the MIS varies widely; the point estimates for sensitivity were only 43 and 49 percent in the two best-quality studies.

MSQ and SPMSQ. The SPMSQ was derived from the MSQ, with a few added questions; both of these instruments have a possible score of 10 errors. Two fair-quality studies evaluated both the MSQ and the SPMSQ,177,178 and two additional fair-quality studies evaluated the SPMSQ.155,162 Only one of these studies evaluated the MSQ or SPMSQ in English; the other studies evaluated the performance of the SPMSQ in Spanish, Finnish, and Dutch. Across these studies, the mean age and proportion of women were not well reported. The percentage with dementia in the study populations ranged from 2.5 to 16.4 percent. Across the four studies (n=1,057), sensitivity for the SPMSQ ranged from 92.3 to 100 percent (range 95% CI, 29 to 100) and specificity ranged from 83.5 to 100 percent (range 95% CI, 76 to 100).155,162,177,178 In the two studies that evaluated both the SPMSQ and MSQ (n=522), both instruments had similar diagnostic accuracy.177,178 Although the cut-points were not specified in two of the four studies, overall the SPMSQ seems to have reasonable performance, albeit with a wide range in 95% CIs.

Verbal Fluency Tests. Verbal fluency tests can be category (measures language ability) or letter fluency tests (measures executive functioning) that assess the ability to name as many items in a category (e.g., animals, fruits, first names) or starting with a specific letter in 1 minute. One good- and five fair-quality studies evaluated verbal fluency tests.161,162,168,170,176,179 Two of the studies evaluated tests in German161,179 and one in Spanish.162 Mean age was similar across studies and ranged from 76.6 to 82.4 years. The proportion of women ranged from 51.7 to 83 percent. Dementia prevalence ranged from 5 to 17.6 percent. Although the cut-points used in each of the studies varied and was not reported in one study, sensitivity and specificity overlapped regardless of chosen cut-point. In three of the studies (n=1,041), sensitivity ranged from 37 to 89.5 percent (range 95% CI, 19 to 100) and specificity ranged from 62 to 97 percent (range 95% CI, 48 to 99) for a cut-point of 12 or 13.^161,168,176^ Again, the highest test performance came from one German study in which the population screened had low levels of education.161 In three of the studies (n=905), sensitivity ranged from 57 to 88 percent (range 95% CI, 35 to 100) and specificity ranged from 43 to 94 percent (range 95% CI, 33 to 97) for a cut-point of 14 or 15.^168,176,179^ Verbal fluency tests have a wide range of sensitivity and specificity, with likely unacceptably low sensitivity for lower thresholds and low specificity for higher cut-points.

#### Brief Instruments

(Table 3, Figure 3)

Figure 3 Diagnostic Accuracy of Brief Screening Instruments for Dementia (Key Question 2)

^*^ Calculated from 2×2 table

^††^ Confidence intervals could not be calculated

^**^ Calculated using the sensitivity, specificity, and prevalence of cognitive impairment

Abbreviations: AMT – Abbreviated Mental Test; CI – Confidence interval; FCSRT – Free and Cued Selective Reminding Test; 7 MS – 7 Minute Screen; TICS – Telephone for Cognitive Status; MMSE – Mini-Mental State Examination; NR – Not reported

Figure 3 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study for brief screening instruments for dementia. This figure refers to KQ2. In addition to the diagnostic accuracy information, the number, prevalence of dementia, and scoring cut-off is presented. Included instruments in this plot are the AMT, FCSRT, 7MS, TICS, and MMSE. This same information is presented in Appendix D, Table 2.

AMT. The AMT is a 10-item instrument that was introduced in 1972 and is not commonly used in the United States.180 Four fair-quality studies evaluated the AMT in different populations and languages (English, Dutch, and South Asian languages), none of which were conducted in the United States.154,178,181,182 The earliest and largest study (n=358) was conducted in Holland and had a sensitivity and specificity of 92.3 percent (95% CI, 64 to 99.8) and 95.4 percent (95% CI, 92.6 to 97.3), respectively, for a cut-point of 7/8.^178^ A subsequent study (n=269) in Australia, however, found a much lower sensitivity of 42 percent (95% CI, 31 to 53), with similar specificity of 93 percent (95% CI, 89 to 96) for the same cut-point.154 The prevalence of dementia in this population was much higher at 29 percent compared with 3.6 percent in the Dutch study. Two smaller studies (n=194) in ethnic minorities in the United Kingdom suggest that the AMT can have relatively high sensitivity and specificity. The 95% CIs are very wide, however, and the optimal choice of cut-point may vary by language/culture or education.181,182 These two studies were also conducted in slightly younger populations (mean age, 69 years) than most included studies. Overall, the AMT has limited reproducibility in similar primary care–relevant populations and it is unclear how applicable these populations are to U.S. primary care populations.

FCSRT. Only two studies evaluated the FCSRT.162,168 One good-quality study conducted by Grober and colleagues (n=318) found that the FCSRT had a sensitivity of 86 percent (95% CI, 41 to 100) and specificity of 73 percent (95% CI, 56 to 96) at a cut-point of 25 in a patient population with a mean age of 78.7 years and 17.6 percent underlying dementia.168 A fair-quality study (n=416) conducted in a Spanish population found that a modified FCSRT (details and cut-point unknown) had high sensitivity (100% [95% CI, 92.6 to 100]) and specificity (87.2% [95% CI, 83.4 to 90.5]). This population had similar age, sex, and proportion of patients with dementia but much lower education levels than the Grober studies. The FCSRT has had limited validation in a primary care–relevant population, and CIs around sensitivity and specificity are wide.

7-Minute Screen. The 7-Minute Screen is a combination of the Benton Temporal Orientation Test, an abbreviated version of the Enhanced Cued Recall test, the CDT, and the animal verbal fluency test. Only two fair-quality studies evaluated the 7-Minute Screen,162,183 one of which was conducted in Spanish.162 These two studies (n=553) included similar aged populations, majority women, and proportion of people with dementia (8.0% and 11.5%). Sensitivity was 100 percent (range 95% CI, 71.5 to 100) and specificity ranged from 95.1 to 100 percent (range 95% CI, 86.8 to 100). Due to limitations in the individual studies, however, the optimal cut-point is not known. Evidence to support the use of the 7-Minute Screen in primary care is very limited (limited number of studies, range and sensitivity, and unknown optimal cut-point).

TICS. The TICS is an 11-item instrument that can be administered by phone or in person, does not require vision, and therefore can be used in visually impaired individuals. Only two fair-quality studies evaluated the TICS.176,184 These two studies were similar in mean age and proportion of women and the prevalence of underlying dementia was 9 and 14.1 percent. In these two studies (n=677), sensitivity ranged from 74 to 88 percent (range 95% CI, 54 to 96) and specificity from 86 to 87 percent (range 95% CI, 81 to 91). The two studies, however, used very different cut-points (28 and 22). At present, the TICS has very limited evidence (limited number of studies and unknown optimal cut-point).

MMSE. The MMSE is by far the most well-studied, and arguably most well-known, instrument to screen for dementia. It is a 30-point instrument with 11 items. In diagnostic studies, the MMSE was often included as a comparator with other index tests and was not the primary instrument being evaluated. Nonetheless, 25 fair-quality studies evaluated the MMSE in primary care–relevant populations.152-154,157-160,163-165,169,170,177-179,181,182,185-192 Researchers have studied the MMSE in multiple languages (English, Spanish, French, Swedish, German, Dutch, Korean, Cantonese, and South Asian languages) across a range of older and very old adults (mean age range, 69 to 95 years) and a wide range of dementia prevalence (1.2% to 38%). Although it is well accepted that the MMSE has different norms by age and education (and ethnicity193), there is no universally accepted cut-point based on age and education level.19 The most commonly reported cut-points were 23/24 and 24/25, although higher and lower cut-points were evaluated in various studies. Pooled estimates across 14 studies (n=10,185) resulted in 88.3 percent sensitivity (95% CI, 81.3 to 92.9) and 86.2 percent specificity (95% CI, 81.8 to 89.7) for a cut-point of 23/24 or 24/25. For a cut-point of 23/24 (k=5; n=3,190), the pooled sensitivity was 85.4 percent (95% CI, 79.1 to 90.0) and specificity was 90.2 percent (95% CI, 86.0 to 93.3). For a cut-point of 24/25 (k=5; n=1,562), the pooled sensitivity was 87.6 percent (95% CI, 81.6 to 93.7) and specificity was 84.1 percent (95% CI, 76.4 to 91.8). The four remaining studies only reported a cut-point of 24 (n=4,866). It is unclear if these studies considered a score of 24 as normal or abnormal. Three studies, two conducted in Spain and the other in South Korea, used much lower cut-points and found overlapping sensitivities similar to those in other studies with higher thresholds.160,163,165 Despite these similarities, however, these studies were conducted in populations with much lower education levels. Although sensitivity and specificity of the MMSE likely varies depending on the individual's age and education, a large body of literature suggests a general cut-point of 23/24 or 24/25 could be appropriate for most primary care populations.

#### Self-Administered Instruments

(Table 4, Figure 4)

Figure 4 Diagnostic Accuracy of Self-Administered Screening Instruments for Dementia (Key Question 2)

^††^ Confidence intervals could not be calculated

^**^ Calculated using the sensitivity, specificity, and prevalence of cognitive impairment

Abbreviations: CI – Confidence interval; F– Full IQCODE; IQCODE – Informant Questionnaire on Cognitive Decline in the Elderly; NR – Not reported; S– Short IQCODE

Figure 4 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study for self-administered screening instruments for dementia. This figure refers to KQ2. In addition to the diagnostic accuracy information, the number, prevalence of dementia, and scoring cut-off is presented. The included instrument in this plot is the IQCODE. This same information is presented in Appendix D, Table 3.

IQCODE. The full version of the IQCODE includes 26 items and the short version includes 16 items. The questionnaire can be self-administered to the patient's informant (i.e., caregiver, family, close friend). Based on similar performance (correlation) between the two instruments, the developers of the instrument recommend using the short version with a cut-point of 3.44 or greater.194 One good-quality study evaluated the short IQCODE,168 one fair-quality study evaluated both the short and long form,188 and three fair-quality studies evaluated the long/full IQCODE.160,165,195 Two of these studies were conducted in Spanish in populations with low levels of education. The cut-points across the studies varied and every study used a different threshold. Despite this heterogeneity, the short IQCODE had a sensitivity of 75 to 81 percent (range 95% CI, 41 to 100) for dementia and specificity from 68 to 80 percent (range 95% CI, 59 to 100) for a cut-point around 3.3 in two studies (n=461).168,188 The full version of the IQCODE had a sensitivity of 79 to 83 percent (range 95% CI, 48 to 98) and specificity from 65 to 90 percent (range 95% CI, not reported to 95) for a cut-point around 3.3 in two studies (n=400).165, 188 In two other studies (n=390) using higher cut-points, sensitivity and specificity overlapped with those from other studies that used lower thresholds in populations with similar age and underlying dementia.160,195 If an informant-based screening tool is desired, the short or full IQCODE is the most well-studied in a primary care–relevant population. It is important to note, however, that the CIs are somewhat wide, and the instrument developer's suggested cut-point was not used/reported in these included studies.

#### Other Instruments

Sixteen other instruments were each only evaluated in a single study. Promising very brief instruments, based on high sensitivity and specificity (>80%), include: 6-Item Screener, VAT, GPCOG, and functional ability/activity instruments (e.g., ADLs, IADLs) (Appendix D Table 1); brief instruments include Benton's Orientation Test and the Delayed Recall Test (10 words, 10 minutes) (Appendix D Table 2); and self-administered instruments include the Short Concord Informant Dementia Scale (adapted from IQCODE) (Appendix D Table 3). One instrument, the GPCOG, was specifically designed for use in primary care.154 Without reproduction/replication of diagnostic accuracy in well-conducted diagnostic studies in populations relevant to outpatient primary care, these instruments cannot be suggested in place of more well-studied instruments.

### Screening for MCI

We found 27 studies designed to assess the diagnostic accuracy of a smaller subset of screening instruments (22 instruments) to detect MCI in primary care–relevant populations (Tables 5–10). Fifteen of these studies estimated (or allowed us to estimate) the diagnostic accuracy for MCI alone (excluded patients with dementia), while 16 of these studies estimated (or allowed us to estimate) the instrument's accuracy of detecting either MCI or dementia. These two estimates of diagnostic accuracy (i.e., detection of MCI vs. detection of MCI plus dementia) may not be comparable, as sensitivity may be relatively lower in populations that exclude dementia patients (because instrument likely has better discrimination in patients with a higher level of cognitive impairment; in other words, we would expect a higher number of false-negatives in the MCI vs. dementia group). As such, we present these data separately.

Although a much smaller body of literature than that of screening for dementia, this evidence base to detect MCI is a new and growing body of literature. In fact, almost all the studies of diagnostic accuracy were published during the past 10 years. All studies included populations to approximate those seen in primary care, most of which were community-dwelling older adults. Only two studies explicitly included patients in assisted living or residential care facilities.153,196 Almost all studies had a majority of women participants, but studies varied in the mean age (range of means, 70 to 83 years) and the prevalence of MCI (range of prevalence, 5% to 84%). Level of education was not reported in several studies. When reported, the education level varied. In the majority of studies, participants had at least a high school education. In eight studies not conducted in the United States, however, participants had on average a primary school education or less.133,160,163,164,196-199

The most commonly evaluated screening instruments to detect MCI were (most to least common): MMSE (k=15; n=5,758), IQCODE (k=4; n=975), CDT (k=4; n=4,191), Mini-Cog (k=3; n=1,092), TICS (k=3; n=568), and MoCA (k=2; n=251). Other commonly known/used instruments that were evaluated in only one study include the AD8, MIS, and SLUMS.

There were only four good-quality studies;163,173,200,201 the remaining fair-quality studies had similar quality concerns as those summarized previously. However, there was more variation in which diagnostic criteria were applied for MCI. The majority of studies applied the Petersen criteria (or “in the spirit” of the Petersen criteria), the international working definition by Winblad and colleagues, or suboptimal performance on cognitive testing (e.g., between 1 to 2 SDs below norm, CDR score of 0.5) without evidence of functional limitations. The Petersen criteria define amnestic MCI, thought to be a prodromal stage of AD, focusing on memory impairment, whether in isolation or in combination with other cognitive domains. In contrast, the Winblad criteria include both amnestic and nonamnestic types of MCI. The CDR is heavily weighted toward testing memory and therefore is more suited to detecting amnestic MCI, but is also inclusive of amnestic and nonamnestic types of MCI. A few studies, however, did not give details (e.g., used judgment, did not meet DSM-III or DSM-IV criteria for dementia). Again, most studies used a combination of history, examination, neuropsychological testing, and/or expert consensus to determine the formal diagnosis. The variation in diagnostic criteria limits comparability of diagnostic estimates across studies and is an important contributor of heterogeneity (along with population differences) leading to variation in screening test performance.

#### Very Brief Instruments

(Tables 5 and 9, Figure 5)

Figure 5 Diagnostic Accuracy of Very Brief Screening Instruments for MCI (Key Question 2)

^‡‡^ Prevalence for MCI only (no demented patients included in the sample and/or analysis)

Figure 5 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study for very brief screening instruments for MCI (including dementia and not including dementia). This figure refers to KQ2. In addition to the diagnostic accuracy information, the number, prevalence of dementia, and scoring cut-off is presented. Included instruments in this plot are the CDT and mini-cog. This same information is presented in Appendix D, Tables 4 and 7.

CDT. Four fair-quality studies evaluated the CDT in English, German, and Korean.196,198,199,202 These studies did not include people with dementia. These studies evaluated the performance of the CDT in different populations, using different cut-points and different diagnostic criteria for MCI. The largest study (n=3,198) was performed in an older, mostly female, poorly educated German population (mean age, 80.1 years). This study used two different reference criteria for MCI. Using the Peterson-like criteria, however, the prevalence of MCI was only 15 percent. Using modified criteria (did not require subjective cognitive impairment), the prevalence was 24.6 percent. Regardless of the diagnostic criteria, the sensitivity and specificity of the CDT was only around 60 percent. Another study from Germany (n=428), using the Winblad criteria, found a range of sensitivity of 48 to 76 percent and specificity of 49 to 79 percent regardless of scoring methods. This study recruited institutionalized (only around 11%) along with community-dwelling older adults, had a mean age of 83 years, and 64 percent of the sample had low education.196 Another study, from South Korea (n=465), was performed in a younger population that was also predominantly comprised of women with lower levels of education.199 Using the Peterson criteria, this study found that about 48 percent of the population had MCI and that the sensitivity was similarly low (range, 40.7% to 56.4%, depending on scoring method). This study also showed that the test performance varied depending on which scoring system the study used. Finally, the estimated sensitivity was higher (85%) in a smaller study (n=100), although the specificity was poor (44%).202 In this study, however, investigators used 1 SD as the cut-point for the instrument, and the diagnostic criteria for MCI was based on 1 SD below the (age adjusted) normative mean on the Dementia Rating Scale. Across four very different studies (n=4,191), the CDT appears to have worse sensitivity or specificity to detect MCI than to detect dementia using different cut-points.

Mini-Cog (Figure 5). Two studies evaluated the diagnostic performance of the Mini-Cog to detect MCI or dementia.172,173 One good-quality study (n=630) by Holsinger and colleagues conducted in a predominantly male population from a U.S. Department of Veterans Affairs (VA) setting with a low prevalence of dementia (3.3%) found a very low sensitivity of the instrument to detect MCI or dementia.173 A smaller fair-quality study (n=371) by Borson and colleagues, however, used the same cut-point and found a much higher sensitivity of 84 percent (95% CI, 78.6 to 88.5) and specificity of 87.9 percent (95% CI, 81.3 to 92.8).172 Although the overall prevalence of cognitive impairment was similar, the relative proportion of people with dementia versus MCI was much higher in the smaller study, likely resulting in a higher estimate of both sensitivity and specificity. Both studies used different diagnostic criteria for MCI. The study conducted by Borson and colleagues showed adequate test performance using a CDR score of 0.5 to define MCI.172 One fair-quality study evaluated the performance of the Mini-Cog to detect MCI alone in an assisted living or residential care population.152 This small study (n=91) estimated a very low sensitivity (50%) in this population, in which about 90 percent of residents had either MCI or dementia. Three very different studies (n=1,092) that used different definitions of MCI and different cut-points found different estimates of sensitivity to detect MCI plus or minus dementia.

#### Brief Instruments

(Tables 6 and 9, Figure 6)

Figure 6 Diagnostic Accuracy of Brief Screening Instruments for MCI (Key Question 2)

^‡‡^ Prevalence for MCI only (no demented patients included In the sample and/or analysis)

^**^ Calculated using the sensitivity, specificity, and prevalence of cognitive impairment

Abbreviations: CI – Confidence interval; HS – High school; TICS – Modified Telephone for Cognitive Status; MMSE – Mini-Mental State Examination; NR – Not reported

Figure 6 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study for brief screening instruments for MCI (including dementia and not including dementia). This figure refers to KQ2. In addition to the diagnostic accuracy information, the number, prevalence of dementia, and scoring cut-off is presented. Included instruments in this plot are the TICS-M, MOCA, and MMSE. This same information is presented in Appendix D, Tables 5 and 8.

TICS-M. Two fair-quality studies evaluated the TICS-M to detect MCI and dementia.184,203 One fair-quality study evaluated the TICS-M to detect MCI alone (excluding dementia patients).204 These three studies each found different optimal cut-points. The largest study (n=377) had a mean age of 81.4 years, with 18 percent of people with MCI.184 This study used the Mayo clinic criteria and found an optimal cut-point of 26 to detect either MCI or dementia, with a sensitivity and specificity of 73 percent (95% CI, 64 to 80) and 77 percent (95% CI, 71 to 82), respectively. In another study (n=120) conducted in French, while the age and prevalence were similar, the optimal cut-point was higher at 31.^203^ This study found that a lower cut-point of 27 had an unacceptably low specificity (46% [95% CI, 35 to 56]) and a higher cut-point of 34 had an unacceptably low sensitivity (47% [95% CI, 28 to 66]). Another small study (n=71) found the optimal cut-point to detect MCI (excluding patients with dementia) was 34, with lower cut-points of 31 and 26 to have low estimates of sensitivity (47.1% and 17%, respectively).204 Three small studies with different populations that used different definitions of MCI arrived at widely varied estimates for sensitivity and specificity.

MMSE. The MMSE was the most studied instrument used to detect MCI. Two good- and 13 fair-quality studies examined the diagnostic accuracy of the MMSE to detect MCI plus or minus dementia.134,152,153,159,160,163,164,185,186,188,197,200,202,203,205 Unfortunately, only 10 of the 15 studies reported sensitivity and specificity or provided sufficient data to allow us to calculate sensitivity and specificity.134,152,153,160,163,185,186,200,202,205 These 10 studies used different definitions of MCI, had different proportions of underlying MCI and dementia, and used different cut-points. In three studies (n=1,235) with high prevalence of MCI (>40%), sensitivity ranged from 45 to 60 percent (range 95% CI, 36 to 74) and specificity ranged from 65 to 90 percent (range 95% CI, 56 to 99) to detect MCI (excluding people with dementia) using a cut-point of 27 or 28.^134,152,200^ Another study conducted in residential care with a high proportion of people with cognitive impairment found that using a similar cut-point of 27 resulted in sensitivity of 71 percent (95% CI, 48 to 89) and specificity of 90 percent (95% CI, 77 to 97) to detect either MCI or dementia. Sensitivity ranged from 53 to 77 percent (range 95% CI, 43 to 85) in three other studies (n=1,544) with a range of prevalence of MCI and dementia (12.6% to 56.3%), and specificity ranged from 70 to 92 percent (range 95% CI, 58 to 99) using a cut-point of 23 or 24.^160,185,186^ Another study (n=701) examined test performance using different cut-points in different ethnic groups.205 The overall prevalence of MCI and dementia was 42.5 percent. The CIs for both the sensitivity and specificity of the MMSE overlapped when using a cut-point of 26 for whites, 25 for Latinos, and 23 for blacks. One small study (n=235) conducted in South Korea found a slightly better sensitivity, with an expected tradeoff in lower specificity, using a lower cut-point of 21.^163^ This lower cut-point was likely chosen based on the low levels of education in this population. Among a limited subset of studies that reported sensitivity and specificity, a cut-point of 27 or 28 had a low (and widely ranging) sensitivity to detect MCI, and a cut-point of 23 or 24 appears to have a better sensitivity and specificity to detect MCI and dementia than most other screening instruments, albeit still less than optimal.

MoCA. The MoCA was specifically designed to detect MCI. One fair-quality133 and one good-quality study201 assessed the test performance of the MoCA to detect MCI (excluding people with dementia). Both of these studies used the Petersen criteria for MCI. One study was conducted in South Korea, with a mean age of 70 years, and had a prevalence of MCI of 24 percent. The other study was conducted in an older population (mean age, 76 years) in the United Kingdom and had a prevalence of MCI of 20 percent. Using a cut-point of 25/26, sensitivity and specificity ranged from 80 to 100 percent (range of 95% CI, 56.3 to 100) and 50 to 76 percent (range of 95% CI, 41 to 84.9), respectively.

#### Self-Administered Instruments

(Tables 7 and 10, Figure 7)

Figure 7 Diagnostic Accuracy of Self-Administered Screening Instruments for MCI (Key Question 2)

^‡‡^ Prevalence for MCI only (no demented patients included in the sample and/or analysis)

^††^ Confidence intervals could not be calculated

^**^ Calculated using the sensitivity, specificity, and prevalence of cognitive impairment

Abbreviations: CI – Confidence interval; F – Full IQCODE; IQCODE – Informant Questionnaire on Cognitive Decline in the Elderly; NR – Not reported; S – Short IQCODE

Figure 7 displays a plot of the sensitivity (95% CI) and specificity (95% CI) by study for self-administered screening instruments for MCI (including dementia and not including dementia). This figure refers to KQ2. In addition to the diagnostic accuracy information, the number, prevalence of dementia, and scoring cut-off is presented. The included instruments in this plot is the IQCODE. This same information is presented in Appendix D, Tables 6 and 9.

IQCODE. Four fair-quality studies evaluated the short or full version of the IQCODE.135,160,188,195 Only three of these four studies presented results on the sensitivity and specificity of these instruments.135,160,195 In two studies (n=390), the full version of the IQCODE using similar cut-points of around 3.3 had differing sensitivity and specificity, ranging from 71 to 83 percent (95% CI, 60.6 to not reported) and 74.3 to 83 percent (95% CI, 62.4 to not reported), respectively, to detect MCI or dementia.160,195 These two studies, however, had different underlying prevalence of MCI and used different criteria to define MCI. The third study (n=441) found that the short version of the IQCODE using a cut-point of 3 had a sensitivity of 74.8 percent (95% CI, 67.7 to 80.7) and specificity of 69.0 percent (95% CI, 63.1 to 74.7) to detect MCI (excluding people with dementia).135 These patients, however, were generally older (mean age, 80.3 years) and had a higher underlying prevalence of cognitive impairment (31.8% with dementia, 28.6% with MCI). Across three different studies, the IQCODE had relatively low sensitivity for detecting MCI.

#### Other Instruments

Seventeen other instruments were evaluated in our included studies; however, each instrument was only evaluated in a single study. Four instruments appear promising given their relatively high sensitivity and specificity compared with other instruments: AD8, abbreviated Fuld Object Memory Evaluation (FOME), SLUMS, and CAMCI. Only the CAMCI was specifically designed to detect MCI. However, currently there is no replication of the test performance for these instruments in adequately-conducted diagnostic accuracy studies in populations similar to those in primary care.

## Key Question 3 What Are the Harms of Screening for Cognitive Impairment?

Screening for cognitive impairment may have direct or indirect harms from the diagnostic inaccuracy of screening (false-positives and false-negatives). We found no studies that directly addressed the adverse psychological effects from screening, adverse effects from unnecessary diagnostic testing (workup for false-positives), adverse effects from labeling or treating someone with dementia without diagnostic testing (false-positives without appropriate followup), or adverse effects from missed or delayed diagnosis (false-negatives).

We found only one fair-quality study that directly commented on the potential harms of screening for cognitive impairment in primary care.206,207 This study found that approximately half (207/434) of older adults who screened positive for cognitive impairment refused to complete a formal diagnostic workup for dementia. This study was conducted in multiple urban, low-income primary care practices in the United States. Authors found that older patients and patients with higher screening scores were more likely to refuse further assessment.207 While this study did not measure or report psychological harms of testing, the high refusal rate for diagnostic workup of screen-positive results may suggest that older adults have concerns about subsequent (yet necessary) diagnostic testing. Notably, the refusal for screening was low (233/3,573). Findings from this study may not be widely applicable to many U.S. practices, as two thirds of the study population were black women. In addition, diagnostic followup was offered by researchers, as opposed to the participant's primary care provider.

## Key Questions 4, 5 Overall Summary of Results for Treatment and Management of Cognitive Impairment

We identified one systematic review and 131 studies that addressed the treatment or management of mild to moderate dementia or MCI (or mixed populations that included people with MCI or early-stage dementia). We discuss the benefits and harms of each type of intervention separately due to the broad range of interventions we examined. This review covers pharmacological interventions, including FDA-approved medications to treat patients with AD for the purpose of preventing cognitive decline (i.e., donepezil, galantamine, rivastigmine, tacrine, and memantine) (Tables 11 and 12); medications primarily aimed at cardiovascular risk reduction for treatment of VaD, including antiplatelet medications and HMG-CoA reductase inhibitors (Table 13); NSAIDs (Table 13); gonadal steroids (estrogen, progesterone, and testosterone) (Table 13); and dietary supplements (i.e., vitamins, minerals, antioxidants) (Table 13). This review covers nonpharmacologic interventions, including interventions aimed primarily at the caregiver or patient-caregiver dyad (Table 14) and those aimed primarily at the patient (i.e., cognitive training, rehabilitation, and/or stimulation with or without motor skills training interventions; exercise interventions; multidisciplinary care interventions involving assessment and care coordination; and education-only interventions) (Table 15).

Table 11 Summary Table: Effectiveness of AChEIs and Memantine (Key Question 4)

Author, Year USPSTF Quality Rating | Daily Dosage(mg) | N randomized | Location | Mean Age (y) | % Female | % Non-white | % Institutionalized or Assisted Living | Mean MMSE Score (MMSE Inclusion Criteria) | Condition | Months to Followup | % Followup | Cognitive Function Outcomes | Global Function Outcomes | Physical Function Outcomes
Donepezil
Doody, 2009^208,277^ Fair | 5-10 | 821 | US | 70 | 46 | 13 | NR | 27.5 (24-28) | MCI | 11 | 61 | ↑ | ↔ | NR
Mori, 2012^214^ Fair | 3-10 | 140 | JP | 79 | 66 | 100 | NR | 19.6 (10-26) | DLB | 3 | 88 | ↑ | ↑ | NR
Requena, 2004^215,440^ Fair | 5-10 | 86 | ES | 77 | 71 | NR | NR | 20.8 (NR) | AD | 24 | 96.5 | ↔ | NA | NA
Raina, 2008^110^ Good | 1-10^*^ | 6506 | Multi | 67-86^*^ | 35-82^*^ | 1-8^*^ | NR | 11.8-27.4^*^ (NR) | VaD, AD, MCI^*^ | 3-36^*^ | 26-100^*^ | ↑ | ↑ | ↔
Galantamine
Auchus, 2007^216^ GAL-INT-26 StudyFair | 16-24 | 788 | Multi | 72 | 36 | 8 | NR | 20.3 (10-26) | VaD | 6 | 80.5 | ↔ | NA | ↔
Rockwood, 2006^217, 441-443^ VISTA Fair | 16-24 | 130 | CA | 77 | 63 | NR | 0 | 20.3 (10-25) | AD | 4 | 84 | ↑ | ↑ | ↑
Raina, 2008^110^ Good | 4-36^*^ | 5090 | Multi | 71-77^*^ | 0-64^*^ | 0-8^*^ | NR | 17.8-20.5^*^ (NR) | VaD, AD, MCI^*^ | 1-6^*^ | 53-84^*^ | ↑ | ↑ | ↔
Rivastigmine
Ballard, 2008^218^ VantagE Study Fair | 3-12 | 710 | Multi | 73 | 38 | 18 | NR | 19.2 (10-24) | VaD | 6 | 80.6 | ↑ | ↔ | ↔
Feldman, 2007^219^ Study 304 Fair | 2-12 | 678 | Multi | 71 | 59 | NR | 0 | 18.6 (10-26) | AD | 6 | 82 | ↑ | ↑ | ↔
Mok, 2007^220^ Fair | 6 | 40 | HK | 75 | 60 | 100 | NR | 13.2 (3-24) | VaD | 6 | 98 | ↑ | ↑ | ↑
Winblad, 2007^221,280, 444-449^ IDEAL Study Fair | 9.5-17.4 (patch); 12 capsule | 1195 | Multi | 74 | 67 | 25 | 2.6 | 16.5 (10-20) | AD | 6 | 81.2 | ↑ | ↔ | ↔
Raina, 2008^110^ Good | 1-12^*^ | 2206 | Multi | 69-84^*^ | 44-80^*^ | 5^*^ | NR | 11.4-20.4^*^ (NR) | AD, DLB^*^ | 3-12^*^ | 75-100^*^ | ↑ | ↑ | ↔
Tacrine
Raina, 2008^110^ Good | 20-160^*^ | 994 | Multi | 68-75^*^ | 46-87^*^ | NR | NR | 16.2-18.5^*^ (NR) | AD | 3-9^*^ | 42-92^*^ | ↑ | ↑ | ↑
Memantine
Bakchine, 2008^224^ Good | 20 | 470 | Multi | 74 | 63 | 0 | NR | 18.7 (11-23) | AD | 6 | 87 | ↔ | ↑ | NR
Ferris, 2007^225^ Fair | 20 | 60 | US | 67 | 65 | 10 | NR | 28.8 (>26) | MCI | 3 | 90 | ↔ | ↔ | ↔
Porsteinsson, 2008^226^ MEM-MD-12 Study Good | 20 | 433 | US | 75 | 52 | NR | 0 | 16.8 (10-22) | AD | 6 | 89 | NR | NR | NR
Saxton, 2012^222^ MEM-MD-71 Good | 10 | 265 | Multi | 75 | 58 | 9 | 0 | 15.8 (10-19) | AD | 3 | 95 | NR | ↑ | NR
Wilkinson, 2012^223^ Fair | 20 | 278 | Multi | 74 | 57 | <1 | 0 | 16.9 (12-20) | AD | 12 | 78 | ↔ | NR | NR
Raina, 2008^110^ Good | 5-20^*^ | 1959 | Multi | 76-78^*^ | 47-67^*^ | 0-6^*^ | NR | 7.9-17.6^*^ (NR) | VaD, AD^*^ | 6 | 72-98^*^ | ↔ | ↔ | ↔

* Range in mean or item reported for each individual study included in Raina 2008.

↑ Statistically significantly favored the intervention.

↔ No statistically significant difference between the intervention and control.

Abbreviations: AChEI = acetylcholinesterase inhibitor; AD = Alzheimer's disease; CA = Canada; DLB = dementia with Lewy bodies; ES = Spain; GAL-INT = galantamine international; HK = Hong Kong; IDEAL =Investigation of transDermal Exelon in Alzheimer's disease; JP = Japan; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; Multi = multiple countries; NR = not reported; USPSTF = U.S. Preventive Services Task Force; VaD = vascular dementia; VISTA = Video-Imaging Synthesis of Treated Alzheimer's Disease.

Table 12 Summary Table: Harms of AChEIs and Memantine (Key Question 5)

Design | Author, Year USPSTF Quality Rating | Daily Dosage (mg) | N | Location | Mean Age (y) | % Female | Mean MMSE Score | Months to Followup | Harm Outcomes
Donepezil
Trials | Raina, 2008^110^ Good | 1-10^†^ | 6506 | NR | 67-86^†^ | 35-82^†^ | 11.8-27.4^†^ | 3-36^†^ | Total AE: NR by Raina Withdrawals due to AE (reported in 17/21 trials) Drug: 14% Placebo: 7% Serious AE (reported in 12/21 trials) Drug: 12% Placebo: 11%
Trials | Burns, 2007α278 | 5-10 | 579 | Multi | 71 | 55 | 20.1 | 22¥ | Total AE Drug: 85% Discontinuation due to AE Drug: 15% Serious AE Drug: 7%
Trials | Wilkinson, 2010α279 | 5-10 | 885 | Multi | 75 | 59 | 22.0 | 12 | Total AE: NR Discontinuation due to AE Drug: 12% Serious AE: NR
Trials | Doody, 2009^208,277^ Fair | 5-10 | 821 | US | 70 | 46 | 27.5 | 11 | Total AE Drug: 81% Placebo: 69% Withdrawals due to AE Drug: 18% Placebo: 8% Serious AE Drug: 12% Placebo: 11%
Trials | Doody, 2009^208,277^ | 5-10 | 145 | US | 73 | 46 | NR | 17 | Total AE Drug: 57% Placebo: 62% Withdrawals due to AE Drug: 10% Placebo: 22% Serious AE Drug: 4% Placebo: 3%
Trials | Boada-Rovira, 2004^286^ Fair | 5-10 | 1113 | Multi | 71 | 60 | 18.7 | 3 | Total AE Drug: 45% Discontinuation due to AE Drug: 5.3% Serious AE: NR
Trials | Mori, 2012^214^ Fair | 3-10 | 140 | JP | 79 | 66 | 19.6 | 3 | Total AE Drug: 79% Placebo: 71% Withdrawals due to AE Drug: 2% Placebo 12% Serious AE Drug: 8% Placebo 6%
Trials | Relkin, 2008^287^ Fair | 5-10 | 1035 | US | 75 | 60 | 19.8^‡^ | 3 | Total AE Drug: 70%^†††^ Discontinuation due to AE Drug: 6% Serious AE Drug: 9%^‡‡‡^
Obs | Babai, 2010^288^ Fair− | NR | 222 | FR | 81 | 70 | NR | NR | Most commonly (voluntary) reported serious AE (to French pharmacovigilence system): bradycardia (10%), weakness (5%), convulsions (4%)^‡‡^
Obs | Dunn, 2000^450^ Fair− | 5-10 | 1762 | UK | 73 | 58 | NR | 6 | Most commonly (voluntary) reported AE (UK surveillance questionnaire to prescribers): nausea/vomiting (16 per 1000 patient-months of rx), diarrhea (16 per 1000 patient-months of rx), and malaise (7 per 1000 patient-months of rx)
Obs | Hernandez, 2009^290^ Good | NR | 2888 | US | 74 | 4 | NR | 29 | Bradycardia^††^ Drug: 57% Control: 52% Adjusted HR, 1.2 (95% CI, 1.1 to 1.3)
Obs | Park-Wyllie, 2009^291^ Fair+ | NR | 627 | CA | 83 | 51 | NR | 9 | Bradycardia-related hospital admission Drug: 86% Control: 75% Adjusted OR, 2.1 (95% CI, 1.3 to 3.5)
Galantamine
Trials | Raina, 2008^110^ Good | 4-36^†^ | 5090 | NR | 71-76.8^†^ | 0-64^†^ | 17.8-20.5^†^ | 1-6^†^ | Total AE: NR by Raina Withdrawals due to AE (reported in 8/10 trials) Drug: 18% Placebo: 7% Serious AE (reported in 6/10 trials) Drug: 8% Placebo: 8%
Trials | Auchus, 2007^216^ GAL-INT-26 Study Fair+ | 16-24 | 788 | Multi | 72.3 | 36 | 20.3 | 6 | Total AE Drug: 76% Placebo: 71% Discontinued due to AE Drug: 14% Placebo: 7% Serious AE Drug: 20% Placebo: 18%
Trials | Rockwood, 2006^217,441-443^ VISTA Fair | 16-24 | 130 | CA | 77.4 | 63 | 20.3 | 4 | Total AE Drug: 84% Placebo: 62% Withdrawal due to AE Drug: 8% Placebo: 3% Serious AE Drug: 8% Placebo: 15%
Trials | Rockwood, 2006^217,441-443^ | 16-24 | 130 | CA | 77.4 | 63 | 20.3 | 8 | Total AE- NR Withdrawal due to AE Drug: 13% Placebo: 11% Serious AE Drug: 14% Placebo: 14%
Trials | Aronson, 2009^451^ | 16-24 | 838 | Multi | 77.0 | 64 | 17.7 | 5 | Total AE Drug: 36% Placebo: 25% Discontinuation due to AE- NR Serious AE Drug: 2% Placebo: 1%
Obs | Hernandez, 2009^290^ Good | NR | 324 | US | 74 | 4 | NR | 29 | Bradycardia^††^ Drug: 43% Control: 52% Adjusted HR, 1.0 (95% CI, 0.76 to 1.3)
Rivastigmine
Trials | Raina, 2008^110^ Good | 1-12^†^ | 2206 | NR | 69.4-83.8^†^ | 44-80^†^ | 11.4-20.4^†^ | 3-12^†^ | Total AE: NR by Raina Withdrawals due to AE (reported in 7/9 trials) Drug: 22% Placebo: 6% Serious AE (reported in 4/9 trials) Drug: 14% Placebo: 12%
Trials | Winblad, 2007^221,280,444-449^ IDEAL Study Fair | 9.5-17.4 (patch); 12 (capsule) | 1195 | Multi | 73.6 | 67 | 16.5 | 6 | Total AE Drug: 60% Placebo: 46% Discontinuation due to AE Drug: 8% Placebo: 5% Serious AE: NR
Trials | Winblad, 2007^221,280, 444-449^ | 9.5-17.4 (patch); 12 (capsule) | 1195 | Multi | 73.6 | 67 | 16.5 | 12 | Total AE Drug: 55% Placebo: 63% Discontinuation due to AE: NR Serious AE: NR
Trials | Ballard, 2008^218^ VantagE Study Fair+ | 3-12 | 710 | Multi | 72.8 | 38 | 19.2 | 6 | Total AE: NR Withdrawal due to AE Drug: 13% Placebo: 6% Serious AE Drug: 15% Placebo: 11%
Trials | Feldman, 2007^219^ Study 304 Fair+ | 2-12 | 678 | Multi | 71.4 | 59 | 18.6 | 6 | Total AE Drug: 91% Placebo: 76% Withdrawal due to AE Drug: 14% Placebo: 9% Serious AE Drug: 18% Placebo: 15%
Trials | Mok, 2007^220^ Fair | 6 | 40 | HK | 74.9 | 60 | 13.2 | 6 | Total AE Drug: 60% Placebo: 50% Withdrawal due to AE Drug: 30% Placebo: 15% Serious AE: NR
Obs | Hernandez, 2009^290^ Good | NR | 218 | US | 74 | 4 | NR | 29 | Bradycardia^††^ Drug: 87% Control: 52% Adjusted HR, 1.6 (95% CI, 1.2 to 2.0)
Tacrine
Trials | Raina, 2008^110^ Good | 20-160^†^ | 994 | NR | 68-75^†^ | 46-87^†^ | 16.2-18.5^†^ | 3-9^†^ | Total AE: NR by Raina Withdrawals due to AE (reported in 4/6 trials) Drug: 44% Placebo: 11% Serious AE (reported in 0/6 trials)
Memantine
Trials | Raina, 2008^110^ Good | 5-20^†^ | 1959 | NR | 76-78^†^ | 47-67^†^ | 7.9-17.6^†^ | 6 | Total AE: NR by Raina Withdrawals due to AE (reported in 5/5 trials) Drug: 10% Placebo: 10% Serious AE (reported in 4/5 trials) Drug: 14% Placebo: 14%
Trials | Ott, 2007α281 MEM-MD-11AB | 20 | 314 | US | 77 | 60 | 17.3 | 12 | Total AE Drug: 75% Placebo: 75% Withdrawal due to AE Drug: 7% Placebo: 6% Serious AE Drug: 10% Placebo: 12%
Trials | Bakchine, 2008^224^ Good | 20 | 470 | Multi | 74 | 63 | 18.7 | 6 | Total AE Drug: 56% Placebo: 53% Withdrawal due to AE Drug: 9% Placebo: 4% Serious AE Drug: 0% Placebo: 0%
Trials | Ferris, 2007^225^ Fair− | 20 | 60 | US | 67 | 65 | 28.8 | 3 | Total AE: NR Withdrawal due to AE: NR Serious AE Drug: 0% Placebo: 0%
Trials | Porsteinsson, 2008^226^ MEM-MD-12 Study Good | 20 | 433 | US | 75.4 | 52 | 16.8 | 6 | Total AE: NR Withdrawal due to AE Drug: 6% Placebo: 8% Serious AE Drug: 12% Placebo: 14%
Trials | Saxton, 2012^222^ MEM-MD-71 Good | 20 | 265 | Multi | 75 | 58 | 15.8 | 3 | Total AE (treatment emergent) Drug: 48.9% Placebo: 49.6% Withdrawals due to AE Drug: 2% Placebo: 3% Serious AE Drug: 3% Placebo: 10.1%
Trials | Wilkinson, 2012^223^ Fair | 20 | 278 | Multi | 74 | 57 | 16.9 | 12 | Total AE: NR Withdrawals due to AE Drug: 11% Placebo: 8% Serious AE Drug: 13% Placebo: 14%
Obs | Babai, 2010^288^ Fair− | NR | 95 | FR | 81 | 61 | NR | NR | Most commonly reported AE: bradycardia (7%), weakness (6%), convulsions (3%)^‡‡^
Obs | Forstl, 2011^292^ Fair | 20 | 4305 | Multi | 76 | 87 | 17.1 | 6 | Total AE Drug: 6% Withdrawal due to AE Drug: 15% Serious AE: NR
Obs | Vidal, 2008^293^ Fair | NR | 5283 | FR | 81 | 69 | NR | 20 | Total AE: NR Withdrawal due to AE Drug: 40% Serious AE: NR
Mixed: Any AChEI and/or Memantine
Obs | Froelich, 2009^294^ Fair− | NR (T, D, R, G, M) | 2288 | Multi | 77^*^ | 63 | 19.0^*^ | 24 | Total AE Drug: 41%^***^ Discontinuation due to AE: NR Serious AE Drug: 18%
Obs | Fosbol, 2012^299^ Fair | D, G, R, M, or mixed | 76233 | Multi | 81 | 70 | NR | 12 | Cardiovascular safety profiles of AChEI and memantine did not differ in the Medicare population. Higher risk of MI and cardiac death in persons taking memantine in the Danish cohort likely attributable to selection of sicker population.
Obs | Pariente, 2010^296^ Fair− | NR (D, R, G) | 773 | FR | 80^*^ | 65 | NR | NR | Most commonly (voluntary) reported serious AE (to French pharmacovigilence system): CNS disorders (19%), heart rate/rhythm disorders (16%), GI disorders (14%)^‡‡^
Obs | Raschetti, 2005^295^ Fair | 5-10 (D) NR (R, G) | 2853 | IT | 76 | 67 | NR | 9 | Total AE Drug: 14% Discontinuation due to AE Drug: 5% Serious AE Drug: 18%
Obs | Stephenson, 2012^297^ Fair | NR (D, G, R) | 14332 | CA | 82 | 54 | NR | 12 | In persons with COPD and dementia, no difference in COPD exacerbations, ED visits, hospitalizations, or ICU admissions in people taking AChEI vs. people not taking this class of medication.
Obs | Van Der Putt, 2006^452^ Fair | NR (T, D, R, G) | 939 | UK | 80 | 61 | NR | NR | Total AE: NR Discontinuation due to AE Drug: 17% Serious AE: NR
Obs | Gill, 2009^298^ Good | NR (D, R, G) | 81302 | CA | 80 | 61 | NR | 12 | Hospitalizations due to: Bradycardia Drug: 7/1000 p-y Control: 4/1000 p-y Adjusted HR, 1.7 (95% CI, 1.3 to 2.2) Hip fracture Drug: 22/1000 p-y Control: 20/1000 p-y Adjusted HR, 1.2 (95% CI, 1.0 to 1.3) Syncope Drug: 32/1000 p-y Control: 19/1000 p-y Adjusted HR, 1.8 (95% CI, 1.6 to 2.0) Pacemaker Drug: 5/1000 p-y Control: 3/1000 p-y Adjusted HR, 1.5 (95% CI, 1.1 to 2.0)
Obs | Hernandez, 2009^290^ Good | NR (D, R, G) | 3430 | US | 74 | 4 | NR | 29 | Bradycardia^††^ Drug: 57% Control: 52% Adjusted HR, 1.2 (95% CI, 1.1 to 1.3) AE secondary to bradycardiaβ Fall adjusted HR, 2.6 (95% CI, 1.9 to 3.5) Fracture adjusted HR, 0.8 (95% CI, 0.4 to 1.4) Syncope adjusted HR, 3.7 (95% CI, 2.5 to 5.5) Pacemaker, 0.7% vs. 0.2%

† Range in mean or item reported for each individual study included in Raina 2008.

¥ Mean followup time (ranged from 8-46 months).

* Median.

‡ Standardized MMSE.

α OLE to an RCT included in Raina.

** Three OLEs of RCTs included in Raina and three additional open-label studies.

†† ICD-9 code or at least one recorded HR <60.

‡‡ No denominator, so these percentages represent relative frequency of AEs of total reported AEs.

β Drug with bradycardia vs. control without bradycardia.

*** 12% possibly or likely drug related.

††† 44% reported as “related.”

‡‡‡ 3% reported as “related.”

Abbreviations: AChEI = acetylcholinesterase inhibitor; AD = Alzheimer's disease; AE = adverse event; CA = Canada; DE = Germany; ES = Spain; FR = France; G = galantamine; GAL-INT = galantamine international; HK = Hong Kong; IDEAL = Investigation of transDermal Exelon in Alzheimer's disease; IT = Italy; JP = Japan; MCI = mild cognitive impairment; MMSE = Mini-Mental State Examination; Multi = multiple countries; NA = not applicable; NR = not reported; Obs = observational; OLE = open-label extension; R = rivastigmine; RCT = randomized, controlled trial; USPSTF = U.S. Preventive Services Task Force; VaD = vascular dementia; VISTA = Video-Imaging Synthesis of Treated Alzheimer's Disease.

Table 13 Summary Table: Effectiveness and Harms of Other Medications (Key Questions 4 and 5)

Author, Year USPSTF Quality Rating | Medication, Daily Dosage | N Randomized | Location | Mean Age (y) | % Female | Mean MMSE Score | Months to Followup | Cognitive Outcomes | Harms Outcomes | Other Outcomes
Vascular Medications
AD2000^305^ Fair | ASA, 75 mg | 310 | UK | 75 (median) | 62.9 | 19 | 36 | ↔ | Total AE ↑ Severe AE ↑^‡‡^ Nonadherence (due to AE) ↑^††^ | Physical function ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔
Clarke, 2003^300^ Fair | Aspirin, 81 mg | 149 | UK | NR (median 75) | NR | 21.0^‡^ | 3 | ↔ | NR | Physical function ↔
Feldman, 2010^306^ Jones, 2008^453^ LEADe study Fair | Atorvastatin, 80 mg | 640 | US | 73.6 | 52.0 | 21.9 | 18 | ↔ | Total AE ↑¥ Severe AE ↔ Nonadherence (due to AE) ↑ | Physical function ↔ Neuropsychiatric disturbances ↔
Sano, 2011^307^ Fair | Simvastatin, 40 mg | 406 | US | 74.6 | 59.4 | 20.4 | 18 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔
Simons, 2002^308^ Fair | Simvastatin, 80 mg | 44 | DE | 68.2 | 55.0 | 17.5 | 6 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) ↔ | None
Sparks, 2005^309^ Sparks, 2006^454^ Sparks, 2006^455^ ADCLT trial Fair | Atorvastatin, 80 mg | 63 | US | 78.5 | 36.5 | 20.8 | 12 | ↔ | NR | Physical function ↔ Depression ↑ Neuropsychiatric disturbances ↔ Caregiver burden ↔
NSAIDs
Pasqualetti, 2009^310^ Fair | Ibuprofen, 800 mg | 132 | IT | 73.9 | 63.0 | 20.0 | 18 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) ↔ | Physical function ↔ Depression ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔
Aisen, 2003^311^ Fair | Naproxen, 220 mg | 351 | US | 73.9 | 53.0 | 20.9 | 12 | ↔ | Total AE NR Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔ HRQL ↔ Neuropsychiatric disturbances ↔
de Jong, 2008^312^ Fair | Indomethacin, 100 mg | 51 | NL | 72.5 | 65.0 | 19.6 | 12 | ↔ | Total AE NR Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔
Soininen, 2007^313^ Fair | Celecoxib, 40 mg | 425 | Multi^‡^ | 73.6 | 54.8 | 19.7 | 12 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔ HRQL ↔ Depression ↔
Gonadal steroids
Henderson, 2000^315^ Fair | Estrogen, 1.25 mg | 42 | US | 77.5 | 100 | 19.5 | 4 | ↔ | NR | Physical function ↔ Depression ↔
Lu, 2006^318^ Fair- | Testosterone, 75 mg | 18 | US | 69.8 | 0 | 22.0 | 6 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) ↔ | HRQL ↔ Depression ↔ Neuropsychiatric disturbances ↔
Mulnard, 2000^316^ Fair | Estrogen, 0.625 mg or 1.25 mg | 120 | US | 75.1 | 100 | 20.7 | 12 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) ↔ | Physical function ↔ Depression ↔
Valen-Sendstad, 2010^317^ Fair | Progesterone, 0.5 mg + estrogen, 1 mg | 65 | NO | 81.0 | 100 | 21.9 | 12 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) NR | Physical function ↔ Depression ↔
Wang, 2000^314^ Fair | Estrogen, 1.25 mg | 50 | TW | 71.8 | 100 | 16.2 | 3 | ↔ | Total AE ↑ Severe AE NR Nonadherence (due to AE) ↔ | Depression ↔
Vitamins and supplements
Aisen, 2008^321^ Good | Folic acid, 5 mg + vitamin B12, 1 mg + vitamin B6, 25 mg | 409 | US | 76.3 | 56.0 | 21.0 | 18 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) NR | Physical function ↔ Depression ↔ Neuropsychiatric disturbances ↔
Clarke, 2003^300^ Fair | Folic acid, 2 mg + vitamin B12, 1 mg | 149 | UK | NR (median 75) | NR | 21.0^‡^ | 3 | ↔ | NR | Physical function ↔
Clarke, 2003^300^ Fair | Vitamin E, 500 mg + vitamin C, 200 mg | 149 | UK | NR (median 75) | NR | 21.0^‡^ | 3 | ↔ | NR | Physical function ↔
Connelly, 2008^456^ Fair | Folic acid, 1 mg^**^ | 57 | UK | 76.3 | 71.0 | 23.5 | 6 | ↔ | NR | Physical function ↑
de Jager, 2012^301^ VITACOG Fair | Folic acid, 0.8 mg + cyanocobalamin, 0.5 mg + pyridoxine HCl, 20 mg | 271 | UK | 77 | 64 | NR | 24 | ↔ | Total AE ↔ Severe AE NR Nonadherence (due to AE) NR | Depression ↔
Freund-Lund, 2006^319^ Freund-Lund, 2008^457^ Fair | DHA, 430 mg + EPA, 150 mg + vitamin E, 4 mg | 204 | SE | 74.0 | 54.0 | 23.4 | 6 | ↔ | NR | Physical function ↔ Depression ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔
Kwok, 2011^458^ Fair | Vitamin B12, 1 mg + folic acid, 5 mg | 140 | HK | 78.2 | 64.0 | 16.6 | 24 | ↔ | NR | Depression ↔ Neuropsychiatric disturbances ↔
Sano, 1997^320^ Good | Vitamin E, 1000 IU | 169 | US | 73.4 | 65.7 | 12.3 | 24 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) NR | Physical function ↔ Neuropsychiatric disturbances ↔
Sinn, 2012^302^ Fair | DHA, 1.55 g + EPA, 0.4 g EPA, 1.67 g + DHA, 0.16 g | 54 | AU | 74 | 32 | 27.2 | 6 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) ↔ | Depression ↑ HRQL ↔
Quinn, 2010^459^ Fair | DHA, 2 g | 402 | US | 76 | 52.2 | 20.7 | 18 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔ Neuropsychiatric disturbances ↔
Sun, 2007^460^ Fair | Vitamin B12, 0.5 mg + multivitamin^†^ | 89 | JP | 75.0 | 49.0 | 18.7 | 6 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔
van Uffelen, 2008^303^ van Uffelen, 2007^461^ van Uffelen, 2005^462^ Fair | Folic acid, 5 mg + vitamin B12, 0.4 mg + vitamin B6, 50 mg | 179 | NL | 75.0 | 44.0 | 29.0 | 12 | ↔ | Total AE NR Severe AE NR Nonadherence (due to AE) ↔ | HRQL ↔
Yurko-Mauro, 2010^304^ Good | DHA, 900 mg | 485 | US | 70.0 | 57.9 | 28.2 | 6 | ↔ | Total AE ↔ Severe AE ↔ Nonadherence (due to AE) ↔ | Physical function ↔ Depression ↔

‡ Median.

† Multivitamin contained folic acid, pyridoxine HCl, ferrous (60 mg), nicotinamind (10 mg), calcium carbonate (250 mg), riboflavin (2 mg), thiamine mononitrate (3 mg), calcium panthothenate (1 mg), ascorbic acid (100 mcg), iodine (100 mcg), copper (150 mcg), vitamin B12 (3 mcg), vitamin A (4,000 IU), and vitamin D3 (400 IU).

** All patients received AChEIs.

¥ Not significant for total AEs, but significant for treatment-related total AEs.

†† Overall nonadherence, not necessarily due to AE.

‡‡ Serious bleeding events.

↔ No statistically significant difference between the intervention and control groups.

Abbreviations: AD = Alzheimer's disease; ADCLT = Alzheimer's disease cholesterol-lowering treatment; AE = adverse events ; ASA = acetylsalicylic acid; AU = Australia; DE = Germany; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; HK = Hong Kong; HRQL = health-related quality of life; IT = Italy; JP = Japan; LEADe = Lipitor's Effect in Alzheimer's Dementia; multi = multiple countries; NL = The Netherlands; NO = Norway; NR = not reported; NSAIDs = nonsteroidal anti-inflammatory drugs; MMSE = Mini Mental State Examination; SE = Sweden; TW = Taiwan; UK = United Kingdom; USPSTF = U.S. Preventive Services Task Force.

Table 14 Summary Table: Effectiveness of Caregiver Interventions (Key Question 4)

Author, Year USPSTF Quality Rating | N Randomized | Location | % Spouse | Minimum Amount of Caregiving | Mean MMSE Score | Months to Followup | Caregiver Burden Outcome | Caregiver Depression Outcome | Patient Institutionalization Outcome | Other Outcomes
Group-Based Psychoeducation
REACH II, 2006^352^ Fair | 642 | US | 43.2 | 4 h/d | 12.9 | 6 | ↑ | ↑ | ↔ | Caregiver self-related health (↑); patient symptoms (↑)
Brodaty, 1989^361^ Fair | 101 | AU | 92.7 | NR | NR^*^ | 18 | NR | NR | ↑ | Caregiver distress (↑); patient mortality (↔)
REACH-Birmingham, 2003^330^ Fair | 140 | US | 50 | 4 h/d | 13.1 | 6 | ↑ | ↔ | NR | Caregiver anxiety (↔); patient behavior (↔)
Chu, 2011^353^ Fair | 85 | TW | 32.2 | 4 h/d | NR | 4 | ↔ | ↑ | NR
Coon, 2003^374^ Fair | 169 | US | 57 | NR | 14.2 | 7 | NR | ↑ | NR
REACH-Palo Alto, 2003 (IG1)325 Fair | 257 | US | NR | 4 h/d | 13.7 | 6 | ↔ | ↔ | NR
De Rotrou, 2011^463^ Fair | 157 | FR | 57 | 4 h/wk | NR | 6 | ↔ | ↔ | ↔ | Patient cognitive (↔), physical (↔), behavior (↔)
Gallagher-Thompson, 2008^367^ Fair+ | 184 | US | 38 | 8 h/d | 14 | 6 | ↑ | ↑ | NR | Caregiver stress (↑)
Hebert, 1994^362^ Fair- | 121 | CA | 68 | Wkly | 14.6 | 8 | ↔ | NR | ↔ | Caregiver symptoms (↔)
Hepburn, 2001^371^ Fair | 117 | US | 66 | NR | NR | 5 | ↑ | ↑ | NR | Caregiver distress (↑)
Hepburn, 2005^146^ Fair- | 223 | US | 66 | NR | 17.7 | 12 | ↔ | NR | NR | Patient cognitive (↔), physical (↔), behavior (↔)
Kurz, 2010^358^ Fair | 292 | AT, CH, DE | 58 | Daily | 13.9 | 15 | NR | ↔ | ↔ | Caregiver emotional role (↑), social role (↔), mental health (↔)
Losada, 2010^377^ Fair | 167 | ES | 35 | 1 h/d | NR | 3 | NR | ↑ | NR | Caregiver dysfunctional thoughts (↑)
Ostwald, 1999^372^ Fair | 117 | US | NR | NR | NR | 5 | ↑ | ↔ | NR | Patient cognitive function (↔)
Ulstein, 2007^360^ Fair | 180 | NO | 70 | Wkly | 20.8 | 12 | ↔ | NR | ↔ | Patient mortality (↔)
Waldorff, 2012^368^ Good | 330 | DK | 65 | Wkly | 24.1 | 12 | NR | ↑ | NR | Caregiver HRQL (↔); patient cognitive function (↔), physical (↔), HRQL (↔), depression (↑)
Individual Psychoeducation
Chang, 1999^375^ Fair | 87 | US | 88.6 | NR | NR | 3 | NR | ↑ | NR | Caregiver anxiety (↔); patient functioning (↔)
Ducharme, 2011^365^ Fair | 121 | CA | 34.2 | NR | NR | 5 | NR | NR | NR | Plan for future treatment needs (↔)
Gitlin, 2001^340^ Fair | 202 | US | 25.1 | NR | NR | 3 | ↔ | NR | NR | Patient problem behaviors (↔), physical function (↔)
REACH-Philadelphia, 2003^332^ Fair | 255 | US | 35.3 | 4 h/d | 12.2 | 6 | ↔ | ↔ | NR | Caregiver wellbeing (↔); patient ADL (↔), IADL (↔), memory-related behavior (↔), disruptive behavior (↔)
Gitlin, 2008^354^ Fair | 60 | US | 61.7 | 4 h/d | 11.6 | 4 | NR | ↔ | NR | Patient morality (↔), QOL (↔), depression (↔), problem behavior (↔)
Gitlin, 2010 (ACT)342 Fair | 272 | US | 51 | NR | 13 | 6 | ↑ | ↑ | NR
Gitlin, 2010 (COPE)341 Fair | 237 | US | 37.8 | 8 h/wk | 13.4 | 4 | NR | NR | NR | Caregiver well-being (↑); patient IADL (↑), ADL (↔), QOL (↔), agitation (↔)
Graff, 2006^343^ Fair | 135 | NL | 58.8 | Wkly | 19.0 | 3 | NR | ↑ | ↔ | Caregiver QOL (↑), distress (↑); patient mortality (↔), function (↑),QOL (↑), depression (↑)
Hebert, 2003^363^ Fair | 158 | CA | 61 | NR | NR | 4 | ↑ | NR | ↔ | Caregiver psychiatric symptoms (↔), anxiety (↔); patient mortality (↔), behavior (↔)
Hinchliffe, 1995^357,357^ Fair | 40 | UK | 70 | NR | NR | 4 | NR | NR | NR | Caregiver distress (↑), mental health diagnosis (↑)
Huang, 2003^366^ Fair | 59 | TW | 35.4 | NR | 13.1 | 3 | NR | NR | NR | Patient behavior (↑)
Marriott, 2000^359^ Fair | 42 | UK | 52.4 | NR | 12.5 | 12 | NR | ↑ | NR | Caregiver distress (↑); patient cognitive function (↔), ADL (↑), depression (↔)
Martin-Carrasco, 2009^355^ Fair | 115 | ES | 54.8 | 4 h/d | 18.7 | 10 | ↑ | NR | NR | Caregiver distress (↑), functioning (↑)
Martin-Cook, 2005^379^ Fair | 49 | US | 91.5 | NR | 19.4 | 4 | NR | ↔ | NR | Patient cognitive function (↔)
Roberts, 1999^364^ Fair | 83 | CA | 52 | NR | NR | 12 | NR | NR | NR | Caregiver adjustment to patient illness (↔)
Schoenmakers, 2010^376^ Fair | 62 | BE | 46 | NR | NR | 12 | NR | ↑ | NR | Patient hospitalization (↔)
Spijker, 2011^337^ Good | 301 | NL | 27.6 | 2 d/wk | NR | 12 | NR | NR | ↔
Teri, 2005^145^ Fair | 95 | US | 55.3 | NR | 13.6 | 6 | ↑ | ↑ | ↔ | Patient QOL (↑), memory-related behavior (↑)
Voigt-Radloff, 2011^344^ Fair | 141 | DE | 56 | 2 d/wk | 20.4 | 12 | ↔ | ↔ | ↔ | Caregiver function (↔), patient mortality (↔), IADL (↔),QOL (↔), depression (↔)
Williams, 2010^378^ Fair | 116 | US | 41 | NR | NR | 6 | NR | ↔ | NR | Caregiver anxiety (↔), stress (↔)
Wright, 2001^464^ Fair | 93 | US | 45 | NR | NR | 12 | ↔ | ↔ | ↔ | Caregiver physical health (↔); patient agitation (↔)
Computer- or Phone-Based Psychoeducation
Brennan, 1995^338^ Fair | 102 | US | 58 | NR | NR | 12 | ↔ | ↔ | ↔
Finkel, 2007^339^ Fair | 46 | US | 44 | 4 h/wk | NR | 6 | ↔ | ↔ | NR | Patient mortality (↔), behavior (↔)
REACH-Boston, 2003^333^ Fair | 100 | US | 54 | 4 h/d | 11.4 | 6 | ↔ | ↔ | NR | Caregiver anxiety (↔)
Family-Based Psychoeducation
Joling, 2012^334,465^ Fair | 192 | NL | 94.3 | NR | 21.6 | 12 | ↔ | ↔ | ↔ | Caregiver anxiety (↔), function (↔)
Mittleman, 2008^335^ Fair | 158 | AU | NR | NR | 20.3 | 24 | NR | ↑ | ↔ | Patient mortality (↔)
Psychoeducation + Care/Case Management
Bass, 2003^345^ Fair | 182 | US | NR | NR | NR | 12 | NR | ↑ | NR | Caregiver health deterioration (↔); patient hospitalization (↔), emergency department visits (↔)
Callahan, 2006^346^ Fair | 153 | US | 44.5 | NR | 18.1 | 18 | ↑ | ↑ | ↔ | Caregiver distress (↑); patient mortality (↔), cognitive function (↑), depression (↔)
Chu 2000^347^ Fair | 78 | CA | NR | NR | 22.8 | 18 | ↑ | NR | ↔ | Patient mortality(↔), cognitive function (↔), depression (↔), behavior (↔)
Eloniemi-Sulkava, 2009^356^ Good | 125 | FI | 100 | NR | 13.8 | 24 | NR | NR | ↔ | Patient mortality (↔)
Eloniemi-Sulvaka, 2001^348^ Fair | 100 | FI | 56 | NR | 14.8 | 24 | NR | NR | ↔ | Patient mortality (↔)
Fortinsky, 2009^349^ Fair | 84 | US | 45 | NR | NR | 12 | ↔ | ↔ | ↔
REACH-Memphis, 2003^332^ Fair | 245 | US | NR | 4 h/d | 11.1 | 6 | ↔ | ↔ | NR
Jansen 2011^350^ Fair | 99 | NL | 40.4 | NR | 22.3 | 12 | ↔ | ↔ | NR | Caregiver function (↔); patient mortality (↔),QOL (↔)
Lam, 2010^351^ Fair | 102 | HK | 29.4 | NR | 17.8 | 12 | ↔ | NR | ↔ | Caregiver distress (↔), QOL (↔); patient cognitive function (↔),QOL (↔), depression (↔), neuropsychiatric symptoms (↔)
Vickrey 2006^336^ Good | 408 | US | 54.8 | NR | NR^†^ | 18 | NR | NR | NR | Caregiver QOL (↔); patient mortality (↔), hospitalization (↔), emergency department visits (↔), QOL (↑)
Assessment and Treatment Planning
Logiudice, 1999^329^ Fair | 50 | AU | 54 | Wkly | 17.0 | 12 | ↔ | NR | ↔ | Caregiver distress (↔); patient mortality (↔)
Peer Support Only
Charlesworth, 2008^322^ Fair | 236 | UK | 67 | 20 h/wk | NR | 24 | NR | ↔ | ↔ | Caregiver anxiety (↔),QOL (↔); patient mortality (↔)
REACH-Palo Alto, 2003 (IG2)325 Fair | 257 | US | NR | 4 h/d | 13.7 | 6 | ↔ | ↔ | NR
Pillemer, 2002^323^ Fair | 147 | US | 40 | NR | NR | 6 | NR | ↔ | NR
Winter, 2006^324^ Fair | 103 | US | 40.8 | NR | NR | 6 | ↔ | ↔ | NR
Physical Activity Counseling
Connell, 2009^326^ Fair | 157 | US | 100 | NR | NR | 12 | ↔ | ↔ | NR | Caregiver stress (↑)
Hirano, 2011^327^ Fair | 36 | JP | NR | NR | 18.3 | 3 | ↔ | ↔ | NR | Patient behavior (↔)
King, 2002^328^ Fair | 100 | US | 53 | 10 h/wk | NR | 12 | ↔ | ↔ | NR | Caregiver stress (↔), anxiety (↔); patient behavior (↔)

* Mean CDR, 1.1.

† Dementia severity score, 6.

↑ Statistically significantly favored the intervention.

↔ No statistically significant difference between the intervention and control groups.

Abbreviations: ACT = Advancing Caregiver Training; ADL = activities of daily living; AT = Austria; AU = Australia; BE = Belgium; CA = Canada; CDR = clinical dementia rating; CH = Switzerland; COPE = Care of Persons with Dementia in their Environments; DE = Germany; DK = Denmark; ES = Spain; FI = Finland; FR = France; HK = Hong Kong; IADL = instrumental activities of daily living; IG = intergenerational; JP = Japan; MMSE = Mini-Mental State Examination; NL = The Netherlands; NO = Norway; NR = not reported; QOL = quality of life; REACH = Resources for Enhancing Alzheimer's Caregiver Health; TW = Taiwan; UK = United Kingdom; USPSTF = U.S. Preventive Services Task Force.

Table 15 Summary Table: Effectiveness and Harms of Other Nonpharmacologic Interventions (Key Questions 4 and 5)

Author, Year USPSTF Quality Rating | n Randomized | Location | Mean Age (y) | % Female | Mean MMSE Score | Months to Followup | Cognitive Function Outcome | Physical/Global Function Outcome | HRQL Outcome | Institutionalization Outcome | Other Outcomes
Cognitive Stimulation
Chapman, 2004^391^ Fair | 54 | US | 76.4 | 54 | 20.9 | 12 | ↔ | ↔ | ↔ | ↔ | Neuropsychiatric disturbances ↔ Caregiver burden ↔
Requena, 2004^215^ Requena, 2006^440^ Fair | 86 | ES | 77.0 | 71 | 20.8 | 24 | ↑ | NR | NR | NR | Depression ↔
Cognitive Stimulation and Training
Buschert, 2011^384^ Fair | 24 | DE | 71.2 | 50 | 27.4 | 6 | ↑ | NR | ↔ | NR | Depression ↔
Tsolaki, 2011^386^ Fair | 196 | GR | 67.8 | 72 | 27.9 | 6 | ↑ | ↑ | NR | NR | None
Buschert, 2011^384^ Fair | 15 | DE | 75.9 | 53 | 24.9 | 6 | ↔ | NR | ↔ | NR | Depression ↑
Olazaran, 2004^385^ Fair | 84 | ES | 74.4 | 60 | NR | 12 | ↔ | ↔ | NR | NR | Depression ↑ Neuropsychiatric disturbances ↑
Quayhagen, 1995^466^* Fair | 95 | US | 73.6 | 35 | NR | 6 | ↑ | NR | NR | NR | None
Cognitive Training
Kinsella, 2009^380^ Fair | 54 | AU | 76.8 | 57 | 26.4 | 4 | Memory ↔ | NR | ↔ | NR | None
Rapp, 2002^381^ Fair | 19 | US | 74.3 | 58 | 27.6 | 6 | NR | NR | NR | NR | None
Troyer, 2008^382^ Fair | 54 | CA | 75.4 | 54 | 27.9 | 6 | Memory ↔ | NR | NR | NR | None
Burgener, 2008^387^ Fair | 43 | US | 77.1 | 47 | NR (CDR, 1.2) | 5 | ↔ | NR | NR | NR | Depression ↔
Cahn-Weiner, 2003^388^ Fair | 34 | US | 76.9 | 59 | 24.7 | 3 | Memory ↔ | ↔ | NR | NR | None
Clare, 2010^389^ Fair | 68 | WAL | 77.5 | 59 | 22.9 | 6 | Memory ↔ | NR | ↔ | NR | Depression ↔
Greenaway, 2012^383^ Fair | 40 | US | 73 | 61 | 26.8 | 6 | ↔ | NR | ↔ | NR | Patient depression ↔ Patient anxiety ↔ Caregiver burden ↑ Caregiver HRQL ↔ Caregiver depression ↑ Caregiver anxiety ↔
Schwenk, 2010^390^ Fair | 61 | DE | 81.5 | 64 | 21.4 | 3 | Other ↔ | NR | NR | NR | None
Other
Kurz, 2012^393^ Fair | 201 | DE | 74 | 44 | 25.1 | 6 | ↔ | ↔ | ↔ | NR | Patient depression ↔ Patient behavior ↔ Caregiver depression ↔ Caregiver burden ↔
Exercise
Baker, 2010^396^ Fair | 33 | US | 69.6 | 52 | 27.4 | 6 | Memory ↔ | NR | NR | NR | None
Lam, 2011^394^ Fair | 389 | HK | 77.8 | 76 | 24.5 | 5 | ↔ | NR | NR | NR | Depression ↔ Neuropsychiatric disturbances ↔
Lautenschlager, 2008 (FAB)213 Fair | 170 | AU | 68.7 | 51 | NR | 18 | ↑ | NR | ↔ | NR | Depression ↔ Total AE ↔
Nagamatsu, 2012^397^ Fair- | 86 | CA | 74.9 | 100 | 26.8 | 6 | Memory ↔ | NR | NR | NR | Total AE ↔
Steinberg, 2009^398^ Fair | 27 | US | 75.3 | 70 | 17.7 | 3 | ↔ | NR | ↔ | NR | Depression ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔ Serious AE ↔
Suzuki, 2012^212^ Fair | 50 | JP | 76 | 46 | 26.7 | 12 | ↑ | NR | NR | NR | NR
Teri, 2008^400^ Good | 153 | US | 78.0 | 41 | 16.7 | 18 | NR | ↑ | ↑ | ↔ | Depression ↔
Tsai, 2012^395^ Fair | 55 | US | 79 | 73 | 25.5 | 5 | ↔ | NR | NR | NR | NR
Venturelli, 2010^401^ Fair | 30 | IT | 83.7 | NR | NR | 3 | ↑ | ↑ | NR | NR | Hospitalization ↔ Total AE ↔
Vreugdenhil, 2012^399^ Fair | 40 | AU | 74 | 60 | 22.0 | 4 | ↑ | ↑ | NR | NR | Patient depression ↔ Caregiver burden ↔
Multidisciplinary Assessment
Bellantonio, 2008^402^ Fair | 100 | US | 82.2 | 63 | 14.8 | 9 | NR | NR | NR | ↔ | Hospitalization ↔ ED visits ↔
Meeuwsen, 2012 Good | 175 | NL | 78 | 61 | 22.7 | 12 | NR | ↔ | ↔ | NR | Patient depression ↔ Patient behavior ↔ Caregiver HRQL ↔ Caregiver depression ↑ Caregiver distress ↔ Caregiver anxiety ↑
Nourhashemi, 2010 (PLASA)404 Fair | 1131 | FR | 80.2 | 69 | 19.7 | 24 | NR | ↔ | NR | ↔ | None
Richard, 2009^403^ Fair | 130 | NL | 76.5 | 57 | 22.3 | 24 | ↔ | ↔ | NR | ↔ | Neuropsychiatric disturbances ↔
Wolfs, 2008^406^ Fair | 230 | NL | 77.9 | 64 | 20.2 | 12 | ↔ | ↔ | ↔ | NR | Depression ↔ Neuropsychiatric disturbances ↔
Education Only
Beer, 2011^407^ Beer, 2010^467^ Fair | 351 | AU | 85.3 | 76 | NR (Median for IG, 10; median for CG, 12) | 6 | NR | NR | ↔ | NR | Hospitalization ↔ Neuropsychiatric disturbances ↔ Caregiver burden ↔
Menn, 2012^408^ Fair | 390 | DE | 80 | 68 | 18.7 | 24 | NA | NA | NA | ↔

↑ Statistically significantly favored the intervention.

↔ No statistically significant difference between the intervention and control groups.

Abbreviations: AU = Australia; CA = Canada; CDR = clinical dementia rating; CG = caregiver; DE = Germany; ES = Spain; FAB = Fitness for the Aging Brain; FR = France; GR = Greece; HK = Hong Kong; HRQL = health-related quality of life; IG = intergenerational; IT = Italy; JP = Japan; MMSE = Mini-Mental State Examination; NA= not abstracted because of poor followup (<60%); NL = The Netherlands; NR = not reported; PLASA = Plan de Soin et d'Aide dans la maladie d'Alzheimer; USPSTF = U.S. Preventive Services Task Force; WAL = Wales.

Overall, based on 54 fair- to good-quality trials (n=19,384) that evaluated AChEIs (i.e., donepezil [k=24; n=7,552], galantamine [k=12; n=6,008], rivastigmine [k=12; n=4,829], tacrine [k=6; n=994]) that are FDA-approved for use in people with mild to moderate AD, this class of medications can improve global cognitive function in the short-term. The magnitude of these changes is small, at approximately 1- to 3-points change on the ADAS-cog. The majority of available evidence comes from trials in people with moderate (as opposed to mild) AD and followup was limited to 6 months. The average effect of these changes may not be clinically meaningful using commonly accepted values to interpret the clinical importance of these changes. On average, rivastigmine appears to have greater benefit than donepezil or galantamine on global cognitive function. A meta-analysis of seven rivastigmine trials (n=3,311) showed a statistically significant difference in ADAS-cog scores, in which the upper 95% CI estimate is clinically significant (weighted mean difference [WMD], -3.06 [95% CI, -4.48 to -1.65]; I^2^=92.6%). The statistical heterogeneity of the analyses, however, was very high, reflecting the clinical heterogeneity in populations, medication doses, and study characteristics across trials. Only four trials (n=1,960) were conducted in persons with MCI.208-211 These trials, for donepezil and galantamine, generally showed a small statistically significant benefit of unclear clinical importance on global cognitive function. While measures of global functioning were less commonly reported, they were still reported in the majority of trials (k=34). AChEIs appear to consistently improve measures of global functioning in people with AD in the short-term. One trial conducted in people with MCI showed a benefit for galantamine on global function, as measured by the CIBIC.209 Outcome measures of global physical function were only reported in half the trials and showed mixed results. Therefore, it is unclear if AChEIs can improve physical functioning given the inconsistent and sparsely reported findings. Only six included trials, and seven OLE studies of included trials, examined outcomes beyond 6 months. These studies generally found persistent statistically significant benefits of unknown clinical importance for commonly reported outcomes consistent with 6-month trial outcomes. Two trials evaluating donepezil in people with MCI did not show any differences in conversion to AD at about 3 years.

Overall, side effects from these medications were quite common. Withdrawal or discontinuation was more common with AChEIs than placebo (14% for donepezil and rivastigmine, 17% for galantamine). There does not appear to be a difference in total serious adverse events for these medications across trials with limited duration of followup. Estimates of total serious adverse events, however, may be higher in observational studies than in randomized trials. The definitions of serious adverse events, which likely vary, were rarely described in the included studies. Observational studies suggest that bradycardia and adverse events related to bradycardia (e.g., fall, syncope) are increased due to AChEIs. Tacrine had very high discontinuation rates when compared with other medications in its class. While there was no mention of serious adverse events in the trials evaluating tacrine, it is known that tacrine has an uncommon but serious adverse effect of liver toxicity. Tacrine is no longer used in the United States because of these effects.

The FDA has currently only approved memantine for use in treatment of moderate to severe AD. Our review, on the other hand, was limited to those trials specifically in people with mild to moderate dementia or MCI. Based on 10 fair- to good-quality trials (n=3,015), memantine has a similar benefit as AChEIs on global cognitive functioning in people with moderate dementia, which is approximately 1- to 2-points change on the ADAS-cog at 6 months. Again, this average effect may not be clinically meaningful using commonly accepted values to interpret the clinical importance of these changes. Only one trial had longer-term followup and showed no differences in cognitive functioning between the memantine and placebo groups at 52 weeks. The impact of memantine on global functioning, as measured by the CIBIC, or global physical functioning are inconsistent. Currently, only one trial was conducted in people with MCI. Unfortunately, this trial did not report outcome measures of global cognitive or physical function. From trial data, memantine appears to be better tolerated than AChEIs, with no difference in percentages of withdrawal of medication due to adverse effects or serious adverse effects compared with placebo.

Twenty-six fair- to good-quality trials (n=5,325) evaluated other medications or supplements, including low-dose aspirin, HMG-CoA reductase inhibitors (simvastatin and atorvastatin), NSAIDs (ibuprofen, naproxen, indomethacin, and celecoxib), gonadal steroids (estrogen plus or minus progesterone and testosterone), and dietary supplements (multivitamins, B vitamins, vitamin E plus or minus vitamin C, and omega-3 fatty acids). We did not find that any of these medications or supplements had any benefit on global cognitive or physical function in people with mild to moderate dementia or MCI.

We identified 59 fair- to good-quality trials evaluating the effect of multiple different types of interventions primarily aimed at the caregiver or the patient-caregiver dyad. Among these trials, 52 trials (n=8,932) evaluated complex caregiver interventions that included a psychoeducational component. Although there were substantial clinical differences among the interventions evaluated and significant statistical heterogeneity among these trials, as a whole there was a generally consistent finding of small benefit on caregiver burden and depression outcomes in people caring for patients with moderate dementia. Pooled analyses of 24 trials (n=2,679) showed a small but statistically significant effect (SMD, -0.23 [95% CI, -0.35 to -0.12]; I^2^=52.7%) on caregiver burden. Most studies reported between 0- and 5-point group differences on the 88-item Zarit Caregiver Burden Interview (CBI) or about 1- to 3-point differences on the 96-point Revised Memory and Behavioral Problems Checklist (RMBPC) caregiver bother subscale. Likewise, pooled analyses of 30 trials (n=3,537) showed a small but statistically significant effect (SMD, -0.21 [95% CI, -0.30 to -0.13]; I^2^=34.1%) on caregiver depression. Most trials reported an approximate 2- to 5-point difference between groups on the 60-point Center for Epidemiologic Studies Depression Scale (CES-D). The clinical meaning of these changes in both caregiver burden and depression is unknown, but on average is likely small at best. However, effect estimates were frequently fairly wide, suggesting that there may be some subpopulations that experience clinically important benefits. The trials that were not included in pooled analyses due to missing data generally showed results consistent with meta-analyses. Our ability to interpret the clinical importance and consistency of findings for other self-reported caregiver outcomes (e.g., global stress or distress, anxiety, HRQL, self-reported health status) and institutionalization was limited by sparse reporting of these outcomes. None of the included trials reported harms. We did not identify any additional studies that explicitly evaluated harms of caregiver interventions.

Although findings were somewhat inconsistent across 15 cognitive intervention trials (n=1,128), cognitive stimulation plus or minus cognitive training (k=6; n=513) appears to improve global cognitive function in the short-term for both people with MCI or dementia. However, the limited number of trials, clinical and statistical heterogeneity combined, and very wide CIs (ranging from clinically not meaningful to a large effect) limit our ability to determine the magnitude and certainty of this benefit. Other important outcomes (e.g., physical function, HRQL, symptoms) were sparsely reported. None of the included trials reported harms. We did not identify any additional studies that explicitly evaluated harms of cognitive interventions.

Based on 10 mostly fair-quality trials (n=1,033), exercise interventions did not have a consistent benefit on global cognitive outcomes and had no benefit on patient depression outcomes. Other self-reported outcomes (e.g., physical function, HRQL) and institutionalization were not commonly reported. Two trials of a multicomponent, self-guided exercise intervention (n=220) in people with MCI found a very small benefit on global cognitive function (approximately 1 point on the MMSE or ADAS-cog) at 12 to 18 months,212,213 but the clinical importance of this small change may not be meaningful. Although there is evidence of a benefit in a few of the better-conducted trials, we were unable to determine if there is a clinically important benefit for exercise interventions on reported outcomes due to the limited number of trials and clinical heterogeneity of the populations, exercise interventions, and reported outcomes. We found no evidence of increased total or serious adverse effects due to exercise interventions in trial participants.

Five trials (n=1,766) evaluating very different multidisciplinary care interventions found no benefit in cognitive or physical function, HRQL, or institutionalization.

## Key Question 4 Do Pharmacological or Nonpharmacologic Interventions for Early Dementia or MCI in Older Adults Improve Decisionmaking, Patient, Family/Caregiver, or Societal Outcomes?

## Key Question 5 What Are the Harms of Pharmacological or Nonpharmacologic Interventions for Cognitive Impairment?

### Pharmacological Interventions

#### AChEIs

(Table 11, Figures 8 and 9)

Figure 8 Meta-Analyses for AChEIs and Memantine on Global Cognitive Function, Measured by the ADAS-Cog (Key Question 4)

^*^ Included in Raina.

Figure 8 displays a forest plot of AChEI and memantine studies reporting the difference in mean change for the intervention group versus the control group for global cognitive function measured by the ADAS-cog. This figure is described under KQ4 of the review.

Figure 9 Meta-Analyses for AChEIs and Memantine on Global Cognitive Function, Measured by the MMSE (Key Question 4)

^*^ Included in Raina.

Figure 9 displays a forest plot of AChEI and memantine studies reporting the difference in mean change for the intervention group versus the control group for global cognitive function measured by the MMSE. This figure is described further under KQ4 of the review.

We identified one good-quality comprehensive systematic review110 published in 2008 and 14 unique fair- to good-quality RCTs published after this review that evaluated AChEIs (k=10; n=19,384)110,208,214-221 and memantine (k=6; n=3,462)110,222-226 for the treatment of MCI or dementia. The systematic review included 55 trials that compared an AChEI with placebo, 50 of which are included in our review. We excluded five studies that did not meet our inclusion criteria: two because they were conducted in people with severe AD,227,228 two because they were conducted in people with PDD,229,230 and one because it was conducted in people with Down syndrome.231 In total, we included 64 trials: 24 of donepezil, 12 of galantamine, 12 of rivastigmine, six of tacrine, and 10 of memantine. While most trials were conducted in people with mild to moderate AD, six trials were conducted in people with VaD, five in people with MCI, two in people with DLB, and one in people with AD and “primary degenerative dementia.”

The systematic review found that using AChEIs and memantine to treat dementia can result in statistically significant but clinically marginal differences in cognition and global functioning.110 Likewise, the trials published since the systematic review generally found similar results of statistically significant, but not necessarily clinically meaningful, differences in cognitive function between treatment and placebo groups. We found no evidence for publication bias or small study effects. Similarly, these trials generated mixed results for global and physical function outcomes. These studies were limited by their relatively short duration of followup, relatively sparse reporting of outcomes other than cognitive outcomes (including limited evaluation of global outcome measures and physical functioning), risk of bias (e.g., industry funding, unreported details of randomization, poor reporting of followup and possible attrition bias, and inadequate handling of missing data), and inclusion of mostly white populations. A brief summary of study characteristics and reported outcomes is shown in Table 11. More detailed study characteristics and outcomes can be found in Appendix E Tables 1 and 2 and Appendix F Tables 1–3.

#### Donepezil

We found one good-quality comprehensive systematic review that included 21 trials meeting our inclusion criteria (n=6,506)110 and three fair-quality trials published since the previous review (n=1,046)208,214,215 that evaluated donepezil versus placebo. Most of the studies we identified addressed AD, but three trials included participants with MCI (n=1,881),208,210,211 two trials included participants with VaD (n=1,219),232,233 and one trial included participants with DLB (n=140).214 Mean baseline MMSE scores for participants in these trials ranged from 11.8 to 27.5. The daily dosage of donepezil ranged from 1 to 10 mg, with most studies evaluating daily doses of 10 mg. These trials followed participants for 3 to 36 months. The mean age of participants ranged from 67 to 86 years. Thirty-five to 82 percent of participants were female, while 87 to 99 percent of participants were white.

All trials included in this systematic review110 (k=21; n=6,506) and three trials published since this review208,214,215 (n=1,047) reported measures of cognitive function. The majority of these used the ADAS-cog or the MMSE to measure cognitive function. Overall, differences in cognitive function with donepezil were statistically significant in participants with AD or VaD.110,208 Differences from placebo in ADAS-cog scores ranged from 0.87 to 2.8 points over 3 to 36 months, less than the generally accepted clinically important change threshold of 4 points, with the vast majority of studies following patients for less than 6 months.211,230,232-247 Only six studies included followup periods longer than 6 months,208,210,215,223,248,249 and most of these had study periods of between 11 and 12 months.208,223,248,249 Trials in people with MCI (k=3; n=1,881) found small statistically significant differences in cognitive outcomes for those taking donepezil that fell below clinically meaningful thresholds.208,210,211 Figure 8 shows summary estimates of the effect sizes for the ADAS-cog for participants with AD, MCI, and VaD. The meta-analysis of the 12 trials (n=4,636) that could be pooled showed a consistent and statistically significant difference in cognitive scores favoring donepezil (WMD, -2.03 [95% CI, -2.68 to -1.38]; I^2^=67.6%) (Figure 8). The 15 trials (n=4,285) that reported MMSE outcomes that could be pooled also showed statistically significant, but not clinically meaningful, differences in change from baseline (WMD, 1.03 [95% CI, 0.70 to 1.36]; I^2^=62.8%) (Figure 9). Statistical heterogeneity for both analyses was high, which likely reflects the clinical heterogeneity in age, length of followup, dementia diagnoses, and baseline MMSE scores between trials. Due to the limited reporting in the systematic review, we were unable to determine if results were similar from trials that could not be pooled.235,238,239,246,248 In general, we found no evidence for publication bias or bias of small study effects.

Trials reported global function less frequently than cognitive function. Only 13 of 21 studies in the previous systematic review210,211,232-234,236,240-245,249 and two of the three trials subsequent to the previous systematic review208,214 reported global function outcomes. However, trials used different instruments to measure global functioning. Based on the results of trials that used similar measures of global functioning, there were significant differences in global function using the CIBIC-plus favoring donepezil in those with AD (k=4; n=2,049; WMD, -0.5 [95% CI, -0.5 to -0.4]), and using the Clinical Dementia Rating Sum of Boxes (CDR-SB) in those with VaD or MCI (k=2; n=1,219; WMD, -0.39 [95% CI, -0.64 to -0.15]).

Physical function outcomes were reported only in 11 of the 21 studies of donepezil included in the previous systematic review232-234,236,241,245,248-252 and in none of the studies published since the systematic review. These trials largely used ADLs to measure physical function. Only two studies in the systematic review used the same outcome to allow for computation of a summary estimate.232,233 These two studies demonstrated borderline statistical significance (p=0.053) for VaD favoring donepezil. The clinical impact of donepezil on physical functioning is unclear given borderline statistical significance and sparse reporting of this outcome.

#### Galantamine

There was one good-quality comprehensive systematic review that included 10 trials110 (n=3,997) and two additional fair-quality trials216,217 (n=916) that evaluated galantamine (Table 11). Participants in eight of these 12 trials had AD, in two trials had VaD and AD, in one trial had VaD, and in one trial had MCI. Most studies aimed for a treatment dose of 24 mg per day. Participants were followed for a much shorter duration than in many of the donepezil trials (only 1 to 6 months). Mean MMSE scores ranged from 17.8 to 20.5, and the average age of participants ranged from 71 to 77 years. Zero to 64 percent of the participants were women, and 92 to 100 percent of participants were white.

All 12 studies reported on cognitive outcomes. Ten of these studies showed a statistically significant difference in scores favoring galantamine, but similar to donepezil, these differences are of unclear clinical importance, as changes in ADAS-cog scores ranged from 1.4 to 2.5 points. Two remaining trials had inconsistent findings. One trial in patients with AD253 reported mixed effects, with improvement in the ADAS-cog in patients taking 24 mg per day but not 32 mg per day. Another trial of 3-day and 7-day washout periods when switching from donepezil to galantamine in patients with AD found no difference between groups.254 A meta-analysis of nine trials (n=5,553) showed a consistent and statistically significant difference in ADAS-cog scores favoring galantamine (WMD, -2.25 [95% CI, -2.94 to -1.55]; I^2^=68.4%) (Figure 8). Statistical heterogeneity was very high, likely reflecting differences in dementia diagnoses, medication doses, and duration of followup. We found no evidence for publication bias or bias due to small study effects.

Six trials included in the previous systematic review252,255-259 and one subsequent trial217 reported global function outcomes using the CIBIC-plus (n=4,346). These trials consistently showed that galantamine was associated with statistically significant better global function outcomes compared with placebo, including its use in participants with AD, VaD, and MCI. The pooled effect in the four trials from the previous review252,255,257,259 showed a statistically significant benefit favoring galantamine using the CIBIC-plus (relative risk, 1.22 [95% CI, 1.1 to 1.3]). The remaining two trials that could not be pooled also found a statistically significant benefit for galantamine using the CIBIC-plus. One trial found that 21 percent of patients taking galantamine, compared with 37 percent taking placebo, had deterioration in global functioning at 3 months (p<0.001),258 and the other trial found a standardized response mean in CIBIC-plus scores at 4 months of -0.36 between groups favoring galantamine (p=0.03).217

Physical function outcomes were reported for galantamine in six studies (n=3,906) using the Disability Assessment for Dementia (DAD)217,252,258,259 and the Alzheimer's Disease Cooperative Study subscale for ADLs (ADCS-ADL).216,255,259 Pooled estimates for studies from the systematic review found better ADL functioning in people with AD, VaD, or MCI taking galantamine than in those taking placebo (WMD for DAD, 4.2 [95% CI, 2.2 to 6.2]; I^2^ not reported;252,258,259 WMD for ADCS-ADL, 1.84 [95% CI, 0.7 to 3.0]; I^2^ not reported).255,259 The two trials of galantamine that were published after the systematic review216,258 found no difference in physical function outcomes between groups. It is unclear if galantamine has clinically important benefit on physical functioning given the inconsistent reporting and findings of physical function outcomes.

#### Rivastigmine

We included eight trials (n=2,206) from a good-quality comprehensive systematic review110 and four fair-quality trials published since the systematic review (n=2,623),218-221 for a total of 12 trials comparing rivastigmine with placebo (n=4,829) (Table 11). Nine trials involved patients with AD (n=3,476), two involved patients with VaD (n=750), and one included patients with DLB (n=120). Mean baseline MMSE scores ranged from 11.4 to 20.4, and mean ages ranged from 69 to 84 years. Women comprised 38 to 80 percent of the sample, while 0 to 95 percent of participants were white. Participants took a mean dose of rivastigmine ranging from 1 to 17.4 mg per day, with a wide range of doses represented. These studies followed participants for 3 to 12 months on average, a followup period that was longer than that for galantamine, but shorter than that for donepezil.

Eleven studies reported cognitive outcomes (n=4,802). All seven studies that used the ADAS-cog218,219,221,260-263 found a statistically significant difference in cognitive function between groups. This difference favored rivastigmine, but did not meet the clinically meaningful threshold of a 4-point mean change, which is similar to results for donepezil and galantamine. The meta-analysis of the seven trials that could be pooled (n=3,311) showed a fairly consistent and statistically significant difference in ADAS-cog scores. The upper 95% CI estimate was also clinically significant (WMD, -3.06 [95% CI, -4.48 to -1.65]; I^2^=92.6%) (Figure 8). The pooled effect among seven trials (n=2,854) reporting MMSE scores at followup was not statistically significant (WMD, 0.61 [95% CI, -0.10 to 1.32]; I^2^=90.9%) (Figure 9). Statistical heterogeneity was again very high, which reflects the clinical heterogeneity in dementia diagnoses, mean MMSE scores, mean doses, age, sex, race, and length of followup.

Nine of the 12 included trials reported global function. Five trials (n=3,624) included in the systematic review (WMD, -0.36 [95% CI, -0.45 to 0.27])260-264 and the one subsequent trial219 (n=678) that used the CIBIC-plus to rate global function (mean difference in CIBIC-plus scores, -0.4; p<0.05) found statistically significant differences that favored rivastigmine. For the two trials (n=710) that used the Alzheimer's Disease Cooperative Study-Clinical Global Impression of Change (ADCS-CGIC) to rate global functioning, one trial of patients with VaD found no statistically significant difference between groups.218 In contrast, a trial of patients with AD found a statistically significant benefit in people randomized to a 9.5 mg per 24 hour rivastigmine patch (mean difference, -0.3; p=0.01) and 12 mg per day rivastigmine capsules (mean difference, -0.3; p=0.009), but not for those patients in a higher dose arm (17.4 mg/24 hour patch).221

Only three rivastigmine trials (n=1,468) included in the systematic review260,262,263 assessed physical function and did not find a statistically significant positive impact with rivastigmine on this outcome. These trials assessed outcomes in patients with AD via the Progressive Deterioration Scale. All four trials published subsequent to the systematic review assessed physical outcomes (n=2,623).218-221 Studies that included patients with AD found significant differences in physical outcomes at 6 months (n=1,873),219,221 while those that enrolled patients with VaD did not find a statistically significant difference (n=750).218,220 It is unclear if rivastigmine has clinically important benefits on physical functioning given the sparse reporting of these outcomes and inconsistent findings.

#### Tacrine

Tacrine is an older AChEI that is no longer used in the United States. Only six trials (n=994)265-270 comparing tacrine with placebo were published between 1991 and 2002. These trials were all included in the previous systematic review. Participants in these trials had AD and mean MMSE scores ranging from 16.2 to 18.5, with daily dosages of tacrine from 80 to 150 mg. Followup ranged from 3 to 9 months. Many of the tacrine trials did not report location or race/ethnicity.

None of the tacrine studies showed clinically meaningful improvement in cognitive function outcomes. The meta-analysis of the two trials (n=763) that could be pooled showed nonstatistically significant differences in MMSE scores between groups (WMD, 0.86 [95% CI, -0.05 to 1.77]; I^2^=0.0) (Figure 9). Two (n=817)265,270 of the three trials that evaluated global function (n=917)265,269,270 found statistically significant improvement in this domain. None of the studies evaluated physical function outcomes, as reported by the systematic review.

#### Memantine

One good-quality systematic review110 of five trials (n=1,959)271-275 and five subsequent trials of fair- to good-quality224-226 (n=1,506) evaluated memantine versus placebo (Table 11). Participants in these trials were diagnosed with AD (k=7; n=2,505), VaD (k=2; n=900), or MCI (k=1; n=60), and mean baseline MMSE scores ranged from 7.9 to 28.8. Memantine doses ranged from 5 to 20 mg per day, with most studies evaluating 20 mg per day. These studies followed participants for a relatively short period of time (3 to 12 months). The mean age of participants ranged from 67 to 78 years. About half of the participants were women and almost all of the participants were white.

Of the six studies of memantine in patients with AD, four reported no difference in cognitive outcomes (n=1,433),223,224,226,273 while the remaining two reported differences in favor of memantine that were statistically significant but likely not clinically meaningful (n=807).272,274 The two trials conducted in patients with VaD271,275 (n=900) found differences between groups on the ADAS-cog that were statistically, but likely not clinically, significant (WMD, -2.21 [95% CI, -3.3 to -1.2]; I^2^=31.5%). The study involving participants with MCI did not report cognitive outcomes.225 A meta-analysis of five trials (n=2,124) showed a consistent and statistically significant difference in ADAS-cog scores favoring memantine that did not reach clinical importance (WMD, -1.36 [95% CI, -2.02 to -0.70]; I^2^=31.5%). Pooled results for the MMSE in the five trials (n=1,863) that could be pooled similarly showed a small but statistically significant effect (WMD, 0.45 [95% CI, 0.023 to 0.89]; I^2^=36.7%) (Figure 9) that is likely not clinically meaningful. Statistical heterogeneity in these trials was lower than that observed in similar analyses for AChEIs, which likely reflects the smaller variation in patient populations and treatments between trials.

The three trials in the previous review that evaluated memantine in patients with AD (n=1,050)272-274 found a significant difference in global outcomes as measured by the CIBIC-plus between memantine and placebo groups (WMD, -0.3 [95% CI, -0.4 to -0.1]; I^2^=0%). However, global outcomes were not significantly different between groups at 6 months in the two trials224,226 (n=830) that included participants with AD that were published after this review. Two trials in people with VaD (n=900) from the previous review found no benefit of memantine on global function outcomes. One trial in patients with MCI (n=60) published since the previous review did not report this outcome.

Results were mixed for the five trials224,226,272-274 (n=1,962) that reported on physical function outcomes. All five of these studies used the ADCS-ADL to measure physical function. Three trials conducted in people with AD (n=1,059)272-274 found that participants who received memantine had better physical function outcomes than those taking placebo (WMD, 1.4 [95% CI, 0.4 to 2.4]; I^2^=5.1%). However, two other trials conducted in people with AD found no statistically significant difference in physical function between groups (n=903).224,226 Two trials conducted in patients with VaD also found no difference in physical function outcomes (n=900).271,275 The trial of patients with MCI did not report this outcome.225

#### Evidence of Longer-Term Effects

The vast majority of AChEI and memantine trials lasted 6 months or less. Only seven RCTs210,248,249,208,223,262,276 and eight OLE studies277-285 examined outcomes longer than 28 weeks.

Donepezil. There were five RCTs208 and four OLEs277-279 that examined longer-term outcomes in donepezil. For cognitive outcomes, one RCT249 and one OLE noted statistically significant differences in patients with AD at 52 weeks (n=286)249 and 54 weeks (30 weeks after the 24-week trial) (n=885);279 however, the differences were not large enough to conclude that they were clinically meaningful. Another OLE of patients with AD showed no differences in cognitive outcomes at 132 weeks (n=579).278 In participants with MCI, differences in cognitive outcomes were statistically significant in favor of donepezil but not thought to be clinically meaningful in a 48-week RCT (n=821)208 and a 76-week (28 weeks after the 48-week trial) OLE (n=145).277 Two RCTs examined conversion from MCI to AD in patients randomized to donepezil, vitamin E, or placebo: one RCT of 769 patients with amnestic MCI found decreased conversion to AD in the donepezil group in the first 12 months but no difference at 3 years,210 while the other RCT of 756 patients found donepezil delayed conversion to AD at 1.7 and 2.2 years but not at 2.7 years, and not in patients without depression.276 Participants with AD treated with donepezil had better global function at 52 weeks in an RCT of 286 patients.249 Results were not statistically significant in participants with AD in a 54-week OLE (n=885)279 or in those with MCI in a 48-week RCT (n=821)208 or a 76-week OLE (n=145).277 Regarding physical function in patients with AD, one RCT found donepezil delayed clinically evident functional decline by 5 months at 54 weeks (n=431),248 another RCT found donepezil delayed decline in ADLs at 52 weeks,249 and a third RCT found donepezil led to less caregiver time at 52 weeks (but not at earlier timepoints).285

Galantamine. There were three OLEs of 6-month trials of galantamine ranging from 52 to 130 weeks, with sample sizes ranging from 326 to 459.^282-284^ All found differences in cognitive outcomes in participants with AD and VaD that were statistically significant but likely not clinically meaningful. One OLE found significant differences in physical functioning at 52 weeks in favor of galantamine (n=459).282

Rivastigmine. There was one OLE of an included rivastigmine study beyond 25 weeks; however, no cognitive outcomes were reported.280 There was only one longer-term study of rivastigmine, a 52-week RCT of 44 participants with AD, which showed statistically significant differences in cognitive outcomes in which the upper CIs reached levels of clinical importance (ADAS-cog score with rivastigmine, 0.8+0.7; ADAS-cog score with placebo, -4.5+0.8; p<0.001).262 Differences in global and physical functioning were statistically significant in favor of rivastigmine at 52 weeks.262

Memantine. There were two longer-term studies of memantine: one RCT of 278 patients with AD that did not show any differences in cognitive function at 52 weeks,223 and one 52-week OLE that did not report on cognitive, global, or physical function outcomes.281

#### Adverse Effects of AChEIs and Memantine

(Table 12, Figures 10 and 11)

Figure 10 Meta-Analyses for AChEIs and Memantine on Withdrawals Due to Adverse Events (Key Question 5)

Figure 10 displays a forest plot of AChEI and memantine studies reporting the relative risk for the intervention group versus the control group for withdrawals due to adverse events. This figure is described further under KQ5 of the review.

Figure 11 Meta-Analyses for AChEIs and Memantine on Serious Adverse Events (Key Question 5)

^*^ Included in Raina.

Figure 11 displays a forest plot of AChEI and memantine studies reporting the relative risk for the intervention group versus the control group for serious adverse events. This figure is described further under KQ5 of the review.

The good-quality systematic review conducted by Raina and colleagues included harms reported in medication trials and their OLE studies.110 We included trials and their associated OLE studies published after those included in the systematic review, as well as several observational studies that focus solely on harms of these medications. We included 50 trials from the systematic review and 16 trials, including two open-label trials, were identified since this systematic review. Harms were reported in 57 of these 66 trials. We also included six studies that were OLEs (published since the systematic review) of included trials that also reported harms. There were an additional 13 observational studies that also addressed harms.

In general, most trials were conducted in North America or western Europe. Participants in these trials had mean ages ranging from 54 to 86 years and had a good representation of both men and women (Table 12). The mean baseline MMSE score ranged from 11 to 28. With the exception of trials conducted in people with MCI, the average MMSE score was generally consistent with participants having moderate (as opposed to mild) dementia. Duration of followup in trials was generally short, usually less than 12 months, although it ranged from 3 to 36 months. The populations in observational studies were also from North America or western Europe, with mean ages ranging from 73 to 83 years. In general, baseline MMSE scores, along with other baseline patient characteristics, were not reported. Observational studies generally included any patient receiving the medication (e.g., as noted through a pharmacovigilance database or health system, such as the VA). The majority of these patients likely had mild to moderate dementia, except for those taking memantine. Doses of medications used in trials in observational studies were representative of dosing used in actual practice.

Most studies reported a combination of adverse outcomes that included withdrawals from trial or discontinuation of medication due to harms/tolerability, serious or severe harms, and specific types of harms/side effects (e.g., nausea, weakness/malaise, bradycardia). We focus on total adverse events (when reported), withdrawal/discontinuation due to adverse events, and serious adverse events. The Discussion section details the types of adverse events and side effects from medications.

Overall, side effects or harms are quite common with these drugs. Withdrawal or discontinuation is more common with AChEIs than placebo (Figure 10). Discontinuation ranged from 14 percent (donepezil and rivastigmine) to 44 percent (tacrine). Memantine appears to be better tolerated, with no difference in percentages of withdrawal of medication compared with placebo (Figure 10). Across trials, there does not appear to be a difference in total serious adverse events for donepezil, galantamine, rivastigmine, or memantine (Figure 11). One large observation study had higher estimates of serious adverse events compared with estimates from trials. Definitions for serious adverse events varied across studies and were often not specified. Followup for most trials was generally 1 year or less. Nearly all trials were industry funded. Case-control studies suggest that bradycardia is increased due to AChEIs, as are adverse events related to bradycardia (e.g., fall, syncope).

Donepezil. The good-quality systematic review included 21 trials of donepezil (n=6,506) conducted in patients with mild to moderate dementia (k=19) or MCI (k=2).110 The systematic review did not report proportion of total adverse events in the trials. Seventeen of the 21 trials included in the review reported withdrawal due to adverse effects. Four of the five new fair-quality trials (n=2,109) also reported withdrawal due to adverse effects.208,214,286,287 Three of these trials, however, had only 3 months of followup.214,286,287 Overall, there was an increased risk for withdrawal due to medication adverse events (RR, 1.82 [95% CI, 1.52 to 2.18]) (Figure 10). In the intervention arm, 14.5 percent had adverse events resulting in discontinuation of the medication versus 7.7 percent in the placebo group. Serious adverse events were less commonly reported (15 of 25 trials). We did not identify a difference in serious adverse events (10.8% in drug group and 10.4% in placebo group) (Figure 11).

We also included five fair- to good-quality observational studies to evaluate harms of donepezil (n=90,267). Two of these studies reported the relative frequency of adverse effects using medication surveillance systems of voluntary reporting of adverse effects. These studies found that gastrointestinal symptoms (i.e., nausea/vomiting, diarrhea) were the most common adverse events and that bradycardia, weakness, and convulsions were the most common serious adverse events.288,289 Two well-conducted case-control studies found that bradycardia and bradycardia-related hospital admissions were more common in people taking donepezil.290,291

Galantamine. We included one good-quality systematic review of 10 trials of galantamine (n=5,090) conducted in patients with mild to moderate dementia (k=9) or MCI (k=1).110 We also included two additional trials (n=918) that were published after the review. Ten of these 12 trials reported withdrawal due to medication of about 17 versus 7 percent in the placebo group (RR, 2.50 [95% CI, 1.78 to 3.50]) (Figure 10). Eight of the 10 trials reported serious adverse events. These trials identified no significant difference in proportions of serious adverse events (11% in the drug groups and 10% in the placebo groups) (Figure 11). Only one observational study (n=324) specifically addressed harms of galantamine.290 This good-quality case-control study found no statistically significant increase in risk of bradycardia in those taking galantamine.

Rivastigmine. We included one good-quality systematic review of eight trials of rivastigmine (n=2,206) in patients with mild to moderate dementia.110 We also included four trials (n=2,623) that were published after this systemic review. Ten of these 12 trials reported withdrawal due to medication. These withdrawal rates were about 14 percent in the intervention group versus 6 percent in the placebo group (RR, 2.35 [95% CI, 1.71 to 3.21]) (Figure 10). Serious adverse events were less commonly reported (six of 12 trials), and we found no significant difference in proportions of serious adverse events between study arms (13% in the drug groups and 12% in the placebo groups) (Figure 11). Only one observational study (n=324)290 specifically addressed harms of rivastigmine. This good-quality study found an increase in risk of bradycardia in those taking rivastigmine.

Tacrine. We included only one good-quality systematic review of six trials of tacrine (n=994) from the 1990s.110 Four of the six trials included in this review reported withdrawal due to medication (44% in the tacrine groups vs. 11% in the placebo groups). None of these trials reported on serious adverse events. Tacrine has an uncommon but serious side effect of liver toxicity, and as a result is no longer used in the United States.

Memantine. We included one good-quality systematic review of five trials of memantine (n=1,959) in patients with mild to moderate dementia.110 We also included five fair- to good-quality trials (n=1,506) published after the systematic review. One of these trials was conducted in people with MCI.225 Nine of the 10 trials reported withdrawal due to the medication, while another eight trials reported serious adverse events. Overall, we found no significant differences in proportions of withdrawal (about 9% in each group) or serious adverse events (about 12% in each group) (Figures 10 and 11). All of these trials, however, had less than 1 year of followup. One study reported safety data from two open-label multicenter studies (n=4,305), which showed similar rates of adverse events as trials and that adverse events were more common with increasing age, and that people with less severe disease were more likely to discontinue treatment.292 Two fair-quality observational studies (n=5,378) showed that the discontinuation rate of memantine (up to 20 months) was about 40 percent. Bradycardia, weakness, and convulsions were the most commonly reported adverse events.288,293

Any AChEI and/or Memantine. We also included eight fair- to good-quality observational studies that examined the harms of any medication (i.e., did not separate harms by specific drug). From these studies, it appears that the proportions of people with serious adverse effects may be higher than that observed in trials, at about 18 percent.294,295 Central nervous system disorders were the most commonly serious adverse events, followed by heart rate/rhythm disorders and gastrointestinal disorders.296 In people with chronic obstructive pulmonary disease and dementia, there was no increased risk of adverse pulmonary events in those receiving AChEIs versus nonusers.297 Well-conducted case-control studies show that people taking AChEIs are at increased risk for bradycardia and bradycardia-related events such as falls, syncope, and pacemaker insertion.290,298 One large comparative study (n=46,737 Medicare beneficiaries) showed that the cardiovascular safety profiles of AChEIs and memantine did not differ substantially in the Medicare population.299

### Other Medications

(Table 13, Figure 12)

Figure 12 Meta-Analyses for Other Medications on Global Cognitive Function, Measured by the ADAS-Cog or MMSE^*^ * MMSE direction has been reversed. (Key Question 4)

Figure 12 displays a forest plot of other medication studies reporting Hedge's g for the intervention group versus the control group for global cognitive function measured by the ADAS-cog or MMSE. This figure is described further under KQ4 of the review.

We identified 26 trials (n=5,325) that evaluated 1) medications primarily aimed at cardiovascular risk reduction to treat VaD, including antiplatelet medications (k=2; n=459) and HMG-CoA reductase inhibitors (k=4; n=1,153); 2) NSAIDs (k=4; n=959); 3) gonadal steroids (estrogen plus or minus progesterone [k=4; n=277] and testosterone [k=1; n=18]); and 4) dietary supplements (i.e., multivitamins [k=1; n=89], B vitamins [k=7; n=1294], vitamin E plus or minus vitamin C [k=3; n=522], and omega-3 fatty acids [k=4; n=1,145]) (Table 13). We did not include trials evaluating herbal supplements. Twenty-one of 26 trials were conducted exclusively in people with mild to moderate dementia. One trial that evaluated aspirin and supplements in a factorial design was conducted in a mixed population (one third of which had MCI),300 and four supplement trials were conducted exclusively in people with MCI.301-304 All but one302 of the included trials reported global outcome measures of cognitive function. While most of these trials also included some outcome measure of physical function or neuropsychiatric disturbances (including depression), other outcomes of HRQL and caregiver burden were not consistently reported. In general, trials did not find a benefit in reported outcomes across the different interventions in different populations. Limitations in the primary evidence do not allow for any meaningful analyses of outcome findings by important subgroups, such as by age, sex, race/ethnicity, type of dementia, or level of cognitive impairment. Table 13 provides a brief summary of study characteristics and reported outcomes and Appendix F Table 4 provides more detailed study characteristics and outcomes.

#### Aspirin and HMG-CoA Reductase Inhibitors

Six fair-quality trials evaluated low-dose aspirin (acetylsalicylic acid [ASA] 75 or 81 mg) or HMG-CoA reductase inhibitors (simvastatin 40 or 80 mg, atorvastatin 80 mg). We found no trials evaluating other medications aimed at cardiovascular risk reduction (e.g., antihypertension medications) that met our inclusion criteria. Although these medications are primarily aimed at mitigating vascular risk, the trials were conducted in people with AD (although some patients had comorbid VaD). The average age of patients in the trials ranged from 68 to 79 years. The trials included both men and women and were conducted in primarily white populations in the United States, United Kingdom, and Germany. All the trials were conducted in people with known dementia (mean baseline MMSE score, 17.5 to 21.9), except for one ASA trial that included a mix of patients (about one third MCI and two thirds dementia).

While the trials of ASA and HMG-CoA reductase inhibitors were generally well conducted, each had at least one major limitation. These limitations included small sample size, limited duration of followup (<12 months), attrition (>20%) or differential attrition, and unclear blinding of outcomes. Additionally, HMG-CoA reductase inhibitor trials were exclusively or partially industry funded.

The two fair-quality low-dose ASA trials (n=459) showed no difference in global cognitive or physical function outcomes between the ASA and placebo groups at 3 months300 or 36 months.305 The larger trial (n=310) with longer followup (36 months) also found no difference in measures of neuropsychiatric symptoms and caregiver burden.305 This was the only trial that reported harms of ASA and found an overall increased number of people with any adverse events with ASA versus placebo control (53% vs. 37%, respectively). This trial also found an increased number of serious bleeding events (6% vs. 1%, respectively).

The four fair-quality HMG-CoA reductase inhibitor trials (n=1,153) showed no difference in global cognitive function at 6 to 18 months.306-309 We also quantitatively pooled cognitive function outcomes among the three trials (n=1,064) that reported sufficient data to determine if the individual trials' null results were simply because they lacked power to detect a finding.306-308 This pooled analysis of standardized effect sizes of ADAS-cog scores resulted in clearly null findings (Hedge g, -0.08 [95% CI, -0.98 to 0.82]; I^2^=0%) (Figure 12). Three of these four trials (n=1,109) also showed no difference in physical function or neuropsychiatric symptoms.306,307,309 One trial (n=63) found a small improvement in depression (Geriatric Depression Scale [GDS]) in those receiving atorvastatin versus placebo at 12 months. Despite this result, there was no difference in overall neuropsychiatric symptoms (neuropsychiatric inventory [NPI]). Three of the four trials (n=1,090) reported harms of HMG-CoA reductase inhibitors. Only one trial that evaluated a high dose of atorvastatin (80 mg) found evidence of increased adverse events in the atorvastatin versus placebo groups, with greater nonadherence due to adverse events (17.8% vs. 9.5%) and an increase in total treatment-related adverse events (32.8% vs. 18.8%). There was no statistically significant difference, however, in total adverse events or serious adverse events.

#### NSAIDs

Four fair-quality trials evaluated four different NSAIDs (ibuprofen 800 mg, naproxen 220 mg, indomethacin 100 mg, and celecoxib 40 mg daily) given alone or in combination with a proton pump inhibitor. These trials were all conducted in persons with mild to moderate AD, with a mean MMSE score ranging from 19.6 to 20.9. The average age of participants was 73 or 74 years and about half were women. Trials were conducted in the United States or western Europe and rarely reported the race/ethnicity of participants.

Trials were generally well conducted, but each had at least one major limitation, including small sample size, differences in baseline characteristics, and attrition (>20%) or differential attrition. The celecoxib trial was industry funded.

Four fair-quality NSAID trials (n=959) showed no difference in global cognitive or physical function outcomes at 12 to 18 months between the medication and placebo groups.310-313 Similarly, pooled results among the three trials (n=399) with sufficient cognitive outcome data to be quantitatively combined showed null findings (Figure 12).310-312 HRQL, depression, neuropsychiatric symptoms, and caregiver burden were not consistently reported and showed no differences when reported. None of the four trials had statistically significant differences in withdrawal from trials due to adverse events. Three trials (n=827) reported no statistically significant differences in adverse events between the medication and placebo group. Only the celecoxib trial (n=425) reported total adverse events and found no statistically significant differences between the treatment arms.

#### Gonadal Steroids

Five fair-quality trials evaluated gonadal steroids: estrogen (k=3; n=212), estrogen plus progesterone (k=1; n=65), or testosterone (k=1; n=18). Estrogen doses ranged from 0.625 to 1.25 mg daily, progesterone 0.5 mg daily, and testosterone (transdermal/topical) 75 mg daily. Trials of estrogen plus or minus progesterone were only conducted in women. Likewise, the testosterone trial was conducted in only men. The average age of patients in the trials ranged from 69.8 to 81 years. All of the trials were conducted in mostly white populations, except for one estrogen replacement trial conducted in Taiwan.314 All the trials were conducted in people with known AD (mean baseline MMSE score, 19.5 to 22), except for one estrogen trial in Taiwan in which the mean MMSE score was much lower (16.2).

Included trials were small and had limited followup (<12 months). Other trial limitations included attrition (>20%) or differential attrition and differences in baseline characteristics.

The four fair-quality estrogen trials (n=277) all showed no difference in global cognitive function outcomes at 3 to 12 months between the gonadal steroid and placebo groups, as did the one small testosterone trial (n=18). Pooled analysis of the standardized effect sizes of global measures of cognitive function also showed null findings (Figure 12). Three of the four estrogen trials (n=227) also showed no difference in physical function outcomes between treatment and control arms.315-317 We identified no significant differences in other outcomes of HRQL and symptoms, and these outcome measures were sparsely reported. Harms outcomes were not consistently reported. Three trials reporting withdrawal due to adverse events with estrogen or progesterone found no differences between the treatment and placebo groups.314,316,318 While one trial reporting total and serious adverse events of estrogen plus progesterone found no differences between treatment arms, one trial with estrogen alone did find an increase in total adverse events in women receiving estrogen compared with placebo, mainly due to vaginal bleeding (44% vs. 0%, respectively).

#### Dietary Supplements

Twelve fair- to good-quality trials evaluated dietary supplements, including one multivitamin trial (n=89); seven B vitamin (n=1,294) trials that included folic acid and vitamins B6 and B12; three vitamin E trials (n=522); and four omega-3 fatty acid trials (n=1,145) that included docosahexaenoic acid plus or minus eicosapentaenoic acid. Doses of supplements varied somewhat but were all within the range of one another (Table 13). One exception is one trial that evaluated omega-3 fatty acids paired with vitamin E and used substantially lower doses of vitamin E (on the order of 100 times less); therefore, this trial is considered to primarily evaluate the effects of omega-3 fatty acids.319 All but five of these trials were conducted exclusively in people with mild to moderate dementia; one trial evaluating B vitamins (folic acid and B12) and vitamins E and C in a factorial design was conducted in a mixed population (one third of which had MCI),300 and four supplement trials (two evaluating B vitamins and two evaluating omega-3 fatty acids) were conducted exclusively in people with MCI.303,304 Because results of these trials do not vary by severity of cognitive impairment, we discuss the results of these trials together (as opposed to MCI vs. dementia).

The average age of patients in these 10 trials ranged from 70 to 78.2 years and they included both men and women. Trials were conducted in United States, northern Europe (United Kingdom, Sweden, the Netherlands), Australia, and Asia (Hong Kong and Japan). The mean MMSE score in trials of patients with dementia ranged from 12.3 to 23.5. The trial with the lowest mean MMSE score (12.3) was conducted in an assisted living facility, evaluating vitamin E.320 The mean MMSE score in trials conducted in patients with MCI ranged from 27.2 to 29.0.

Included trials were generally well conducted. We included three good-quality trials with no significant threats to validity.304,320,321 The remaining nine trials had at least one major limitation, which included suboptimal reporting of details to assess risk of bias and attrition (>20%) or evidence of attrition bias.

Collectively, these trials (k=12; n=2,608) represented a variety of different interventions in somewhat heterogeneous clinical populations. Despite this diversity, none of the trials found a difference in global cognitive outcomes between the supplement and placebo groups. Our ability to interpret these results or pool the analyses is limited due to differences in supplements and populations and limited number of trials providing sufficient data to be included in the analysis. Despite these limitations, pooled analyses (k=6; n=1,450) also had null findings (Figure 12).

Eight of the 12 included trials also reported outcomes of global physical function, none of which found any differences between treatment arms. In addition, eight of the 12 included trials reported some measure of neuropsychiatric disturbances and/or depression. Only one small trial (n=54) conducted in people with MCI showed a benefit of omega-3 fatty acids on depression scores at 6 months.302 Other outcome measures of HRQL and caregiver burden were sparsely reported and also found no significant differences between treatment arms. These trials did not consistently report harms. Among the six trials that reported total adverse effects, serious adverse effects, or discontinuation of supplement due to adverse effects, none of the trials found statistically significant differences of events between treatment arms. One trial of high-dose vitamin E (1,000 IU daily) in more cognitively impaired patients (mean MMSE score, 12.3) in assisted living reported more syncopal events in the vitamin E group versus the placebo group (7% vs. 4%, respectively).

### Nonpharmacologic Interventions

#### Caregiver Interventions

(Table 14, Figures 13 and 14)

Figure 13 Meta-Analyses for Psychoeducational Caregiver Interventions on Caregiver Burden (Key Question 4)

Figure 13 displays a forest plot of psychoeducational caregiver intervention studies reporting Hedge's g for the intervention group versus the control group for caregiver burden. This figure is described further under KQ4 of the review.

Figure 14 Meta-Analyses for Psychoeducational Caregiver Interventions on Caregiver Depression (Key Question 4)

Figure 14 displays a forest plot of psychoeducational caregiver intervention studies reporting Hedge's g for the intervention group versus the control group for caregiver depression. This figure is described further under KQ4 of the review.

We identified 59 trials (n=8,932) that targeted the caregiver or the caregiver-patient dyad with the primary aim of improving caregiver outcomes or skills, representing a wide variety of different interventions. Most of the trials (k=52; n=8,103) evaluated interventions with some type of psychoeducational component. These interventions provided information about dementia and/or caregiving and sought to increase caregiver skills (specific caregiving skills or general skills, such as problem solving and communication applied to caregiving). Other trials evaluated interventions that provided little or no dementia education or caregiver skills development, but instead involved peer support only322-325 (k=4; n=644), physical activity for caregivers326-328 (k=3; n=293), or an assessment and treatment plan development (k=1; n=50).329 Due to the different types of interventions, we summarize findings for the 52 psychoeducation interventions first and other interventions separately. A group of trials, the Resources for Enhancing Alzheimer's Caregiver Health (REACH) trials,325,330-333 were part of a consortium that used common methods and measurement instruments, but examined different intervention approaches. We excluded one of the REACH trials from this review because it was limited to patients with moderate to severe dementia. The remaining REACH trials were treated as independent studies. Table 14 provides a brief summary of study characteristics and reported outcomes. Appendix E Tables 4–8 and Appendix F Tables 5–7 provide more detailed study characteristics and outcomes.

#### Psychoeducation Interventions

Intervention Characteristics. The psychoeducation intervention trials encompassed a wide range of approaches. While the target of the intervention was usually the caregiver or the caregiver-patient dyad, two trials targeted the whole family334,335 and two trials focused on provider training.336,337 The most common format was for interventionists to meet individually with caregivers, dyads, or families (k=32). A substantial number of interventions, however, took place in group settings (k=17), and three trials used computer-based systems (usually linked to a phone system) to deliver education, training, and support from other caregivers.333,338,339 Interventions took place in medical settings or in the home. In addition to providing information about dementia and available community resources, most interventions also included training in stress management, problem solving, and communication techniques. A variety of additional components were sometimes used, including supportive counseling (counseling focused on the caregiver's emotional or psychological issues), home safety assessments or information, occupational therapy, and environmental modifications.

Psychoeducation intervention providers were generally health care nurses or social workers, or health educators of some kind. Four trials that integrated occupational assessment and interventions used occupational therapists as the interventionist.340-344 Ten trials used a medical liaison for care or case management in addition to psychoeducation.332,336,345-351 Interventions in included trials ranged in intensity and duration; the number of sessions ranged from three to 18 sessions and the median number of sessions was 10 sessions (interquartile range [IQR], 6 to 12). The duration of included interventions ranged from 3 weeks to more than a year (median, 17 weeks [IQR, 7 to 44]).

Population Characteristics. The patients included in these trials had mild to moderate dementia and were community-dwelling individuals who required caregiving. The average MMSE score was consistent with patients having moderate, as opposed to mild, dementia. Some trials had a minimum requirement for time spent in caregiving, which ranged from one visit per week to (most commonly) 4 hours per day. All of the REACH trials325,330,332,333,352 required 4 hours per day of caregiving, as did three others.353-355 The average MMSE score was 15.9 across all studies reporting it (n=5,274). Baseline MMSE scores were an average of 5.3 points lower in trials conducted in the United States (mean score, 13.6 in U.S.-based trials vs. 18.9 in other trials).

Half (k=26) of the 52 psychoeducation trials were conducted in the United States. The remaining studies were conducted in Europe,334,337,343,348,350,355-360 Australia,335,361 Canada,362-365 Taiwan,347, 353,366 and Hong Kong.351 The majority (76%) of caregivers in psychoeducation interventions were women, and about half were the patients' spouses. Trials conducted outside of the United States rarely reported race/ethnicity distribution of their samples, and samples in U.S.-based trials generally included less than one third nonwhite participants. However, at least 40 percent of the participants in four trials were black or Latino.325,330,332,367

Study Characteristics. We only rated four of the psychoeducation trials as good quality,336,337,356, 368 including both trials that targeted providers. These trials used good procedures and statistical methods and had followup on at least 80 percent of their participants. The remaining 46 trials were rated fair quality for a variety of reasons. Most commonly, more than a third of the trials failed to report whether allocation was concealed, almost half of the trials failed to describe blinding of outcomes assessment, and just under one third reported followup on less than 80 percent of participants after 6 to 12 months.

Findings. Burden and depression were the two most commonly reported caregiver outcomes; 81 percent of the psychoeducation trials reported at least one of these two outcomes. None of the trials reported on adverse effects. Caregiver burden was reported in 29 (n=4,598) of the trials that employed psychoeducation interventions, and this burden was measured by a variety of self-report instruments (Appendix E Table 6). The Zarit CBI was the most commonly used instrument, which defined burden as a subjective sense that resources are insufficient to meet role demands. This instrument specifically measures perceived social, physical, financial, and emotional burden of caregiving, as well as providing a total summary score.369 This instrument has been widely used and has demonstrated acceptable reliability and construct validity, although given the multidimensional nature of caregiver burden, a single summary score is limited in the degree to which burden can be fully captured. The RMBPC caregiver bother subscale was the second most commonly used instrument. This instrument asks caregivers to rate the degree to which they are bothered by 24 patient behaviors.370

Effect sizes for caregiver burden were generally small, and 11 (38%) of the trials that reported this outcome found a statistically significant benefit of psychoeducation interventions after 3 to 18 months.145,330,342,346,347,352,355,363,367,371,372 The standardized pooled effect for those reporting sufficient data to be included in the meta-analysis (k=24; n=2,679) showed a small but statistically significant effect (SMD, -0.23 [95% CI, -0.35 to -0.12]; I^2^=52.7%) (Figure 13). Statistical heterogeneity was fairly substantial, consistent with the clinical heterogeneity among the interventions studied. Using visual inspection of forest plots, summary tables, and exploratory meta-regressions, we determined that no design feature, population characteristic, or treatment component robustly explained the variability in effect sizes (including time to followup, study quality, year of publication, type of control group used, caregiver age, percent of caregivers who were female, patient baseline MMSE score, number of sessions offered as part of the intervention, total hours of contact with an interventionist, group sessions, one-on-one sessions, peer support, problem-solving training, communication training, stress management, supportive counseling, provision of dementia information, use of active techniques, intervention geared toward whole family, home safety assessment or information, direct patient care, care or case management, or total number of specified treatment components included in the intervention). However, provision of information about dementia did have a statistically significant association with effect size (p=0.048), in that effect sizes were slightly larger for studies that clearly provided caregivers with information about dementia, such as prevalence, course, and possible treatment options. We could not include six of the studies (n=1,059) that reported burden in the meta-analysis because they were missing important information or reported an incompatible outcome.334,347,351-353,362 In these studies, the effect sizes were similarly small, with few statistically significant group differences. Overall, we found no evidence of bias of small study effects (i.e., smaller or more imprecise trials showing larger effects).

The clinical importance of these small changes, however, is unclear. Most studies reported between 0- and 5-point group differences on the 88-item Zarit CBI or about 1- to 3-point differences on the 96-point RMBPC caregiver bother subscale. Baseline Zarit CBI scores ranged widely across studies, and only one study reported average changes of 6 points or more in either group (the equivalent of changing from being bothered “quite frequently” to “rarely” on three of 22 items). However, CIs were frequently quite wide, suggesting the possibility that some patients showed substantial benefit and others did not benefit at all. Unfortunately, we could not identify such a subgroup based on study-level data. While we did not identify a relationship between study size and effect size, the high degree of statistical and clinical heterogeneity limits confidence in any single point estimate from a meta-analysis. There is no indication that omitting six trials with missing or incompatible data from the meta-analysis substantially biased the analysis. The true average effect is likely small at best, which is consistent with the results of the meta-analysis.

Thirty-four of the psychoeducation trials (n=5,423) reported caregiver depression, measured by a variety of self-report instruments (Appendix E Table 7). The CES-D, a 20-point screening instrument, was the most commonly used instrument.373 Other instruments were only used in one or two studies. While the effect sizes were generally small, 16 (47%) of the trials reporting caregiver depression found statistically significant results after 3 to 24 months.145,335,342,343,345,346, 352, 353,359,367,368,371,374-377 Our meta-analysis included the pooled effect for 30 trials (n=3,537) and found a small but statistically significant effect (SMD, -0.21 [95% CI, -0.30 to -0.13]; I^2^=34.1%) (Figure 14). We could not include six of the trials reporting depression in the meta-analysis due to missing or incompatible data. Three of these studies showed statistically significant benefit in reduction of symptoms or in the percent of participants meeting a threshold.342,352,353,376,378,379 Evidence regarding small study effects bias was mixed. Begg's test and the trim-and-fill procedure did not suggest small study bias; however, Egger's test of bias was statistically significant, and a cumulative meta-analysis sorted by the study's standard error (a measure of precision and related to effect size) showed generally increasing effect sizes as studies with larger standard errors were added to the analysis. Due to this potential bias, the pooled estimate may overestimate the true effect.

Similar to changes in caregiver burden, the clinical importance of these small changes in depression scores is unclear. Most trials reported an approximate 2- to 5-point difference between groups on the 60-point CES-D. A 2-point difference could mean that a person moved from endorsing a symptom 3 to 4 days to rarely or never in the past week, or from 5 to 7 days to 1 to 2 days in the past week. In these trials, control groups typically changed very little and intervention groups showed small improvements. Baseline depression was typically in the minimal or mild range, or an average score of 12 to 15 on the CES-D (where 16 indicates possible depression). Several study features were related to effect size in exploratory qualitative and quantitative analysis, including year of publication (later years were associated with smaller effects), baseline patient MMSE score (smaller effects were seen in trials with higher baseline average MMSE scores), and the intervention's provision of dementia information (trials that did not clearly provide general information about dementia had effect sizes that were smaller than average). Trials reported a wide variety of additional self-reported outcomes that were similar to burden and depression, including adjustment to a relative's illness, global stress or distress, anxiety, HRQL, or self-reported health status. However, most of these outcomes were only reported in one to three studies and results were generally mixed. Emotional distress was the most commonly reported of these outcomes, as measured by the General Health Questionnaire. This result was reduced with psychoeducational interventions compared with control groups in four of five studies reporting this result, although other measures of global distress usually showed no group differences.

Twenty-one psychoeducation trials additionally reported institutionalization. While few of the trials were powered to detect a change in this outcome, many reported on institutionalization when describing participant attrition. Eight of the trials identified institutionalization as a primary outcome,335,337,344,347-349,356,361 and all but one of these trials were conducted outside the United States.349 Group differences were only statistically significant in one older trial.361 Time until institutionalization in this trial was 42 months for treatment participants and 28 months in the control group after an average of 7.7 years of followup.361

Other Interventions. Eight fair-quality trials examined other types of interventions aimed at caregivers or caregiver-patient dyads, which involved little to no general education about dementia or caregiving skills development. Three trials (n=293) counseled caregivers to increase physical activity, usually through home-based regimens.326-328 Three trials (n=486) provided caregivers with peer support.322-324 One additional psychoeducation trial included an arm targeting peer support (n=257).325 One trial (n=50) conducted multidisciplinary assessments and treatment planning, including two intensive assessment sessions and one family conference with the patient, caregiver, and other family members.329 None of these trials or comparisons showed a reduction in caregiver burden or depression outcomes. While one caregiver physical activity trial showed a 6-month reduction in perceived stress, this group difference disappeared at the 12-month followup.326 Two caregiver physical activity trials reported dementia patient outcomes and found no group differences in patient behavior.327,328 None of these trials reported on adverse effects.

#### Other Nonpharmacologic Interventions

(Table 15, Figure 15)

Figure 15 Meta-Analyses for Cognitive Stimulation Interventions on Global Cognitive Function^*^ * All instruments except the ADAS-cog are reversed. (Key Question 4)

Figure 15 displays a forest plot of cognitive therapy studies reporting Hedge's g for the intervention group versus the control group for global cognitive function and domain-specific measures of cognitive function. This figure is described further under KQ4 of the review.

We identified 32 trials (n=4,668) that evaluated nonpharmacologic interventions that targeted the patient, rather than the caregiver or patient-caregiver dyad. These interventions included: 1) cognitive training, rehabilitation, and/or stimulation, with or without motor skills training interventions (k=15; n=1,128); 2) exercise interventions (k=10; n=1,033); 3) multidisciplinary care interventions involving assessment and care coordination (k=5; n=1,766); and 4) education-only interventions (k=2; n=741). Many of these interventions targeted people with MCI or included people with MCI and dementia, including seven of the cognitive training or stimulation trials, six of the exercise trials, and one multidisciplinary care intervention. The remaining trials targeted people with mild to moderate dementia, who were usually identified as having AD. Two trials evaluating multidisciplinary care interventions were conducted in assisted living facilities. While the types of outcomes and duration of followup varied across trials, cognitive intervention and exercise trials primarily reported measures of cognitive function. These trials less commonly reported measures of physical function, HRQL, and depression, while multidisciplinary care intervention trials were less consistent in types of outcomes reported and also reported measures of institutionalization and hospitalization. Trials rarely mentioned harms.

Although the findings of the 15 cognitive intervention trials (n=1,128) were somewhat inconsistent, they generally support cognitive stimulation with or without cognitive training (k=6; n=513) to improve short-term global cognitive function (6 to 12 months) for people with MCI or dementia. Based on very sparse reporting of other outcomes, however, it is still unclear if this approach can improve other important outcomes, such as physical function, HRQL, or depression. The magnitude of benefit on global cognitive function, however, is also not clear given the very wide CIs and wide range of absolute mean differences on the ADAS-cog (0 to 13 points), ranging from clinically not meaningful to a large effect. Ten exercise intervention trials (n=1,033) did not find consistent benefit for global cognitive function outcomes, found no benefit on depression, and other outcomes (including physical function outcomes) were not consistently reported. Although there is evidence of benefit in a few of the better-conducted trials, we are unable to determine if there is a clinically important benefit for exercise interventions on reported outcomes due to the limited number of trials and clinical heterogeneity of the populations, exercise interventions, and reported outcomes. We found no evidence of increased total or serious adverse effects due to exercise interventions among trial participants.

The limited number of exercise trials prevents us from determining the consistency and generalizability of this reported benefit. None the five trials evaluating multidisciplinary care interventions and neither of the two trials evaluating provider education-only interventions found benefits in cognitive or physical function, HRQL, or institutionalization. Cognitive and multidisciplinary care interventions did not report harms. Included trials found no evidence of increased total or serious adverse effects due to exercise interventions. Additionally, limitations in the primary evidence do not allow for any meaningful analyses of outcome findings by important patient subgroups. A brief summary of important study characteristics and reported outcomes is shown in Table 15. More detailed study characteristics and outcomes can be found in Appendix E Tables 9–11 and Appendix F Tables 8–11.

#### Cognitive Interventions

Intervention Characteristics. Fifteen included trials (n=1,128) evaluated a variety of cognitive interventions, including cognitive training, cognitive rehabilitation, and/or stimulation with or without motor skills training interventions (Table 15).

Seven trials (n=486) were conducted exclusively or partially in people with MCI. Three of these seven trials evaluated cognitive training interventions in conjunction with relaxation or stress management training compared with a wait-list control group. These interventions included between five and 12 sessions.380-383 The other three trials evaluated cognitive training plus cognitive stimulation interventions, which included between 20 and 104 sessions.384-386 Two trials evaluated intensive interventions given in conjunction with psychomotor training compared with a minimally active control group.384,385 Both of these trials were conducted in mixed populations of people with either MCI or dementia.

Eight trials (n=642) were conducted exclusively in people with dementia, the majority of which specified AD. Four of the seven trials evaluated cognitive training or cognitive rehabilitation interventions, which ranged widely in intensity from six to 120 sessions. These trials also included different cointerventions, including exercise, cognitive behavioral training, and stress management.387-390 Two trials evaluated cognitive stimulation interventions; one intervention lasted eight sessions, the other included 260 sessions. These two interventions were compared with a wait-list or no intervention control group.215,391 One trial evaluated a cognitive training and cognitive stimulation intervention that included six sessions compared with a wait-list control group.392 One trial evaluated a unique intervention focusing on caregiver training, support, patient memory, and coping strategies.393

Population Characteristics. These trials were conducted in people exclusively with MCI (k= 5; n=363), people with MCI or dementia (k=2; n=123), or people exclusively with dementia (k=8; n=642). In one of the two trials with a mixed population, results were reported separately for persons with MCI versus dementia.384 The average age of patients in the MCI trials ranged from 68 to 74 years. The trial that included a population with the average age of 68 years was an outlier, as this population had lower education (conducted in Greece).386 These trials included both men and women and were conducted in primarily white populations in the United States, Canada, Australia, and western Europe. The mean MMSE score ranged from 26.4 to 27.9.

The average age of patients with dementia ranged from 74 to 82 years. These trials included a good distribution of both men and women, but were conducted in mostly white populations in the United States and western Europe. Most trials only included patients with dementia who had AD. The mean MMSE score ranged from 20.8 to 25.1.

Study Characteristics. We rated all these trials as fair quality. In general, trials were relatively small (n<100), of limited duration (3 to 6 months followup), and conducted completers-only analyses.

Findings. While all trials reported some measure of cognitive functioning as an outcome, only 10 of the 15 trials reported global cognitive measures. The majority of the remaining trials reported memory-specific measures of cognitive function (Table 15). Isolated trials also reported outcome measures of physical function, HRQL, institutionalization, caregiver burden, or patient symptoms (most commonly depression). These results are only mentioned briefly, however, due to the sparse nature of these outcomes and concern of selective reporting.

Overall, cognitive training alone does not appear to improve global or memory-specific cognitive functioning at 3 to 6 months (Table 15). Only one trial reported global cognitive function; the remaining trials did not find any statistically significant difference in memory-specific cognitive outcomes at 3 to 6 months. However, it appears that cognitive stimulation with or without cognitive training in people with MCI or dementia can improve global cognitive function at 6 to 12 months. A meta-analysis of these trials (k=6; n=513) showed a moderate standardized effect size for global cognitive functioning favoring the intervention (-0.59 [95% CI, -0.93 to -0.25]; I^2^=52.7%) (Figure 15). CIs were quite wide. Consequently, the effect on global cognitive functioning can range from small to large. The three trials that included cognitive stimulation reported a very wide range of differences in means, ranging from approximately 0 to 13 points on the ADAS-cog between the intervention and control groups.215, 384,392 The two trials that used the MMSE had an approximate 1-point difference between groups.386,387 The statistical heterogeneity was also quite high. One trial (n=84) in people with both MCI and dementia could not be included in the meta-analysis because of limitations in how the data were reported. This trial evaluated an intensive cognitive stimulation plus cognitive training intervention and found no statistically significant difference in ADAS-cog or MMSE scores at 12 months between the intervention group and a minimally active control group (Table 15).385 There were important differences in the populations and interventions evaluated, as well as study design. Despite these differences, however, we cannot explain the differences in trial findings through MCI versus dementia, intervention intensity, or length of followup individually. The small number of trials limits our ability to determine if these or other characteristics are moderating the effects and effect sizes seen in these trials. Only one of the included trials (n=86) evaluated a cognitive stimulation intervention lasting 1 year, reported longer-term followup, and showed beneficial differences in cognitive improvement between the two groups that were still statistically significant at 24 months.

Only one of the five trials that reported physical function outcomes found small but statistically significant improvement in physical function with a cognitive stimulation and training intervention in people with MCI, in addition to global cognitive function, at 6 months (Table 15).386 Likewise, two of the eight trials that reported depression outcomes found small but statistically significant improvement. These trials did not find improvements in global cognitive function with cognitive stimulation and training interventions in people with MCI or dementia at 6 and 12 months (Table 15).384,385 However, these and other outcomes (i.e., HRQL, institutionalization, neuropsychiatric disturbances, and caregiver burden) were sparsely reported. As such, the interpretation of these outcomes should not be in isolation of the primary outcome findings for each of these trials. None of these included trials reported on harms.

#### Exercise Interventions

Intervention Characteristics. Ten included trials (n=1,033) evaluated a variety of exercise interventions, including aerobic training, strength/resistance training, balance training (or some combination of the three), or Tai Chi (Table 15).

Six trials (n=783) were conducted exclusively in people with MCI. These trials evaluated different interventions (self-guided or guided exercise). Two trials (n=444) evaluated Tai Chi interventions.394,395 One was conducted in the United States and the other in Hong Kong. Shorter trials had fully- or partially-guided exercise interventions that occurred one to four times weekly.212,394,396,397 The longest trial evaluated a self-guided exercise intervention occurring three times a week for 18 months. All of these trials included an active control group in which people received stretching, balance, relaxation exercises, or nonexercise educational materials.

Four trials (n=250) were conducted exclusively in people with dementia, three of which specified AD. All trials generally included aerobic and/or strength training. Three of the four trials evaluated a self-guided intervention.337,398,399 Three trials included an active control in which people received nonexercise-based interventions, and one trial used a wait-list control group.399

Population Characteristics. The average age of patients in the MCI trials ranged from 69 to 79 years. While these trials included both men and women, one trial was conducted exclusively in women.397 Trials were conducted in the United States, Canada, Australia, Japan, and Hong Kong. The mean MMSE score ranged from 24.5 to 26.8. The trial in Hong Kong was conducted in generally older people with a lower education level, which might explain the low MMSE score for people with MCI.394 The average age of patients with dementia ranged from 74 to 84 years. These trials were conducted in primarily white populations in the United States, Italy, and Australia. Three trials only included patients with AD.398,400 The mean MMSE score ranged from 16.7 to 22.0.

Study Characteristics. We rated all but one of these trials as fair quality. Common limitations in quality for this body of literature included: differences in baseline characteristics, small sample sizes, relatively short followup, limited reporting, and completers-only analyses.

Findings. Included trials reported either measures of cognitive or physical functioning as the primary outcome. Seven of these trials reported global measures of cognitive function,212,213,394, 395,398,399,401 two of which reported memory-only measures396,397 and three of which reported measures of physical functioning (Table 15).399-401 Five trials also reported measures of depression213,394, 398-400 and four trials reported on adverse effects.213,397,398,401 Other outcomes of HRQL, institutionalization, hospitalization, neuropsychiatric disturbances, and caregiver burden were not commonly reported.

Overall, the exercise trials showed no benefit on outcomes of cognitive function for people with MCI or dementia; however, findings from these trials were inconsistent. Inconsistent findings of benefit are possibly due to the heterogeneity in populations and interventions studied. For MCI, four of the six trials showed no significant effects on cognitive outcomes, three of which used measures of global cognitive function. Two trials (n=444) evaluated a Tai Chi intervention in older adults with a relatively low mean MMSE score for MCI.394,395 Two trials (n=220) found a very small benefit in global cognitive function (about 1 point on the MMSE or ADAS-cog) at 12 to 18 months for people in the multicomponent exercise arm.212,213 Only two trials reported on harms and found no difference in total adverse events between the treatment and control groups.213,397

Likewise, findings in people with dementia were inconsistent among the four included exercise trials. One small trial (n=27) conducted in the United States evaluated a self-guided aerobic, strength, and balance training intervention versus home safety assessment and found no benefit in cognitive function, HRQL, symptoms, or caregiver burden at 3 months (Table 15).398 Two small trials (n=70) found a statistically significant benefit in both cognitive and physical functioning outcomes for the exercise group versus a nonexercise active control in the short-term (3 to 4 months).399,401 One good-quality trial (n=153) conducted in the United States evaluated an exercise plus caregiver education and skills training intervention versus usual care and found a clinically and statistically significant benefit in physical function and HRQL, but not institutionalization or depression symptoms, at 18 months (mean difference in Sickness Impact Profile (SIP) score, 8.1 [p=0.02]; mean difference in Short-Form Health Survey (SF-36) score, -15.9 [p<0.01]).400 Two of these four trials reported no difference in total or serious adverse events between treatment arms.398,401

#### Multidisciplinary Care Interventions

Intervention Characteristics. We included five trials (n=1,766) of multidisciplinary care interventions that involved some aspect of assessment and care coordination. Each of these five trials evaluated different interventions (Table 15, Appendix E Table 11). The first trial (n=100), the only one conducted in the United States, evaluated four multidisciplinary assessments in residents of an assisted living facility versus medical evaluation by the resident's primary care physician.402 This intervention's primary aim was to reduce unexpected transitions of care. The other interventions were delivered through specialty care clinics. One trial (n=230) conducted in the Netherlands evaluated a one-time multidisciplinary assessment with recommendations sent to the patient's general practitioner versus usual care. Another trial (n=130) conducted in the Netherlands evaluated an assessment and management intervention delivered through a neurologist or geriatrician that focused on optimizing vascular care (using ASA, vitamin B6, folate, HMG-CoA reductase inhibitors, and, if indicated, therapies targeting blood pressure, glucose, smoking, and diet/activity) in patients with AD (not VaD) versus usual care delivered through general practitioners.403 Two well-conducted trials (n=1,306), one in France and one in the Netherlands, evaluated a multidisciplinary assessment and management intervention delivered through memory clinics, with ongoing consultations that involved the caregiver, using guidelines/protocols for management of care versus usual care.404,405

Population Characteristics. All trials were conducted in people with dementia. While one trial (n=230) stated that it included people with both MCI and dementia, the mean MMSE score in this trial was only 20.2. As such, we discuss this trial with the other trials focusing exclusively on people with dementia. The average age of patients ranged from 76.5 to 82.2 years (Table 15). Trials included both men and women and were conducted in primarily white populations in the United States, the Netherlands, and France. Only two trials specified that patients had AD.403,404 The mean baseline MMSE score ranged from 14.8 to 22.7. One trial conducted exclusively in residents of an assisted living facility in the United States had the lowest average MMSE score.402

Study Characteristics. Only one trial was rated as good quality; the other four were rated as fair quality and had at least one major limitation, including high attrition (>20%), evidence of attrition bias, or nonblinded assessment of outcomes.

Findings. Outcome measures varied across trials due to the different types and aims of these interventions. Overall, none of the trials (n=1,766) demonstrated a benefit in people receiving the multidisciplinary intervention (Table 15). None of the trials specifically mentioned harms. The trial conducted in U.S assisted living facilities (n=100) aimed at decreasing unexpected transitions of care found no difference in institutionalization, hospitalizations, or ED visits between intervention and usual care groups at 9 months.402 The other three trials evaluating assessment plus or minus management interventions (n=1,666) showed no benefit in global cognitive or physical functioning, HRQL, institutionalization, or patient symptoms at 12 to 24 months.403-406 While two trials evaluated similar multidisciplinary interventions that included the caregiver, only one of these trials reported any caregiver outcomes.405 This trial reported statistically significant benefits in caregiver depression and anxiety, but not overall caregiver HRQL or distress, in the intervention group compared with usual care at 12 months.

#### Education-Only Interventions

Two fair-quality trials (n=741), one in Australia and one in Germany, evaluated educational interventions aimed at residential care staff and/or general practitioners caring for people with dementia (Table 15).407,408 In both interventions, residential care staff and/or general practitioners received intensive education across a variety of topics, such as dementia and delirium, concerning behaviors, pain management, personal care and activities, communication with patients and family, medical treatment options, caregiver counseling, and effective working between general practitioners and residential care facilities. Patients in one trial were all permanent residents of residential care facilities and were quite old (mean age, 85.3 years), with a fairly low median MMSE score (approximately 11).407 In the other trial, patients were from general practitioner practices in Germany, with a mean age of 80 years and a mean MMSE score of 18.7.^408^ These cluster RCTs were generally well-conducted but of fair quality, as they both had suboptimal followup (<80%), and one also had evidence of attrition bias.407 In addition, they either reported low adherence to the educational intervention or did not report adherence.

The trial conducted in residential care facilities showed no statistically significant differences in any of the reported outcomes, including HRQL (as rated by the patient, staff, or next of kin), neuropsychiatric disturbances, or proportion of people hospitalized at 30 days, between education groups and control groups at 6 months.407 The other trial, in general practitioner practices, showed no statistically significant differences in its primary outcome of time to institutionalization between groups at 24 months.408 Neither of the two trials specifically mentioned harms.