# Methods

The USPSTF will use this evidence review to update its 2003 USPSTF recommendation statement on screening for cognitive impairment in primary care. To accomplish this, our review assesses 1) the net benefit and diagnostic accuracy of brief screening instruments to detect cognitive impairment in older adults, and 2) the net benefit of the major treatment and management options for older adults with MCI or early dementia and their caregivers.

This review's scope differs from that of the 2003 evidence review in two important ways.2 First, we broadened the scope to include MCI screening and treatment, in addition to dementia screening and treatment. In practice, clinicians use screening tests to detect cognitive impairment, which includes both dementia and MCI. MCI is increasingly viewed as a preclinical stage to dementia and clinicians may also be treating or intervening earlier in the disease process (e.g., off-label use of pharmacologic agents).107 Second, we broadened the framework to address the impact of screening and/or diagnosis of cognitive impairment on decisionmaking by the patient, family/caregiver, or clinician. Our decision to add decisionmaking outcomes reflects the importance of developing an accurate understanding of cognitive ability for patient, family, and clinician planning, as well as care delivery.

## Analytic Framework and Key Questions

The analytic framework is presented in Figure 1.

Figure 1 Analytic Framework

Abbreviation: QOL = quality of life.

Figure 1 is an analytic framework for the key questions of this report that depicts the events that adults over 65 years could experience while undergoing screening, diagnostic work-up, and treatment/management for cognitive impairment. In general, the figure illustrates how screening for cognitive impairment could lead to a diagnosis of mild cognitive impairment or dementia and subsequent treatment/management. Diagnosis could affect decision making outcomes and treatment/management could have an impact patient outcomes, family/caregiver outcomes, and societal outcomes. The figure also depicts the possibility of harms or adverse events occurring as a result of screening and the treatment/management.

### Screening Key Questions (1–3)

Key Question 1. Does screening for cognitive impairment (dementia or MCI) in community-dwelling older adults in primary care–relevant settings improve decisionmaking, patient, family/caregiver, or societal outcomes?

Key Question 2. What is the test performance of screening instruments to detect MCI and/or dementia in community-dwelling older adult primary care patients?

Key Question 3. What are the harms of screening for cognitive impairment?

### Treatment/Management Key Questions (4, 5)

Key Question 4. Do pharmacological or nonpharmacologic interventions for MCI and/or early dementia in older adults improve decisionmaking, patient, family/caregiver, or societal outcomes?

Key Question 5. What are the harms of pharmacological or nonpharmacologic interventions for cognitive impairment?

### Definitions of Terms Used in Key Questions

- Cognitive impairment: Dementia or MCI. Cognitive impairment in this report does not include delirium.
- MCI: Loosely defined term that encompasses cognitive impairment that does not interfere with independence in daily life. Mutually exclusive from dementia.
- Early dementia: Mild or moderate dementia. Traditionally, an MMSE score of 21 to 24 is considered mild dementia and a score of 13 to 20 is considered moderate dementia.
- Screening: Methodically administering an instrument to patients in order to detect a disease/condition in “apparently” healthy individuals. The term screening, in this report, is in contrast to “case-finding,” which is testing targeted to individuals or groups who are suspected to be at risk for a particular disease/condition. Case-finding (as opposed to diagnostic testing) involves actively and systematically searching for at-risk people, rather than waiting for them to present with obvious symptoms or signs of active disease.
- Screening instruments: Instruments designed to assess cognitive function that take 10 minutes or less to administer by clinic staff or 20 minutes or less to self-administer (by patient or informant).
- Community-dwelling older adults: Adults who live at home or in senior living communities, assisted living, adult foster care, or residential care facilities. This excludes institutionalized people who reside in intermediate care facilities (i.e., rehabilitation centers or skilled nursing facilities).
- Primary care–relevant settings: Primary care, outpatient settings (ambulatory care). This excludes hospitals, emergency departments (EDs), or specialty (referral) outpatient settings (i.e., memory, dementia, geropsychology, or neurology clinics).
- Decisionmaking outcomes: For patients and family/caregivers: health care, legal, and financial planning (e.g., advanced directives); safety planning; and living arrangements. For clinicians: health care planning, including advanced directives; patient and caregiver education; safety planning (change, monitored medication use); screening and diagnostic decisions (e.g., cancer screening); and other treatment or management decisions (e.g., treatment of reversible causes of dementia, management of comorbid conditions). Test performance: sensitivity, specificity, predictive values, likelihood ratios, or area under the curve.

## Data Sources and Searches

Given the breadth and volume of literature for this topic, we first conducted a search for recent existing systematic reviews addressing both the screening and treatment key questions, using MEDLINE, Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effects, and publications from the Institute of Medicine, the Agency for Healthcare Research and Quality (AHRQ), and the National Institute for Health and Clinical Excellence (NICE) (Appendix A). This search identified 771 potentially relevant reviews on screening or treatment for dementia and 283 additional potentially relevant reviews on screening or treatment for MCI. We used the most relevant existing systematic reviews, one screening for dementia review,19 and 11 treatment of dementia and MCI reviews108-118 to develop a comprehensive search strategy from the end of the existing systematic review (if available) until December 10, 2012. Existing systematic reviews were primarily used to locate studies for inclusion (as part of our search strategy). However, in one instance, we used a recent, good-quality systematic review commissioned by AHRQ to summarize the primary results for FDA-approved medications to treat AD (i.e., donepezil, rivastigmine, galantamine, tacrine, and memantine), on a variety of outcomes.119 This review by Santiguida and Raina was subsequently published in Annals of Internal Medicine with an updated search through 2006 by Raina and colleagues.110 We supplemented this body of literature with newly identified trials and their open-label extension (OLE) studies through our own literature searches that incorporated the searches used in the existing (original) systematic review.

In many cases, existing systematic reviews were not available for the screening or treatment of MCI. In these instances, we searched from 1990 to December 10, 2012 because MCI was not widely recognized as a clinical entity until 1991.^120^ We searched MEDLINE, PsycINFO, and the Cochrane Central Register of Controlled Trials to locate relevant studies for all key questions. We supplemented our searches with expert suggestions and through reviewing reference lists from all other recent relevant existing systematic reviews. We also searched selected grey literature sources, including ClinicalTrials.gov, World Health Organization International Clinical Trials Registry Platform, and Current Controlled Trials (ISRCTN Register) for ongoing trials.

## Study Selection

Two investigators independently reviewed 16,179 abstracts and 1,190 articles (Appendix A Figure 1) against the specified inclusion criteria (Appendix A Table 2). We resolved discrepancies through consensus and consultation with a third investigator. We excluded articles that did not meet inclusion criteria or were rated as poor quality. These trials are listed in Appendix B.

For screening questions (Key Questions 1–3), we included studies that evaluated any brief screening instrument that could be delivered in primary care in 10 minutes or less by a clinician or self-administered in 20 minutes or less. We excluded instruments with longer administration times (e.g., modified MMSE, Addenbrooke's Cognitive Examination), as these cannot be reasonably administered in primary care, although many are used in specialty care settings, such as neurology or memory clinics. Screening instruments could be administered to the patient or their family member or caregiver (informant) in person or by telephone. We excluded all diagnostic imaging (e.g., CT, MRI, PET), or biomarker testing (e.g., CSF, plasma, or urine), as these may be used as part of a diagnostic workup for cognitive impairment, rather than as screening tests (and/or are still considered investigational/experimental tests). Diagnostic accuracy studies of screening tests had to compare the index test with a reference standard (i.e., clinical assessment or neuropsychological testing, with explicit diagnostic criteria with or without expert consensus/conference). We excluded diagnostic accuracy studies that only compared the index test with another screening test (e.g., MMSE). We included studies that were relevant to community-dwelling older adults being seen in primary care in the United States. As a result, we excluded screening studies in hospitals or intermediate care facilities (i.e., nursing homes, rehabilitation facilities, and subacute care facilities) or studies conducted in developing countries (those rated as high, medium, or low on the 2011 Human Development Index121). However, we included studies in noninstitutionalized older adults living in senior communities, assisted living facilities, adult foster care homes, or residential care. We also excluded screening studies in which populations were selected from referred settings (e.g., memory, neurology, psychogeriatric, or geriatric clinics in nonU.S. settings that serve a consultant role, Alzheimer's Disease Research Centers).

Screening studies had to include decisionmaking outcomes, patient health or safety outcomes, family or caregiver burden or health outcomes, or societal outcomes (Key Question 1) or include diagnostic accuracy (sensitivity, specificity for dementia or MCI) outcomes (Key Question 2) or harms (unwanted or unexpected direction of effect on health outcomes, psychological harms, harms due to labeling, poor adherence to diagnostic followup) (Key Question 3). Screening studies for Key Question 1 were limited to good-quality systematic reviews; randomized, controlled trials (RCTs); or controlled clinical trials (CCTs). Studies included for Key Question 2 were limited to good-quality systematic reviews or prospectively conducted diagnostic accuracy studies. We excluded case-control studies in which cases were selected based on having known dementia or MCI. Distorted selection of patients in selective recruitment or case-control designs have repeatedly been shown to overestimate sensitivity.122-126 Although a distorted selection of patients directly affects the applicability of the study findings (and predictive values due to prevalence of underlying disease), we excluded case-control studies from our review because of the threats to validity (i.e., spectrum bias). Spectrum bias refers to the phenomenon that the diagnostic test performance may change between clinical settings due to changes in patient case-mix. We considered any study design for Key Question 3 except for case series and case reports.

We did not have the resources to review all possible treatment modalities for treatment or management questions (Key Questions 4 and 5). As a result, we focused on the major pharmacologic and nonpharmacologic interventions intended for use during the earlier stages of dementia. For this review, we included FDA-approved medications used to treat patients with AD for the purpose of preventing/delaying cognitive decline (i.e., donepezil, galantamine, rivastigmine, tacrine, memantine); medications primarily aimed at cardiovascular risk reduction for treatment of VaD, including antiplatelet medications, antihypertension medications, and HMG-CoA reductase inhibitors; nonsteroidal anti-inflammatory drugs (NSAIDs); gonadal steroids (i.e., estrogen, progesterone, testosterone); and dietary supplements (i.e., vitamins, minerals, antioxidants). We excluded nonFDA-approved AChEIs (e.g., metrifonate, velnacrine); medications aimed at neuropsychiatric symptoms (i.e., antidepressants, antiepileptics, antipsychotics); medications without FDA approval for the treatment of cognitive impairment (e.g., glitozones, nicergoline, piracetam, posatirelin, selegiline, sabeluzole); all experimental drug therapies (e.g., antiamyloid disease-modifying treatments, IVIG, GHRH); medical foods and nutritional interventions; and herbal supplements (e.g., gingko biloba, DHEA, L-carnitine, hyperzine, curcumin) (Appendix C Table 1). We also included a broad range of nonpharmacologic interventions aimed at patients or their nonprofessional caregivers. We defined caregivers as those who are, or are about to be, engaged in taking some kind of responsibility for the care of the patient. They have some existing relationship to the patient, such as spouse/partner, relative, or friend. Specifically, nonprofessional caregivers have no formal training as caregivers and are nonsalaried, although they may (often) receive some financial compensation for their role. Nonpharmacologic interventions include multidisciplinary or multicomponent interventions aimed at the patient or dyad, peer support interventions aimed at the caregiver, education-only interventions aimed at the patient or dyad, cognitive training (with or without motor training) or cognitive rehabilitation interventions aimed at the patient, cognitive stimulation interventions aimed at the patient, and exercise interventions aimed at the patient or caregiver.

We only included treatment studies that were conducted in community-dwelling older adults with MCI or mild to moderate dementia. Due to our focus on the treatment and management of screen-detected people with cognitive impairment, we excluded treatment studies that focused on moderately-severe or severe dementia or patients exclusively in hospitals or intermediate care facilities. Therefore, we also excluded interventions primarily aimed at noncognitive symptom management (e.g., music, light, pet, reminiscence, or psychodynamic interpersonal therapy; nighttime home monitoring systems; snoezelen) and respite care or day care interventions designed for patients with more significant symptoms and/or functional limitations, which are therefore less representative of screen-detected people. We also excluded primary prevention trials in which treatment was aimed at preventing or delaying the onset of cognitive impairment in healthy older adults without known cognitive impairment. We included treatment or management studies with outcomes on decisionmaking for patients and family or clinicians (e.g., health care planning, including advance directives; screening and diagnostic decisions; safety planning; legal and financial planning); patient health outcomes (e.g., cognitive function, physical function, overall function, health related quality of life [HRQL], safety, medication use/adherence, neuropsychiatric symptoms [insomnia, depression, agitation, aggression, wandering], ED use, hospitalizations, or institutionalization); caregiver outcomes (e.g., caregiver burden, HRQL); or societal outcomes (e.g., automobile accidents). We excluded studies if they only included patient satisfaction or cost outcomes. Treatment effectiveness studies (Key Question 4) were limited to good-quality systematic reviews of trials or RCTs/CCTs with a control group. As such, we excluded comparative effectiveness trials without a usual care, placebo, wait-list, or minimally active control group. For example, we excluded trials that explicitly compared two active interventions (e.g., cognitive stimulation vs. cognitive training, skills-based vs. support-based education, general occupational vs. tailored occupational therapy).

For harms (Key Question 5), we only searched for harms on interventions that were shown to have a potential benefit (i.e., any evidence of efficacy). We primarily focused on serious harms that resulted in unexpected medical care, morbidity, or mortality. We report on less serious harms, namely adverse effects (and discontinuation rates as a proxy for adverse effects) of medications, from trials or observational studies with comparator populations. We included all trials that were included for the efficacy questions (Key Question 4), OLEs of included drug trials, and larger trials or observational studies (cohort or case-control studies with n≥1,000). We excluded smaller trials (not meeting criteria for Key Question 4) and cohort studies (n<1,000) because these studies did not have power to detect rare events, were nearly all shorter-term (<1 or 2 years followup), and/or were conducted in selected populations. As a result, these studies did not add any new information on harms to the included trial literature (Key Question 4) or included larger observational studies. We excluded case series and case reports.

We only included studies that published their results in the English language.

## Data Extraction and Quality Assessment

For screening studies, we extracted details about each study's screening instrument(s) (e.g., administration time, language, cut-point); recruitment and inclusion criteria; sample sizes (n) recruited, eligible, and analyzed; patient characteristics (e.g., age, sex, race/ethnicity, education); prevalence (proportion) of dementia and/or MCI; reference standard (e.g., how it was conducted, diagnostic criteria, whether applied to all or a subset); diagnostic outcomes for given cut-points (e.g., raw numbers, sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, area under the curve); and any reported adverse effects. For treatment trials, we extracted details about each study's intervention(s) (e.g., description, intervention components, dose/intensity, frequency and duration) and control group(s); recruitment and inclusion criteria; sample sizes (n) recruited, eligible, and analyzed; patient characteristics (e.g., age, sex, race/ethnicity, education); prevalence (proportion) of dementia and/or MCI; any decisionmaking outcomes; any societal outcomes; and important patient outcomes (i.e., mortality, institutionalization, hospitalizations, ED visits, measures of cognitive function [global and domain-specific measures], measures of global physical function, measures of overall function and HRQL, measures of neuropsychiatric symptoms [global and symptom-specific measures], measures of caregiver burden, and any adverse events). We present diagnostic studies that evaluated more than one screening instrument and trials with multiple intervention arms in multiple tables, if appropriate. A second reviewer verified all extracted data.

At least two reviewers critically appraised all articles that met inclusion criteria using the USPSTF's design-specific quality criteria (Appendix A Table 3).127 We supplemented this criteria with NICE methodology checklists,128 Assessment of Multiple Systematic Reviews for systematic reviews,129 Newcastle Ottawa Scales for cohort and case-control studies,130 and Quality Assessment of Diagnostic Accuracy Studies for studies of diagnostic accuracy.131 We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet, or it was unclear if it met, at least one criterion, but also had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. The most common fatal flaw for diagnostic studies included application of the reference standard to only those patients who screened positive (because when missing data is not random or selective, analysis will generate biased estimates of diagnostic accuracy,123-125,132 and verification of only screen-positive patients will generally lead to an overestimation of both sensitivity and specificity). Common fatal flaws for treatment trials included very high attrition (>40%), small sample size with high attrition and/or differential attrition, and very poor reporting limiting evaluation of risk of bias. We excluded poor-quality studies from this review.

## Data Synthesis and Analysis

For diagnostic accuracy studies on screening for MCI or dementia (Key Question 2), our primary outcomes of interest were sensitivity and specificity at a given cut-point for the instrument. We present our synthesis of results in summary tables and figures organized by instrument type (according to length of administration) and separated by screening for dementia, MCI and dementia, or MCI only. When applicable and possible, we synthesized and reported the results for the most commonly used cut-point(s). We categorized these instruments as very brief (administered in ≤5 minutes), brief (within 6 to 10 minutes), or self-administered. We relied on published administration times or administration times reported in the individual studies, although there is some variation in administration time based on the impairment of the individual (e.g., cognitive impairment, sensory impairment, depression).

We synthesized results around diagnostic accuracy (i.e., sensitivity and specificity) of instruments that were evaluated in more than one study. We reported the sensitivity and specificity for the most commonly accepted or reported cut-points, although cut-points varied according to the population characteristics (e.g., age, education) for some instruments, and in some cases, cut-point(s) were not reported. While we also extracted and/or calculated positive and negative predictive values, we did not focus on these measures because the prevalence of cognitive impairment varied widely across studies. We address the impact of underlying prevalence on positive and negative predictive values in the Discussion section to inform issues around the optimal age at which to start and stop screening. We synthesized results for test performance to detect 1) dementia, 2) MCI or dementia, and 3) MCI only (excludes people with dementia). We did not report test performance outcomes for the detection of dementia if the study removed persons with MCI from the study sample altogether because the sensitivity and specificity were not comparable with other studies that included the full sample. Additionally, this method of calculation was more similar to nested case-control diagnostic studies that we excluded from our review (only applied to three studies).133-135 Test performance was either directly extracted from individual study results, calculated using study presented 2×2 tables, or calculated using the prevalence of cognitive impairment and the reported sensitivity and specificity (dementia, MCI, or dementia and MCI). We used SAS software (SAS Institute, Inc., Cary, NC) to generate 95% CIs. In general, we summarized ranges of sensitivity and specificity for each instrument, as we were unable to quantitatively pool the majority of the results given the limited number of studies per instrument, heterogeneity or lack of reporting around cut-points (and scoring), and in some cases, heterogeneity around populations and diagnostic criteria. We also used figures to visually display the diagnostic accuracy without producing summary estimates. We conducted quantitative synthesis of diagnostic screening studies if sufficient data were presented to determine test performance (sensitivity and specificity) in more than two similar studies. Similar studies needed to report similar outcomes (i.e., to detect dementia only, to detect MCI plus dementia, or to detect MCI only), be conducted in similar enough populations (i.e., based on underlying proportions of MCI and/or dementia), use similar scoring/cut-points, and apply a similar diagnostic criteria (e.g., Peterson criteria for amnestic MCI vs. suboptimal performance on Clinical Dementia Rating [CDR] scale). We could only conduct this quantitative synthesis for one instrument, the MMSE. For the analysis of dementia screening, cut-points were reported as being between 23 and 24 (23/24), between 24 and 25 (24/25), or simply 24 (some studies reported a cut-point of 24). We analyzed all studies reporting any of these three cut-points combined and then ran separate analyses for the three cut-points. We ran a bivariate model using the metandi procedure, which models sensitivity and specificity simultaneously, thus accounting for the correlation between these variables.136 When the model failed for the 24/25 cut-point, likely due to sparse data, we analyzed sensitivity and specificity in separate random effect meta-analyses using the metan procedure. Similarly, since there were only three studies of MCI or dementia screening, we also ran separate random effects meta-analyses for sensitivity and specificity for this group.

For treatment trials (Key Questions 4, 5), we grouped interventions into four broad categories: 1) FDA-approved medications to treat AD (i.e., AChEIs and memantine); 2) other medications or dietary supplements (i.e., to treat VaD, NSAIDs, gonadal steroids, and vitamins); 3) nonpharmacologic interventions aimed primarily at the caregiver or caregiver-patient dyad; and 4) nonpharmacologic interventions aimed primarily at the patient, including: cognitive training, rehabilitation, and/or stimulation with or without motor skills training interventions; exercise interventions; multidisciplinary care interventions involving assessment and care coordination; and education-only interventions. Cognitive training interventions aim to enhance cognitive skills, most often memory and attention, through practice; cognitive rehabilitation aims to improve coping with cognitive deficits and preservation of remaining skills; and cognitive stimulation aims to enhance cognitive function through structured group discussions on various topics (e.g., current affairs, word association) to create both an optimal learning environment and social benefits of a group.137 We synthesized results within each category (results as an entire category and by similar interventions within each category). We examined results and the association of key study characteristics on results and effect sizes on primary outcomes (when possible). These study characteristics included population characteristics (i.e., age, sex, severity of cognitive impairment, caregiver hours), setting characteristics (i.e., residential care or assisted living, country), intervention characteristics (i.e., intervention components, dosing/frequency or intensity), length of followup, and study quality.

Dementia can be characterized by progressive decline in three areas: cognition, global functioning, and physical functioning. For assessment of global cognitive function, the most commonly used measures in our included studies were the Alzheimer's Disease Assessment Scale-cognitive subscale (ADAS-cog)138 and the MMSE. We used ADAS-cog as the primary measure. We used the MMSE when the ADAS-cog was not available. In the rare instance in which neither of these two measures was used, we accepted other measures of global cognitive functioning (e.g., Mattis Dementia Rating Scale). The ADAS-cog is a validated instrument that assesses memory, attention, orientation, language, and praxis. Scores range from 0 to 70, with higher scores signifying greater cognitive impairment, and a change of 4 points or more is considered clinically significant for patients with mild to moderate dementia.139 The MMSE is a validated instrument that assesses memory, attention, orientation, language, and praxis. Scores range from 0 to 30, with lower scores signifying greater cognitive impairment, and a change of 3 points or more is generally considered to be clinically significant.140 Assessment of global function was not commonly reported except in trials evaluating FDA-approved medications for AD. The most commonly used instrument in this body of literature is the Clinician-based Impression of Change plus caregiver input (CIBIC-plus).141 With the CIBIC-plus, an experienced and independent clinician interviews the patient and a caregiver and rates the patient on a 7-point scale (1=very much better, 4=no change, 7=very much worse) in four areas: general, cognitive, behavioral, and ADLs. Any change in score is considered clinically significant. Global physical functioning was measured by a variety of different instruments capturing the patient's ability to complete basic ADLs (i.e., bathing, grooming, toileting, dressing, transferring, ambulating, and feeding)142 and/or IADLs (i.e., shopping, managing transportation, driving, walking outdoors, climbing stairs, managing finances, doing housework or laundry, using the phone, managing medications, preparing meals, or holding a job).143

For each body of literature, we conducted qualitative syntheses for each of the commonly reported outcomes, which varied by intervention type. While we also address less commonly reported outcomes, we primarily focus on the commonly reported outcomes due to the bias from selective reporting. For each body of literature, we created summary tables to capture the key study characteristics and sources of clinical heterogeneity (e.g., study quality, sample size, location, age, sex, baseline cognitive function/MMSE score, duration of followup), as well as the overall results for each included study. We conducted quantitative analyses on important patient outcomes reported in more than half of the included trials; most often this included global cognitive function. Pooled analyses were conducted for FDA-approved medications to treat AD and other medications and dietary supplements on global cognitive outcomes, caregiver interventions on caregiver burden and depression outcomes, and other nonpharmacologic interventions aimed at the patient on global and domain-specific (i.e., memory only) cognitive outcomes. Trials generally had limited duration of followup; summary tables focus on the longest duration of followup for each trial. For quantitative analyses, we focus on 12-month (i.e., 6 to 18 months) outcomes.

For continuous outcomes (i.e., global cognitive function, caregiver burden, caregiver depression), we analyzed a standardized effect size (Hedge g) based on the differences in change between groups from baseline to followup. For most trials, the Hedge g was calculated from mean change from baseline to followup in each group, along with an associated standard deviation, using standard formulae.144 When given baseline and followup means and standard deviations (rather than change from baseline), we had to calculate a standard deviation of change, which required estimating the correlation between baseline and followup scores for each outcome. We used the following correlation estimates: global cognitive outcomes, 0.82 (intervention group) and 0.82 (control group); caregiver burden, 0.79 (intervention group) and 0.92 (control group); and depression, 0.72 (intervention group) and 0.75 (control group). These correlations were derived from included studies that reported both mean change (and standard deviation) and baseline and followup means (and standard deviations).145,146 We used commonly accepted values to interpret the clinical significance of actual differences in means for specific outcome measures (i.e., ADAS-cog, MMSE), as well as commonly accepted values to interpret the clinical significance of standardized effect sizes. For global cognitive measures, an ADAS-cog change of 4 points or more or a MMSE change of 3 points or more are considered clinically important improvement in mild to moderate dementia.94 For standardized effect sizes, standardized mean differences of 0.2 to less than 0.5 are considered small, 0.5 to less than 0.8 are medium, and 0.8 and above are large.147

In quantitative analyses with at least 10 trials, we used meta-regressions to explore heterogeneity in effect sizes. We examined key study characteristics, including: length of followup, study quality, year of publication, age, percent women, patient baseline MMSE score, and intervention characteristics (i.e., number of sessions offered as part of the intervention, total hours of contact with an interventionist, group sessions, one-on-one sessions, peer support, problem-solving training, communication training, stress management, supportive counseling, provision of dementia information, use of active techniques, intervention geared toward whole family, home safety assessment or information, direct patient care, care or case management, and total number of specified treatment components included in the intervention). We entered each of these predictors into a separate meta-regression model. We created forest plots with studies sorted by effect size for all analyses (regardless of number of included trials), using visual inspection to examine if certain key characteristics may be associated with effect size. For caregiver interventions, we also examined effect size estimates separately for four different types of control groups: usual care in primary care in the United States; usual care outside the United States or in specialty clinics in the United States; usual care plus print materials, generic (nontailored) computer- or Web-based information, referral to support group or other community resources, and/or a single phone or in-person contact estimated to last 15 minutes or less, or attention control; and multiple contacts for caregiver or patient, or a single contact lasting more than 15 minutes.

We assessed the presence of statistical heterogeneity among the studies using standard chi-square tests and estimated the magnitude of heterogeneity using the I^2^statistic.148 We also conducted analyses to determine prediction intervals, which provide an estimate of where 95 percent of newly conducted trials would fall, assuming the between-study variability in the included trials held for new trials.144 The prediction intervals are not shown in our results but are mentioned in the Discussion section. We used a variety of approaches to examine whether pooled effects may have been biased due to small, imprecise studies having larger than expected effect sizes. We first performed tests of publication bias that examine whether the distribution of the effect sizes was symmetric with respect to effect precision using funnel plots, Egger's linear regression method, and Begg and Mazumdar's rank correlation test.149 We also used a trim-and-fill procedure to look at the degree to which pooled estimates changed after the trim-and-fill procedure has adjusted the estimate for the potential effect of missing studies.150 Finally, we ran a cumulative meta-analysis, entering studies in the order of the standard error of the effect estimate (which is highly related to sample size). We visually examined the resulting forest plot to see if the pooled effect increased as smaller studies were added to the analysis. We conducted these analyses of small study effects only in analyses that included at least 10 trials.151

We used Stata 11.2 (StataCorp LP, College Station, TX) for all statistical analyses unless otherwise noted.

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis. This research was funded by AHRQ under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in external review of the draft evidence synthesis.