# Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2003 recommendation on dementia screening. In 2003, the USPSTF concluded that there was insufficient evidence to recommend for or against routine screening for dementia in older adults (I statement).1 This recommendation was based on an evidence review that indicated that while some screening tests had good sensitivity, they had only fair specificity in detecting cognitive impairment and dementia.2 While this review found evidence that several drug therapies had a beneficial effect on cognitive function, the magnitude of this benefit was small. Additionally, this review concluded there was insufficient evidence to determine whether the benefits observed in drug trials were applicable to screen-detected patients in primary care settings.

In 2011, we developed a work plan for this evidence review to address the previous review's evidence gaps and support the USPSTF in updating its previous recommendation. This updated recommendation is focused more broadly on screening for cognitive impairment, including both dementia and mild cognitive impairment (MCI). This evidence review was designed to assess 1) the net benefit and diagnostic accuracy of brief screening instruments to detect cognitive impairment in older adults, and 2) the net benefit of the commonly used treatment and management options for older adults with MCI or early dementia and their caregivers. Our review primarily focuses on screening adults in primary care, rather than specialty care settings (e.g., neurology or memory clinics), and the management of screen-detected people with cognitive impairment, excluding delirium. As a result, this review includes the treatment and management of people with MCI and mild to moderate dementia, as opposed to moderately-severe or severe dementia.

## Background

### Condition Definition and Etiology

Dementia is an acquired condition that is characterized by a decline in at least two cognitive domains (e.g., loss of memory, attention, language, or visuospatial or executive functioning) that is severe enough to affect social or occupational functioning.3 Patients with dementia may also exhibit behavioral and psychological symptoms. The proposed Diagnostic and Statistical Manual, version 5 (DSM-V) subsumes dementia under a new syndrome, “major neurocognitive disorder.”4 Patients with major neurocognitive disorder experience a significant cognitive decline that is significant enough to interfere with independence in instrumental activities of daily living (IADLs), but this decline cannot be wholly due to delirium or another mental disorder, such as schizophrenia.

Based on its etiology, dementia can be classified as degenerative, vascular, or other. The major dementia syndromes in older adults include: Alzheimer's disease (AD), vascular dementia (VaD), frontotemporal dementia (FTD), dementia with Lewy bodies (DLB), Parkinson's disease with dementia (PDD), and dementia of mixed etiology.5 In AD, FTD, DLB, and PDD, abnormal deposits that accumulate in the brain are believed to contribute to deterioration of brain function and dementia (amyloid plaques, neurofibrillary tangles, Lewy bodies).6 Other neuropathological changes associated with dementia include: cortical atrophy, hemorrhages, small-vessel disease, and neural and white matter loss.7 The exact etiological mechanisms for many types of dementia (e.g., AD, FTD, DLB, and PDD), however, have not been clearly defined.8 For example, amyloid plaques and Lewy bodies found during brain autopsy are associated with AD and DLB or PDD, respectively. These pathological findings, however, are not always consistent with premorbid clinical diagnoses.9 Other causes of cognitive impairment can include depression, alcohol abuse, medications (e.g., antihistamines, anticholinergics), metabolic disorders (e.g., thyroid disorders), intracranial tumors, normal pressure hydrocephalus, subdural hematomas, infections (e.g., HIV, prion diseases), traumatic brain or anoxic injury, and rare neurodegenerative disorders (e.g., Huntington's disease, progressive supranuclear palsy).10,11

MCI is distinguished from dementia in that cognitive impairment is not severe enough to interfere with independence in daily life (e.g., IADLs). Researchers describe this condition using various terminology that includes differences in diagnostic criteria and underlying constructs, such as MCI, cognitive impairment no dementia (CIND), age-related cognitive decline (ARCD), mild neurocognitive disorder, and mild cognitive disorder.12 The International Working Group on Mild Cognitive Impairment established the current, and perhaps most commonly used, criteria for MCI as: cognitive decline as evidenced by self and/or informant and/or clinician report and impairment on objective cognitive tasks, and/or evidence of decline over time on objective tasks; preserved basic activities of daily living (ADLs) (or minimal impairment in complex instrumental functions); and does not meet DSM-IV, ICD-10 criteria for a dementia syndrome.13 This definition contrasts with earlier working definitions, most commonly the definition Petersen and colleagues developed in 1999 (which focused on amnestic MCI): memory complaint (corroborated by an informant), memory impairment on objective testing, normal performance in nonmemory cognitive domains, preserved ADLs, and no dementia.14,15 While the exact definition of MCI is evolving, experts in this field have proposed several subtypes, including amnestic and nonamnestic MCI, as well as single- or multidomain MCI.16-18 MCI is thought to be an intermediate phase between normal cognition and dementia.18 The proposed changes to DSM-V introduce “mild neurocognitive disorder,” which subsumes MCI and other related entities such as CIND and ARCD. Mild neurocognitive disorder is characterized by cognitive impairment that, while not severe enough to interfere with IADLs, may require compensatory strategies.4

### Prevalence and Burden of Disease

#### Dementia

While the exact prevalence of dementia is unknown, we know that dementia is a common and costly condition. Researchers estimate that dementia affects between 2.4 to 5.5 million Americans.5,7,19 By 2050, the prevalence of AD is projected to be 13.8 million people in the United States, with approximately 1 million new cases a year.20 The estimated total health, long-term, and hospice care costs for dementia in the United States were $200 billion in 2012. Medicare and Medicaid pays approximately 70 percent of these costs, representing $140 billion. These costs do not include the estimated $210 billion in uncompensated care that informal caregivers provide anually.20

The prevalence of dementia is strongly related to increasing age. Attempts to provide prevalence estimates have arrived at slightly different estimates. Data from large population-based surveys indicate that the prevalence of dementia in the United States is 5 percent in individuals ages 71 to 79 years, rising to 24 percent at ages 80 to 89 years, and 37 percent in those older than age 90 years.5 These prevalence estimates, however, are highly dependent on the methods and operational criteria used for diagnosis.21 An international Delphi consensus and review of published dementia prevalence studies estimated mean prevalence in the United States and Canada at 0.8 percent (standard deviation [SD], 0.1) in individuals ages 60 to 64 years, 1.7 percent (SD, 0.1) in individuals ages 65 to 69 years, 3.3 percent (SD, 0.3) in individuals ages 70 to 74 years, 6.5 percent (SD, 0.5) in individuals ages 75 to 79 years, 12.8 percent (SD, 0.5) in individuals ages 80 to 84 years, and 30.1 percent (SD, 1.1) in individuals age 85 years or older.22

The prevalence of dementia also varies by race and ethnicity. A recent population-based study found the prevalence of dementia in adults age 71 years and older was 21.3 percent for blacks compared with 11.2 percent for whites.23 Dementia also affects more women than men. In individuals age 71 years and older, approximately 16 percent of women have dementia compared with 11 percent of men.20 Although research has revealed significant differences in the prevalence of dementia based on sex,5 this difference is not seen in incidence rates. These differences are primarily explained by women's longer life expectancy rather than any sex-based risk factors.20AD accounts for between 60 to 80 percent of all dementia, while FTD accounts for 12 to 25 percent, 10 to 20 percent are considered VaD, 5 to 10 percent are DLB, and between 10 to 30 percent are dementia with mixed etiologies.5,19,24 The proportions of dementia caused by each of these etiologies, however, varies widely between studies due to differences in diagnostic criteria, study setting, and age of participants. One systematic review of the etiology of dementia identified 39 studies, a third of which included community-based populations.25 This review found AD accounted for 56.3 percent of cases, followed by VaD (20.3%) and mixed etiologies (6.2%). Other causes were much less common and included PDD (1.6%), metabolic (1.1%), intracranial tumors (1.1%), normal pressure hydrocephalus (1.0%), depression (0.9%), alcohol abuse (0.6%), subdural hematoma (0.3%), infections (0.3%), trauma (0.2%), anoxic brain injury (0.2%), medications (0.1%), and Huntington's disease (0.1%).25 About 4 percent of dementia cases in nine of the 12 community-based studies included in that review were due to potentially reversible causes. Actual reversal of symptoms, however, occurred in much smaller proportions. Indeed, only 0.6 percent of dementia cases actually reversed to normal cognition in studies that reported followup.25 Reversible causes of dementia may occur more frequently in younger patients, those with more recent onset of symptoms, and those with mild symptoms.

While AD is the single most common type of dementia overall, its prevalence varies across ethnic groups. Studies have found that the prevalence of AD in elderly blacks is roughly double (10.5% vs. 5.4%) the prevalence in nonHispanic whites.26 The prevalence of AD in Hispanics is approximately 1.5 times that observed in the white population.23,27,28 Epidemiological data suggests that certain risk factors are more common in blacks and Hispanics than whites, such as hypertension, coronary artery disease, and stroke, which may account for some of the racial disparities observed in AD.27 There is little consensus, however, on the cause for observed disparities in prevalence.

#### MCI

The prevalence of MCI is even more difficult to ascertain due to between-study differences in sampling and methods of clinical assessment. Available studies also have important differences in the criteria used to define the condition.29 Varying definitions and terminology (e.g., MCI, CIND, ARCD) hinders our ability to estimate the true prevalence of cognitive impairment without functional limitations. These estimates range widely from 3 to 42 percent in adults age 65 years and older and vary depending on the population and diagnostic criteria used.29,30 One systematic review that included 35 population-based studies found the median prevalence was 4.9 percent (range, 0.5% to 31.9%) for amnestic MCI, 26.4 percent (range, 3% to 42%) for MCI, 20.6 percent (range, 5.1% to 35.9%) for CIND, and 15.6 percent (range, 3.6% to 38.4%) for age-associated memory impairment, across a broad age range of older adults.30 While the prevalence of MCI and CIND appear to increase with age,30 these studies did not identify a consistent relationship with age across different definitions.29,30 Likewise, these studies found no consistent relationship between MCI and sex, race/ethnicity, or education.29,30

### Natural History

#### Dementia

The most common types of dementia are irreversible and usually progressive, including AD, FTD, VaD, and DLB. Early stages of dementia generally affect IADLs along with the ability to learn and retain new information. As dementia progresses, patients are unable to carry out basic ADLs.31,32 The onset and progression of dementia is highly variable and depends on the etiology or type. The median survival time from diagnosis of dementia is estimated to range from 4.5 to 6.7 years, although this varies by how onset of disease is defined, the degree of impairment at diagnosis, age at diagnosis, and the type of dementia.33,34 For example, median survival time for AD is thought to be longer than for FTD; some patients can live as long as 20 years with AD.20,35-37 The rate of progression of cognitive decline also varies with the type of dementia. Patients with AD, for example, can experience a decline of 2 points or less per year on the Mini Mental State Examination (MMSE), whereas the decline in those with other types of dementia can be somewhat more rapid (e.g., decline of 2 to 4 MMSE points annually).38 The rate of decline, however, can also depend on the stage of disease, and patients may experience an accelerated rate of decline as their disease progresses.39,40 In addition to cognitive decline, neuropsychiatric symptoms can also accompany dementia, such as psychotic symptoms (e.g., delusions, paranoia, and hallucinations), depressive symptoms, apathy, and agitation or aggression, as well as personality changes.6 Neuropsychiatric symptoms can occur with any type of dementia, although different neuropsychiatric symptoms are more common with specific types. FTD, for example, is commonly associated with euphoria or disinhibition, whereas PDD and DLB are commonly associated with hallucinations.41-44

#### MCI

MCI may have some clinical utility for predicting later dementia. While the level of cognition remains stable over time in the majority of individuals with MCI, smaller proportions will experience either a return to normal cognition or worsening cognition, resulting in functional impairment and progression to dementia. The rates of stability, progression, and regression of MCI vary markedly between studies. Again, this variation likely reflects the complex underlying pathology, differences in diagnostic criteria, and differences in population settings and participants. Variations in diagnostic criteria have real implications for understanding the natural history of MCI. For example, the 1999 Petersen criteria define MCI as amnestic MCI versus broader criteria which include amnestic and nonamnestic, along with single- and multidomain dementia. This distinction is important because amnestic MCI is more likely to represent underlying AD or a similar condition and therefore progress to dementia. Likewise, multidomain MCI is more likely to progress to dementia.45 Single-domain MCI is often a precursor of multidomain MCI; therefore, single-domain impairment may be the earliest detectable stage of a progressive condition, but also more likely to revert to normal.45-47 Differences in populations also have implications on understanding the natural history of MCI. There is a selection bias of people with MCI in clinical studies as opposed to community-based studies. People seeking care for mild cognitive deficits, for example, may be more likely to have an underlying dementia disease, fewer comorbid conditions, more behavioral symptoms, or be at a later/more severe stage of disease.48

A recent systematic review of 41 cohort studies examining the progression from MCI to dementia provides strong evidence that individuals with MCI have a much greater risk of progressing to dementia compared with individuals with normal cognition.17 In a subset of five studies, the annual conversion rate to dementia over a mean followup of 6.0 years was 3.6 percent for individuals with MCI compared with 0.43 percent for healthy subjects (relative risk [RR], 13.8 [95% CI, 8.44 to 22.6]). Overall, the annual rate of progression from MCI to dementia in community settings (adjusted for sample size and dementia type) was 4.9 percent (95% CI, 1.6 to 9.9). The adjusted rate from MCI to AD was 6.8 percent (95% CI, 1.9 to 14.5) and 1.6 percent (95% CI, 0.3 to 9.4) from MCI to VaD.17 Studies using different definitions of MCI found similar rates of progression. The cumulative rate of progression for MCI to dementia was 22 to 40 percent in these studies, which had mean study periods of 5 to 10 years. Despite these rates of progression, MCI may also regress to normal cognition over time in 10 to 40 percent of individuals with MCI.45,49,50 Additionally, patients who revert to normal cognition may also later progress to dementia, which complicates these progression estimates.51 Although several population-based studies have noted an increased risk of mortality in people with MCI compared with those with normal cognition,52-56 the literature is not consistent because other studies have found no associated increase in mortality.57,58

### Risk Factors for Cognitive Decline and Factors Associated With the Reduction of Risk of Cognitive Decline in Older Adults

Increasing age is the strongest known risk factor for cognitive decline in general and for AD specifically.19 Other risk factors for cognitive decline and dementia have been proposed, however, and each carries with it a varying evidence for strength of association. The ɛ4 allele of the lipoprotein E gene has good observational evidence in whites (and Asians) as a risk factor for AD.59 Other risk factors for cognitive decline or dementia with lower-quality observational evidence include cardiovascular risk factors (e.g., diabetes, tobacco use, hypercholesterolemia, hypertension, metabolic syndrome, obesity), depression, physical frailty, low educational level, low social support, and having never been married.59-62

In contrast, several dietary and lifestyle factors have been associated with a decreased risk of dementia, including adequate folic acid intake, low saturated fat and longer-chain omega-3 fatty acids intake, high fruit and vegetable intake, Mediterranean diet, moderate alcohol intake, educational attainment, cognitive engagement, and participation in physical activity.59,62-65 It is important to note, however, that the evidence supporting these associations is weaker than the evidence for the factors that are associated with increased risk of dementia.

### Rationale for Screening in Older Adults

Primary care clinicians may fail to recognize cognitive impairment during clinic visits using routine history and physical examination.19,66 As many as 29 to 76 percent of patients with dementia or probable dementia are not diagnosed by primary care physicians.67-69 Moreover, the sensitivity of a clinician's diagnosis appears to be strongly related to dementia severity.70 Because of this, most people with dementia are not diagnosed until they are at moderate to severe stages of the disease. Therefore, screening tests in all or targeted older adults may help identify patients with dementia or MCI who are otherwise missed. Early identification of cognitive impairment would ideally allow patients and their families to receive care at an earlier stage in the disease process, leading to improved prognosis and decreased morbidity.

Early identification of cognitive impairment potentially facilitates discussions regarding decisionmaking (e.g., health care, financial, or legal) while the patient still retains decisionmaking capacity. Clinical experts and researchers have suggested that the health, psychological, and social benefits from early recognition of dementia include: early education of caregivers on how to manage the patient; advanced planning (e.g., establishing a will, health care proxy, power of attorney, advanced directives, timely discussion of care transitions and appropriate placement options); reduced patient and family anxiety and stress, as well as reduced caregiver burden, blame, and denial; patient safety (e.g., monitoring driving, medication compliance, cooking); and promotion of advocacy for research and treatment development.71

Knowledge of the patient's cognitive status is important for the management of comorbid conditions. Nearly all older adults with cognitive impairment have one or more serious comorbid conditions and take multiple medications.72 Cognitive impairment can affect the management of these comorbid conditions and may lead to worsened outcomes of the comorbid conditions. Cognitive impairment may lead patients to report symptoms and health behaviors inaccurately, may decrease their ability to consent to treatments, may make medication adherence challenging, and may make followup of chronic conditions sporadic or nonexistent. Medication management of comorbid conditions may pose higher risks in people with cognitive impairment. Treating incontinence with anticholinergic medications, for example, can worsen cognition, as can treatment of chronic pain with opioids or tricyclic antidepressants.73 In addition, cognitive impairment may limit quality of life and life expectancy in patients with other chronic conditions, which makes patients less likely to realize a benefit and more likely to realize harm from aggressive or invasive treatments.74,75 These benefits of early diagnosis may make screening valuable even if it is unclear whether early treatment alters the natural history of dementia by preventing or slowing the rate of cognitive decline.59

Clinicians can employ many different brief cognitive screening instruments in primary care. Instruments that take 10 minutes or less to administer, for example, may include: the MMSE, Clock Draw Test (CDT), Mini-Cog, St. Louis University Mental Status Exam (SLUMS), Abbreviated Mental Test (AMT), Blessed Orientation Memory Test, General Practitioner Assessment of Cognition (GPCOG), Short Portable Mental Status Questionnaire (SPMSQ), and Montreal Cognitive Assessment (MoCA).19,76-80 In addition to brief tests, more extensive screening and diagnostic instruments are available for use in secondary care or other settings, although their longer administration time (10 to 45 minutes) render them infeasible for use in primary care.81

### Diagnostic Workup of Cognitive Impairment

These brief cognitive tests are generally not diagnostic of dementia or MCI. A positive screening test triggers subsequent diagnostic testing that assesses the level and possible etiology of cognitive impairment. In addition to a more detailed and focused clinical history and physical examination, this diagnostic workup may also include more comprehensive cognitive and functional assessments (e.g., neuropsychological testing or clinical evaluation by a trained clinician), laboratory tests to identify potentially reversible causes of dementia due to treatable underlying disorders (e.g., hypothyroidism, vitamin B12 deficiency), and sometimes structural and functional imaging of the brain (e.g., computed tomography [CT], magnetic resonance imaging [MRI], single-photon emission CT, and positron emission tomography [PET]).82 Neuropsychological testing involves a detailed evaluation of each of the multiple cognitive domains. A diagnosis of dementia requires that the patient has developed requisite cognitive deficits (impairments in learning and memory, language, or visuospatial or executive function), which can be established with specific tests and interpreted relative to appropriate norms. The American Academy of Neurology (AAN) recommends screening for B12 deficiency and hypothyroidism and neuroimaging with noncontrast head CT or MRI in all patients with dementia.83 Currently, however, there is no evidence to support or refute routine laboratory testing or neuroimaging as part of the routine diagnostic workup of cognitive impairment. As a result, each individual's clinical presentation should guide further testing. Genetic testing for autosomal dominant genes for AD (APP, PS1, PS2) are appropriate only in early-onset familial cases. Genetic testing for APOEɛ4 allele has been studied as a susceptibility marker and is not useful in the diagnostic workup of cognitive impairment.

Additional diagnostic tools are currently in development.84,85 Cerebrospinal fluid (CSF) and plasma and urine biomarkers (e.g., amyloid beta peptides, tau, and molecular markers) to diagnose AD and other types of dementia are still at the discovery stage or undergoing initial validation for use in early dementia or MCI.86 Recent research shows promise for using plasma biomarkers to screen for different types of dementia, with model predictions showing sensitivity and specificity of up to 80 and 90 percent, respectively.87,88 Imaging techniques, such as MRI, diffusion tensor imaging, CT, magnetic resonance spectroscopy, and PET scans are also being evaluated to aid in the diagnostic workup of dementia or MCI.89-92 None of these biomarker or imaging tools have been evaluated for screening purposes.

### Interventions and Treatments for Cognitive Impairment

Treatment for cognitive impairment seeks to improve quality of life and maximize functional performance by addressing cognitive, mood, and behavioral impairments,82 as well as to treat any modifiable or reversible causes of impairment.

#### Interventions Aimed at Cognitive Decline

There are multiple pharmacologic and nonpharmacologic interventions aimed at (permanently or temporarily) preventing, slowing, or reversing cognitive decline in older adults. In support of a 2010 National Institutes of Health State of the Science Conference Statement on Preventing Alzheimer Disease and Cognitive Decline,93 Plassman and colleagues conducted a systematic review of factors associated with reduction of risk of cognitive decline and the net benefit of interventions to improve or maintain cognitive ability or function.59 The review found moderate- to high-quality evidence that treatment with vitamins (i.e., multivitamins, vitamins B6 and B12, folic acid, vitamins C and E, and beta-carotene), postmenopausal hormone replacement therapy, HMG-CoA reductase inhibitors, aspirin, dehydroepiandrosterone (DHEA), or acetylcholinesterase inhibitors (AChEIs) does not prevent cognitive decline in mild to moderate dementia.59 Another targeted review of U.S. Food and Drug Administration (FDA)-approved pharmacologic interventions for AD, in support of a joint American College of Physicians (ACP) and American Academy of Family Physicians (AAFP) clinical practice guideline, concluded that many of the statistically significant improvements in scores on various instruments to evaluate changes in patients with dementia were very small or had short durations of effect, so that these changes were not clinically important (or the clinical importance could not be determined).94

There is some evidence, however, that suggests that nonpharmacologic treatments decrease rates of cognitive decline. The systematic review by Plassman and colleagues identified high-quality evidence to support cognitive training, as well as observational evidence to suggest that lifestyle behaviors (e.g., Mediterranean diet, vegetable intake, omega-3 fatty acids, physical activity, and nonphysical leisure activity) were associated with a decreased rate of cognitive decline.59

#### Interventions to Improve Patient or Caregiver Quality of Life

Informal family caregivers provide about 80 percent of home care for people with dementia.95 Care for people with dementia can be difficult, and informal caregivers often have high levels of depression and stress. As a result, caregiving may lead to a negative impact on the caregiver's health and employment and the family's finances.20,96 Available evidence suggests that interventions to improve caregiver or dyad (patient and caregiver) quality of life may improve patient and caregiver outcomes. Two independently conducted systematic reviews, which included studies of psychosocial interventions aimed at caregivers of community-dwelling people with dementia, showed that some interventions can indeed reduce caregiver morbidity and delay institutionalization of people with dementia.97,98

#### Experimental Therapies

Available research has evaluated very few interventions specifically in people with MCI or mild (or earlier stage) dementia. Disease-modifying therapies to slow cognitive decline is an extremely active area of research, and promising therapies include: intravenous immunoglobulin (IVIG), growth hormone-releasing hormone (GHRH), and various immunotherapies targeting beta-amyloid.99-101

### Current Clinical Practice and Recommendations of Other Groups

Currently, diagnosis of dementia is initiated mostly based on a clinician's suspicion of patient symptoms or caregiver concerns.102 As many as 29 to 76 percent of patients with dementia or probable dementia, however, are not diagnosed by primary care physicians.67-69 Although no professional organizations explicitly recommend screening for dementia in asymptomatic adults, many groups (including the USPSTF, AAN, American Geriatrics Society, and European Federation of Neurological Societies) have recommended assessing the cognitive abilities of older adults who present with cognitive or cognitive-related functional complaints.1,82,83,103 The onset of dementia can be insidious and the early symptoms of dementia are extremely common, which could also contribute to the possible underdiagnosis of dementia. For example, about 40 to 50 percent of older adults report subjective memory complaints.70 Cognitive or cognitive-related functional complaints, however, may not be apparent during routine office visits unless they are directly assessed, and individuals with subjective memory complaints often have normal cognition when tested. Additionally, barriers that may contribute to missed or delayed diagnosis of dementia include: physician and patient lack of knowledge, physicians' concerns about overdiagnosis and labeling, lack of appropriate assessment tools, difficulty in communication of diagnosis, and the patient's refusal to be assessed for dementia, as well as time and financial constraints.70

In 2011, Medicare began covering the “detection of cognitive impairment” as a part of the new Annual Wellness Visit benefit, which was mandated by the Affordable Care Act.104 Currently, however, the recommendations issued by the Centers for Medicare and Medicaid Services (CMS) provide little guidance on recommended screening instruments or techniques, other than directing providers to use direct observation and consider information from informants.105 In 2013, the Alzheimer's Association published recommendations for operationalizing the detection of cognitive impairment during the Annual Wellness Visit, and recommended the use of a brief structured assessment (i.e., GPCOG, Mini-Cog, Memory Impairment Screen [MIS], AD8, or short Informant Questionnaire on Cognitive Decline in the Elderly [IQCODE]) if signs or symptoms of cognitive impairment are present upon review of a health risk assessment, through clinical observation or self-reported (patient or informant) concerns.106