# References Used in Appendixes

1 Lonie JA, Tierney KM, Ebmeier KP. Screening for mild cognitive impairment: a systematic review. Int J Geriatr Psychiatry. Sep. 2009;24(9):902-15. [pmid: 19226524].
2 Ehreke L, Luppa M, Konig HH, et al. Is the Clock Drawing Test a screening tool for the diagnosis of mild cognitive impairment? A systematic review. Int Psychogeriatr. Feb. 2010;22(1):56-63. [pmid: 19691908].
3 Mitchell AJ. A meta-analysis of the accuracy of the mini-mental state examination in the detection of dementia and mild cognitive impairment. J Psychiatr Res. Jan. 2009;43(4):411-31. [pmid: 18579155].
4 Holsinger T, Deveau J, Boustani M, et al. Does this patient have dementia?. JAMA. Jun. 6. 2007;297(21):2391-404. [pmid: 17551132].
5 Mitchell AJ, Malladi S. Screening and case finding tools for the detection of dementia. Part I: evidence-based meta-analysis of multidomain tests. Am J Geriatr Psychiatry. Sep. 2010;18(9):759-82. [pmid: 20808118].
6 Mitchell AJ, Malladi S. Screening and case-finding tools for the detection of dementia. Part II: evidence-based meta-analysis of single-domain tests. Am J Geriatr Psychiatry. Sep. 2010;18(9):783-800. [pmid: 20808094].
7 Kansagara D, Freeman M. A Systematic Evidence Review of the Signs and Symptoms of Dementia and Brief Cognitive Tests Available in VA. Washington, DC. Department of Veterans Affairs; Veterans Health Administration;Health Services Research & Development Service. 2010. [pmid: 21155200].
8 Castilla-Rilo J, Lopez-Arrieta J, Bermejo-Pareja F, et al. Instrumental activities of daily living in the screening of dementia in population studies: a systematic review and meta-analysis. Int J Geriatr Psychiatry. Sep. 2007;22(9):829-36. [pmid: 17236250].
9 Cherbuin N, Anstey KJ, Lipnicki DM. Screening for dementia: a review of self- and informant-assessment instruments. Int Psychogeriatr. Jun. 2008;20(3):431-58. [pmid: 18289452].
10 Milne A, Culverwell A, Guss R, et al. Screening for dementia in primary care: a review of the use, efficacy and quality of measures. Int Psychogeriatr. Oct. 2008;20(5):911-26. [pmid: 18533066].
11 McGuinness B, O'Hare J, Craig D, et al. Statins for the treatment of dementia. Cochrane Database of Systematic Reviews. 2010;(8).
12 Plassman BL, Williams JW Jr., Burke JR, et al. Systematic review: factors associated with risk for and possible prevention of cognitive decline in later life. Ann Intern Med. Aug. 3. 2010;153(3):182-93. [pmid: 20547887].
13 Shah K, Qureshi SU, Johnson M, et al. Does use of antihypertensive drugs affect the incidence or progression of dementia? A systematic review. Am J Geriatr Pharmacother. Oct. 2009;7(5):250-61. [pmid: 19948301].
14 Langa KM, Foster NL, Larson EB. Mixed dementia: emerging concepts and therapeutic implications. JAMA. Dec. 15. 2004;292(23):2901-8. [pmid: 15598922].
15 Rands G, Orrell M, Spector AE. Aspirin for vascular dementia. Cochrane Database Sys Rev. 2000;(4):CD001296. [pmid: 11034710].
16 Tabet N, Feldman H. Ibuprofen for Alzheimer's disease. Cochrane Database Sys Rev. 2003;(2):CD004031. [pmid: 12804498].
17 Tabet N, Feldman H. Indomethacin for Alzheimer's disease. Cochrane Database Sys Rev. 2002;(2):CD003673. [pmid: 12076498].
18 Hogervorst E, Yaffe K, Richards M, et al. Hormone replacement therapy to maintain cognitive function in women with dementia. Cochrane Database Sys Rev. 2009;(1):CD003799. [pmid: 19160224].
19 Raina P, Santaguida P, Ismaila A, et al. Effectiveness of cholinesterase inhibitors and memantine for treating dementia: evidence review for a clinical practice guideline. Ann Intern Med. Mar. 4. 2008;148(5):379-97. [pmid: 18316756].
20 Malouf R, Grimley EJ. The effect of vitamin B6 on cognition. Cochrane Database Syst Rev. 2003;(4):CD004393. [pmid: 14584010].
21 Malouf R, Areosa SA. Vitamin B12 for cognition. Cochrane Database Syst Rev. 2003;(3):CD004326. [pmid: 12918012].
22 Malouf R, Grimley EJ. Folic acid with or without vitamin B12 for the prevention and treatment of healthy elderly and demented people. Cochrane Database of Systematic Reviews. 2008;(4).
23 Balk E, Chung M, Raman G, et al. B-vitamins and Berries and Age-Related Neurodegenerative Disorders. AHRQ Publication No. 06-E008. Rockville, MD. Agency for Healthcare Research and Quality. 2006. [pmid: 17628125].
24 Jia X, McNeill G, Avenell A. Does taking vitamin, mineral and fatty acid supplements prevent cognitive decline? A systematic review of randomized controlled trials. J Hum Nutr Diet. Aug. 2008;21(4):317-36. [pmid: 18721399].
25 Wald DS, Kasturiratne A, Simmonds M. Effect of folic acid, with or without other B vitamins, on cognitive decline: meta-analysis of randomized trials. Am J Med. Jun. 2010;123(6):522-7. [pmid: 20569758].
26 Dangour AD, Whitehouse PJ, Rafferty K, et al. B-vitamins and fatty acids in the prevention and treatment of Alzheimer's disease and dementia: a systematic review. J Alzheimers Dis. 2010;22(1):205-24. [pmid: 20847412].
27 Isaac MG, Quinn R, Tabet N. Vitamin E for Alzheimer's disease and mild cognitive impairment. Cochrane Database Syst Rev. 2008;(3):CD002854. [pmid: 18646084].
28 Boothby LA, Doering PL. Vitamin C and vitamin E for Alzheimer's disease. Ann Pharmacother. Dec. 2005;39(12):2073-80. [pmid: 16227450].
29 Issa AM, Mojica WA, Morton SC, et al. The efficacy of omega-3 fatty acids on cognitive function in aging and dementia: a systematic review. Dement Geriatr Cogn Disord. 2006;21(2):88-96. [pmid: 16340205].
30 Maclean CH, Issa AM, Newberry SJ, et al. Effects of omega-3 fatty acids on cognitive function with aging, dementia, and neurological diseases. Evid Rep Technol Assess (Summ). Feb. 2005;(114):1-3. [pmid: 15777112].
31 van Uffelen JG, Chin APM, Hopman-Rock M, et al. The effects of exercise on cognition in older adults with and without cognitive decline: a systematic review. Clin J Sport Med. Nov. 2008;18(6):486-500. [pmid: 19001882].
32 Forbes D, Forbes S, Morgan DG, et al. Physical activity programs for persons with dementia. [Review] [65 refs]. Cochrane Database of Systematic Reviews. 2008;(3):CD006489. [pmid: 18646158].
33 Olazaran J, Reisberg B, Clare L, et al. Nonpharmacological therapies in Alzheimer's disease: a systematic review of efficacy. Dement Geriatr Cogn Disord. 2010;30(2):161-78. [pmid: 20838046].
34 Bates J, Boote J, Beverley C. Psychosocial interventions for people with a milder dementing illness: a systematic review. J Adv Nurs. Mar. 2004;45(6):644-58. [pmid: 15012642].
35 Brodaty H, Green A, Koschera A. Meta-analysis of psychosocial interventions for caregivers of people with dementia. J Am Geriatr Soc. 2003;51(5):657-64. [pmid: 12752841].
36 Lee H, Cameron MH. Respite care for people with dementia and their carers. Cochrane Database Sys Rev. 2004;(1):CD004396. [pmid: 15106250].
37 Chien LY, Chu H, Guo JL, et al. Caregiver support groups in patients with dementia: a meta-analysis. Int J Geriatr Psychiatry. 2011. Feb. 9. [pmid: 21308785].
38 Cooper C, Balamurali TB, Selwood A, et al. A systematic review of intervention studies about anxiety in caregivers of people with dementia. Int J Geriatr Psychiatry. Mar. 2007;22(3):181-8. [pmid: 17006872].
39 Schoenmakers B, Buntinx F, DeLepeleire J. Supporting the dementia family caregiver: The effect of home care intervention on general well-being. Aging Ment Health. 2010;14(1):44-56. [pmid: 20155520].
40 Selwood A, Johnston K, Katona C, et al. Systematic review of the effect of psychological interventions on family caregivers of people with dementia. J Affect Disord. Aug. 2007;101(1-3):75-89. [pmid: 17173977].
41 Smits CH, de LJ, Droes RM, et al. Effects of combined intervention programmes for people with dementia living at home and their caregivers: a systematic review. Int J Geriatr Psychiatry. 2007;22(12):1181-93. [pmid: 17457793].
42 Thompson CA, Spilsbury K, Hall J, et al. Systematic review of information and support interventions for caregivers of people with dementia. BMC Geriatrics. 2007;7(18). [pmid: 17662119].
43 Pinquart M, Sorensen S. Helping caregivers of persons with dementia: which interventions work and how large are their effects?. Int Psychogeriatr. Dec. 2006;18(4):577-95. [pmid: 16686964].
44 Jean L, Bergeron ME, Thivierge S, et al. Cognitive intervention programs for individuals with mild cognitive impairment: systematic review of the literature. Am J Geriatr Psychiatry. Apr. 2010;18(4):281-96. [pmid: 20220584].
45 Frank W, Konta B. Cognitive training for dementia. GMS Health Technol Assess. 2005;1:1-10. [pmid: 21289931].
46 Pimouguet C, Lavaud T, Dartigues JF, et al. Dementia case management effectiveness on health care costs and resource utilization: a systematic review of randomized controlled trials. J Nutr Health Aging. Oct. 2010;14(8):669-76. [pmid: 20922344].
47 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
48 National Institute for Health and Clinical Excellence. The guidelines manual. London. National Institute for Health and Clinical Excellence. 2006.
49 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
50 Ball LJ, Ogden A, Mandi D, et al. The validation of a mailed health survey for screening of dementia of the Alzheimer's type. J Am Geriatr Soc. Jun. 2001;49(6):798-802. [pmid: 11454121].
51 Del Ser T, Sanchez-Sanchez F, Garcia de Yebenes MJ, et al. Validation of the seven-minute screen neurocognitive battery for the diagnosis of dementia in a Spanish population-based sample. Dement Geriatr Cogn Disord. 2006;22(5-6):454-64. [pmid: 16988506].
52 Fuchs A, Wiese B, Altiner A, et al. Cued Recall and Other Cognitive Tasks to Facilitate Dementia Recognition in Primary Care. J Am Geriatr Soc. 2012. Jan. [pmid: 22150245].
53 Grober E, Hall C, McGinn M, et al. Neuropsychological strategies for detecting early dementia. J Int Neuropsychol Soc. Jan. 2008;14(1):130-42. [pmid: 18078539].
54 Kirby M, Denihan A, Bruce I, et al. The clock drawing test in primary care: sensitivity in dementia detection and specificity against normal and depressed elderly. Int J Geriatr Psychiatry. Oct. 2001;16(10):935-40. [pmid: 11607936].
55 Lavery LL, Lu SY, Chang CC, et al. Cognitive assessment of older primary care patients with and without memory complaints. J Gen Intern Med. Jul. 2007;22(7):949-54. [pmid: 17453265].
56 Wolf-Klein GP, Silverstone FA, Levy AP, et al. Screening for Alzheimer's disease by clock drawing. J Am Geriatr Soc. Aug. 1989;37(8):730-4. [pmid: 2754158].
57 Borson S, Scanlan JM, Watanabe J, et al. Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. Apr. 2006;21(4):349-55. [pmid: 16534774].
58 Holsinger T, Plassman BL, Stechuchak KM, et al. Screening for Cognitive Impairment: Comparing the Performance of Four Instruments in Primary Care. J Am Geriatr Soc. May. 30. 2012;60(6):1027-36. [pmid: 22646750].
59 Kaufer DI, Williams CS, Braaten AJ, et al. Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. Oct. 2008;9(8):586-93. [pmid: 19083293].
60 Buschke H, Kuslansky G, Katz M, et al. Screening for dementia with the memory impairment screen. Neurology. Jan. 15. 1999;52(2):231-8. [pmid: 9932936].
61 Kuslansky G, Buschke H, Katz M, et al. Screening for Alzheimer's disease: the memory impairment screen versus the conventional three-word memory test. J Am Geriatr Soc. Jun. 2002;50(6):1086-91. [pmid: 12110070].
62 Lipton RB, Katz MJ, Kuslansky G, et al. Screening for dementia by telephone using the memory impairment screen. J Am Geriatr Soc. Oct. 2003;51(10):1382-90. [pmid: 14511157].
63 Erkinjuntti T, Sulkava R, Wikstrom J, et al. Short Portable Mental Status Questionnaire as a screening test for dementia and delirium among the elderly. J Am Geriatr Soc. May. 1987;35(5):412-6. [pmid: 3571790].
64 Fillenbaum G, Heyman A, Williams K, et al. Sensitivity and specificity of standardized screens of cognitive impairment and dementia among elderly black and white community residents. J Clin Epidemiol. 1990;43(7):651-60. [pmid: 2370572].
65 Hooijer C, Dinkgreve M, Jonker C, et al. Short screening tests for dementia in the elderly population. I. A comparison between AMTS, MMSE, MSQ and SPMSQ. Int J Geriatr Psychiatry. 1992;7(8):559-71.
66 Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. Jun. 1998;13(6):368-80. [pmid: 9658272].
67 Callahan CM, Unverzagt FW, Hui SL, et al. Six-item screener to identify cognitive impairment among potential subjects for clinical research. Med Care. Sep. 2002;40(9):771-81. [pmid: 12218768].
68 Fong TG, Jones RN, Rudolph JL, et al. Development and validation of a brief cognitive assessment tool: the sweet 16. Arch Intern Med. Mar. 14. 2011;171(5):432-7. [pmid: 21059967].
69 Brodaty H, Pond D, Kemp NM, et al. The GPCOG: a new screening test for dementia designed for general practice. J Am Geriatr Soc. Mar. 2002;50(3):530-4. [pmid: 11943052].
70 Juva K, Makela M, Erkinjuntti T, et al. Functional assessment scales in detecting dementia. Age Ageing. Sep. 1997;26(5):393-400. [pmid: 9351484].
71 Cruz-Orduna I, Bellon JM, Torrero P, et al. Detecting MCI and dementia in primary care: efficiency of the MMS, the FAQ and the IQCODE. Fam Pract. Aug. 2012;29(4):401-6. [pmid: 22121012].
72 Rait G, Morley M, Burns A, et al. Screening for cognitive impairment in older African-Caribbeans. Psychol Med. Jul. 2000;30(4):957-63. [pmid: 11037103].
73 Rait G, Burns A, Baldwin R, et al. Validating screening instruments for cognitive impairment in older South Asians in the United Kingdom. Int J Geriatr Psychiatry. Jan. 2000;15(1):54-62. [pmid: 10637405].
74 Solomon PR, Brush M, Calvo V, et al. Identifying dementia in the primary care practice. Int Psychogeriatr. Dec. 2000;12(4):483-93. [pmid: 11263715].
75 Manly JJ, Schupf N, Stern Y, et al. Telephone-based identification of mild cognitive impairment and dementia in a multicultural cohort. Arch Neurol. May. 2011;68(5):607-14. [pmid: 21555635].
76 Cullen B, Fahy S, Cunningham CJ, et al. Screening for dementia in an Irish community sample using MMSE: a comparison of norm-adjusted versus fixed cut-points. Int J Geriatr Psychiatry. Apr. 2005;20(4):371-6. [pmid: 15799072].
77 Gagnon M, Letenneur L, Dartigues JF, et al. Validity of the Mini-Mental State examination as a screening instrument for cognitive impairment and dementia in French elderly community residents. Neuroepidemiology. 1990;9(3):143-50. [pmid: 2402325].
78 Grut M, Fratiglioni L, Viitanen M, et al. Accuracy of the Mini-Mental Status Examination as a screening test for dementia in a Swedish elderly population. Acta Neurol Scand. Apr. 1993;87(4):312-7. [pmid: 8503262].
79 Jeong SK, Cho KH, Kim JM. The usefulness of the Korean version of modified Mini-Mental State Examination (K-mMMSE) for dementia screening in community dwelling elderly people. BMC Public Health. Jul. 30. 2004;4:31. [pmid: 15283869].
80 Jorm AF, Broe GA, Creasy H, et al. Further data on the validity of the informant questionnaire on cognitive decline in the elderly (IQCODE). Int J Geriatr Psychiatry. 1996;11(2):131-9.
81 Kahle-Wrobleski K, Corrada MM, Li B, et al. Sensitivity and specificity of the mini-mental state examination for identifying dementia in the oldest-old: the 90+ study. J Am Geriatr Soc. Feb. 2007;55(2):284-9. [pmid: 17302668].
82 Kay DW, Henderson AS, Scott R, et al. Dementia and depression among the elderly living in the Hobart community: the effect of the diagnostic criteria on the prevalence rates. Psychol Med. Nov. 1985;15(4):771-88. [pmid: 4080881].
83 Lam LC, Tam CW, Lui VW, et al. Screening of mild cognitive impairment in Chinese older adults--a multistage validation of the Chinese abbreviated mild cognitive impairment test. Neuroepidemiology. 2008;30(1):6-12. [pmid: 18204291].
84 McDowell I, Kristjansson B, Hill GB, et al. Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini-Mental State Exam (3MS) compared. J Clin Epidemiol. Apr. 1997;50(4):377-83. [pmid: 9179095].
85 Morales JM, Bermejo F, Romero M, et al. Screening of dementia in community-dwelling elderly through informant report. Int J Geriatr Psychiatry. Aug. 1997;12(8):808-16. [pmid: 9283925].
86 Reischies FM, Geiselmann B. Age-related cognitive decline and vision impairment affecting the detection of dementia syndrome in old age. Br J Psychiatry. Nov. 1997;171:449-51. [pmid: 9463604].
87 Scharre DW, Chang SI, Murden RA, et al. Self-administered Gerocognitive Examination (SAGE): a brief cognitive assessment Instrument for mild cognitive impairment (MCI) and early dementia. Alzheimer Dis Assoc Disord. Jan. 2010;24(1):64-71. [pmid: 20220323].
88 Waite LM, Broe GA, Casey B, et al. Screening for Dementia Using an Informant Interview. Aging Neuropsychol Cogn. Sep. 1. 1998;5(3):194-202.
89 Markwick A, Zamboni G, de Jager CA. Profiles of cognitive subtest impairment in the Montreal Cognitive Assessment (MoCA) in a research cohort with normal Mini-Mental State Examination (MMSE) scores. [References]. J Clin Exp Neuropsychol. 2012;34(7):750-7. [pmid: 22468719].
90 Tokuhara KG, Valcour VG, Masaki KH, et al. Utility of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) for dementia in a Japanese-American population. Hawaii Med J. Mar. 2006;65(3):72-5. [pmid: 16724448].
91 Swearer JM, Drachman DA, Li L, et al. Screening for dementia in “real world” settings: the cognitive assessment screening test: CAST. Clin Neuropsychol. May. 2002;16(2):128-35. [pmid: 12221476].
92 Donnelly K, Donnelly JP, Cory E. Primary care screening for cognitive impairment in elderly veterans. Am J Alzheimers Dis Other Demen. Jun. 2008;23(3):218-26. [pmid: 18375531].
93 Ehreke L, Luppa M, Luck T, et al. Is the clock drawing test appropriate for screening for mild cognitive impairment?--Results of the German study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Dement Geriatr Cogn Disord. 2009;28(4):365-72. [pmid: 19887799].
94 Ehreke L, Luck T, Luppa M, et al. Clock drawing test - screening utility for mild cognitive impairment according to different scoring systems: results of the Leipzig Longitudinal Study of the Aged (LEILA 75+). Int Psychogeriatr. Dec. 2011;23(10):1592-601. [pmid: 21813037].
95 Lee KS, Kim EA, Hong CH, et al. Clock drawing test in mild cognitive impairment: quantitative analysis of four scoring methods and qualitative analysis. Dement Geriatr Cogn Disord. 2008;26(6):483-9. [pmid: 18987468].
96 Ayalon L. The IQCODE Versus a Single-Item Informant Measure to Discriminate Between Cognitively Intact Individuals and Individuals With Dementia or Cognitive Impairment. J Geriatr Psychiatry Neurol. Sep. 2011;24(3):168-73. [pmid: 21856971].
97 Li M, Ng TP, Kua EH, et al. Brief informant screening test for mild cognitive impairment and early Alzheimer's disease. Dement Geriatr Cogn Disord. 2006;21(5-6):392-402. [pmid: 16645272].
98 Cook SE, Marsiske M, McCoy KJ. The use of the Modified Telephone Interview for Cognitive Status (TICS-M) in the detection of amnestic mild cognitive impairment. J Geriatr Psychiatry Neurol. Jun. 2009;22(2):103-9. [pmid: 19417219].
99 Rideaux T, Beaudreau SA, Fernandez S, et al. Utility of the abbreviated Fuld Object Memory Evaluation and MMSE for detection of dementia and cognitive impairment not dementia in diverse ethnic groups. J Alzheimers Dis. 2012;31(2):371-86. [pmid: 22555374].
100 Saxton J, Morrow L, Eschman A, et al. Computer assessment of mild cognitive impairment. Postgrad Med. Mar. 2009;121(2):177-85. [pmid: 19332976].
101 Tariq SH, Tumosa N, Chibnall JT, et al. Comparison of the Saint Louis University mental status examination and the mini-mental state examination for detecting dementia and mild neurocognitive disorder--a pilot study. Am J Geriatr Psychiatry. Nov. 2006;14(11):900-10. [pmid: 17068312].
102 Lee JY, Dong WL, Cho SJ, et al. Brief screening for mild cognitive impairment in elderly outpatient clinic: validation of the Korean version of the Montreal Cognitive Assessment. J Geriatr Psychiatry Neurol. Jun. 2008;21(2):104-10. [pmid: 18474719].
103 Galvin JE, Roe CM, Powlishta KK, et al. The AD8: a brief informant interview to detect dementia. Neurology. Aug. 23. 2005;65(4):559-64. [pmid: 16116116].
104 Vercambre MN, Cuvelier H, Gayon YA, et al. Validation study of a French version of the modified telephone interview for cognitive status (F-TICS-m) in elderly women. Int J Geriatr Psychiatry. Nov. 2010;25(11):1142-9. [pmid: 20054838].
105 Doody RS, Ferris SH, Salloway S, et al. Donepezil treatment of patients with MCI: a 48-week randomized, placebo-controlled trial. Neurology. May. 5. 2009;72(18):1555-61. [pmid: 19176895].
106 Doody RS, Ferris S, Salloway S, et al. Safety and tolerability of donepezil in mild cognitive impairment: open-label extension study. Am J Alzheimers Dis Other Demen. Mar. 2010;25(2):155-9. [pmid: 19949165].
107 Mori E, Ikeda M, Kosaka K. Donepezil for dementia with Lewy bodies: a randomized, placebo-controlled trial. Ann Neurol. Jul. 2012;72(1):41-52. [pmid: 22829268].
108 Requena C, Maestu F, Campo P, et al. Effects of cholinergic drugs and cognitive training on dementia: 2-year follow-up. Dement Geriatr Cogn Disord. 2006;22(4):339-45. [pmid: 16954689].
109 Requena C, Lopez Ibor MI, Maestu F, et al. Effects of cholinergic drugs and cognitive training on dementia. Dement Geriatr Cogn Disord. 2004;18(1):50-4. [pmid: 15084794].
110 Auchus AP, Brashear HR, Salloway S, et al. Galantamine treatment of vascular dementia: a randomized trial. Neurology. Jul. 31. 2007;69(5):448-58. [pmid: 17664404].
111 Rockwood K, Fay S, Song X, et al. Attainment of treatment goals by people with Alzheimer's disease receiving galantamine: a randomized controlled trial. CMAJ. Apr. 11. 2006;174(8):1099-105. [pmid: 16554498].
112 Rockwood K, Fay S, Jarrett P, et al. Effect of galantamine on verbal repetition in AD: a secondary analysis of the VISTA trial. Neurology. Apr. 3. 2007;68(14):1116-21. [pmid: 17404193].
113 Rockwood K, Fay S, Gorman M. The ADAS-cog and clinically meaningful change in the VISTA clinical trial of galantamine for Alzheimer's disease. Int J Geriatr Psychiatry. Feb. 2010;25(2):191-201. [pmid: 19548273].
114 Wong VS. Effect of galantamine on verbal repetition in AD: a secondary analysis of the VISTA trial. Neurology. Aug. 21. 2007;69(8):809-10. [pmid: 17709718].
115 Ballard C, Sauter M, Scheltens P, et al. Efficacy, safety and tolerability of rivastigmine capsules in patients with probable vascular dementia: the VantagE study. Curr Med Res Opin. Sep. 2008;24(9):2561-74. [pmid: 18674411].
116 Feldman HH, Lane R, Study 304 Group. Rivastigmine: a placebo controlled trial of twice daily and three times daily regimens in patients with Alzheimer's disease. J Neurol Neurosurg Psychiatry. Oct. 2007;78(10):1056-63. [pmid: 17353259].
117 Mok V, Wong A, Ho S, et al. Rivastigmine in Chinese patients with subcortical vascular dementia. Neuropsychiatr Dis Treat. Dec. 2007;3(6):943-8. [pmid: 19300631].
118 Winblad B, Cummings J, Andreasen N, et al. A six-month double-blind, randomized, placebo-controlled study of a transdermal patch in Alzheimer's disease--rivastigmine patch versus capsule. Int J Geriatr Psychiatry. May. 2007;22(5):456-67. [pmid: 17380489].
119 Winblad B, Grossberg G, Frolich L, et al. IDEAL: a 6-month, double-blind, placebo-controlled study of the first skin patch for Alzheimer disease. Neurology. Jul. 24. 2007;69(4:Suppl 1):S14-S22. [pmid: 17646619].
120 Grossberg G, Meng X, Olin JT. Impact of rivastigmine patch and capsules on activities of daily living in Alzheimer's disease. Am J Alzheimers Dis Other Demen. Feb. 2011;26(1):65-71. [pmid: 21282280].
121 Grossberg GT, Schmitt FA, Meng X, et al. Reviews: Effects of transdermal rivastigmine on ADAS-cog items in mild-to-moderate Alzheimer's disease. Am J Alzheimers Dis Other Demen. Dec. 2010;25(8):627-33. [pmid: 21131668].
122 Cummings JL, Ferris SH, Farlow MR, et al. Effects of rivastigmine transdermal patch and capsule on aspects of clinical global impression of change in Alzheimer's disease: a retrospective analysis. Dementia & Geriatric Cognitive Disorders. 2010;29(5):406-12. [pmid: 20502014].
123 Lee JH, Sevigny J. Effects of body weight on tolerability of rivastigmine transdermal patch: a post-hoc analysis of a double-blind trial in patients with Alzheimer disease. Alzheimers Dis Assoc Disord. Jan. 2011;25(1):58-62. [pmid: 20975519].
124 Grossberg G, Sadowsky C, Frostl H, et al. Safety and tolerability of the rivastigmine patch: results of a 28-week open-label extension. Alzheimer Dis Assoc Disord. Apr. 2009;23(2):158-64. [pmid: 19484917].
125 Cummings JL, Farlow MR, Meng X, et al. Rivastigmine transdermal patch skin tolerability: results of a 1-year clinical trial in patients with mild-to-moderate Alzheimer's disease. Clin Drug Invest. 2010;30(1):41-9. [pmid: 19995097].
126 Farlow MR, Grossberg GT, Meng X, et al. Rivastigmine transdermal patch and capsule in Alzheimer's disease: influence of disease stage on response to therapy. Int J Geriatr Psychiatry. Dec. 2011;26(12):1236-43. [pmid: 22068922].
127 Grossberg GT, Olin JT, Somogyi M, et al. Dose effects associated with rivastigmine transdermal patch in patients with mild-to-moderate Alzheimer's disease. Int J Clin Pract. Apr. 2011;65(4):465-71. [pmid: 21309961].
128 Bakchine S, Loft H. Memantine treatment in patients with mild to moderate Alzheimer's disease: results of a randomised, double-blind, placebo-controlled 6-month study. J Alzheimers Dis. Feb. 2008;13(1):97-107. [pmid: 18334761].
129 Ferris S, Schneider L, Farmer M, et al. A double-blind, placebo-controlled trial of memantine in age-associated memory impairment (memantine in AAMI). Int J Geriatr Psychiatry. May. 2007;22(5):448-55. [pmid: 17117395].
130 Porsteinsson AP, Grossberg GT, Mintzer J, et al. Memantine treatment in patients with mild to moderate Alzheimer's disease already receiving a cholinesterase inhibitor: a randomized, double-blind, placebo-controlled trial. Curr Alzheimer Res. Feb. 2008;5(1):83-9. [pmid: 18288936].
131 Saxton J, Hofbauer RK, Woodward M, et al. Memantine and functional communication in Alzheimer's disease: results of a 12-week, international, randomized clinical trial. J Alzheimers Dis. 2012;28(1):109-18. [pmid: 21955815].
132 Wilkinson D, Fox NC, Barkhof F, et al. Memantine and brain atrophy in Alzheimer's disease: a 1-year randomized controlled trial. J Alzheimers Dis. 2012;29(2):459-69. [pmid: 22269160].
133 AD2000 Collaborative Group, Bentham P, Gray R, et al. Aspirin in Alzheimer's disease (AD2000): a randomised open-label trial. Lancet Neurology. Jan. 2008;7(1):41-9. [pmid: 18068522].
134 Feldman HH, Doody RS, Kivipelto M, et al. Randomized controlled trial of atorvastatin in mild to moderate Alzheimer disease: LEADe. Neurology. Mar. 23. 2010;74(12):956-64. [pmid: 20200346].
135 Jones RW, Kivipelto M, Feldman H, et al. The Atorvastatin/Donepezil in Alzheimer's Disease Study (LEADe): design and baseline characteristics. Alzheimers Dement. Mar. 2008;4(2):145-53. [pmid: 18631958].
136 Sano M, Bell KL, Galasko D, et al. A randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. Aug. 9. 2011;77(6):556-63. [pmid: 21795660].
137 Simons M, Schwarzler F, Lutjohann D, et al. Treatment with simvastatin in normocholesterolemic patients with Alzheimer's disease: A 26-week randomized, placebo-controlled, double-blind trial. Ann Neurol. Sep. 2002;52(3):346-50. [pmid: 12205648].
138 Sparks DL, Sabbagh MN, Connor DJ, et al. Atorvastatin for the treatment of mild to moderate Alzheimer disease: preliminary results. Arch Neurol. May. 2005;62(5):753-7. [pmid: 15883262].
139 Sparks DL, Connor DJ, Sabbagh MN, et al. Circulating cholesterol levels, apolipoprotein E genotype and dementia severity influence the benefit of atorvastatin treatment in Alzheimer's disease: results of the Alzheimer's Disease Cholesterol-Lowering Treatment (ADCLT) trial. Acta Neurol Scand. 2006;114(Suppl 185):3-7. [pmid: 16866904].
140 Sparks DL, Sabbagh M, Connor D, et al. Statin therapy in Alzheimer's disease. Acta Neurol Scand. 2006;114(Suppl 185):78-86. [pmid: 16866915].
141 Clarke R, Harrison G, Richards S, et al. Effect of vitamins and aspirin on markers of platelet activation, oxidative stress and homocysteine in people at high risk of dementia. J Intern Med. Jul. 2003;254(1):67-75. [pmid: 12823643].
142 Pasqualetti P, Bonomini C, Dal Forno G, et al. A randomized controlled study on effects of ibuprofen on cognitive progression of Alzheimer's disease. Aging-Clinical & Experimental Research. Apr. 2009;21(2):102-10. [pmid: 19448381].
143 Aisen PS, Schafer KA, Grundman M, et al. Effects of rofecoxib or naproxen vs placebo on Alzheimer disease progression: a randomized controlled trial. JAMA. Jun. 4. 2003;289(21):2819-26. [pmid: 12783912].
144 de Jong D, Jansen R, Hoefnagels W, et al. No effect of one-year treatment with indomethacin on Alzheimer's disease progression: a randomized controlled trial. PLoS One. 2008;3(1):e1475. [pmid: 18213383].
145 Soininen H, West C, Robbins J, et al. Long-term efficacy and safety of celecoxib in Alzheimer's disease. Dement Geriatr Cogn Dis. 2007;23(1):8-21. [pmid: 17068392].
146 Henderson VW, Paganini-Hill A, Miller BL, et al. Estrogen for Alzheimer's disease in women: randomized, double-blind, placebo-controlled trial. Neurology. Jan. 25. 2000;54(2):295-301. [pmid: 10668686].
147 Lu PH, Masterman DA, Mulnard R, et al. Effects of testosterone on cognition and mood in male patients with mild Alzheimer disease and healthy elderly men. Arch Neurol. Feb. 2006;63(2):177-85. [pmid: 16344336].
148 Mulnard RA, Cotman CW, Kawas C, et al. Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: A randomized controlled trial. [Erratum appears in JAMA 2000 Nov 22-29;284(20):2597]. JAMA. 2000;283(8):1007-15. [pmid: 10697060].
149 Valen-Sendstad A, Engedal K, Stray-Pedersen B, et al. Effects of hormone therapy on depressive symptoms and cognitive functions in women with Alzheimer disease: a 12 month randomized, double-blind, placebo-controlled study of low-dose estradiol and norethisterone. American Journal of Geriatric Psychiatry. Jan. 2010;18(1):11-20. [pmid: 20094015].
150 Wang PN, Liao SQ, Liu RS, et al. Effects of estrogen on cognition, mood, and cerebral blood flow in AD: a controlled study. Neurology. Jun. 13. 2000;54(11):2061-6. [pmid: 10851363].
151 Aisen PS, Schneider LS, Sano M, et al. High-dose B vitamin supplementation and cognitive decline in Alzheimer disease: a randomized controlled trial. JAMA. Oct. 15. 2008;300(15):1774-83. [pmid: 18854539].
152 Connelly PJ, Prentice NP, Cousland G, et al. A randomised double-blind placebo-controlled trial of folic acid supplementation of cholinesterase inhibitors in Alzheimer's disease. Int J Geriatr Psychiatry. Feb. 2008;23(2):155-60. [pmid: 17600848].
153 de Jager CA, Oulhaj A, Jacoby R, et al. Cognitive and clinical outcomes of homocysteine-lowering B-vitamin treatment in mild cognitive impairment: a randomized controlled trial. Int J Geriatr Psychiatry. Jun. 2012;27(6):592-600. [pmid: 21780182].
154 Freund-Levi Y, Eriksdotter-Jonhagen M, Cederholm T, et al. Omega-3 fatty acid treatment in 174 patients with mild to moderate Alzheimer disease: OmegAD study: a randomized double-blind trial. Arch Neurol. Oct. 2006;63(10):1402-8. [pmid: 17030655].
155 Freund-Levi Y, Basun H, Cederholm T, et al. Omega-3 supplementation in mild to moderate Alzheimer's disease: effects on neuropsychiatric symptoms. Int J Geriatr Psychiatry. Feb. 2008;23(2):161-9. [pmid: 17582225].
156 Kwok T, Lee J, Law CB, et al. A randomized placebo controlled trial of homocysteine lowering to reduce cognitive decline in older demented people. Clin Nutr. Jun. 2011;30(3):297-302. [pmid: 21216507].
157 Sano M, Ernesto C, Thomas RG, et al. A controlled trial of selegiline, alpha-tocopherol, or both as treatment for Alzheimer's disease. The Alzheimer's Disease Cooperative Study. N Engl J Med. Apr. 24. 1997;336(17):1216-22. [pmid: 9110909].
158 Sinn N, Milte CM, Street SJ, et al. Effects of n-3 fatty acids, EPA v. DHA, on depressive symptoms, quality of life, memory and executive function in older adults with mild cognitive impairment: a 6-month randomised controlled trial. Br J Nutr. Jun. 2012;107(11):1682-93. [pmid: 21929835].
159 Quinn JF, Raman R, Thomas RG, et al. Docosahexaenoic acid supplementation and cognitive decline in Alzheimer disease: a randomized trial. JAMA. Nov. 3. 2010;304(17):1903-11. [pmid: 21045096].
160 Sun Y, Lu CJ, Chien KL, et al. Efficacy of multivitamin supplementation containing vitamins B6 and B12 and folic acid as adjunctive treatment with a cholinesterase inhibitor in Alzheimer's disease: a 26-week, randomized, double-blind, placebo-controlled study in Taiwanese patients. Clin Ther. Oct. 2007;29(10):2204-14. [pmid: 18042476].
161 van Uffelen JG, Chinapaw MJ, van MW, et al. Walking or vitamin B for cognition in older adults with mild cognitive impairment? A randomised controlled trial. Br J Sports Med. May. 2008;42(5):344-51. [pmid: 18308888].
162 van Uffelen JG, Chin APM, Hopman-Rock M, et al. The effect of walking and vitamin B supplementation on quality of life in community-dwelling adults with mild cognitive impairment: a randomized, controlled trial. Qual Life Res. Sep. 2007;16(7):1137-46. [pmid: 17616840].
163 van Uffelen JG, Hopman-Rock M, Chin APM, et al. Protocol for Project FACT: a randomised controlled trial on the effect of a walking program and vitamin B supplementation on the rate of cognitive decline and psychosocial wellbeing in older adults with mild cognitive impairment [ISRCTN19227688]. BMC Geriatrics. 2005;5:18. [pmid: 16375760].
164 Yurko-Mauro K, McCarthy D, Rom D, et al. Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimer's & Dementia. Nov. 2010;6(6):456-64. [pmid: 20434961].
165 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Int Med. Nov. 21. 2006;145(10):727-38. [pmid: 17116917].
166 Brodaty H, Gresham M. Effect of a training programme to reduce stress in carers of patients with dementia. BMJ. Dec. 2. 1989;299(6712):1375-9. [pmid: 2513967].
167 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. Aug. 2003;43(4):568-79. [pmid: 12937335].
168 Chu H, Yang CY, Liao YH, et al. The effects of a support group on dementia caregivers' burden and depression. J Aging Health. 2011;23(2):228-41. [pmid: 20847363].
169 Coon DW, Thompson L, Steffen A, et al. Anger and depression management: psychoeducational skill training interventions for women caregivers of a relative with dementia. Gerontologist. Oct. 2003;43(5):678-89. [pmid: 14570964].
170 De Rotrou J, Cantegreil I, Faucounau V, et al. Do patients diagnosed with Alzheimer's disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. Aug. 2011;26(8):833-42. [pmid: 20922772].
171 Gallagher-Thompson D, Coon DW, Solano N, et al. Change in indices of distress among Latino and Anglo female caregivers of elderly relatives with dementia: site-specific results from the REACH national collaborative study. Gerontologist. Aug. 2003;43(4):580-91. [pmid: 12937336].
172 Gallagher-Thompson D, Gray HL, Dupart T, et al. Effectiveness of cognitive/behavioral small group intervention for reduction of depression and stress in non-Hispanic White and Hispanic/Latino women dementia family caregivers: Outcomes and mediators of change. J Ration Emot Cogn Behav Ther. 2008;26(4):286-303.
173 Hebert R, Leclerc G, Bravo G, et al. Efficacy of a support group programme for care-givers of demented patients in the community: a randomized controlled trial. Arch Gerontol Geriatr. Jan. 1994;18(1):1-14. [pmid: 15374309].
174 Hepburn KW, Tornatore J, Center B, et al. Dementia family caregiver training: affecting beliefs about caregiving and caregiver outcomes. J Am Geriatr Soc. Apr. 2001;49(4):450-7. [pmid: 11347790].
175 Hepburn KW, Lewis M, Narayan S, et al. Partners in Caregiving: A Psychoeducation Program Affecting Dementia Family Caregivers' Distress and Caregiving Outlook. Clin Gerontol. 2005;29(1):53-69.
176 Kurz A, Wagenpfeil S, Hallauer J, et al. Evaluation of a brief educational program for dementia carers: the AENEAS study. Int J Geriatr Psychiatry. Aug. 2010;25(8):861-9. [pmid: 19946869].
177 Losada A, Marquez-Gonzalez M, Romero-Moreno R. Mechanisms of action of a psychological intervention for dementia caregivers: effects of behavioral activation and modification of dysfunctional thoughts. Int J Geriatr Psychiatry. 2010. Nov. 9. [pmid: 21061414].
178 Ostwald SK, Hepburn KW, Caron W, et al. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. [pmid: 10396888].
179 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients--effects on patients and carers. Dement Geriatr Cogn Disord. 2007;24(6):469-75. [pmid: 17986818].
180 Waldorff FB, Buss DV, Eckermann A, et al. Efficacy of psychosocial intervention in patients with mild Alzheimer's disease: the multicentre, rater blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ. 2012;345:e4693. [pmid: 22807076].
181 Chang BL. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. May. 1999;48(3):173-82. [pmid: 10337848].
182 Ducharme FC, Levesque LL, Lachance LM, et al. “Learning to become a family caregiver” efficacy of an intervention program for caregivers following diagnosis of dementia in a relative. Gerontologist. Aug. 2011;51(4):484-94. [pmid: 21383112].
183 Gitlin LN, Winter L, Burke J, et al. Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. Mar. 2008;16(3):229-39. [pmid: 18310553].
184 Gitlin LN, Corcoran M, Winter L, et al. A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. Feb. 2001;41(1):4-14. [pmid: 11220813].
185 Gitlin LN, Belle SH, Burgio LD, et al. Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. Sep. 2003;18(3):361-74. [pmid: 14518800].
186 Gitlin LN, Winter L, Corcoran M, et al. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. Aug. 2003;43(4):532-46. [pmid: 12937332].
187 Gitlin LN, Winter L, Dennis MP, et al. Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. Aug. 2010;58(8):1465-74. [pmid: 20662955].
188 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. Sep. 1. 2010;304(9):983-91. [pmid: 20810376].
189 Graff MJ, Vernooij-Dassen MJ, Thijssen M, et al. Community based occupational therapy for patients with dementia and their care givers: randomised controlled trial. BMJ. Dec. 9. 2006;333(7580):1196. [pmid: 17114212].
190 Hebert R, Levesque L, Vezina J, et al. Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. Jan. 2003;58(1):S58-S67. [pmid: 12496309].
191 Hinchliffe AC, Hyman IL, Blizard B, et al. Behavioural complications of dementia-Can they be treated?. Int J Geriatr Psychiatry. 1995;10(10):839-47.
192 Huang HL, Shyu YI, Chen MC, et al. A pilot study on a home-based caregiver training program for improving caregiver self-efficacy and decreasing the behavioral problems of elders with dementia in Taiwan. Int J Geriatr Psychiatry. Apr. 2003;18(4):337-45. [pmid: 12673611].
193 Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. Jun. 2000;176:557-62. [pmid: 10974962].
194 Martin-Carrasco M, Martin MF, Valero CP, et al. Effectiveness of a psychoeducational intervention program in the reduction of caregiver burden in Alzheimer's disease patients' caregivers. Int J Geriatr Psychiatry. May. 2009;24(5):489-99. [pmid: 18949763].
195 Martin-Cook K, Davis BA, Hynan LS, et al. A randomized, controlled study of an Alzheimer's caregiver skills training program. Am J Alzheimers Dis Other Demen. Jul. 2005;20(4):204-10. [pmid: 16136843].
196 Roberts J, Browne G, Milne C, et al. Problem-solving counseling for caregivers of the cognitively impaired: effective for whom?. Nurs Res. May. 1999;48(3):162-72. [pmid: 10337847].
197 Schoenmakers B, Buntinx F, DeLepeleire J. Supporting family carers of community-dwelling elder with cognitive decline: a randomized controlled trial. Int J Family Med. 2010;2010:184152. [pmid: 22332005].
198 Spijker A, Wollersheim H, Teerenstra S, et al. Systematic care for caregivers of patients with dementia: a multicenter, cluster-randomized, controlled trial. Am J Geriatr Psychiatry. 2011. Feb. 24. [pmid: 21358385].
199 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-11. [pmid: 16326662].
200 Voigt-Radloff S, Graff M, Leonhart R, et al. A multicentre RCT on community occupational therapy in Alzheimer's disease: 10 sessions are not better than one consultation. BMJ Open. Jan. 1. 2011;1(1):e000096. [pmid: 22021760].
201 Williams VP, Bishop-Fitzpatrick L, Lane JD, et al. Video-based coping skills to reduce health risk and improve psychological and physical well-being in Alzheimer's disease family caregivers. Psychosom Med. Nov. 2010;72(9):897-904. [pmid: 20978227].
202 Wright LK, Litaker M, Laraia MT, et al. Continuum of care for Alzheimer's disease: a nurse education and counseling program. Issues Ment Health Nurs. Apr. 2001;22(3):231-52. [pmid: 11885210].
203 Bass DM, Clark PA, Looman WJ, et al. The Cleveland Alzheimer's managed care demonstration: outcomes after 12 months of implementation. Gerontologist. Feb. 2003;43(1):73-85. [pmid: 12604748].
204 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. May. 10. 2006;295(18):2148-57. [pmid: 16684985].
205 Chu P, Edwards J, Levin R, et al. The use of clinical case management for early state Alzheimer's patients and their families. Am J Alzheimers Dis Other Demen. 2000;15(5):284-90.
206 Eloniemi-Sulkava U, Notkola IL, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: a randomized trial. J Am Geriatr Soc. Oct. 2001;49(10):1282-7. [pmid: 11890485].
207 Fortinsky RH, Kulldorff M, Kleppinger A, et al. Dementia care consultation for family caregivers: collaborative model linking an Alzheimer's association chapter with primary care physicians. Aging Ment Health. Mar. 2009;13(2):162-70. [pmid: 19347683].
208 Jansen AP, van Hout HP, Nijpels G, et al. Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. Aug. 2011;48(8):933-43. [pmid: 21356537].
209 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. Apr. 2010;25(4):395-402. [pmid: 19606455].
210 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial. Ann Int Med. Nov. 21. 2006;145(10):713-26. [pmid: 17116916].
211 LoGiudice D, Waltrowicz W, Brown K, et al. Do memory clinics improve the quality of life of carers? A randomized pilot trial. Int J Geriatr Psychiatry. Aug. 1999;14(8):626-32. [pmid: 10489653].
212 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res. May. 1995;44(3):166-72. [pmid: 7761293].
213 Finkel S, Czaja SJ, Schulz R, et al. E-care: a telecommunications technology intervention for family caregivers of dementia patients. Am J Geriatr Psychiatry. May. 2007;15(5):443-8. [pmid: 17463195].
214 Mahoney DF, Tarlow BJ, Jones RN. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. Aug. 2003;43(4):556-67. [pmid: 12937334].
215 Joling KJ, van Marwijk HW, Smit F, et al. Does a family meetings intervention prevent depression and anxiety in family caregivers of dementia patients? A randomized trial. PLoS One. 2012;7(1):e30936. [pmid: 22303473].
216 Joling KJ, van Marwijk HW, van der Horst HE, et al. Effectiveness of family meetings for family caregivers on delaying time to nursing home placement of dementia patients: a randomized trial. PLoS One. 2012;7(8):e42145. [pmid: 22876304].
217 Mittelman MS, Brodaty H, Wallen AS, et al. A three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: effects on caregiver depression. Am J Geriatr Psychiatry. Nov. 2008;16(11):893-904. [pmid: 18978250].
218 Charlesworth G, Shepstone L, Wilson E, et al. Befriending carers of people with dementia: randomised controlled trial. BMJ. Jun. 7. 2008;336(7656):1295-7. [pmid: 18505757].
219 Pillemer K, Jill SJ. Peer support for Alzheimer's caregivers: Is it enough to make a difference?. Res Aging. 2002;24(2):171-92.
220 Winter L, Gitlin LN. Evaluation of a telephone-based support group intervention for female caregivers of community-dwelling individuals with dementia. Am J Alzheimers Dis Other Demen. Dec. 20. 2006;21(6):391-7. [pmid: 17267370].
221 Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: A randomized controlled trial. J Appl Gerontol. 2009;28(2):171-94. [pmid: 21709757].
222 Hirano A, Suzuki Y, Kuzuya M, et al. Influence of regular exercise on subjective sense of burden and physical symptoms in community-dwelling caregivers of dementia patients: a randomized controlled trial. Arch Gerontol Geriatr. Sep. 2011;53(2):e158-e163. [pmid: 20850878].
223 King AC, Baumann K, O'Sullivan P, et al. Effects of Moderate-Intensity Exercise on Physiological, Behavioral, and Emotional Responses to Family Caregiving. J Gerontol A Biol Sci Med Sci. Jan. 1. 2002;57(1):M26-M36. [pmid: 11773209].
224 Signe A, Elmstahl S. Psychosocial intervention for family caregivers of people with dementia reduces caregiver's burden: development and effect after 6 and 12 months. Scand J Caring Sci. Mar. 2008;22(1):98-109. [pmid: 18269429].
225 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen ML, et al. Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. Dec. 2009;57(12):2200-8. [pmid: 20121986].
226 Baker LD, Frank LL, Foster-Schubert K, et al. Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. Jan. 2010;67(1):71-9. [pmid: 20065132].
227 Lam LC, Chau RC, Wong BM, et al. Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. Int J Geriatr Psychiatry. Jul. 2011;26(7):733-40. [pmid: 21495078].
228 Lautenschlager NT, Cox KL, Flicker L, et al. Effect of physical activity on cognitive function in older adults at risk for Alzheimer disease: a randomized trial. [Erratum appears in JAMA. 2009 Jan 21;301(3):276]. JAMA. Sep. 3. 2008;300(9):1027-37. [pmid: 18768414].
229 Nagamatsu LS, Handy TC, Hsu CL, et al. Resistance training promotes cognitive and functional brain plasticity in seniors with probable mild cognitive impairment. Arch Intern Med. Apr. 23. 2012;172(8):666-8. [pmid: 22529236].
230 Steinberg M, Leoutsakos JM, Podewils LJ, et al. Evaluation of a home-based exercise program in the treatment of Alzheimer's disease: the Maximizing Independence in Dementia (MIND) study. Int J Geriatr Psychiatry. Jul. 2009;24(7):680-5. [pmid: 19089875].
231 Suzuki T, Shimada H, Makizako H, et al. Effects of multicomponent exercise on cognitive function in WMS-LM older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. Oct. 31. 2012;12(1):128. [pmid: 23113898].
232 Teri L, Logsdon RG, McCurry SM. Exercise interventions for dementia and cognitive impairment: the Seattle Protocols. [Review] [22 refs]. Journal of Nutrition, Health & Aging. Jun. 2008;12(6):391-4. [pmid: 18548177].
233 Tsai PF, Chang JY, Beck C, et al. A Pilot Cluster-Randomized Trial of a 20-Week Tai Chi Program in Elders With Cognitive Impairment and Osteoarthritic Knee: Effects on Pain and Other Health Outcomes. J Pain Symptom Manage. 2012. Sep. 24. [pmid: 23017610].
234 Venturelli M, Lanza M, Muti E, et al. Positive effects of physical training in activity of daily living-dependent older adults. Exp Aging Res. Apr. 2010;36(2):190-205. [pmid: 20209421].
235 Vreugdenhil A, Cannell J, Davies A, et al. A community-based exercise programme to improve functional ability in people with Alzheimer's disease: a randomized controlled trial. Scand J Caring Sci. Mar. 2012;26(1):12-9. [pmid: 21564154].
236 Greenaway MC, Duncan NL, Smith GE. The memory support system for mild cognitive impairment: randomized trial of a cognitive rehabilitation intervention. Int J Geriatr Psychiatry. 2012. Jun. 7. [pmid: 22678947].
237 Kinsella GJ, Mullaly E, Rand E, et al. Early intervention for mild cognitive impairment: a randomised controlled trial. J Neurol Neurosurg Psychiatry. Jul. 2009;80(7):730-6. [pmid: 19332424].
238 Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging Ment Health. Feb. 2002;6(1):5-11. [pmid: 11827617].
239 Troyer AK, Murphy KJ, Anderson ND, et al. Changing everyday memory behaviour in amnestic mild cognitive impairment: a randomised controlled trial. Neuropsychol Rehabil. Jan. 2008;18(1):65-88. [pmid: 17943615].
240 Tsolaki M, Kounti F, Agogiatou C, et al. Effectiveness of nonpharmacological approaches in patients with mild cognitive impairment. Neurodegener Dis. 2011;8(3):138-45. [pmid: 21135531].
241 Buschert VC, Friese U, Teipel SJ, et al. Effects of a newly developed cognitive intervention in amnestic mild cognitive impairment and mild Alzheimer's disease: a pilot study. J Alzheimers Dis. 2011;25(4):679-94. [pmid: 21483095].
242 Burgener SC, Yang Y, Gilbert R, et al. The effects of a multimodal intervention on outcomes of persons with early-stage dementia. Am J Alzheimers Dis Other Demen. Aug. 2008;23(4):382-94. [pmid: 18453642].
243 Cahn-Weiner DA, Malloy PF, Rebok GW, et al. Results of a randomized placebo-controlled study of memory training for mildly impaired Alzheimer's disease patients. Appl Neuropsychol. 2003;10(4):215-23. [pmid: 14690802].
244 Chapman SB, Weiner MF, Rackley A, et al. Effects of cognitive-communication stimulation for Alzheimer's disease patients treated with donepezil. J Speech Lang Hear Res. Oct. 2004;47(5):1149-63. [pmid: 15603468].
245 Clare L, Linden DE, Woods RT, et al. Goal-oriented cognitive rehabilitation for people with early-stage Alzheimer disease: a single-blind randomized controlled trial of clinical efficacy. Am J Geriatr Psychiatry. Oct. 2010;18(10):928-39. [pmid: 20808145].
246 Kurz A, Thone-Otto A, Cramer B, et al. CORDIAL: cognitive rehabilitation and cognitive-behavioral treatment for early dementia in Alzheimer disease: a multicenter, randomized, controlled trial. Alzheimer Dis Assoc Disord. Jul. 2012;26(3):246-53. [pmid: 21986341].
247 Olazaran J, Muniz R, Reisberg B, et al. Benefits of cognitive-motor intervention in MCI and mild to moderate Alzheimer disease. Neurology. Dec. 28. 2004;63(12):2348-53. [pmid: 15623698].
248 Schwenk M, Zieschang T, Oster P, et al. Dual-task performances can be improved in patients with dementia: a randomized controlled trial. Neurology. Jun. 15. 2010;74(24):1961-8. [pmid: 20445152].
249 Quayhagen MP, Quayhagen M, Corbeil RR, et al. A dyadic remediation program for care recipients with dementia. Nurs Res. May. 1995;44(3):153-9. [pmid: 7761291].
250 Bellantonio S, Kenny AM, Fortinsky RH, et al. Efficacy of a geriatrics team intervention for residents in dementia-specific assisted living facilities: effect on unanticipated transitions. J Am Geriatr Soc. Mar. 2008;56(3):523-8. [pmid: 18179497].
251 Richard E, Van den HE, Moll van Charante EP, et al. Prevention of dementia by intensive vascular care (PreDIVA): a cluster-randomized trial in progress. Alzheimer Dis Assoc Disord. Jul. 2009;23(3):198-204. [pmid: 19812459].
252 Meeuwsen EJ, Melis RJ, Van Der Aa GC, et al. Effectiveness of dementia follow-up care by memory clinics or general practitioners: randomised controlled trial. BMJ. 2012;344:e3086. [pmid: 22589500].
253 Nourhashemi F, Andrieu S, Gillette-Guyonnet S, et al. Effectiveness of a specific care plan in patients with Alzheimer's disease: cluster randomised trial (PLASA study). BMJ. 2010;340:c2466. [pmid: 20522656].
254 Wolfs CAG, Kessels A, Dirksen CD, et al. Integrated multidisciplinary diagnostic approach for dementia care: Randomised controlled trial. Br J Psychiatry. 2008;192(4):300-5. [pmid: 18378994].
255 Beer C, Horner B, Flicker L, et al. A cluster-randomised trial of staff education to improve the quality of life of people with dementia living in residential care: the DIRECT study. PLoS One. 2011;6(11):e28155. [pmid: 22140531].
256 Beer CD, Horner B, Almeida OP, et al. Dementia in residential care: education intervention trial (DIRECT); protocol for a randomised controlled trial. Trials. 2010;11:63. [pmid: 20500891].
257 Menn P, Holle R, Kunz S, et al. Dementia care in the general practice setting: a cluster randomized trial on the effectiveness and cost impact of three management strategies. Value Health. Sep. 2012;15(6):851-9. [pmid: 22999135].
258 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. Oct. 15. 2003;290(15):2015-22. [pmid: 14559955].