# Trials Pending Assessment

Table 1 Trials Pending Assessment