# Abbreviated Evidence Tables for Key Question 4

Table 1 Cognitive Status Outcomes From AChEI Trials

Table 2 Global Function Status Outcomes From AChEI Trials

Table 3 Physical Function Status Outcomes From AChEI Trials

Table 4 Cognitive Status Outcomes From Other Pharmacologic Intervention Trials

Table 5 Caregiver Depression Outcomes From Caregiver Intervention Trials

Table 6 Caregiver Burden Outcomes From Caregiver Intervention Trials

Table 7 Patient Institutionalization Outcomes From Caregiver Trials

Table 8 Cognitive Function Outcomes for Exercise Interventions

Table 9 Cognitive Function Outcomes for Cognitive Interventions (Stimulation and Training)

Table 10 Cognitive Function Outcomes for Cognitive Interventions (Stimulation and Training)

Table 11 Depression Outcomes for Exercise Interventions