# Study, Population, and Intervention Characteristics for Key Questions 4 and 5

Table 1 Baseline Population Characteristics for AChEI Trials

Table 2 Study Characteristics for AChEI Trials

Table 3 Study Characteristics for Other Medication and Supplement Trials

Table 4 Population Characteristics of Caregiver Intervention Trials

Table 5 Caregiver Intervention Characteristics

Table 6 Selected Instruments Measuring Caregiver Burden or Stress

Table 7 Selected Depression and Hopelessness Screening Instruments

Table 8 Selected Instruments Measuring Caregiver Psychological or Physical Well-Being

Table 9 Study Characteristics for Exercise Intervention Trials

Table 10 Study Characteristics for Cognitive Intervention Trials

Table 11 Study Characteristics for Other Behavioral Intervention Trials