# Abbreviated Evidence Tables for Key Question 2

Table 1 Study Characteristics and Outcomes for Dementia Screening (Dementia vs. MCI/Normal), Very Brief Instruments

Table 2 Study Characteristics and Outcomes for Dementia Screening (Dementia vs. MCI/Normal), Brief Instruments

Table 3 Study Characteristics and Outcomes for Dementia Screening (Dementia vs. MCI/Normal), Self-Administered Instruments

Table 4 Study Characteristics and Outcomes for Mild Cognitive Impairment Screening (MCI vs. Normal, Dementia Not Included), Very Brief Instruments

Table 5 Study Characteristics and Outcomes for Mild Cognitive Impairment Screening (MCI vs. Normal, Dementia Not Included), Brief Instruments

Table 6 Study Characteristics and Outcomes for Mild Cognitive Impairment Screening (MCI vs. Normal, Dementia Not Included), Self-Administered Instruments

Table 7 Study Characteristics and Outcomes for Cognitive Impairment Screening (MCI/Dementia vs. Normal), Very Brief Instruments

Table 8 Study Characteristics and Outcomes For Cognitive Impairment Screening (MCI/Dementia vs. Normal), Brief Instruments

Table 9 Study Characteristics and Outcomes for Cognitive Impairment Screening (MCI/Dementia vs. Normal), Self-Administered Instruments