# Excluded Treatments

Treatment Category | Drug Name/Type
Drugs for symptom management | Anti-depressants (all)
Drugs for symptom management | Anti-epileptics (all)
Drugs for symptom management | Anti-psychotics (all)
Drugs for symptom management | Nutritional supplements to prevent weight loss (all)
Drugs for symptom management | Ondansetron
Cholinesterase inhibitors not FDA-approved | Eptastigmine
Cholinesterase inhibitors not FDA-approved | Metrifonate
Cholinesterase inhibitors not FDA-approved | Physostigmine
Cholinesterase inhibitors not FDA-approved | Velnacrine
Other drugs not FDA-approved for the treatment of cognitive impairment | Almitrine/raubasine
Other drugs not FDA-approved for the treatment of cognitive impairment | Amitriptyline
Other drugs not FDA-approved for the treatment of cognitive impairment | Ateroid
Other drugs not FDA-approved for the treatment of cognitive impairment | Cerebrolysin
Other drugs not FDA-approved for the treatment of cognitive impairment | Choro-San
Other drugs not FDA-approved for the treatment of cognitive impairment | Choto-San
Other drugs not FDA-approved for the treatment of cognitive impairment | Citicoline
Other drugs not FDA-approved for the treatment of cognitive impairment | Cyclandelate
Other drugs not FDA-approved for the treatment of cognitive impairment | Denbufylline
Other drugs not FDA-approved for the treatment of cognitive impairment | Desferrioxamine
Other drugs not FDA-approved for the treatment of cognitive impairment | Ergokryptine (CMB 36-733)
Other drugs not FDA-approved for the treatment of cognitive impairment | Ergokryptine (Dek)
Other drugs not FDA-approved for the treatment of cognitive impairment | Glycosaminoglycan Polysulfate
Other drugs not FDA-approved for the treatment of cognitive impairment | Hydergine
Other drugs not FDA-approved for the treatment of cognitive impairment | Hydroxychloroquine
Other drugs not FDA-approved for the treatment of cognitive impairment | Idebenone
Other drugs not FDA-approved for the treatment of cognitive impairment | Linopirdine
Other drugs not FDA-approved for the treatment of cognitive impairment | LU25
Other drugs not FDA-approved for the treatment of cognitive impairment | Mifepristone
Other drugs not FDA-approved for the treatment of cognitive impairment | Monosialotetrahexosylganglioside (GM-1)
Other drugs not FDA-approved for the treatment of cognitive impairment | N-Acetylcysteine
Other drugs not FDA-approved for the treatment of cognitive impairment | Naftidrofuryl
Other drugs not FDA-approved for the treatment of cognitive impairment | Nicergoline
Other drugs not FDA-approved for the treatment of cognitive impairment | Nimesulide
Other drugs not FDA-approved for the treatment of cognitive impairment | Nootropic
Other drugs not FDA-approved for the treatment of cognitive impairment | ORG 2766
Other drugs not FDA-approved for the treatment of cognitive impairment | Oxiracetam
Other drugs not FDA-approved for the treatment of cognitive impairment | Piracetam
Other drugs not FDA-approved for the treatment of cognitive impairment | Posatirelin
Other drugs not FDA-approved for the treatment of cognitive impairment | Prednisone
Other drugs not FDA-approved for the treatment of cognitive impairment | Propentofylline
Other drugs not FDA-approved for the treatment of cognitive impairment | Reactivan
Other drugs not FDA-approved for the treatment of cognitive impairment | Rosiglitozone/pioglitozone
Other drugs not FDA-approved for the treatment of cognitive impairment | Sabeluzole
Other drugs not FDA-approved for the treatment of cognitive impairment | Selegiline
Other drugs not FDA-approved for the treatment of cognitive impairment | Silymarin + Tacrine
Other drugs not FDA-approved for the treatment of cognitive impairment | Sulodexide
Other drugs not FDA-approved for the treatment of cognitive impairment | Sulphomucopolysaccharides
NSAID not FDA-approved | Rofecoxib
Herbal drugs and supplements | Anapsos
Herbal drugs and supplements | Curcumin
Herbal drugs and supplements | Dehydroepiandrosterone (DHEA)
Herbal drugs and supplements | Ginko Biloba
Herbal drugs and supplements | Huperzine (herbal cholinesterase inhibitor)
Herbal drugs and supplements | L-carnitine
Herbal drugs and supplements | Phosphatidylserine
Herbal drugs and supplements | Alpha lipoic acid
Experimental drug therapies | Anti-amyloids
Non-pharmacologic therapies | Light therapy
Non-pharmacologic therapies | Multi-sensory stimulation (MSS) or snoezelen
Non-pharmacologic therapies | Music therapy
Non-pharmacologic therapies | Night-time home monitoring systems
Non-pharmacologic therapies | Peripheral electrical stimulation
Non-pharmacologic therapies | Pet therapy
Non-pharmacologic therapies | Medical foods
Non-pharmacologic therapies | Nutritional interventions

Abbreviations: MSS = multisensory stimulation; DHEA = dehydroepiandrosterone.