# Excluded Studies

Exclusion Criteria

CODE | DEFINITION
KQ | Key Question
E1 | Study relevance
E1b | Study design: Not an RCT, CCT, or SER (KQ1, 4); Good quality systematic reviews, diagnostic accuracy studies (KQ2); or good quality systematic reviews, RCT/CCT, prospective observational studies for efficacy, retrospective and case-control studies for harms (KQ3,5)
E2b | Study design: Follow up from baseline <3 months (12 weeks) [Does not apply to harms trials (KQ3,5)]
E2d | Study design: Case control (only applies to screening trials)
E2e | Study design: n<1000 (only applies to treatment harms trials)
E3a | Setting: Not a country with a very high HDL ranking
E3b | Setting: Hospitals, intermediate care facilities (ICF), skilled nursing facilities, rehabilitation facilities, sub-acute care facilities, emergency departments
E3c | Setting: Unrepresentative Settings (memory clinic, ADRC, referred population setting where the prevalence of dementia is not similar to the general population
E4a | Population: Adults < 65 years or average age < 65 years
E4b | Population: Populations exclusively with HIV/AIDS, Down's syndrome, post-traumatic brain injuries, Parkinson's Disease, stroke, and vitamin deficiency
E4c | Population: Adults with severe dementia
E4d | Population: Professional caregiver (formally or professionally trained, paid salary)
E5 | No Relevant Outcomes
E6a | Intervention (Screening): Instruments > 10 min for clinician administration or > 20 min for self-administration; biomarkers (CSF, plasma, urine) or imaging (CT, MRI, PET)
E6b, E6c | Intervention (Treatment): Not one of the specified interventions
E7a | Poor Study Quality: High or differential attrition
E7b | Poor Study Quality: Does not use a reference standard
E7c | Poor Study Quality: Other quality issue
E8 | Part of an included SER

1 Study links exercise, improved mental ability. Geriatrics. 1986;41(3):24. PMID: None. KQ4E1b, KQ5E1b.
2 At-home Alzheimer's test may do more harm than good. Health News. Sep. 2003;9(9):7. KQ3E2a. [pmid: 14584472].
3 Aarsland D, Ballard C, Walker Z, et al. Memantine in patients with Parkinson's disease dementia or dementia with Lewy bodies: a double-blind, placebo-controlled, multicentre trial. Lancet Neurol. Jul. 2009;8(7):613-8. KQ4E4b, KQ5E4b. [pmid: 19520613].
4 Adam S, Van der LM, Ivanoiu A, et al. Optimization of encoding specificity for the diagnosis of early AD: the RI-48 task. J Clin Exp Neuropsychol. Jul. 2007;29(5):477-87. KQ2E3c, KQ3E3c. [pmid: 17564913].
5 ADAPT Research Group, Lyketsos CG, Breitner JC, et al. Naproxen and celecoxib do not prevent AD in early results from a randomized controlled trial. Neurology. May. 22. 2007;68(21):1800-8. KQ4E1b, KQ5E1b. [pmid: 17460158].
6 ADAPT Research Group, Martin BK, Szekely C, et al. Cognitive function over time in the Alzheimer's Disease Anti-inflammatory Prevention Trial (ADAPT): results of a randomized, controlled trial of naproxen and celecoxib. Arch Neurol. Jul. 2008;65(7):896-905. KQ4E1b, KQ5E1b. [pmid: 18474729].
7 ADAPT Research Group, Meinert CL, McCaffrey LD, et al. Alzheimer's Disease Anti-inflammatory Prevention Trial: design, methods, and baseline results. Alzheimers Dement. Mar. 2009;5(2):93-104. KQ4E1b, KQ5E1b. [pmid: 19328435].
8 Agid Y, Dubois B, Anand R, et al. Efficacy and tolerability of rivastigmine in patients with dementia of the Alzheimer type. Curr Ther Res Clin Exp. 1998;59:837-45. PMID: None. KQ4E8, KQ5E8.
9 Aguglia E, Onor ML, Saina M, et al. An open-label, comparative study of rivastigmine, donepezil and galantamine in a real-world setting. Curr Med Res Opin. Nov. 2004;20(11):1747-52. KQ4E2a, KQ5E2e. [pmid: 15537474].
10 Aguirre E, Spector A, Hoe J, et al. Maintenance Cognitive Stimulation Therapy (CST) for dementia: a single-blind, multi-centre, randomized controlled trial of Maintenance CST vs. CST for dementia. Trials. 2010;11:46. KQ4E2b, KQ5E2b. [pmid: 20426866].
11 Ahmed S, De JC, Wilcock G. A comparison of screening tools for the assessment of mild cognitive impairment: preliminary findings. Neurocase. 2012;18(4):336-51. KQ2E2d. [pmid: 22044211].
12 Ainslie NK, Murden RA. Effect of education on the clock-drawing dementia screen in non-demented elderly persons. J Am Geriatr Soc. Mar. 1993;41(3):249-52. KQ2E3c. [pmid: 8440847].
13 Aisen PS. Anti-inflammatory therapy for Alzheimer's disease: implications of the prednisone trial. Acta Neurol Scand. Suppl 176. 2000:85-9. KQ4E6c, KQ5E6c. [pmid: 10685853].
14 Aisen PS, Schmeidler J, Pasinetti GM. Randomized pilot study of nimesulide treatment in Alzheimer's disease. Neurology. Apr. 9. 2002;58(7):1050-4. KQ4E6c, KQ5E6c. [pmid: 11940691].
15 Aisen PS, Thal LJ, Ferris SH, et al. Rofecoxib in patients with mild cognitive impairment: further analyses of data from a randomized, double-blind, trial. Current Alzheimer Research. Feb. 2008;5(1):73-82. KQ4E6c, KQ5E6c. [pmid: 18288935].
16 Akkerman RL, Ostwald SK. Reducing anxiety in Alzheimer's disease family caregivers: the effectiveness of a nine-week cognitive-behavioral intervention. Am J Alzheimers Dis Other Demen. Mar. 2004;19(2):117-23. KQ4E7c, KQ5E7c. [pmid: 15106393].
17 Albert M, Smith LA, Scherr PA, et al. Use of brief cognitive tests to identify individuals in the community with clinically diagnosed Alzheimer's disease. Int J Neurosci. Apr. 1991;57(3-4):167-78. KQ2E7c. [pmid: 1938160].
18 Alessi CA, Schnelle JF, MacRae PG, et al. Does physical activity improve sleep in impaired nursing home residents?. J Am Geriatr Soc. Oct. 1995;43(10):1098-102. KQ4E3b, KQ5E3b. [pmid: 7560698].
19 Alessi CA, Yoon EJ, Schnelle JF, et al. A randomized trial of a combined physical activity and environmental intervention in nursing home residents: do sleep and agitation improve?. J Am Geriatr Soc. Jul. 1999;47(7):784-91. KQ4E3b, KQ5E3b. [pmid: 10404920].
20 Alexopoulos GS, Mattis S. Diagnosing cognitive dysfunction in the elderly: primary screening tests. Geriatrics. 1991;46(12):33-8. KQ2E2a. [pmid: 1743529].
21 Anand R, Messina J, Hartman R. Dose-response effect of rivastigmine in the treatment of Alzheimer's disease. Int J Geriatric Psychopharmacol. 2000;2:68-72. PMID: None. KQ4E5, KQ5E5.
22 Ancoli-Israel S, Amatniek J, Ascher S, et al. Effects of galantamine versus donepezil on sleep in patients with mild to moderate Alzheimer disease and their caregivers: a double-blind, head-to-head, randomized pilot study. Alzheimer Dis Assoc Disord. Oct. 2005;19(4):240-5. KQ4E2b, KQ5E2e. [pmid: 16327351].
23 Anderson-Hanley C, Arciero PJ, Brickman AM, et al. Exergaming and older adult cognition: A cluster randomized clinical trial. Am J Prev Med. 2012;42(2):109-19. KQ4E2b, KQ5E2b. [pmid: 22261206].
24 Anderson C, Teo K, Gao P, et al. Renin-angiotensin system blockade and cognitive function in patients at high risk of cardiovascular disease: analysis of data from the ONTARGET and TRANSCEND studies. Lancet Neurol. Jan. 2011;10(1):43-53. KQ4E1b, KQ5E1b. [pmid: 20980201].
25 Andreeva VA, Kesse-Guyot E, Barberger-Gateau P, et al. Cognitive function after supplementation with B vitamins and long-chain omega-3 fatty acids: ancillary findings from the SU.FOL.OM3 randomized trial. Am J Clin Nutr. Jul. 2011;94(1):278-86. KQ4E1b, KQ5E1b. [pmid: 21593490].
26 Annweiler C, Schott AM, van Kan GA, et al. The Five-Times-Sit-to-Stand test, a marker of global cognitive functioning among community-dwelling older women. J Nutr Health Aging. 2011;15(4):271-6. KQ2E7b. [pmid: 21437558].
27 Aprahamian I, Martinelli JE, Cecato J, et al. Screening for Alzheimer's disease among illiterate elderly: accuracy analysis for multiple instruments. J Alzheimers Dis. 2011;26(2):221-9. KQ2E3a. [pmid: 21593559].
28 Arkin SM. Student-led exercise sessions yield significant fitness gains for Alzheimer's patients. Am J Alzheimers Dis Other Demen. 2003;18(3):159-70. KQ4E2a, KQ5E2a. [pmid: 12811991].
29 Artero S, Ritchie K. The detection of mild cognitive impairment in the general practice setting. Aging Ment Health. Jul. 2003;7(4):251-8. KQ2E1. [pmid: 12888436].
30 Articus K, Baier M, Tracik F, et al. A 24-week, multicentre, open evaluation of the clinical effectiveness of the rivastigmine patch in patients with probable Alzheimer's disease. Int J Clin Pract. Jul. 2011;65(7):790-6. KQ5E2e. [pmid: 21645184].
31 Ashendorf L, Jefferson AL, O'Connor MK, et al. Trail Making Test errors in normal aging, mild cognitive impairment, and dementia. Arch Clin Neuropsychol. Mar. 2008;23(2):129-37. KQ2E2d. [pmid: 18178372].
32 Ashford JW, Adamson M, Beale T, et al. MR spectroscopy for assessment of memantine treatment in mild to moderate Alzheimer dementia. J Alzheimers Dis. 2011;26:Suppl-6. KQ4E7c, KQ5E7c. [pmid: 21971472].
33 Assal F, Allali G, Kressig RW, et al. Galantamine improves gait performance in patients with Alzheimer's disease. J Am Geriatr Soc. May. 2008;56(5):946-7. KQ4E2a, KQ5E5. [pmid: 18454755].
34 Asthana S, Baker LD, Craft S, et al. High-dose estradiol improves cognition for women with AD: results of a randomized study. Neurology. Aug. 28. 2001;57(4):605-12. KQ4E2c, KQ5E2c. [pmid: 11524467].
35 Atri A, Shaughnessy LW, Locascio JJ, et al. Long-term course and effectiveness of combination therapy in Alzheimer disease. Alzheimer Dis Assoc Disord. Jul. 2008;22(3):209-21. KQ4E2a, KQ5E5. [pmid: 18580597].
36 Au A, Li S, Lee K, et al. The coping with caregiving group program for Chinese caregivers of patients with Alzheimer's disease in Hong Kong. Patient Educ Couns. Feb. 2010;78(2):256-60. KQ4E7c, KQ5E7c. [pmid: 19619974].
37 Auriacombe S, Pere JJ, Loria-Kanza Y, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease who failed to benefit from treatment with donepezil. Curr Med Res Opin. 2002;18(3):129-38. KQ4E2a, KQ5E2e. [pmid: 12094822].
38 Avila R, Carvalho IA, Bottino CM, et al. Neuropsychological rehabilitation in mild and moderate Alzheimer's disease patients. Behav Neurol. 2007;18(4):225-33. KQ4E3a, KQ5E3a. [pmid: 18430980].
39 Ayalon L. The IQCODE Versus a Single-Item Informant Measure to Discriminate Between Cognitively Intact Individuals and Individuals With Dementia or Cognitive Impairment. J Geriatr Psychiatry Neurol. Sep. 2011;24(3):168-73. KQ3E5. [pmid: 21856971].
40 Babacan-Yildiz G, Isik AT, Ur E, et al. COST: Cognitive State Test, a brief screening battery for Alzheimer disease in illiterate and literate patients. Int Psychogeriatr. Nov. 2012;9:1-10. KQ2E3a. [pmid: 23137551].
41 Babins L, Slater ME, Whitehead V, et al. Can an 18-point clock-drawing scoring system predict dementia in elderly individuals with mild cognitive impairment?. J Clin Exp Neuropsychol. Feb. 2008;30(2):173-86. KQ2E3c. [pmid: 18938669].
42 Bachynsky J, McCracken P, Lier D, et al. Propentofylline treatment for Alzheimer disease and vascular dementia: an economic evaluation based on functional abilities. Alzheimer Dis Assoc Disord. Apr. 2000;14(2):102-11. KQ4E6c, KQ5E6c. [pmid: 10850749].
43 Baek MJ, Kim HJ, Kim S. Comparison between the story recall test and the word-list learning test in Korean patients with mild cognitive impairment and early stage of Alzheimer's disease. J Clin Exp Neuropsychol. 2012;34(4):396-404. KQ2E2d. [pmid: 22263656].
44 Baker LD, Frank LL, Foster-Schubert K, et al. Effects of aerobic exercise on mild cognitive impairment: a controlled trial. Arch Neurol. Jan. 2010;67(1):71-9. KQ5E5. [pmid: 20065132].
45 Bakker TJ, Duivenvoorden HJ, van der LJ, et al. Integrative psychotherapeutic nursing home program to reduce multiple psychiatric symptoms of cognitively impaired patients and caregiver burden: randomized controlled trial. Am J Geriatr Psychiatry. Jun. 2011;19(6):507-20. KQ4E3b, KQ5E3b. [pmid: 20808147].
46 Ball LJ, Ogden A, Mandi D, et al. The validation of a mailed health survey for screening of dementia of the Alzheimer's type. J Am Geriatr Soc. Jun. 2001;49(6):798-802. KQ3E5. [pmid: 11454121].
47 Ballard C, Kahn Z, Corbett A. Treatment of dementia with lewy bodies and Parkinson's disease dementia. Drugs Aging. Oct. 1. 2011;28(10):769-77. KQ4E2a, KQ5E2a. [pmid: 21970305].
48 Barak Y, Bodner E, Zemishlani H, et al. Donepezil for the treatment of behavioral disturbances in Alzheimer's disease: A 6-month open trial. Arch Gerontol Geriatr. 2001;33(3):237-41. KQ4E3c, KQ5E3c. [pmid: 15374020].
49 Barberger-Gateau P, Letenneur L, Deschamps V, et al. Fish, meat, and risk of dementia: cohort study. BMJ. Oct. 26. 2002;325(7370):932-3. KQ4E6b, KQ5E6b. [pmid: 12399342].
50 Barncord SW, Wanlass RL. The Symbol Trail Making Test: Test development and utility as a measure of cognitive impairment. Appl Neuropsychol. 2001;8(2):99-103. KQ2E5, KQ3E5. [pmid: 11515246].
51 Barzilay JI, Gao P, O'Donnell M, et al. Albuminuria and decline in cognitive function: The ONTARGET/TRANSCEND studies. Arch Intern Med. Jan. 24. 2011;171(2):142-50. KQ4E1b, KQ5E1b. [pmid: 21263104].
52 Basic D, Khoo A, Conforti D, et al. Rowland Universal Dementia Assessment Scale, Mini-Mental State Examination and General Practitioner Assessment of Cognition in a multicultural cohort of community-dwelling older persons with early dementia. Aust Psychol. 2009;44(1):40-53. PMID: None. KQ2E3c.
53 Basic D, Rowland JT, Conforti DA, et al. The validity of the Rowland Universal Dementia Assessment Scale (RUDAS) in a multicultural cohort of community-dwelling older persons with early dementia. Alzheimer Dis Assoc Disord. Apr. 2009;23(2):124-9. KQ2E3c. [pmid: 19484915].
54 Bass DM, McClendon MJ, Brennan PF, et al. The buffering effect of a computer support network on caregiver strain. J Aging Health. Feb. 1998;10(1):20-43. KQ5E5. [pmid: 10182416].
55 Bass DM, Clark PA, Looman WJ, et al. The Cleveland Alzheimer's managed care demonstration: outcomes after 12 months of implementation. Gerontologist. Feb. 2003;43(1):73-85. KQ5E5. [pmid: 12604748].
56 Bastone AC, Jacob FW. Effect of an exercise program on functional performance of institutionalized elderly. J Rehabil Res Dev. Sep. 2004;41(5):659-68. KQ4E3a, KQ5E3a. [pmid: 15558395].
57 Batman MW. The effects of therapeutic aquatic exercise on patients with Alzheimer's Disease. Diss Abstr Int. 1999;60(6):2933. PMID: None. KQ4E7c, KQ5E7c.
58 Baum EE, Jarjoura D, Polen AE, et al. Effectiveness of a group exercise program in a long-term care facility: a randomized pilot trial. J Am Med Dir Assoc. Mar. 2003;4(2):74-80. KQ4E3b, KQ5E3b. [pmid: 12807578].
59 Beauchamp N, Irvine AB, Seeley J, et al. Worksite-based internet multimedia program for family caregivers of persons with dementia. Gerontologist. Dec. 2005;45(6):793-801. KQ4E3c, KQ5E3c. [pmid: 16326661].
60 Beer C, Flicker L, Horner B, et al. Factors associated with self and informant ratings of the quality of life of people with dementia living in care facilities: a cross sectional study. PLoS One. 2010;5(12):e15621. KQ4E5, KQ5E5. [pmid: 21179448].
61 Beer C, Horner B, Flicker L, et al. A cluster-randomised trial of staff education to improve the quality of life of people with dementia living in residential care: the DIRECT study. PLoS One. 2011;6(11):e28155. KQ5E5. [pmid: 22140531].
62 Beer CD, Horner B, Almeida OP, et al. Dementia in residential care: education intervention trial (DIRECT); protocol for a randomised controlled trial. Trials. 2010;11:63. KQ5E5. [pmid: 20500891].
63 Beinhoff U, Hilbert V, Bittner D, et al. Screening for cognitive impairment: a triage for outpatient care. Dement Geriatr Cogn Disord. 2005;20(5):278-85. KQ2E3c. [pmid: 16158010].
64 Belanoff JK, Jurik J, Schatzberg LD, et al. Slowing the progression of cognitive decline in Alzheimer's disease using mifepristone. J Mol Neurosci. 2002;19(1-2):201-6. KQ4E6b, KQ5E6b. [pmid: 12212781].
65 Bellantonio S, Kenny AM, Fortinsky RH, et al. Efficacy of a geriatrics team intervention for residents in dementia-specific assisted living facilities: effect on unanticipated transitions. J Am Geriatr Soc. Mar. 2008;56(3):523-8. KQ5E5. [pmid: 18179497].
66 Belle SH, Mendelsohn AB, Seaberg EC, et al. A brief cognitive screening battery for dementia in the community. Neuroepidemiology. Jan. 2000;19(1):43-50. KQ2E7c. [pmid: 10654287].
67 Belle SH, Burgio L, Burns R, et al. Enhancing the quality of life of dementia caregivers from different ethnic or racial groups: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2006 Nov 21;145(10):I39; PMID: 17116914]. Ann Int Med. Nov. 21. 2006;145(10):727-38. KQ5E5. [pmid: 17116917].
68 Belleville S, Gilbert B, Fontaine F, et al. Improvement of episodic memory in persons with mild cognitive impairment and healthy older adults: evidence from a cognitive intervention program. Dement Geriatr Cogn Disord. 2006;22(5-6):486-99. KQ4E2c, KQ5E2c. [pmid: 17050952].
69 Bermejo F, Gabriel R, Vega S, et al. Problems and issues with door-to-door, two-phase surveys: an illustration from central Spain. Neuroepidemiology. Oct. 2001;20(4):225-31. KQ3E3c. [pmid: 11684897].
70 Beversdorf DQ, Warner JL, Davis RA, et al. Donepezil in the treatment of Dementia with lewy bodies. Am J Geriatr Psychiatry. 2004;12(5):542-3. KQ4E7c, KQ5E7c. [pmid: 15353396].
71 Bhasin M, Rowan E, Edwards K, et al. Cholinesterase inhibitors in dementia with Lewy bodies: a comparative analysis. Int J Geriatr Psychiatry. Sep. 2007;22(9):890-5. KQ4E2b, KQ5E2b. [pmid: 17265415].
72 Bier JC, Ventura M, Donckels V, et al. Is the Addenbrooke's cognitive examination effective to detect frontotemporal dementia?. J Neurol. Apr. 2004;251(4):428-31. KQ2E3c, KQ3E3c. [pmid: 15083287].
73 Bier JC, Donckels V, Van EE, et al. The French Addenbrooke's cognitive examination is effective in detecting dementia in a French-speaking population. Dement Geriatr Cogn Disord. 2005;19(1):15-7. KQ2E6a. [pmid: 15383740].
74 Black S, Roman GC, Geldmacher DS, et al. Efficacy and tolerability of donepezil in vascular dementia: positive results of a 24-week, multicenter, international, randomized, placebo-controlled clinical trial. Stroke. Oct. 2003;34(10):2323-30. KQ4E8, KQ5E8. [pmid: 12970516].
75 Bland RC, Newman SC. Mild dementia or cognitive impairment: the Modified Mini-Mental State examination (3MS) as a screen for dementia. Can J Psychiatry. Aug. 2001;46(6):506-10. KQ2E6a. [pmid: 11526806].
76 Blass JP, Gleason P, Brush D, et al. Thiamine and Alzheimer's disease. A pilot study. Arch Neurol. Aug. 1988;45(8):833-5. KQ4E7c, KQ5E7c. [pmid: 2969232].
77 Blesa Gonzalez R, Boada RM, Martinez PC, et al. Evaluation of the convenience of changing the rivastigmine administration route in patients with Alzheimer disease. Neurologia. Jun. 2011;26(5):262-71. KQ5E2e. [pmid: 21227548].
78 Boada-Rovira M, Brodaty H, Cras P, et al. Efficacy and safety of donepezil in patients with Alzheimer's disease: results of a global, multinational, clinical experience study. Drugs Aging. 2004;21(1):43-53. KQ4E2a. [pmid: 14715043].
79 Boorsma M, Frijters DHM, Knol DL, et al. Effects of multidisciplinary integrated care on quality of care in residential care facilities for elderly people: A cluster randomized trial. Can Med Assoc J. 2011;183(11):E724-E732. KQ4E1, KQ5E1. [pmid: 21708967].
80 Bordier P, Garrigue S, Lanusse S, et al. Cardiovascular effects and risk of syncope related to donepezil in patients with Alzheimer's disease. CNS Drugs. 2006;20(5):411-7. KQ5E2e. [pmid: 16696580].
81 Borson S, Brush M, Gil E, et al. The Clock Drawing Test: utility for dementia detection in multiethnic elders. J Gerontol A Biol Sci Med Sci. Nov. 1999;54(11):M534-M540. KQ2E3c. [pmid: 10619314].
82 Borson S, Scanlan J, Brush M, et al. The mini-cog: a cognitive 'vital signs' measure for dementia screening in multi-lingual elderly. Int J Geriatr Psychiatry. Nov. 2000;15(11):1021-7. KQ2E3c. [pmid: 11113982].
83 Borson S, Scanlan JM, Chen P, et al. The Mini-Cog as a screen for dementia: validation in a population-based sample. J Am Geriatr Soc. Oct. 2003;51(10):1451-4. KQ2E7c. [pmid: 14511167].
84 Borson S, Scanlan JM, Watanabe J, et al. Simplifying detection of cognitive impairment: comparison of the Mini-Cog and Mini-Mental State Examination in a multiethnic sample. J Am Geriatr Soc. May. 2005;53(5):871-4. KQ2E3c. [pmid: 15877567].
85 Borson S, Scanlan JM, Watanabe J, et al. Improving identification of cognitive impairment in primary care. Int J Geriatr Psychiatry. Apr. 2006;21(4):349-55. KQ3E5. [pmid: 16534774].
86 Bottiggi KA, Salazar JC, Yu L, et al. Concomitant use of medications with anticholinergic properties and acetylcholinesterase inhibitors: impact on cognitive and physical functioning in Alzheimer disease. Am J Geriatr Psychiatry. Apr. 2007;15(4):357-9. KQ5E2e. [pmid: 17384320].
87 Bottino CM, Carvalho IA, Alvarez AM, et al. Cognitive rehabilitation combined with drug treatment in Alzheimer's disease patients: a pilot study. Clin Rehabil. Dec. 2005;19(8):861-9. KQ4E7c, KQ5E7c. [pmid: 16323385].
88 Boustani M, Watson L, Fultz B, et al. Acceptance of dementia screening in continuous care retirement communities: a mailed survey. Int J Geriatr Psychiatry. Sep. 2003;18(9):780-6. KQ3E5. [pmid: 12949845].
89 Boustani M, Callahan CM, Unverzagt FW, et al. Implementing a screening and diagnosis program for dementia in primary care. J Gen Intern Med. Jul. 2005;20(7):572-7. KQ2E7b. [pmid: 16050849].
90 Boustani M, Perkins AJ, Monahan P, et al. Measuring primary care patients' attitudes about dementia screening. Int J Geriatr Psychiatry. Aug. 2008;23(8):812-20. KQ3E5. [pmid: 18232061].
91 Boustani MA, Justiss MD, Frame A, et al. Caregiver and noncaregiver attitudes toward dementia screening. J Am Geriatr Soc. Apr. 2011;59(4):681-6. KQ3E5. [pmid: 21438862].
92 Brandt J, Spencer M, Folstein M. The telephone interview for cognitive status. Neuropsychiatry Neuropsychol Behav Neurol. 1988;1(2):111-8. PMID: None. KQ2E3c.
93 Breitner J, Evans D, Lyketsos C, et al. ADAPT trial data. Am J Med. Mar. 2007;120(3):e3. KQ4E2a, KQ5E2a. [pmid: 17349430].
94 Breitner JC, Baker LD, Montine TJ, et al. Extended results of the Alzheimer's disease anti-inflammatory prevention trial. Alzheimers Dement. Jul. 2011;7(4):402-11. KQ4E1b, KQ5E1b. [pmid: 21784351].
95 Brennan PF, Moore SM, Smyth KA. The effects of a special computer network on caregivers of persons with Alzheimer's disease. Nurs Res. May. 1995;44(3):166-72. KQ5E5. [pmid: 7761293].
96 Breuil V, De Rotrou J, Forette F, et al. Cognitive stimulation of patients with dementia: Preliminary results. Int J Geriatr Psychiatry. 1994;9(3):211-7. PMID: None. KQ4E2c, KQ5E2c.
97 Brittle N, Patel S, Wright C, et al. An exploratory cluster randomized controlled trial of group exercise on mobility and depression in care home residents. Clin Rehabil. Feb. 2009;23(2):146-54. KQ4E1, KQ5E1. [pmid: 19164402].
98 Brodaty H, Gresham M. Effect of a training programme to reduce stress in carers of patients with dementia. BMJ. Dec. 2. 1989;299(6712):1375-9. KQ5E5. [pmid: 2513967].
99 Brodaty H, Peters KE. Cost effectiveness of a training program for dementia carers. Int Psychogeriatr. 1991;3(1):11-22. KQ4E5, KQ5E5. [pmid: 1907508].
100 Brodaty H. Can interventions with family caregivers make a difference to them and to people with dementia. Neurobiol Aging. 1994;15(Suppl 1):S3. PMID: None. KQ4E7c, KQ5E7c.
101 Brodaty H, Roberts K, Peters K. Quasi-experimental evaluation of an educational model for dementia caregivers. Int J Geriatr Psychiatry. 1994;9:195-204. PMID: None. KQ4E7c, KQ5E7c.
102 Brodaty H, Gresham M, Luscombe G. The Prince Henry Hospital dementia caregivers' training programme. Int J Geriatr Psychiatry. Feb. 1997;12(2):183-92. KQ5E5. [pmid: 9097211].
103 Brodaty H, Pond D, Kemp NM, et al. The GPCOG: a new screening test for dementia designed for general practice. J Am Geriatr Soc. Mar. 2002;50(3):530-4. KQ3E5. [pmid: 11943052].
104 Brodaty H, Kemp NM, Low LF. Characteristics of the GPCOG, a screening tool for cognitive impairment. Int J Geriatr Psychiatry. Sep. 2004;19(9):870-4. KQ3E5. [pmid: 15352145].
105 Brodaty H, Corey-Bloom J, Potocnik FC, et al. Galantamine prolonged-release formulation in the treatment of mild to moderate Alzheimer's disease. Dement Geriatr Cogn Disord. 2005;20(2-3):120-32. KQ4E8, KQ5E8. [pmid: 15990426].
106 Brodaty H, Woodward M, Boundy K, et al. A naturalistic study of galantamine for Alzheimer's disease. CNS Drugs. 2006;20(11):935-43. KQ4E2a, KQ5E2e. [pmid: 17044730].
107 Brodaty H, Woodward M, Boundy K, et al. Naturalistic treatment of Alzheimer's disease with galantamine: 12-month follow-up from the NATURE study. CNS Drugs. 2007;21(4):335-6. KQ5E5. [pmid: 17381186].
108 Brodaty H, Mittelman M, Gibson L, et al. The effects of counseling spouse caregivers of people with Alzheimer disease taking donepezil and of country of residence on rates of admission to nursing homes and mortality. Am J Geriatr Psychiatry. Sep. 2009;17(9):734-43. KQ5E5. [pmid: 19705519].
109 Broe GA, Grayson DA, Creasey HM, et al. Anti-inflammatory drugs protect against Alzheimer disease at low doses. Arch Neurol. Nov. 2000;57(11):1586-91. KQ4E2a, KQ5E5. [pmid: 11074790].
110 Brooke P, Bullock R. Validation of a 6 item cognitive impairment test with a view to primary care usage. Int J Geriatr Psychiatry. Nov. 1999;14(11):936-40. KQ2E2d. [pmid: 10556864].
111 Brooker DJ, Argyle E, Scally AJ, et al. The enriched opportunities programme for people with dementia: A cluster-randomised controlled trial in 10 extra care housing schemes. Aging Ment Health. 2011;15(8):1008-17. KQ4E1, KQ5E1. [pmid: 21702705].
112 Brooks JO, Yesavage JA, Carta A, et al. Acetyl L-carnitine slows decline in younger patients with Alzheimer's disease: a reanalysis of a double-blind, placebo-controlled study using the trilinear approach. Int Psychogeriatr. 1998;10(2):193-203. KQ4E6b, KQ5E6b. [pmid: 9677506].
113 Brouillette RM, Martin CK, Correa JB, et al. Memory for names test provides a useful confrontational naming task for aging and continuum of dementia. J Alzheimers Dis. 2011;23(4):655-71. KQ2E2d. [pmid: 21157022].
114 Brouwer IA, van DM, Thomas CMG, et al. Low-Dose folic acid supplementation decreases plasma homocysteine concentrations: a randomised trial. Indian Heart J. Nov. 2000;52(7 Suppl):S53-S58. KQ4E1, KQ5E1. [pmid: 11339442].
115 Brown J, Pengas G, Dawson K, et al. Self administered cognitive screening test (TYM) for detection of Alzheimer's disease: cross sectional study. BMJ. 2009;338:b2030. KQ2E2d. [pmid: 19509424].
116 Bruce JM, McQuiggan M, Williams V, et al. Burden among spousal and child caregivers of patients with mild cognitive impairment. Dement Geriatr Cogn Disord. 2008;25(4):385-90. KQ4E1, KQ5E1. [pmid: 18376128].
117 Bryan J, Calvaresi E, Hughes D. Short-term folate, vitamin B-12 or vitamin B-6 supplementation slightly affects memory performance but not mood in women of various ages. J Nutr. Jun. 2002;132(6):1345-56. KQ4E1b, KQ5E1b. [pmid: 12042457].
118 Buchanan JA. Generalization of the effects of a cognitive-behavioral intervention for family caregivers of individuals with dementia. 65 ed. US. ProQuest Information & Learning. 2004. PMID: None. KQ4E7c, KQ5E7c.
119 Bullock R, Erkinjuntti T, Lilienfeld S. Management of patients with Alzheimer's disease plus cerebrovascular disease: 12-month treatment with Galantamine. Dement Geriatr Cogn Disord. 2004;17(1-2):29-34. KQ4E8, KQ5E8. [pmid: 14560062].
120 Bullock R, Bergman H, Touchon J, et al. Effect of age on response to rivastigmine or donepezil in patients with Alzheimer's disease. Curr Med Res Opin. Mar. 2006;22(3):483-94. KQ4E2b, KQ5E2e. [pmid: 16574032].
121 Burdz MP, Eaton WO, Bond JB Jr. Effect of respite care on dementia and nondementia patients and their caregivers. Psychol Aging. Mar. 1988;3(1):38-42. KQ4E2c, KQ5E5. [pmid: 3268241].
122 Burgener SC, Yang Y, Gilbert R, et al. The effects of a multimodal intervention on outcomes of persons with early-stage dementia. Am J Alzheimers Dis Other Demen. Aug. 2008;23(4):382-94. KQ5E5. [pmid: 18453642].
123 Burgio L, Stevens A, Guy D, et al. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. Aug. 2003;43(4):568-79. KQ5E5. [pmid: 12937335].
124 Burke V, Giangiulio N, Gillam HF, et al. Changes in cognitive measures in a randomized controlled trial of a health promotion program for couples targeting diet and physical activity. Am J Health Promot. 2004;18(4):300-11. KQ4E1b, KQ5E1b. [pmid: 15011930].
125 Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease - results from a multinational trial. Dement Geriatr Cogn Disord. May. 1999;10(3):237-44. KQ4E8, KQ5E8. [pmid: 10325453].
126 Burns A, Guthrie E, Marino-Francis F, et al. Brief psychotherapy in Alzheimer's disease: randomised controlled trial. Br J Psychiatry. Aug. 2005;187:143-7. KQ4E6c, KQ5E6c. [pmid: 16055825].
127 Burns R, Nichols LO, Martindale-Adams J, et al. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. Aug. 2003;43(4):547-55. KQ4E2b, KQ5E2b. [pmid: 12937333].
128 Buschert VC, Friese U, Teipel SJ, et al. Effects of a newly developed cognitive intervention in amnestic mild cognitive impairment and mild Alzheimer's disease: a pilot study. J Alzheimers Dis. 2011;25(4):679-94. KQ5E5. [pmid: 21483095].
129 Buschke H, Kuslansky G, Katz M, et al. Screening for dementia with the memory impairment screen. Neurology. Jan. 15. 1999;52(2):231-8. KQ3E5. [pmid: 9932936].
130 Caffo AO, De Caro MF, Picucci L, et al. Reorientation deficits are associated with amnestic mild cognitive impairment. Am J Alzheimers Dis Other Demen. Aug. 2012;27(5):321-30. KQ2E3c. [pmid: 22815081].
131 Cahn-Weiner DA, Malloy PF, Rebok GW, et al. Results of a randomized placebo-controlled study of memory training for mildly impaired Alzheimer's disease patients. Appl Neuropsychol. 2003;10(4):215-23. KQ5E5. [pmid: 14690802].
132 Calabrese P, Essner U, Forstl H. Memantine (Ebixa) in clinical practice - results of an observational study. Dement Geriatr Cogn Disord. 2007;24(2):111-7. KQ4E4c, KQ5E4c. [pmid: 17622714].
133 Calero MD, Arnedo ML, Navarro E, et al. Usefulness of a 15-item version of the Boston Naming Test in neuropsychological assessment of low-educational elders with dementia. J Gerontol B Psychol Sci Soc Sci. Mar. 2002;57(2):187-91. KQ2E2d. [pmid: 11867666].
134 Callahan CM, Unverzagt FW, Hui SL, et al. Six-item screener to identify cognitive impairment among potential subjects for clinical research. Med Care. Sep. 2002;40(9):771-81. KQ3E5. [pmid: 12218768].
135 Callahan CM, Boustani MA, Unverzagt FW, et al. Effectiveness of collaborative care for older adults with Alzheimer disease in primary care: a randomized controlled trial. JAMA. May. 10. 2006;295(18):2148-57. KQ5E5. [pmid: 16684985].
136 Cameron I, Curran S, Newton P, et al. Use of donepezil for the treatment of mild-moderate Alzheimer's disease: an audit of the assessment and treatment of patients in routine clinical practice. Int J Geriatr Psychiatry. Oct. 2000;15(10):887-91. KQ4E2a, KQ5E2e. [pmid: 11044869].
137 Canonici AP, de Andrade LP, Gobbi S, et al. Functional dependence and caregiver burden in Alzheimer's disease: A controlled trial on the benefits of motor intervention. Psychogeriatrics. 2012;12(3):186-92. KQ4E3a, KQ5E3a. [pmid: 22994617].
138 Carbonin PU, Greco A, Pisanti P, et al. Efficacy of almitrine-raubasine in cognitive disorders of aging: a double-blind, placebo-controlled, clinical and psychometric study. Clin Neuropharmacol. 1990;13(Suppl 3):S92-S99. KQ4E6c, KQ5E6c. [pmid: 2093422].
139 Carmel R, Gott PS, Waters CH, et al. The frequently low cobalamin levels in dementia usually signify treatable metabolic, neurologic and electrophysiologic abnormalities. Eur J Haematol. Apr. 1995;54(4):245-53. KQ4E2a, KQ5E5. [pmid: 7789470].
140 Carnero-Pardo C, Espejo-MartÃnez B, LÃ3pez-Alcalde S, et al. Diagnostic Accuracy, Effectiveness and Cost for Cognitive Impairment and Dementia Screening of Three Short Cognitive Tests Applicable to Illiterates. PLoS One. Nov. 2. 2011;6(11). KQ2E3c. [pmid: 22073256].
141 Carney MW, Cashman MD, King A, et al. Severly demented patients beyond help of drugs. Modern Geriatrics. 1976;6(10):36-9. PMID: None. KQ4E6b, KQ5E6b.
142 Carpenter CR, Bassett ER, Fischer GM, et al. Four sensitive screening tools to detect cognitive dysfunction in geriatric emergency department patients: brief Alzheimer's Screen, Short Blessed Test, Ottawa 3DY, and the caregiver-completed AD8. Acad Emerg Med. Apr. 2011;18(4):374-84. KQ2E7b. [pmid: 21496140].
143 Carpenter CR, DesPain B, Keeling TN, et al. The Six-Item Screener and AD8 for the detection of cognitive impairment in geriatric emergency department patients. Ann Emerg Med. Jun. 2011;57(6):653-61. KQ2E7b. [pmid: 20855129].
144 Carr DB, Gray S, Baty J, et al. The value of informant versus individual's complaints of memory impairment in early dementia. Neurology. Dec. 12. 2000;55(11):1724-6. KQ2E1. [pmid: 11113230].
145 Carrasco MM, Aguera L, Gil P, et al. Safety and effectiveness of donepezil on behavioral symptoms in patients with Alzheimer disease. Alzheimer Dis Assoc Disord. Oct. 2011;25(4):333-40. KQ4E2a, KQ5E2e. [pmid: 21399485].
146 Carthery-Goulart MT, Caramelli P, Nitrini R. The diagnosis of dementia in subjects with heterogeneous educational levels. Maccioni RB, Perry G, editors. Current Hypotheses and Research Milestones in Alzheimer's Disease. Springer. 2009:229-36. PMID: None. KQ2E2a.
147 Castro CM, Wilcox S, O'Sullivan P, et al. An exercise program for women who are caring for relatives with dementia. Psychosom Med. May. 2002;64(3):458-68. KQ5E5. [pmid: 12021419].
148 Ceccato E, Vigato G, Bonetto C, et al. STAM protocol in dementia: A multicenter, single-blind, randomized, and controlled trial. Am J Alzheimers Dis Other Demen. 2012;27(5):301-10. KQ4E6b, KQ5E6b. [pmid: 22815078].
149 Ceramidas DM. Faith-based cognitive behavioral therapy: easing depression in the elderly with cognitive decline. J Christ Nurs. Jan. 2012;29(1):42-8. KQ4E2a, KQ5E2a. [pmid: 22359836].
150 Cercy SP. Diagnostic accuracy of a new instrument for detecting cognitive dysfunction. Int J Geriatr Psychiatry. 2012;27(9):914-23. KQ2E3c. [pmid: 22020766].
151 Cetin E, Top EC, Sahin G, et al. Effect of vitamin E supplementation with exercise on cognitive functions and total antioxidant capacity in older people. J Nutr Health Aging. 2010;14(9):763-9. KQ4E3a, KQ5E3a. [pmid: 21085907].
152 Chan SSM, Li CHM, Pang SLK, et al. Optimal cut-off score on the Chinese version of Executive Interview (C-EXIT25) in a Hong Kong Chinese population. Hong Kong Journal of Psychiatry. 2009;19(3). PMID: None. KQ2E6a.
153 Chandler JM, Duncan PW, Kochersberger G, et al. Is lower extremity strength gain associated with improvement in physical performance and disability in frail, community-dwelling elders?. Arch Phys Med Rehabil. Jan. 1998;79(1):24-30. KQ4E2c, KQ5E2c. [pmid: 9440412].
154 Chandra RK. Effect of vitamin and trace-element supplementation on cognitive function in elderly subjects. Nutrition. Sep. 2001;17(9):709-12. KQ4E1b, KQ5E1b. [pmid: 11527656].
155 Chang BL. Cognitive-behavioral intervention for homebound caregivers of persons with dementia. Nurs Res. May. 1999;48(3):173-82. KQ5E5. [pmid: 10337848].
156 Chang BL, Nitta S, Carter PA, et al. Perceived helpfulness of telephone calls--providing support for caregivers of family members with dementia. J Gerontol Nurs. Sep. 2004;30(9):14-21. KQ4E5, KQ5E5. [pmid: 15471059].
157 Chang JY, Tsai PF, Beck C, et al. The effect of tai chi on cognition in elders with cognitive impairment. Medsurg Nurs. 1970;20(2):63-9. KQ4E2a, KQ5E2a. [pmid: 21560956].
158 Chang SH, Chen CY, Shen SH, et al. The effectiveness of an exercise programme for elders with dementia in a Taiwanese day-care centre. Int J Nurs Pract. 2011;17(3):213-20. KQ4E2a, KQ5E2a. [pmid: 21605260].
159 Chapman SB, Weiner MF, Rackley A, et al. Effects of cognitive-communication stimulation for Alzheimer's disease patients treated with donepezil. J Speech Lang Hear Res. Oct. 2004;47(5):1149-63. KQ5E5. [pmid: 15603468].
160 Charlesworth G, Shepstone L, Wilson E, et al. Does befriending by trained lay workers improve psychological well-being and quality of life for carers of people with dementia, and at what cost? A randomised controlled trial. Health Technol Assess. v. 2008;12(4):iii-iii. 78. KQ5E5. [pmid: 18284895].
161 Charlesworth G, Shepstone L, Wilson E, et al. Befriending carers of people with dementia: randomised controlled trial. BMJ. Jun. 7. 2008;336(7656):1295-7. KQ5E5. [pmid: 18505757].
162 Chen CY, Leung KK, Chen CY. A quick dementia screening tool for primary care physicians. Arch Gerontol Geriatr. Jul. 2011;53(1):100-3. KQ2E7b. [pmid: 20638142].
163 Chenoweth L, King MT, Jeon YH, et al. Caring for Aged Dementia Care Resident Study (CADRES) of person-centred care, dementia-care mapping, and usual care in dementia: a cluster-randomised trial. [Erratum appears in Lancet Neurol. 2009 May;8(5):419]. Lancet Neurol. Apr. 2009;8(4):317-25. KQ4E4c, KQ5E4c. [pmid: 19282246].
164 Cherbuin N, Anstey KJ. DIY dementia screening and online assessment tools. Int Psychogeriatr. Jun. 2008;20(3):641-2. KQ2E2a. [pmid: 18373889].
165 Cherrier MM, Matsumoto AM, Amory JK, et al. Testosterone improves spatial memory in men with Alzheimer disease and mild cognitive impairment. Neurology. Jun. 28. 2005;64(12):2063-8. KQ4E2c, KQ5E5. [pmid: 15985573].
166 Chien WT, Lee YM. A disease management program for families of persons in Hong Kong with dementia. Psychiatr Serv. Apr. 2008;59(4):433-6. KQ4E2b, KQ5E2b. [pmid: 18378844].
167 Chien WT, Lee IY. Randomized controlled trial of a dementia care programme for families of home-resided older people with dementia. J Adv Nurs. Apr. 2011;67(4):774-87. KQ4E2b, KQ5E2b. [pmid: 21198803].
168 Chiu CC, Su KP, Cheng TC, et al. The effects of omega-3 fatty acids monotherapy in Alzheimer's disease and mild cognitive impairment: a preliminary randomized double-blind placebo-controlled study. Prog Neuropsycholpharmacol Biol Psychiatry. Aug. 1. 2008;32(6):1538-44. KQ4E7c, KQ5E7c. [pmid: 18573585].
169 Chiu PY, Dai DE, Hsu HP, et al. Safety/Tolerability and efficacy of rivastigmine in taiwanese patients with Alzheimer's disease: a prospective post-marketing surveillance study. Clin Drug Invest. 2009;29(11):729-38. KQ5E2e. [pmid: 19813776].
170 Chiu TM. Usage and non-usage behaviour of ehealth services among chinese canadians caring for a family member with dementia. 71 ed. US. ProQuest Information & Learning. 2010. PMID: None. KQ4E7c, KQ5E7c.
171 Chiverton P, Caine ED. Education to assist spouses in coping with Alzheimer's disease. A controlled trial. J Am Geriatr Soc. Jul. 1989;37(7):593-8. KQ4E2c, KQ5E2c. [pmid: 2738277].
172 Cho A, Sugimura M, Nakano S, et al. The Japanese MCI screen for early detection of Alzheimer's disease and related disorders. Am J Alzheimers Dis Other Demen. Apr. 2008;23(2):162-6. KQ2E3c. [pmid: 18223126].
173 Chodosh J, Berry E, Lee M, et al. Effect of a dementia care management intervention on primary care provider knowledge, attitudes, and perceptions of quality of care. [Erratum appears in J Am Geriatr Soc. 2006 Sep;54(9):1479]. J Am Geriatr Soc. Feb. 2006;54(2):311-7. KQ4E5, KQ5E5. [pmid: 16460384].
174 Choi SH, Park KW, Na DL, et al. Tolerability and efficacy of memantine add-on therapy to rivastigmine transdermal patches in mild to moderate Alzheimer's disease: a multicenter, randomized, open-label, parallel-group study. Curr Med Res Opin. Jul. 2011;27(7):1375-83. KQ4E2b, KQ5E2e. [pmid: 21561398].
175 Chopard G, Pitard A, Ferreira S, et al. Combining the Memory Impairment Screen and the Isaacs Set Test: a practical tool for screening dementias. J Am Geriatr Soc. Sep. 2007;55(9):1426-30. KQ2E2d. [pmid: 17767686].
176 Christofoletti G, Oliani MM, Gobbi S, et al. A controlled clinical trial on the effects of motor intervention on balance and cognition in institutionalized elderly patients with dementia. Clin Rehabil. Jul. 2008;22(7):618-26. KQ4E3a, KQ5E3a. [pmid: 18586813].
177 Chu H, Yang CY, Liao YH, et al. The effects of a support group on dementia caregivers' burden and depression. J Aging Health. 2011;23(2):228-41. KQ5E5. [pmid: 20847363].
178 Chu LW, Yik PY, Mok W, et al. A 2-year open-label study of galantamine therapy in Chinese Alzheimer's disease patients in Hong Kong. Int J Clin Pract. Mar. 2007;61(3):403-10. KQ4E2a, KQ5E2e. [pmid: 17313606].
179 Chu P, Edwards J, Levin R, et al. The use of clinical case management for early state Alzheimer's patients and their families. Am J Alzheimers Dis Other Demen. 2000;15(5):284-90. PMID: None. KQ5E5.
180 Clare L, Wilson BA, Carter G, et al. Relearning face-name associations in early Alzheimer's disease. Neuropsychol. Oct. 2002;16(4):538-47. KQ4E2a, KQ5E2a. [pmid: 12382992].
181 Clare L, Linden DE, Woods RT, et al. Goal-oriented cognitive rehabilitation for people with early-stage Alzheimer disease: a single-blind randomized controlled trial of clinical efficacy. Am J Geriatr Psychiatry. Oct. 2010;18(10):928-39. KQ5E5. [pmid: 20808145].
182 Clark PA, Bass DM, Looman WJ, et al. Outcomes for patients with dementia from the Cleveland Alzheimer's Managed Care Demonstration. Aging Ment Health. Jan. 2004;8(1):40-51. KQ4E7a, KQ5E7a. [pmid: 14690867].
183 Clarke M, Jagger C, Anderson J, et al. The prevalence of dementia in a total population: a comparison of two screening instruments. Age Ageing. Nov. 1991;20(6):396-403. KQ2E7c. [pmid: 1776585].
184 Clarke R, Harrison G, Richards S, et al. Effect of vitamins and aspirin on markers of platelet activation, oxidative stress and homocysteine in people at high risk of dementia. J Intern Med. Jul. 2003;254(1):67-75. KQ5E5. [pmid: 12823643].
185 Clarke R. Vitamin B12, folic acid, and the prevention of dementia. N Engl J Med. 2006;354(26):2817-9. KQ4E2a, KQ5E2a. [pmid: 16807420].
186 Clarke R. Homocysteine-lowering vitamin B supplements do not improve cognitive performance in healthy older adults after two years. Evid Based Ment Health. Feb. 2007;10(1):27. KQ4E2a, KQ5E2a. [pmid: 17255396].
187 Clay OJ, Roth DL, Wadley VG, et al. Changes in social support and their impact on psychosocial outcome over a 5-year period for African American and White dementia caregivers. Int J Geriatr Psychiatry. Aug. 2008;23(8):857-62. KQ4E2a, KQ5E1. [pmid: 18338341].
188 Clionsky MI, Clionsky E. Development and validation of the Memory Orientation Screening Test (MOSTTM): A better screening test for dementia. Am J Alzheimers Dis Other Demen. Dec. 2010;25(8):650-6. KQ2E3c. [pmid: 21131671].
189 Cockle SM, Haller J, Kimber S, et al. The influence of multivitamins on cognitive function and mood in the elderly. Aging Ment Health. Nov. 1. 2000;4(4):339-53. PMID: None. KQ4E1b, KQ5E1b.
190 Coen RF, Flynn B, Rigney E, et al. Efficacy of a cognitive stimulation therapy programme for people with dementia. Ir J Psychol Med. 2011;28(3):145-7. PMID: None. KQ4E3b, KQ5E3b.
191 Coen RF, Flynn B, Rigney E, et al. Efficacy of cognitive stimulation therapy programme for people with dementia. Ir J Psychol Med. 2011;28(3):145-7. KQ4E3b, KQ5E3b. [pmid: 12948999].
192 Colvez A, Joel ME, Ponton-Sanchez A, et al. Health status and work burden of Alzheimer patients' informal caregivers: comparisons of five different care programs in the European Union. Health Policy. Jun. 2002;60(3):219-33. KQ4E2a, KQ5E2a. [pmid: 11965332].
193 Commissaris K, Verhey FR, Jolles J. A controlled study into the effects of psychoeducation for patients with cognitive disturbances. J Neuropsychiatry Clin Neurosci. 1996;8(4):429-35. KQ4E2b, KQ5E2b. [pmid: 9116480].
194 Conlin MM, Caranasos GJ, Davidson RA. Reduction of caregiver stress by respite care: a pilot study. South Med J. Nov. 1992;85(11):1096-100. KQ4E2c, KQ5E5. [pmid: 1439947].
195 Connell CM, Janevic MR. Effects of a telephone-based exercise intervention for dementia caregiving wives: A randomized controlled trial. J Appl Gerontol. 2009;28(2):171-94. KQ5E5. [pmid: 21709757].
196 Connelly PJ, Prentice NP, Cousland G, et al. A randomised double-blind placebo-controlled trial of folic acid supplementation of cholinesterase inhibitors in Alzheimer's disease. Int J Geriatr Psychiatry. Feb. 2008;23(2):155-60. KQ5E5. [pmid: 17600848].
197 Connor KI, Neese-Smith DK, Vickrey BG, et al. Determining care management activities associated with mastery and relationship strain for dementia caregivers. J Am Geriatr Soc. May. 2008;56(5):891-7. KQ4E5, KQ5E5. [pmid: 18384590].
198 Cook C, Fay S, Rockwood K. Decreased initiation of usual activities in people with mild-to-moderate Alzheimer's disease: a descriptive analysis from the VISTA clinical trial. Int Psychogeriatr. Oct. 2008;20(5):952-63. KQ4E5, KQ5E5. [pmid: 18405399].
199 Cook SE, Marsiske M, McCoy KJ. The use of the Modified Telephone Interview for Cognitive Status (TICS-M) in the detection of amnestic mild cognitive impairment. J Geriatr Psychiatry Neurol. Jun. 2009;22(2):103-9. KQ3E5. [pmid: 19417219].
200 Coon DW, Thompson L, Steffen A, et al. Anger and depression management: psychoeducational skill training interventions for women caregivers of a relative with dementia. Gerontologist. Oct. 2003;43(5):678-89. KQ5E5. [pmid: 14570964].
201 Corey-Bloom J, Anand R, Veach J. A randomized trial evaluating the efficacy and safety of ENA 713 (rivastigmine tartrate), a new acetylcholinesterase inhibitor, in patients with mild ot moderately severe Alzheimer's disease. Int J Geriatr Psychopharmacol. 1998;1(2):55-65. PMID: None. KQ4E8, KQ5E8.
202 Cortes F, Portet F, Touchon J, et al. Six and 18-month changes in mild to moderate Alzheimer's patients treated with acetylcholinesterase inhibitors: what can we learn for clinical outcomes of therapeutic trials?. J Nutr Health Aging. Jul. 2007;11(4):330-7. KQ4E2a, KQ5E5. [pmid: 17653493].
203 Courtney C, Farrell D, Gray R, et al. Long-term donepezil treatment in 565 patients with Alzheimer's disease (AD2000): randomised double-blind trial. Lancet. Jun. 26. 2004;363(9427):2105-15. KQ4E8, KQ5E8. [pmid: 15220031].
204 Crane PK, Doody RS. Donepezil treatment of patients with MCI: a 48-week randomized, placebo- controlled trial--Letter to the Editor. Neurology. 2009;73(18):1514-5. KQ4E2a, KQ5E2a. [pmid: 19884584].
205 Cromwell DA, Eagar K, Poulos RG. The performance of instrumental activities of daily living scale in screening for cognitive impairment in elderly community residents. J Clin Epidemiol. Feb. 2003;56(2):131-7. KQ2E7b. [pmid: 12654407].
206 Crooks VC, Clark L, Petitti DB, et al. Validation of multi-stage telephone-based identification of cognitive impairment and dementia. BMC Neurol. 2005;5(1):8. KQ2E3c. [pmid: 15829005].
207 Crooks VC, Buckwalter JG, Petitti DB, et al. Self-reported severe memory problems as a screen for cognitive impairment and dementia. Dementia. Nov. 1. 2005;4(4):539-51. PMID: None. KQ2E7b.
208 Croston J, Meuser TM, Berg-Weger M, et al. Driving Retirement in Older Adults with Dementia. Top Geriatr Rehabil. Apr. 1. 2009;25(2):154-62. KQ4E1, KQ5E1. [pmid: 20161565].
209 Crowell TA, Paramadevan J, Abdullah L, et al. Beneficial effect of cholinesterase inhibitor medications on recognition memory performance in mild to moderate Alzheimer's disease: preliminary findings. J Geriatr Psychiatry Neurol. Mar. 2006;19(1):13-5. KQ4E2b, KQ5E5. [pmid: 16449754].
210 Cruz-Orduna I, Bellon JM, Torrero P, et al. Detecting MCI and dementia in primary care: efficiency of the MMS, the FAQ and the IQCODE. Fam Pract. Aug. 2012;29(4):401-6. KQ3E5. [pmid: 22121012].
211 Cullen B, Fahy S, Cunningham CJ, et al. Screening for dementia in an Irish community sample using MMSE: a comparison of norm-adjusted versus fixed cut-points. Int J Geriatr Psychiatry. Apr. 2005;20(4):371-6. KQ3E5. [pmid: 15799072].
212 Cummings JL, Cyrus PA, Bieber F, et al. Metrifonate treatment of the cognitive deficits of Alzheimer's disease. Metrifonate Study Group. [Erratum appears in Neurology 1998 Jul;51(1):332]. Neurology. May. 1998;50(5):1214-21. KQ4E6b, KQ5E6b. [pmid: 9595966].
213 Cummings JL, Schneider L, Tariot PN, et al. Reduction of behavioral disturbances and caregiver distress by galantamine in patients with Alzheimer's disease. Am J Psychiatry. Mar. 2004;161(3):532-8. KQ4E8, KQ5E8. [pmid: 14992980].
214 Cummings JL. Searching for methods to detect, prevent, and treat Alzheimer's disease. Am J Psychiatry. Apr. 2005;162(4):645-7. KQ2E2a, KQ3E2a, KQ4E2a, KQ5E2a. [pmid: 15800132].
215 Cusi C, Cantisani TA, Celani MG, et al. Galantamine for Alzheimer's disease and mild cognitive impairment. Neuroepidemiology. 2007;28(2):116-7. KQ4E2a, KQ5E2a. [pmid: 17409773].
216 Czaja SJ, Schulz R, Belle SH, et al. Data and safety monitoring in social behavioral intervention trials: the REACH II experience. Clinical Trials. 2006;3(2):107-18. KQ5E5. [pmid: 16773953].
217 Daiello LA, Ott BR, Festa EK, et al. Effects of cholinesterase inhibitors on visual attention in drivers with Alzheimer disease. J Clin Psychopharmacol. Jun. 2010;30(3):245-51. KQ5E2e. [pmid: 20473058].
218 Damian AM, Jacobson SA, Hentz JG, et al. The Montreal Cognitive Assessment and the mini-mental state examination as screening instruments for cognitive impairment: item analyses and threshold scores. Dement Geriatr Cogn Disord. 2011;31(2):126-31. KQ2E3c. [pmid: 21282950].
219 Dautzenberg PL, Wouters CJ, Bootsma JE. Observations from a 14-week open-label trial with memantine suggest variable response on behavioral symptoms and cognition, depending on former treatment of AD. Int Psychogeriatr. Mar. 2006;18(1):179-81. KQ4E2a, KQ5E2e. [pmid: 16734932].
220 Davis LL, Burgio LD, Buckwalter KC, et al. A comparison of in-home and telephone-based skill training interventions with caregivers of persons with Dementia. J Ment Health Aging. 2004;10(1):31-44. PMID: None. KQ4E7c, KQ5E7c.
221 Davis RN, Massman PJ, Doody RS. Cognitive intervention in Alzheimer disease: a randomized placebo-controlled study. Alzheimer Dis Assoc Disord. Jan. 2001;15(1):1-9. KQ4E2c, KQ5E2c. [pmid: 11236819].
222 Davous P, Lamour Y, Debrand E, et al. A comparative evaluation of the short orientation memory concentration test of cognitive impairment. J Neurol Neurosurg Psychiatry. Oct. 1987;50(10):1312-7. KQ2E3c. [pmid: 3681309].
223 de Jager CA, Milwain E, Budge M. Early detection of isolated memory deficits in the elderly: the need for more sensitive neuropsychological tests. Psychol Med. Apr. 2002;32(3):483-91. KQ2E5. [pmid: 11989993].
224 de Jager CA, Budge MM, Clarke R. Utility of TICS-M for the assessment of cognitive function in older adults. Int J Geriatr Psychiatry. Apr. 2003;18(4):318-24. KQ2E5. [pmid: 12673608].
225 de Jesus Moreno Moreno M. Cognitive Improvement in Mild to Moderate Alzheimer's Dementia After Treatment with the Acetylcholine Precursor Choline Alfoscerate: A Multicenter, Double-Blind, Randomized, Placebo-Controlled Trial. Clin Ther. 2003;25(1):178-93. KQ4E6c, KQ5E6c. [pmid: 12637119].
226 de Jong N, Chin APM, de Groot LC, et al. Nutrient-dense foods and exercise in frail elderly: effects on B vitamins, homocysteine, methylmalonic acid, and neuropsychological functioning. Am J Clin Nutr. Feb. 2001;73(2):338-46. KQ4E6b, KQ5E6b. [pmid: 11157333].
227 De Lepeleire J, Heyrman J, Baro F, et al. A combination of tests for the diagnosis of dementia had a significant diagnostic value. J Clin Epidemiol. Mar. 2005;58(3):217-25. KQ2E3c. [pmid: 15718109].
228 de Paula JJ, Moreira L, Nicolato R, et al. The Tower of London Test: different scoring criteria for diagnosing Alzheimer's disease and mild cognitive impairment. Psychol Rep. Apr. 2012;110(2):477-88. KQ2E3a. [pmid: 22662402].
229 de Paula JJ, Bertola L, Nicolato R, et al. Evaluating language comprehension in Alzheimer's disease: The use of the Token test. Arq Neuropsiquiatr. 2012;70(6):435-40. KQ2E2d. [pmid: 22699541].
230 De Rotrou J, Cantegreil I, Faucounau V, et al. Do patients diagnosed with Alzheimer's disease benefit from a psycho-educational programme for family caregivers? A randomised controlled study. Int J Geriatr Psychiatry. Aug. 2011;26(8):833-42. KQ5E5. [pmid: 20922772].
231 De Rotrou J, Wu YH, Hugonot-Diener L, et al. DAD-6: A 6-item version of the Disability Assessment for Dementia Scale which may differentiate Alzheimer's disease and mild cognitive impairment from controls. Dement Geriatr Cogn Disord. 2012;33(2-3):210-8. KQ2E3c. [pmid: 22584691].
232 de Rover M, Morein-Zamir S, Sahakian BJ. Early detection of mild cognitive impairment and Alzheimer's disease: An example using the CANTAB PAL. Cooper CL, Field J, Goswami U, et al., editors. Mental capital and wellbeing. Chichester, West Sussex, UK; Ames, Iowa. Wiley-Blackwell. 2010:149-56. PMID: None. KQ2E2a.
233 De Silva ML, McLaughlin MT, Rodrigues EJ, et al. A Mini-Mental Status Examination for the hearing impaired. Age Ageing. Sep. 2008;37(5):593-5. KQ2E3c. [pmid: 18687874].
234 Deakin JB, Rahman S, Nestor PJ, et al. Paroxetine does not improve symptoms and impairs cognition in frontotemporal dementia: a double-blind randomized controlled trial. Psychopharmacology (Berl). Apr. 2004;172(4):400-8. KQ4E6b, KQ5E6b. [pmid: 14666399].
235 Deijen JB, van der Beek EJ, Orlebeke JF, et al. Vitamin B-6 supplementation in elderly men: effects on mood, memory, performance and mental effort. Psychopharmacology (Berl). 1992;109(4):489-96. KQ4E1b, KQ5E1b. [pmid: 1365868].
236 Del Ser T, Sanchez-Sanchez F, Garcia de Yebenes MJ, et al. Validation of the seven-minute screen neurocognitive battery for the diagnosis of dementia in a Spanish population-based sample. Dement Geriatr Cogn Disord. 2006;22(5-6):454-64. KQ3E5. [pmid: 16988506].
237 Devi G, Massimi S, Schultz S, et al. A double-blind, placebo-controlled trial of donepezil for the treatment of menopause-related cognitive loss. Gender Medicine. Dec. 2007;4(4):352-8. KQ4E1b, KQ5E1b. [pmid: 18215726].
238 Dias A, Dewey ME, D'Souza J, et al. The effectiveness of a home care program for supporting caregivers of persons with dementia in developing countries: a randomised controlled trial from Goa, India. PLoS One. 2008;3(6):e2333. KQ4E3a, KQ5E3a. [pmid: 18523642].
239 Dichgans M, Markus HS, Salloway S, et al. Donepezil in patients with subcortical vascular cognitive impairment: a randomised double-blind trial in CADASIL. Lancet Neurol. Apr. 2008;7(4):310-8. KQ4E4a, KQ5E4a. [pmid: 18296124].
240 Doi T, Makizako H, Shimada H, et al. Effects of multicomponent exercise on spatial-temporal gait parameters among the elderly with amnestic mild cognitive impairment (aMCI): Preliminary results from a randomized controlled trial (RCT). Arch Gerontol Geriatr. Jan. 2013;56(1):104-8. KQ4E5, KQ5E5. [pmid: 23063111].
241 Donath C, Grassel E, Grossfeld-Schmitz M, et al. Effects of general practitioner training and family support services on the care of home-dwelling dementia patients--results of a controlled cluster-randomized study. BMC Health Serv Res. 2010;10:314. KQ4E5, KQ5E5. [pmid: 21087474].
242 Done DJ, Thomas JA. Training in communication skills for informal carers of people suffering from dementia: a cluster randomized clinical trial comparing a therapist led workshop and a booklet. Int J Geriatr Psychiatry. Aug. 2001;16(8):816-21. KQ4E2c, KQ5E2c. [pmid: 11536349].
243 Doniger GM, Simon ES. Computerized cognitive testing in aging. Alzheimers Dement. Sep. 2009;5(5):439-40. KQ2E2a, KQ3E2a. [pmid: 19751926].
244 Donnelly K, Donnelly JP, Cory E. Primary care screening for cognitive impairment in elderly veterans. Am J Alzheimers Dis Other Demen. Jun. 2008;23(3):218-26. KQ3E5. [pmid: 18375531].
245 Doody RS, Dunn JK, Clark CM, et al. Chronic donepezil treatment is associated with slowed cognitive decline in Alzheimer's disease. Dement Geriatr Cogn Disord. 2001;12(4):295-300. KQ4E2a, KQ5E5. [pmid: 11351141].
246 Doody RS, Corey-Bloom J, Zhang R, et al. Safety and tolerability of donepezil at doses up to 20 mg/day: results from a pilot study in patients with Alzheimer's disease. Drugs Aging. 2008;25(2):163-74. KQ4E2b, KQ5E2e. [pmid: 18257603].
247 Doody RS, Geldmacher DS, Farlow MR, et al. Efficacy and safety of donepezil 23 mg versus donepezil 10 mg for moderate-to-severe Alzheimer's disease: a subgroup analysis in patients already taking or not taking concomitant memantine. Dement Geriatr Cogn Disord. 2012;33(2-3):164-73. KQ4E4c, KQ5E4c. [pmid: 22572767].
248 Dooley NR, Hinojosa J. Improving quality of life for persons with Alzheimer's disease and their family caregivers: brief occupational therapy intervention. Am J Occup Ther. Sep. 2004;58(5):561-9. KQ4E2c, KQ5E2c. [pmid: 15481783].
249 Doraiswamy PM, Krishnan KR, Oxman T, et al. Does antidepressant therapy improve cognition in elderly depressed patients?. J Gerontol A Biol Sci Med Sci. 2003;58(12):M1137-M1144. KQ4E6b, KQ5E6b. [pmid: 14684712].
250 Drachman DA, Swearer JM, Kane K, et al. The cognitive assessment screening test (CAST) for dementia. J Geriatr Psychiatry Neurol. Oct. 1996;9(4):200-8. KQ2E2d. [pmid: 8970013].
251 Drentea P, Clay OJ, Roth DL, et al. Predictors of improvement in social support: Five-year effects of a structured intervention for caregivers of spouses with Alzheimer's disease. Soc Sci Med. Aug. 2006;63(4):957-67. KQ4E5, KQ5E5. [pmid: 16616406].
252 Droes RM, Breebaart E, Ettema TP, et al. Effect of integrated family support versus day care only on behavior and mood of patients with dementia. Int Psychogeriatr. 2000;12(1):99-115. KQ4E4c, KQ5E5c. [pmid: 10798457].
253 Droes RM, Meiland FJM, Schmitz M, et al. Effect of combined support for people with dementia and carers versus regular day care on behaviour and mood of persons with dementia: Results from a multi-centre implementation study. Tijdschr Gerontol Geriatr. 2005;36(2):60-71. PMID: None. KQ4E2a, KQ5E2a.
254 Drummond MF, Mohide EA, Tew M, et al. Economic evaluation of a support program for caregivers of demented elderly. Int J Technol Assess Health Care. 1991;7(2):209-19. KQ4E4c, KQ5E4c. [pmid: 1907599].
255 Dsurney J. TEST REVIEW: Alzheimer's Quick Test: Assessment Of Parietal Lobe Function. Appl Neuropsychol. 2007;14(3):232-3. KQ2E6a, KQ3E6a. [pmid: 17848135].
256 Ducharme F, Levesque L, Giroux F, et al. Follow-up of an intervention program for caregivers of a relative with dementia living in a long-term care setting: Are there any persistent and delayed effects?. Aging Ment Health. Sep. 2005;9(5):461-9. KQ4E3b, KQ5E3b. [pmid: 16024406].
257 Ducharme FC, Levesque LL, Lachance LM, et al. “Learning to become a family caregiver” efficacy of an intervention program for caregivers following diagnosis of dementia in a relative. Gerontologist. Aug. 2011;51(4):484-94. KQ5E5. [pmid: 21383112].
258 Dunbar F, Zhu Y, Brashear HR. Post hoc comparison of daily rates of nausea and vomiting with once- and twice-daily galantamine from a double-blind, placebo-controlled, parallel-group, 6-month study. Clin Ther. Mar. 2006;28(3):365-72. KQ5E8. [pmid: 16750451].
259 Durga J, van Boxtel MP, Schouten EG, et al. Effect of 3-year folic acid supplementation on cognitive function in older adults in the FACIT trial: a randomised, double blind, controlled trial. Lancet. Jan. 20. 2007;369(9557):208-16. KQ4E1b, KQ5E1b. [pmid: 17240287].
260 Duru OK, Ettner SL, Vassar SD, et al. Cost evaluation of a coordinated care management intervention for dementia. Am J Manag Care. Aug. 2009;15(8):521-8. KQ5E5. [pmid: 19670955].
261 Dwolatzky T, Dimant L, Simon ES, et al. Validity of a short computerized assessment battery for moderate cognitive impairment and dementia. Int Psychogeriatr. Aug. 2010;22(5):795-803. KQ2E3c. [pmid: 20519066].
262 Dysken M, Kuskowski M, Love S. Ondansetron in the treatment of cognitive decline in Alzheimer dementia. Am J Geriatr Psychiatry. 2002;10(2):212-5. KQ4E6b, KQ5E6b. [pmid: 11925283].
263 Edwards K, Royall D, Hershey L, et al. Efficacy and safety of galantamine in patients with dementia with Lewy bodies: a 24-week open-label study. Dement Geriatr Cogn Disord. 2007;23(6):401-5. KQ4E2a, KQ5E2e. [pmid: 17409748].
264 Eggermont LH, Blankevoort CG, Scherder EJ. Walking and night-time restlessness in mild-to-moderate dementia: a randomized controlled trial. Age Ageing. Nov. 2010;39(6):746-9. KQ4E3b, KQ5E3b. [pmid: 20823127].
265 Ehreke L, Luppa M, Luck T, et al. Is the clock drawing test appropriate for screening for mild cognitive impairment?--Results of the German study on Ageing, Cognition and Dementia in Primary Care Patients (AgeCoDe). Dement Geriatr Cogn Disord. 2009;28(4):365-72. KQ3E5. [pmid: 19887799].
266 Ehreke L, Luppa M, Konig HH, et al. Does the clock drawing test predict dementia? Results of the Leipzig longitudinal study of the aged (LEILA 75+). Dement Geriatr Cogn Disord. 2011;31(2):89-97. KQ2E1. [pmid: 21242690].
267 Eisdorfer C, Czaja SJ, Loewenstein DA, et al. The effect of a family therapy and technology-based intervention on caregiver depression. Gerontologist. Aug. 2003;43(4):521-31. KQ4E4c, KQ5E4c. [pmid: 12937331].
268 Elliott AF, Burgio LD, DeCoster J. Enhancing caregiver health: findings from the resources for enhancing Alzheimer's caregiver health II intervention. J Am Geriatr Soc. Jan. 2010;58(1):30-7. KQ5E5. [pmid: 20122038].
269 Eloniemi-Sulkava U, Sivenius J, et al. Support program for demented patients and their carers: The role of dementia family care coordinator is crucial. Iqbal K, Swaab DF, Winblad B, et al., editors. Alzheimer's Disease and Related Disorders. West Susex. John Wiley & Sons. 1999:795-802. PMID: None. KQ4E5, KQ5E5.
270 Eloniemi-Sulkava U, Notkola IL, Hentinen M, et al. Effects of supporting community-living demented patients and their caregivers: a randomized trial. J Am Geriatr Soc. Oct. 2001;49(10):1282-7. KQ5E5. [pmid: 11890485].
271 Eloniemi-Sulkava U, Saarenheimo M, Laakkonen ML, et al. Family care as collaboration: effectiveness of a multicomponent support program for elderly couples with dementia. Randomized controlled intervention study. J Am Geriatr Soc. Dec. 2009;57(12):2200-8. KQ5E5. [pmid: 20121986].
272 Emeriau JP, Lehert P, Mosnier M. Efficacy of naftidrofuryl in patients with vascular or mixed dementia: Results of a multicenter, double-blind trial. Clin Ther. 2000;22(7):834-44. KQ4E6c, KQ5E6c. [pmid: 10945510].
273 Engedal K. Day care for demented patients in general nursing homes. Effects on admissions to institutions and mental capacity. Scand J Prim Health Care. Oct. 1989;7(3):161-6. KQ4E6c, KQ5E6c. [pmid: 2511612].
274 Engedal K, Davis B, Richarz U, et al. Two galantamine titration regimens in patients switched from donepezil. Acta Neurol Scand. Jul. 2012;126(1):37-44. KQ4E2b, KQ5E2e. [pmid: 21992111].
275 Erkinjuntti T, Sulkava R, Wikstrom J, et al. Short Portable Mental Status Questionnaire as a screening test for dementia and delirium among the elderly. J Am Geriatr Soc. May. 1987;35(5):412-6. KQ3E5. [pmid: 3571790].
276 Erkinjuntti T, Skoog I, Lane R, et al. Rivastigmine in patients with Alzheimer's disease and concurrent hypertension. Int J Clin Pract. Dec. 2002;56(10):791-6. KQ4E8, KQ5E8. [pmid: 12510954].
277 Erkinjuntti T, Kurz A, Gauthier S, et al. Efficacy of galantamine in probable vascular dementia and Alzheimer's disease combined with cerebrovascular disease: a randomised trial. Lancet. Apr. 13. 2002;359(9314):1283-90. KQ4E8, KQ5E8. [pmid: 11965273].
278 Erkinjuntti T, Gauthier S, Bullock R, et al. Galantamine treatment in Alzheimer's disease with cerebrovascular disease: responder analyses from a randomized, controlled trial (GAL-INT-6). J Psychopharmacol (Oxf). Sep. 2008;22(7):761-8. KQ4E8, KQ5E8. [pmid: 18308781].
279 Erkinjuntti T, Kurz A, Small GW, et al. An open-label extension trial of galantamine in patients with probable vascular dementia and mixed dementia. Clin Ther. 2003;25(6):1765-82. KQ4E2a, KQ5E8. [pmid: 12860497].
280 Espeland MA, Rapp SR, Shumaker SA, et al. Conjugated equine estrogens and global cognitive function in postmenopausal women: Women's Health Initiative Memory Study. JAMA. Jun. 23. 2004;291(24):2959-68. KQ4E1b, KQ5E1b. [pmid: 15213207].
281 Espeland MA, Brunner RL, Hogan PE, et al. Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women's Health Initiative study of cognitive aging extension. J Am Geriatr Soc. Jul. 2010;58(7):1263-71. KQ4E1b, KQ5E1b. [pmid: 20649689].
282 Eussen SJ, de Groot LC, Joosten LW, et al. Effect of oral vitamin B-12 with or without folic acid on cognitive function in older people with mild vitamin B-12 deficiency: a randomized, placebo-controlled trial. Am J Clin Nutr. Aug. 2006;84(2):361-70. KQ4E4b, KQ5E4b. [pmid: 16895884].
283 Evers A, Klusmann V, Schwarzer R, et al. Improving cognition by adherence to physical or mental exercise: a moderated mediation analysis. Aging Ment Health. May. 2011;15(4):446-55. KQ4E1b, KQ5E1b. [pmid: 21500011].
284 Farina E, Mantovani F, Fioravanti R, et al. Efficacy of recreational and occupational activities associated to psychologic support in mild to moderate Alzheimer disease: a multicenter controlled study. Alzheimer Dis Assoc Disord. Oct. 2006;20(4):275-82. KQ4E2a, KQ5E2a. [pmid: 17132973].
285 Farlow M, Gracon SI, Hershey LA, et al. A controlled trial of tacrine in Alzheimer's disease. The Tacrine Study Group. JAMA. 1992;268(18):2523-9. KQ4E7c, KQ5E7c. [pmid: 1404819].
286 Farlow M, Potkin S, Koumaras B, et al. Analysis of outcome in retrieved dropout patients in a rivastigmine vs placebo, 26-week, Alzheimer disease trial. Arch Neurol. Jun. 2003;60(6):843-8. KQ4E1, KQ5E1. [pmid: 12810489].
287 Farlow M, Veloso F, Moline M, et al. Safety and tolerability of donepezil 23 mg in moderate to severe Alzheimer's disease. BMC Neurol. 2011;11:57. KQ4E4c, KQ5E4c. [pmid: 21612646].
288 Farlow MR, Lilly ML, Study Group. Rivastigmine: an open-label, observational study of safety and effectiveness in treating patients with Alzheimer's disease for up to 5 years. BMC Geriatr. 2005;5:3. KQ5E5. [pmid: 15659242].
289 Farlow MR, Graham SM, Alva G. Memantine for the treatment of Alzheimer's disease: tolerability and safety data from clinical trials. Drug Saf. 2008;31(7):577-85. KQ5E5. [pmid: 18558791].
290 Farlow MR, Salloway S, Tariot PN, et al. Effectiveness and tolerability of high-dose (23 mg/d) versus standard-dose (10 mg/d) donepezil in moderate to severe Alzheimer's disease: A 24-week, randomized, double-blind study. Clin Ther. Jul. 2010;32(7):1234-51. KQ4E4c, KQ5E4c. [pmid: 20678673].
291 Farlow MR, Alva G, Meng X, et al. A 25-week, open-label trial investigating rivastigmine transdermal patches with concomitant memantine in mild-to-moderate Alzheimer's disease: a post hoc analysis. Curr Med Res Opin. Feb. 2010;26(2):263-9. KQ4E2b, KQ5E2e. [pmid: 19929593].
292 Farlow MR, Grossberg GT, Meng X, et al. Rivastigmine transdermal patch and capsule in Alzheimer's disease: influence of disease stage on response to therapy. Int J Geriatr Psychiatry. Dec. 2011;26(12):1236-43. KQ5E5. [pmid: 22068922].
293 Farran CJ, Gilley DW, McCann JJ, et al. Psychosocial interventions to reduce depressive symptoms of dementia caregivers: A randomized clinical trial comparing two approaches. J Ment Health Aging. 2004;10(4):337-50. PMID: None. KQ4E2b, KQ5E2b.
294 Fayers PM, Hjermstad MJ, Ranhoff AH, et al. Which mini-mental state exam items can be used to screen for delirium and cognitive impairment?. J Pain Symptom Manage. Jul. 2005;30(1):41-50. KQ2E3c, KQ3E3c. [pmid: 16043006].
295 Feldman H, Gauthier S, Hecker J, et al. Efficacy of donepezil on maintenance of activities of daily living in patients with moderate to severe Alzheimer's disease and the effect on caregiver burden. J Am Geriatr Soc. Jun. 2003;51(6):737-44. KQ4E4c, KQ5E4c. [pmid: 12757558].
296 Feldman HH, Jacova C. Assessing mental status in dementia: the behavioral neurology assessment--right time? Right place?. Can J Neurol Sci. May. 2005;32(2):138-9. KQ2E6a, KQ3E6a. [pmid: 16018148].
297 Feldman HH, Ferris S, Winblad B, et al. Effect of rivastigmine on delay to diagnosis of Alzheimer's disease from mild cognitive impairment: the InDDEx study. Lancet Neurol. Jun. 2007;6(6):501-12. KQ4E7c, KQ5E7c. [pmid: 17509485].
298 Feliciano L, Horning SM, Klebe KJ, et al. Utility of the SLUMS as a Cognitive Screening Tool Among a Nonveteran Sample of Older Adults. Am J Geriatr Psychiatry. 2012. Jul. 27. KQ2E5.
299 Ferrucci L, Del L I, Guralnik JM, et al. Is the telephone interview for cognitive status a valid alternative in persons who cannot be evaluated by the Mini Mental State Examination?. Aging (Milano). Aug. 1998;10(4):332-8. KQ2E7b. [pmid: 9825025].
300 Fiatarone MA, O'Neill EF, Ryan ND, et al. Exercise training and nutritional supplementation for physical frailty in very elderly people. N Engl J Med. Jun. 23. 1994;330(25):1769-75. KQ4E3b, KQ5E3b. [pmid: 8190152].
301 Figiel GS, Sadowsky CH, Strigas J, et al. Safety and efficacy of rivastigmine in patients with Alzheimer's disease not responding adequately to donepezil: an open-label study. Prim Care Companion J Clin Psychiatry. 2008;10(4):291-8. KQ5E2e. [pmid: 18787673].
302 Filip V, Kolibás E. Selegiline in the treatment of Alzheimer's disease: a long-term randomized placebo-controlled trial. Czech and Slovak Senile Dementia of Alzheimer Type Study Group. J Psychiatry Neurosci. 1999;24(3):234-43. KQ4E6b, KQ5E6b. [pmid: 10354658].
303 Fillenbaum G, Heyman A, Williams K, et al. Sensitivity and specificity of standardized screens of cognitive impairment and dementia among elderly black and white community residents. J Clin Epidemiol. 1990;43(7):651-60. KQ3E5. [pmid: 2370572].
304 Fillenbaum GG, Landerman LR, Simonsick EM. Equivalence of two screens of cognitive functioning: the Short Portable Mental Status Questionnaire and the Orientation-Memory-Concentration test. J Am Geriatr Soc. Dec. 1998;46(12):1512-8. KQ2E7b. [pmid: 9848811].
305 Fillit H. Atorvastatin does not slow cognitive decline in patients with mild to moderate probable Alzheimer's disease who are taking donepezil. Evid Based Ment Health. Jul. 20. 2010;13(4):117. KQ4E2a, KQ5E2a. [pmid: 21036979].
306 Finkel S, Czaja SJ, Schulz R, et al. E-care: a telecommunications technology intervention for family caregivers of dementia patients. Am J Geriatr Psychiatry. May. 2007;15(5):443-8. KQ5E5. [pmid: 17463195].
307 Finn M, McDonald S. Computerised cognitive training for older persons with mild cognitive impairment: A pilot study using a randomised controlled trial design. Brain Impair. 2011;12(3):187-99. PMID: None. KQ4E2c, KQ5E2c.
308 Fioravanti M, Ferrario E, Massaia M, et al. Low folate levels in the cognitive declide of elderly patients and efficacy of folate as a treatment for improving memory deficits. Arch Gerontol Geriatr. 1997;26(1):1-13. KQ4E1, KQ5E1. [pmid: 18653121].
309 Fischer-Terworth C, Probst P. Evaluation of a TEACCH- and music therapy-based psychological intervention in mild to moderate dementia: A controlled trial. GeroPsych. 2011;24(2):93-101. PMID: None. KQ4E6c, KQ5E6c.
310 Flicker L, Grimley EJ. Piracetam for dementia or cognitive impairment. Cochrane Database Sys Rev. 2000;(2):CD001011. KQ4E6b, KQ5E6b. [pmid: 10796585].
311 Flicker L, Grimley EG. Piracetam for dementia or cognitive impairment. Cochrane Database Sys Rev. 2001;(2):CD001011. KQ4E6b, KQ5E6b. [pmid: 11405971].
312 Flicker L, Martins RN, Thomas J, et al. B-vitamins reduce plasma levels of beta amyloid. Neurobiol Aging. Feb. 2008;29(2):303-5. KQ4E5, KQ5E5. [pmid: 17113685].
313 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. Nov. 1975;12(3):189-98. KQ2E3c. [pmid: 1202204].
314 Fong TG, Jones RN, Rudolph JL, et al. Development and validation of a brief cognitive assessment tool: the sweet 16. Arch Intern Med. Mar. 14. 2011;171(5):432-7. KQ3E5. [pmid: 21059967].
315 Forbes D. A support programme for patients with dementia and their caregivers lowered institutionalisation rates initially. Evid Based Nurs. 2002;5(2):58. KQ4E2a, KQ5E2a. [pmid: 11995661].
316 Ford AH, Flicker L, Alfonso H, et al. Vitamins B(12), B(6), and folic acid for cognition in older men. Neurology. Oct. 26. 2010;75(17):1540-7. KQ4E1b, KQ5E1b. [pmid: 20861451].
317 Forster S, Buschert VC, Teipel SJ, et al. Effects of a 6-month cognitive intervention on brain metabolism in patients with amnestic MCI and mild Alzheimer's disease. J Alzheimers Dis. 2011;26:Suppl-48. KQ4E5, KQ5E5. [pmid: 21971473].
318 Forster S, Buschert VC, Buchholz HG, et al. Effects of a 6-month cognitive intervention program on brain metabolism in amnestic mild cognitive impairment and mild Alzheimer's disease. J Alzheimers Dis. 2011;25(4):695-706. KQ4E5, KQ5E5. [pmid: 21498904].
319 Fortinsky RH, Kulldorff M, Kleppinger A, et al. Dementia care consultation for family caregivers: collaborative model linking an Alzheimer's association chapter with primary care physicians. Aging Ment Health. Mar. 2009;13(2):162-70. KQ5E5. [pmid: 19347683].
320 Fortinsky RH, Unson CG, Garcia RI. Helping family caregivers by linking primary care physicians with community-based dementia care services: The Alzheimer's Service Coordination Program. Dementia. 2002;1(2):227-40. PMID: None. KQ4E2a, KQ5E2a.
321 Fossati C, De BG, Bellomo A, et al. A self-administered questionnaire to screen the risk of dementia: A pilot study and the results of a comparison with the mini-mental state examination (MMSE). Arch Gerontol Geriatr. Jan. 2013;56(1):27-31. KQ2E5. [pmid: 22088935].
322 Fountoulakis KN, Tsolaki M, Mohs RC, et al. Epidemiological dementia index: a screening instrument for Alzheimer's disease and other types of dementia suitable for use in populations with low education level. Dement Geriatr Cogn Disord. Nov. 1998;9(6):329-38. KQ2E3c. [pmid: 9769446].
323 Fowler NR, Boustani MA, Frame A, et al. Effect of patient perceptions on dementia screening in primary care. J Am Geriatr Soc. Jun. 2012;60(6):1037-43. KQ3E5. [pmid: 22690979].
324 Fox C, Crugel M, Maidment I, et al. Efficacy of memantine for agitation in Alzheimer's dementia: a randomised double-blind placebo controlled trial. PLoS One. 2012;7(5):e35185. KQ4E3b, KQ5E3b. [pmid: 22567095].
325 Franceschi M, Scarcelli C, Niro V, et al. Prevalence, clinical features and avoidability of adverse drug reactions as cause of admission to a geriatric unit: a prospective study of 1756 patients. Drug Saf. 2008;31(6):545-56. KQ4E1, KQ5E1. [pmid: 18484788].
326 Frank RM, Byrne GJ. The clinical utility of the Hopkins Verbal Learning Test as a screening test for mild dementia. Int J Geriatr Psychiatry. Apr. 2000;15(4):317-24. KQ2E3c. [pmid: 10767731].
327 Frankfort SV, Appels BA, de BA, et al. Discontinuation of rivastigmine in routine clinical practice. Int J Geriatr Psychiatry. Dec. 2005;20(12):1167-71. KQ4E2a, KQ5E2e. [pmid: 16315150].
328 Fratiglioni L, Jorm AF, Grut M, et al. Predicting dementia from the Mini-Mental State Examination in an elderly population: the role of education. J Clin Epidemiol. Mar. 1993;46(3):281-7. KQ2E5. [pmid: 8455053].
329 Freitas S, Simoes MR, Alves L, et al. Montreal Cognitive Assessment: Validation Study for Mild Cognitive Impairment and Alzheimer Disease. Alzheimer Dis Assoc Disord. 2011. Dec. 20. KQ2E2d. [pmid: 22193353].
330 Freitas S, Simoes MR, Alves L, et al. Montreal Cognitive Assessment (MoCA): normative study for the Portuguese population. J Clin Exp Neuropsychol. Nov. 2011;33(9):989-96. KQ2E4a. [pmid: 22082082].
331 Freitas S, Simoes MR, Alves L, et al. Montreal Cognitive Assessment (MoCA): Validation Study for Vascular Dementia. J Int Neuropsychol Soc. Nov. 2012;18(6):1031-40. KQ2E2d. [pmid: 22676901].
332 Freitas S, Simoes MR, Alves L, et al. Montreal Cognitive Assessment (MoCA): Validation study for Frontotemporal Dementia. J Geriatr Psychiatry Neurol. Sep. 2012;25(3):146-54. KQ2E2d. [pmid: 22859702].
333 Freund-Levi Y, Eriksdotter-Jonhagen M, Cederholm T, et al. Omega-3 fatty acid treatment in 174 patients with mild to moderate Alzheimer disease: OmegAD study: a randomized double-blind trial. Arch Neurol. Oct. 2006;63(10):1402-8. KQ5E5. [pmid: 17030655].
334 Froehlich TE, Robison JT, Inouye SK. Screening for dementia in the outpatient setting: the time and change test. J Am Geriatr Soc. Dec. 1998;46(12):1506-11. KQ2E7b. [pmid: 9848810].
335 Frolich L, Ashwood T, Nilsson J, et al. Effects of AZD3480 on cognition in patients with mild-to-moderate Alzheimer's disease: a phase IIb dose-finding study. J Alzheimers Dis. 2011;24(2):363-74. KQ4E6c, KQ5E6c. [pmid: 21258153].
336 Fuchs A, Wiese B, Altiner A, et al. Cued Recall and Other Cognitive Tasks to Facilitate Dementia Recognition in Primary Care. J Am Geriatr Soc. 2012. Jan. KQ3E5. [pmid: 22150245].
337 Fuh JL, Teng EL, Lin KN, et al. The Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) as a screening tool for dementia for a predominantly illiterate Chinese population. Neurology. Jan. 1995;45(1):92-6. KQ2E2d. [pmid: 7824143].
338 Fukai S, Akishita M, Yamada S, et al. Effects of testosterone in older men with mild-to-moderate cognitive impairment. J Am Geriatr Soc. Jul. 2010;58(7):1419-21. KQ4E2a, KQ5E5. [pmid: 20672465].
339 Fung W, Chien W. The effectiveness of a mutual support group for family caregivers of a relative with dementia. Arch Psychiatr Nurs. 2002;16(3):134-44. KQ4E2b, KQ5E2b. [pmid: 12037799].
340 Fuschillo C, La Pia S, Campana F, et al. Cognitive deficits in Alzheimer's disease: Treatment with acetylcholinesterase inhibitor agents. Arch Gerontol Geriatr. Suppl 7. 2001:151-8. KQ4E2b, KQ5E2e. [pmid: 11431059].
341 Gagnon M, Letenneur L, Dartigues JF, et al. Validity of the Mini-Mental State examination as a screening instrument for cognitive impairment and dementia in French elderly community residents. Neuroepidemiology. 1990;9(3):143-50. KQ3E5. [pmid: 2402325].
342 Gaitan A, Garolera M, Cerulla N, et al. Efficacy of an adjunctive computer-based cognitive training program in amnestic mild cognitive impairment and Alzheimer's disease: a single-blind, randomized clinical trial. Int J Geriatr Psychiatry. 2012. Apr. 3. KQ4E2b, KQ5E2b. [pmid: 22473855].
343 Galante E, Venturini G, Fiaccadori C. Computer-based cognitive intervention for dementia: preliminary results of a randomized clinical trial. G Ital Med Lav Ergon. Jul. 2007;29(3 Suppl B):B26-B32. KQ4E2b, KQ5E2b. [pmid: 18575355].
344 Galasko D, Kershaw PR, Schneider L, et al. Galantamine Maintains Ability to Perform Activities of Daily Living in Patients with Alzheimer's Disease. J Am Geriatr Soc. 2004;52(7):1070-6. KQ4E8, KQ5E8. [pmid: 15209643].
345 Gallagher-Thompson D, Coon DW, Solano N, et al. Change in indices of distress among Latino and Anglo female caregivers of elderly relatives with dementia: site-specific results from the REACH national collaborative study. Gerontologist. Aug. 2003;43(4):580-91. KQ5E5. [pmid: 12937336].
346 Gallagher-Thompson D, Wang PC, Liu W, et al. Effectiveness of a psychoeducational skill training DVD program to reduce stress in Chinese American dementia caregivers: results of a preliminary study. Aging Ment Health. Apr. 2010;14(3):263-73. KQ4E2b, KQ5E2b. [pmid: 20425645].
347 Gallagher-Thompson D, Gray HL, Dupart T, et al. Effectiveness of cognitive/behavioral small group intervention for reduction of depression and stress in non-Hispanic White and Hispanic/Latino women dementia family caregivers: Outcomes and mediators of change. J Ration Emot Cogn Behav Ther. 2008;26(4):286-303. PMID: None. KQ5E5.
348 Galluzzi S, Cimaschi L, Ferrucci L, et al. Mild cognitive impairment: clinical features and review of screening instruments. Aging Clin Exp Res. Jun. 2001;13(3):183-202. KQ2E2a. [pmid: 11442301].
349 Galvin JE, Roe CM, Powlishta KK, et al. The AD8: a brief informant interview to detect dementia. Neurology. Aug. 23. 2005;65(4):559-64. KQ3E5. [pmid: 16116116].
350 Galvin JE, Roe CM, Xiong C, et al. Validity and reliability of the AD8 informant interview in dementia. Neurology. Dec. 12. 2006;67(11):1942-8. KQ2E3c, KQ3E3c. [pmid: 17159098].
351 Ganguli M, Belle S, Ratcliff G, et al. Sensitivity and specificity for dementia of population-based criteria for cognitive impairment: the MoVIES project. J Gerontol. Jul. 1993;48(4):M152-M161. KQ2E2d. [pmid: 8315228].
352 Garand L, Buckwalter KC, Lubaroff D, et al. A pilot study of immune and mood outcomes of a community-based intervention for dementia caregivers: the PLST intervention. Arch Psychiatr Nurs. Aug. 2002;16(4):156-67. KQ4E2b, KQ5E2b. [pmid: 12143075].
353 Garand LJ. Psychoimmunological outcomes of a dementia caregiver intervention: The progressively lowered stress threshold. 61 ed. US. ProQuest Information & Learning. 2000. PMID: None. KQ4E2b, KQ5E2b.
354 Gardette V, Andrieu S, Lapeyre-Mestre M, et al. Predictive factors of discontinuation and switch of cholinesterase inhibitors in community-dwelling patients with Alzheimer's disease: a 2-year prospective, multicentre, cohort study. CNS Drugs. May. 1. 2010;24(5):431-42. KQ5E2e. [pmid: 20369907].
355 Gatz M, Reynolds CA, John R, et al. Telephone screening to identify potential dementia cases in a population-based sample of older adults. Int Psychogeriatr. Sep. 2002;14(3):273-89. KQ2E7c. [pmid: 12475088].
356 Gaudig M, Richarz U, Han J, et al. Effects of galantamine in Alzheimer's disease: double-blind withdrawal studies evaluating sustained versus interrupted treatment. Curr Alzheimer Res. Nov. 2011;8(7):771-80. KQ5E4. [pmid: 21707533].
357 Gaugler JE, Roth DL, Haley WE, et al. Can counseling and support reduce burden and depressive symptoms in caregivers of people with Alzheimer's disease during the transition to institutionalization? Results from the New York University caregiver intervention study. J Am Geriatr Soc. Mar. 2008;56(3):421-8. KQ4E2b, KQ5E2b. [pmid: 18179495].
358 Gauthier S, Feldman H, Hecker J, et al. Functional, cognitive and behavioral effects of donepezil in patients with moderate Alzheimer's disease. Curr Med Res Opin. 2002;18(6):347-54. KQ4E4c, KQ5E4c. [pmid: 12442882].
359 Gauthier S, Feldman H, Hecker J, et al. Efficacy of donepezil on behavioral symptoms in patients with moderate to severe Alzheimer's disease. Int Psychogeriatr. Dec. 2002;14(4):389-404. KQ4E4c, KQ5E4c. [pmid: 12670060].
360 Gauthier S, Wirth Y, Mobius HJ. Effects of memantine on behavioural symptoms in Alzheimer's disease patients: an analysis of the Neuropsychiatric Inventory (NPI) data of two randomised, controlled studies. Int J Geriatr Psychiatry. May. 2005;20(5):459-64. KQ4E4c, KQ5E4c. [pmid: 15852444].
361 Gauthier S, Herrmann N, Ferreri F, et al. Use of memantine to treat Alzheimer's disease. [Erratum appears in CMAJ. 2006 Sep 26;175(7):777 Note: Agokou, Catherine [corrected to Agbokou, Catherine]]. Can Med Assoc J. Aug. 29. 2006;175(5):501-2. KQ4E2a, KQ5E2a. [pmid: 16940271].
362 Gauthier S, Juby A, Morelli L, et al. A large, naturalistic, community-based study of rivastigmine in mild-to-moderate AD: the EXTEND Study. Curr Med Res Opin. Nov. 2006;22(11):2251-65. KQ5E7a. [pmid: 17076986].
363 Gavett BE, Lou KR, Daneshvar DH, et al. Diagnostic accuracy statistics for seven Neuropsychological Assessment Battery (NAB) test variables in the diagnosis of Alzheimer's disease. Appl Neuropsychol. 2012;19(2):108-15. KQ2E3c. [pmid: 23373577].
364 Gavrilova SI, Ferri CP, Mikhaylova N, et al. Helping carers to care-The 10/66 dementia research group's randomized control trial of a caregiver intervention in Russia. Int J Geriatr Psychiatry. 2009;24(4):347-54. KQ4E3a, KQ5E3a. [pmid: 18814197].
365 Geldmacher DS, Provenzano G, McRae T, et al. Donepezil is associated with delayed nursing home placement in patients with Alzheimer's disease. J Am Geriatr Soc. Jul. 2003;51(7):937-44. KQ4E8, KQ5E5. [pmid: 12834513].
366 Gendron C, Poitras L, Dastoor DP, et al. Cognitive-behavioral group intervention for spousal caregivers: Findings and clinical considerations. Clin Gerontol. 1996;17(1):3-9. PMID: None. KQ4E7c, KQ5E7c.
367 George DR. Intergenerational volunteering and quality of life: mixed methods evaluation of a randomized control trial involving persons with mild to moderate dementia. Qual Life Res. Sep. 2011;20(7):987-95. KQ4E6b, KQ5E6b. [pmid: 21221815].
368 George DR, Singer ME. Intergenerational volunteering and quality of life for persons with mild to moderate dementia: results from a 5-month intervention study in the United States. Am J Geriatr Psychiatry. Apr. 2011;19(4):392-6. KQ4E6b, KQ5E6b. [pmid: 21427644].
369 Gerdner LA, Buckwalter KC, Reed D. Impact of a psychoeducational intervention on caregiver response to behavioral problems. Nurs Res. Nov. 2002;51(6):363-74. KQ4E2b, KQ5E2b. [pmid: 12464756].
370 Giaquinto S, Parnetti L. Early detection of dementia in clinical practice. Mech Ageing Dev. Feb. 2006;127(2):123-8. KQ2E7b. [pmid: 16289254].
371 Gillette-Guyonnet S, Cortes F, Cantet C, et al. Long-term cholinergic treatment is not associated with greater risk of weight loss during Alzheimer's disease: data from the French REAL.FR cohort. J Nutr Health Aging. 2005;9(2):69-73. KQ5E2e. [pmid: 15791348].
372 Gillette-Guyonnet S, Andrieu S, Dantoine T, et al. Commentary on “A roadmap for the prevention of dementia II. Leon Thal Symposium 2008.” The Multidomain Alzheimer Preventive Trial (MAPT): a new approach to the prevention of Alzheimer's disease. Alzheimers Dement. Mar. 2009;5(2):114-21. KQ4E1b, KQ5E1b. [pmid: 19328438].
373 Girtler N, Brugnolo A, Campus C, et al. The short cognitive evaluation battery in cognitive disorders of the elderly--Italian version. Dement Geriatr Cogn Disord. 2012;33(4):255-65. KQ2E2d. [pmid: 22738937].
374 Gitlin LN, Corcoran M, Winter L, et al. A randomized, controlled trial of a home environmental intervention: effect on efficacy and upset in caregivers and on daily function of persons with dementia. Gerontologist. Feb. 2001;41(1):4-14. KQ5E5. [pmid: 11220813].
375 Gitlin LN, Belle SH, Burgio LD, et al. Effect of multicomponent interventions on caregiver burden and depression: the REACH multisite initiative at 6-month follow-up. Psychol Aging. Sep. 2003;18(3):361-74. KQ5E5. [pmid: 14518800].
376 Gitlin LN, Winter L, Corcoran M, et al. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. Aug. 2003;43(4):532-46. KQ5E5. [pmid: 12937332].
377 Gitlin LN, Hauck WW, Dennis MP, et al. Maintenance of effects of the home environmental skill-building program for family caregivers and individuals with Alzheimer's disease and related disorders. J Gerontol A Biol Sci Med Sci. Mar. 2005;60(3):368-74. KQ4E7a, KQ5E7a. [pmid: 15860476].
378 Gitlin LN, Winter L, Burke J, et al. Tailored activities to manage neuropsychiatric behaviors in persons with dementia and reduce caregiver burden: a randomized pilot study. Am J Geriatr Psychiatry. Mar. 2008;16(3):229-39. KQ5E5. [pmid: 18310553].
379 Gitlin LN, Hodgson N, Jutkowitz E, et al. The cost-effectiveness of a nonpharmacologic intervention for individuals with dementia and family caregivers: the tailored activity program. Am J Geriatr Psychiatry. Jun. 2010;18(6):510-9. KQ4E5, KQ5E5. [pmid: 20847903].
380 Gitlin LN, Winter L, Dennis MP, et al. Targeting and managing behavioral symptoms in individuals with dementia: a randomized trial of a nonpharmacological intervention. J Am Geriatr Soc. Aug. 2010;58(8):1465-74. KQ5E5. [pmid: 20662955].
381 Gitlin LN, Winter L, Dennis MP, et al. A biobehavioral home-based intervention and the well-being of patients with dementia and their caregivers: the COPE randomized trial. JAMA. Sep. 1. 2010;304(9):983-91. KQ5E5. [pmid: 20810376].
382 Gliebus G, Lippa CF. The Influence of Beta-Blockers on Delayed Memory Function in pepole With Cognitive Impairment. Am J Alzheimers Dis Other Demen. 2007;22(1):57-61. KQ4E2a, KQ5E5. [pmid: 17534003].
383 Glueckauf RL, Davis WS, Willis F, et al. Telephone-based, cognitive-behavioral therapy for African American dementia caregivers with depression: initial findings. Rehabil Psychol. May. 2012;57(2):124-39. KQ4E2b, KQ5E2b. [pmid: 22686551].
384 Gonyea JG, O'Connor MK, Boyle PA. Project CARE: a randomized controlled trial of a behavioral intervention group for Alzheimer's disease caregivers. Gerontologist. Dec. 2006;46(6):827-32. KQ4E2c, KQ5E5. [pmid: 17169938].
385 Gorus E, Lambert M, De RR, et al. The influence of galantamine on reaction time, attention processes, and performance variability in elderly Alzheimer patients. J Clin Psychopharmacol. Apr. 2007;27(2):182-7. KQ4E2a, KQ5E2e. [pmid: 17414243].
386 Grace J, Daniel S, Stevens T, et al. Long-term use of rivastigmine in patients with dementia with Lewy bodies: An open-label trial. Int Psychogeriatr. 2001;13(2):199-205. KQ4E2a, KQ5E8. [pmid: 11495394].
387 Grady D, Yaffe K, Kristof M, et al. Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med. Nov. 2002;113(7):543-8. KQ4E1b, KQ5E1b. [pmid: 12459399].
388 Graf A, Wallner C, Schubert V, et al. The effects of light therapy on mini-mental state examination scores in demented patients. Biol Psychiatry. Nov. 1. 2001;50(9):725-7. KQ4E6b, KQ5E6b. [pmid: 11704081].
389 Graff MJ, Adang EM, Vernooij-Dassen MJ, et al. Community occupational therapy for older patients with dementia and their care givers: cost effectiveness study. BMJ. Jan. 19. 2008;336(7636):134-8. KQ4E5, KQ5E5. [pmid: 18171718].
390 Graff MJL, Vernooij-Dassen MJFJ, Hoefnagels WHL, et al. Occupational therapy at home for older individuals with mild to moderate cognitive impairments and their primary caregivers: a pilot study. OTJR. 2003;23(4):155-64. PMID: None. KQ4E2c, KQ5E5.
391 Grant I, McKibbin CL, Taylor MJ, et al. In-home respite intervention reduces plasma epinephrine in stressed Alzheimer caregivers. Am J Geriatr Psychiatry. Jan. 2003;11(1):62-72. KQ4E2d, KQ5E2d. [pmid: 12527541].
392 Greenaway MC, Duncan NL, Smith GE. The memory support system for mild cognitive impairment: randomized trial of a cognitive rehabilitation intervention. Int J Geriatr Psychiatry. 2012. Jun. 7. KQ5E5. [pmid: 22678947].
393 Greenberg SM, Tennis MK, Brown LB, et al. Donepezil therapy in clinical practice: a randomized crossover study. Arch Neurol. Jan. 2000;57(1):94-9. KQ4E2a, KQ5E2a. [pmid: 10634454].
394 Griffith P, Lichtenberg P, Goldman R, et al. Safety and efficacy of donepezil in African Americans with mild-to-moderate Alzheimer's disease. J Natl Med Assoc. Oct. 2006;98(10):1590-7. KQ4E2a, KQ5E2e. [pmid: 17052048].
395 Grober E, Hall C, McGinn M, et al. Neuropsychological strategies for detecting early dementia. J Int Neuropsychol Soc. Jan. 2008;14(1):130-42. KQ3E5. [pmid: 18078539].
396 Grober E, Hall C, Lipton RB, et al. Primary care screen for early dementia. J Am Geriatr Soc. Feb. 2008;56(2):206-13. KQ2E5, KQ3E5. [pmid: 18179486].
397 Grober E, Sanders AE, Hall C, et al. Free and cued selective reminding identifies very mild dementia in primary care. Alzheimer Dis Assoc Disord. Jul. 2010;24(3):284-90. KQ3E5. [pmid: 20683186].
398 Grodstein F, Kang JH, Glynn RJ, et al. A randomized trial of beta carotene supplementation and cognitive function in men: the Physicians' Health Study II. Arch Intern Med. Nov. 12. 2007;167(20):2184-90. KQ4E1b, KQ5E1b. [pmid: 17998490].
399 Gron G, Brandenburg I, Wunderlich AP, et al. Inhibition of hippocampal function in mild cognitive impairment: targeting the cholinergic hypothesis. Neurobiol Aging. Jan. 2006;27(1):78-87. KQ4E1, KQ5E1. [pmid: 16298243].
400 Grossberg G, Irwin P, Satlin A, et al. Rivastigmine in Alzheimer disease: efficacy over two years. [Erratum appears in Am J Geriatr Psychiatry. 2004 Nov-Dec;12(6):679]. Am J Geriatr Psychiatry. Jul. 2004;12(4):420-31. KQ4E2a, KQ5E8. [pmid: 15249280].
401 Grossberg G, Meng X, Olin JT. Impact of rivastigmine patch and capsules on activities of daily living in Alzheimer's disease. Am J Alzheimers Dis Other Demen. Feb. 2011;26(1):65-71. KQ5E5. [pmid: 21282280].
402 Grossberg GT, Sadowsky C, Olin JT. Rivastigmine transdermal system for the treatment of mild to moderate Alzheimer's disease. Int J Clin Pract. Apr. 2010;64(5):651-60. KQ4E2a, KQ5E2a. [pmid: 20102418].
403 Grossberg GT, Olin JT, Somogyi M, et al. Dose effects associated with rivastigmine transdermal patch in patients with mild-to-moderate Alzheimer's disease. Int J Clin Pract. Apr. 2011;65(4):465-71. KQ5E5. [pmid: 21309961].
404 Grut M, Fratiglioni L, Viitanen M, et al. Accuracy of the Mini-Mental Status Examination as a screening test for dementia in a Swedish elderly population. Acta Neurol Scand. Apr. 1993;87(4):312-7. KQ3E5. [pmid: 8503262].
405 Guerra M, Ferri CP, Fonseca M, et al. Helping carers to care: the 10/66 dementia research group's randomized control trial of a caregiver intervention in Peru. Rev Bras Psiquiatr. Mar. 2011;33(1):47-54. KQ4E3a, KQ5E3a. [pmid: 20602013].
406 Guo QH, Zhou B, Zhao QH, et al. Memory and Executive Screening (MES): a brief cognitive test for detecting mild cognitive impairment. BMC Neurol. 2012;12:119. KQ2E3a. [pmid: 23050770].
407 Gutterman E, Markowitz JS, Lilienfeld S. Cognitive maintenance of Alzheimer's disease patients in pooled randomized, placebo-controlled clinical trials of Galantamin: The effect of statins. Int J Neuropsychopharmacol. 2002;5(Suppl 1):S93. PMID: None. KQ4E2a, KQ5E2a.
408 Gutzmann H, hl KP, Hadler D, et al. Safety and efficacy of idebenone versus tacrine in patients with Alzheimer's disease: Results of a randomized, double-blind, parallel-group multicenter study. Pharmacopsychiatry. 2002;35(1):12-8. KQ4E3c, KQ5E3c. [pmid: 11819153].
409 Hager K, Calabrese P, Frolich L, et al. An observational clinical study of the efficacy and tolerability of donepezil in the treatment of Alzheimer's disease. Dement Geriatr Cogn Disord. 2003;15(4):189-98. KQ4E2a. [pmid: 12626851].
410 Hager K, Kenklies M, McAfoose J, et al. Alpha-lipoic acid as a new treatment option for Alzheimer's disease--a 48 months follow-up analysis. J Neural Trans. Supplementum. 2007;(72):189-93. KQ4E6c, KQ5E6c. [pmid: 17982894].
411 Hager K, Marahrens A, Kenklies M, et al. Alpha-lipoic acid as a new treatment option for Alzheimer type dementia. Arch Gerontol Geriatr. 2001;32(3):275-82. KQ4E6c, KQ5E6c. [pmid: 11395173].
412 Haight BK, Gibson F, Michel Y. The Northern Ireland life review/life storybook project for people with dementia. Alzheimers Dement. Jan. 2006;2(1):56-8. KQ4E2c, KQ5E5. [pmid: 19595856].
413 Hajjar I, Zhao P, Alsop D, et al. Hypertension and cerebral vasoreactivity: a continuous arterial spin labeling magnetic resonance imaging study. Hypertension. Nov. 2010;56(5):859-64. KQ4E1, KQ5E1. [pmid: 20876450].
414 Hajjar I, Hart M, Chen YL, et al. Memory and Executive Screening (MES): a brief cognitive test for detecting mild cognitive impairment. Arch Intern Med. Mar. 12. 2012;172(5):442-4. KQ4E2a, KQ5E2a. [pmid: 22412114].
415 Hall CD, Miszko T, Wolf SL. Effects of Tai Chi intervention on dual-task ability in older adults: a pilot study. Arch Phys Med. Mar. 2009;90(3):525-9. KQ4E1b, KQ5E1b. [pmid: 19254623].
416 Hall KS, Gao S, Emsley CL, et al. Community screening interview for dementia (CSI 'D'); performance in five disparate study sites. Int J Geriatr Psychiatry. Jun. 2000;15(6):521-31. KQ2E6a. [pmid: 10861918].
417 Hammers D, Spurgeon E, Ryan K, et al. Validity of a brief computerized cognitive screening test in dementia. J Geriatr Psychiatry Neurol. 2012;25(2):89-99. KQ2E5. [pmid: 22689701].
418 Hamuro A. Combination therapy with galantamine and memantine improves behavioral and psychological symptoms of dementia (BPSD) in patients with early-onset Alzheimer's disease. Aust N Z J Psychiatry. 2012. Oct. 23. KQ4E2a, KQ5E2a. [pmid: 23093052].
419 Hanon O, Berrou JP, Negre-Pages L, et al. Effects of hypertension therapy based on eprosartan on systolic arterial blood pressure and cognitive function: primary results of the Observational Study on Cognitive function And Systolic Blood Pressure Reduction open-label study. J Hypertens. Aug. 2008;26(8):1642-50. KQ4E1b, KQ5E1b. [pmid: 18622244].
420 Hashimoto M, Yatabe Y, Kaneda K, et al. Impact of donepezil hydrochloride on the care burden of family caregivers of patients with Alzheimer's disease. Psychogeriatrics. Dec. 2009;9(4):196-203. KQ4E2a, KQ5E2e. [pmid: 20377821].
421 Hattori H, Hattori C, Hokao C, et al. Controlled study on the cognitive and psychological effect of coloring and drawing in mild Alzheimer's disease patients. Geriatr Gerontol Int. 2011;11(4):431-7. KQ4E2b, KQ5E2b. [pmid: 21518170].
422 Haubois G, de DL, Annweiler C, et al. Derivation and validation of a Short form of the Mini-Mental State Examination for the screening of dementia in older adults with a memory complaint. Eur J Neurol. 2012. Aug. 23. KQ2E3c. [pmid: 22913655].
423 Hauer K, Schwenk M, Zieschang T, et al. Physical training improves motor performance in people with dementia: a randomized controlled trial. J Am Geriatr Soc. Jan. 2012;60(1):8-15. KQ4E5, KQ5E5. [pmid: 22211512].
424 Hayden KM, Khachaturian AS, Tschanz JT, et al. Characteristics of a two-stage screen for incident dementia. J Clin Epidemiol. Nov. 2003;56(11):1038-45. KQ2E7c. [pmid: 14614994].
425 Hayden KM, Zandi PP, Khachaturian AS, et al. Does NSAID use modify cognitive trajectories in the elderly? The Cache County study. Neurology. Jul. 17. 2007;69(3):275-82. KQ4E1b, KQ5E1b. [pmid: 17636065].
426 Hebert R, Leclerc G, Bravo G, et al. Efficacy of a support group programme for care-givers of demented patients in the community: a randomized controlled trial. Arch Gerontol Geriatr. Jan. 1994;18(1):1-14. KQ5E5. [pmid: 15374309].
427 Hebert R, Girouard D, Leclerc G, et al. The impact of a support group programme for care-givers on the institutionalisation of demented patients. Arch Gerontol Geriatr. Mar. 1995;20(2):129-34. KQ4E5, KQ5E5. [pmid: 15374241].
428 Hebert R, Levesque L, Vezina J, et al. Efficacy of a psychoeducative group program for caregivers of demented persons living at home: a randomized controlled trial. J Gerontol B Psychol Sci Soc Sci. Jan. 2003;58(1):S58-S67. KQ5E5. [pmid: 12496309].
429 Hedrick SC, Rothman ML, Chapko M, et al. Summary and discussion of methods and results of the Adult Day Health Care Evaluation Study. Med Care. Sep. 1993;31(9 Suppl):SS94-103. KQ4E6c, KQ5E6c. [pmid: 8361252].
430 Heinik J, Solomesh I, Bleich A, et al. Are the clock-drawing test and the MMSE combined interchangeable with CAMCOG as a dementia evaluation instrument in a specialized outpatient setting?. J Geriatr Psychiatry Neurol. Jun. 2003;16(2):74-9. KQ2E3c. [pmid: 12801155].
431 Heiss WD, Kessler J, Mielke R, et al. Long-term effects of phosphatidylserine, pyritinol, and cognitive training in Alzheimer's disease. A neuropsychological, EEG, and PET investigation. Dementia. Mar. 1994;5(2):88-98. KQ4E2b, KQ5E2b. [pmid: 8038871].
432 Helmes E. Cognitive screening of older adults: the utility of pentagon drawing. Int Psychogeriatr. Nov. 2012;30:1-7. KQ2E7b. [pmid: 23194975].
433 Helou R, Rhalimi M. Cholinesterase inhibitors and the risk of pulmonary disorders in hospitalized dementia patients. J Popul Ther Clin Pharmacol. 2010;17(3):e379-e389. KQ5E2e. [pmid: 21041864].
434 Henderson AS, Jorm AF, Christensen H, et al. Aspirin, anti-inflammatory drugs and risk of dementia. Int J Geriatr Psychiatry. Sep. 1997;12(9):926-30. KQ4E2a, KQ5E5. [pmid: 9309471].
435 Henderson VW, Paganini-Hill A, Miller BL, et al. Estrogen for Alzheimer's disease in women: randomized, double-blind, placebo-controlled trial. Neurology. Jan. 25. 2000;54(2):295-301. KQ5E5. [pmid: 10668686].
436 Heo JH, Lee KM, Park TH, et al. Validation of the Korean Addenbrooke's Cognitive Examination for diagnosing Alzheimer's dementia and mild cognitive impairment in the Korean elderly. Appl Neuropsychol. 2012;19(2):127-31. KQ2E3c. [pmid: 23373580].
437 Hepburn KW, Tornatore J, Center B, et al. Dementia family caregiver training: affecting beliefs about caregiving and caregiver outcomes. J Am Geriatr Soc. Apr. 2001;49(4):450-7. KQ5E5. [pmid: 11347790].
438 Hepburn KW, Lewis M, Narayan S, et al. Partners in Caregiving: A Psychoeducation Program Affecting Dementia Family Caregivers' Distress and Caregiving Outlook. Clin Gerontol. 2005;29(1):53-69. PMID: None. KQ5E5.
439 Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. Jun. 1998;13(6):368-80. KQ3E5. [pmid: 9658272].
440 Heyn P. The effect of a multisensory exercise program on engagement, behavior, and selected physiological indexes in persons with dementia. Am J Alzheimers Dis Other Demen. 2003;18(4):247-51. KQ4E2c, KQ5E2c. [pmid: 12955790].
441 Hilgeman MM. Preserving Identity and Planning for Advance Care (PIPAC): An intervention to increase coping in the early stages of dementia. 71 ed. US. ProQuest Information & Learning. 2011. PMID: None. KQ4E7c, KQ5E7c.
442 Hinchliffe AC, Hyman IL, Blizard B, et al. Behavioural complications of dementia-Can they be treated?. Int J Geriatr Psychiatry. 1995;10(10):839-47. PMID: None. KQ5E5.
443 Hirano A, Suzuki Y, Kuzuya M, et al. Influence of regular exercise on subjective sense of burden and physical symptoms in community-dwelling caregivers of dementia patients: a randomized controlled trial. Arch Gerontol Geriatr. Sep. 2011;53(2):e158-e163. KQ5E5. [pmid: 20850878].
444 Hirazakura A, Nagaoka M, Hatakeyama R, et al. Educational therapy for patients with dementia. Geriatr Gerontol Int. 2006;6(2):147-8. PMID: None. KQ4E3b, KQ5E3b.
445 Hirsch C. The Mini-Cog had sensitivity similar to the longer 3MS for detecting cognitive impairment or dementia. Ann Int Med. Oct. 16. 2012;157(8):JC4-JC8. KQ2E2a. [pmid: 23070510].
446 Hock C, Konietzko U, Streffer JR, et al. Antibodies against beta-amyloid slow cognitive decline in Alzheimer's disease. Neuron. May. 22. 2003;38(4):547-54. KQ4E6b, KQ5E6b. [pmid: 12765607].
447 Hogervorst E, Combrinck M, Lapuerta P, et al. The Hopkins Verbal Learning Test and screening for dementia. Dement Geriatr Cogn Disord. 2002;13(1):13-20. KQ2E2d. [pmid: 11731710].
448 Holmes C, Wilkinson D, Dean C, et al. The efficacy of donepezil in the treatment of neuropsychiatric symptoms in Alzheimer disease. Neurology. Jul. 27. 2004;63(2):214-9. KQ4E8, KQ5E8. [pmid: 15277611].
449 Holsinger T, Boustani M, Abbot D, et al. Acceptability of dementia screening in primary care patients. Int J Geriatr Psychiatry. Apr. 2011;26(4):373-9. KQ3E5. [pmid: 20845398].
450 Holsinger T, Plassman BL, Stechuchak KM, et al. Screening for Cognitive Impairment: Comparing the Performance of Four Instruments in Primary Care. J Am Geriatr Soc. May. 30. 2012;60(6):1027-36. KQ3E5. [pmid: 22646750].
451 Homma A, Takeda M, Imai Y, et al. Clinical efficacy and safety of donepezil on cognitive and global function in patients with Alzheimer's disease. A 24-week, multicenter, double-blind, placebo-controlled study in Japan. E2020 Study Group. Dement Geriatr Cogn Disord. Nov. 2000;11(6):299-313. KQ4E7c, KQ5E7c. [pmid: 11044775].
452 Hooijer C, Dinkgreve M, Jonker C, et al. Short screening tests for dementia in the elderly population. I. A comparison between AMTS, MMSE, MSQ and SPMSQ. Int J Geriatr Psychiatry. 1992;7(8):559-71. PMID: None. KQ3E5.
453 Huang HL, Shyu YI, Chen MC, et al. A pilot study on a home-based caregiver training program for improving caregiver self-efficacy and decreasing the behavioral problems of elders with dementia in Taiwan. Int J Geriatr Psychiatry. Apr. 2003;18(4):337-45. KQ5E5. [pmid: 12673611].
454 Huppert FA, Brayne C, Gill C, et al. CAMCOG--a concise neuropsychological test to assist dementia diagnosis: socio-demographic determinants in an elderly population sample. Br J Clin Psychol. Nov. 1995;34(Pt 4):529-41. KQ2E6a. [pmid: 8563660].
455 Huppert FA, Jorm AF, Brayne C, et al. Psychometric properties of the CAMCOG and its efficacy in the diagnosis of dementia. Aging Neuropsychol Cogn. Jul. 1. 1996;3(3):201-14. PMID: None. KQ2E6a.
456 Huppert FA, Cabelli ST, Matthews FE. Brief cognitive assessment in a UK population sample -- distributional properties and the relationship between the MMSE and an extended mental state examination. BMC Geriatr. 2005;5:7. KQ2E5. [pmid: 15869717].
457 Hvas AM, Juul S, Lauritzen L, et al. No effect of vitamin B-12 treatment on cognitive function and depression: a randomized placebo controlled study. J Affect Disord. Sep. 2004;81(3):269-73. KQ4E1, KQ5E1. [pmid: 15337331].
458 Hvas AM, Ellegaard JÃ, NexÃ¸ E. Vitamin B12 treatment normalizes metabolic markers but has limited clinical effect: a randomized placebo-controlled study. Clin Chem. 2001;47(8):1396-404. KQ4E1, KQ5E1. [pmid: 11468228].
459 Hwang HR, Choi SH, Yoon DH, et al. The effect of cognitive training in patients with mild cognitive impairment and early Alzheimer's disease: a preliminary study. J Clin Neurol. Sep. 2012;8(3):190-7. KQ4E7c, KQ5E7c. [pmid: 23091528].
460 Ideno Y, Takayama M, Hayashi K, et al. Evaluation of a Japanese version of the Mini-Mental State Examination in elderly persons. Geriatr Gerontol Int. Apr. 2012;12(2):310-6. KQ2E5. [pmid: 22122408].
461 Ikeda T, Yamamoto K, Takahashi K, et al. Treatment of Alzheimer-type dementia with intravenous mecobalamin. Clin Ther. May. 1992;14(3):426-37. KQ4E2a, KQ5E5. [pmid: 1638584].
462 Irving GF, Freund-Levi Y, Eriksdotter-Jonhagen M, et al. Omega-3 fatty acid supplementation effects on weight and appetite in patients with Alzheimer's disease: the omega-3 Alzheimer's disease study. [Erratum appears in J Am Geriatr Soc. 2009 Mar;57(3):579]. J Am Geriatr Soc. Jan. 2009;57(1):11-7. KQ4E5, KQ5E5. [pmid: 19054188].
463 Ishizaki J, Meguro K, Ohe K, et al. Therapeutic psychosocial intervention for elderly subjects with very mild Alzheimer disease in a community: the tajiri project. Alzheimer Dis Assoc Disord. Oct. 2002;16(4):261-9. KQ4E6c, KQ5E6c. [pmid: 12468901].
464 Isik AT, Bozoglu E, Naharci MI, et al. Evaluation of the effects of galantamine on cardiac function in elderly patients with Alzheimer's disease. Am J Geriatr Pharmacother. Oct. 2010;8(5):454-9. KQ4E3a, KQ5E3a. [pmid: 21335298].
465 Isik AT, Yildiz GB, Bozoglu E, et al. Cardiac safety of donepezil in elderly patients with Alzheimer disease. Intern Med. 2012;51(6):575-8. KQ5E2e. [pmid: 22449664].
466 Ito T, Yamadera H, Ito R, et al. Effects of vitamin B12 on bright light on cognitive and sleep-wake rhythm in Alzheimer-type dementia. Psychiatry Clin Neurosci. Jun. 2001;55(3):281-2. KQ4E2c, KQ5E5. [pmid: 11422876].
467 Ito T, Meguro K, Akanuma K, et al. A randomized controlled trial of the group reminiscence approach in patients with vascular dementia. Dement Geriatr Cogn Disord. 2007;24(1):48-54. KQ4E6b, KQ5E6b. [pmid: 17565213].
468 Jagger C, Clarke M, Anderson J, et al. Misclassification of dementia by the mini-mental state examination--are education and social class the only factors?. Age Ageing. Nov. 1992;21(6):404-11. KQ2E1. [pmid: 1471577].
469 Jansen AP, van Hout HP, van Marwijk HW, et al. (Cost)-effectiveness of case-management by district nurses among primary informal caregivers of older adults with dementia symptoms and the older adults who receive informal care: design of a randomized controlled trial [ISCRTN83135728]. BMC Public Health. 2005;5:133. KQ5E5. [pmid: 16343336].
470 Jansen AP, van Hout HP, Nijpels G, et al. Effectiveness of case management among older adults with early symptoms of dementia and their primary informal caregivers: A randomized clinical trial. Int J Nurs Stud. Aug. 2011;48(8):933-43. KQ5E5. [pmid: 21356537].
471 Jarvenpaa T, Rinne JO, Raiha I, et al. Characteristics of two telephone screens for cognitive impairment. Dement Geriatr Cogn Disord. 2002;13(3):149-55. KQ2E2d. [pmid: 11893836].
472 Jefferson AL, Wong S, Gracer TS, et al. Geriatric performance on an abbreviated version of the Boston naming test. Appl Neuropsychol. 2007;14(3):215-23. KQ2E3c, KQ3E3c. [pmid: 17848132].
473 Jensen LE, Padilla R. Effectiveness of interventions to prevent falls in people with Alzheimer's disease and related dementias. Am J Occup Ther. 2011;65(5):532-40. KQ4E1, KQ5E1. [pmid: 22026321].
474 Jeong SK, Cho KH, Kim JM. The usefulness of the Korean version of modified Mini-Mental State Examination (K-mMMSE) for dementia screening in community dwelling elderly people. BMC Public Health. Jul. 30. 2004;4:31. KQ3E5. [pmid: 15283869].
475 Jha A, Tabet N, Orrell M. To tell or not to tell-comparison of older patients' reaction to their diagnosis of dementia and depression. Int J Geriatr Psychiatry. Sep. 2001;16(9):879-85. KQ3E5. [pmid: 11571768].
476 Jha A, Jan F, Gale T, et al. Effectiveness of a recovery-orientated psychiatric intervention package on the wellbeing of people with early dementia: a preliminary randomised controlled trial. Int J Geriatr Psychiatry. 2012. Jul. 30. KQ4E6c, KQ5E6c. [pmid: 22847712].
477 Joffres C, Bucks RS, Haworth J, et al. Patterns of clinically detectable treatment effects with galantamine: a qualitative analysis. Dement Geriatr Cogn Disord. 2003;15(1):26-33. KQ4E8, KQ5E8. [pmid: 12457076].
478 Johannsen P, Salmon E, Hampel H, et al. Assessing therapeutic efficacy in a progressive disease: a study of donepezil in Alzheimer's disease. CNS Drugs. 2006;20(4):311-25. KQ4E7c, KQ5E7c. [pmid: 16599649].
479 Johansson M, Wressle E. Validation of the neurobehavioral cognitive status examination and the Rivermead Behavioural Memory Test in investigations of dementia. Scand J Occup Ther. May. 2012;19(3):282-7. KQ2E3c. [pmid: 21105840].
480 Joling KJ, van Hout HP, Scheltens P, et al. (Cost)-effectiveness of family meetings on indicated prevention of anxiety and depressive symptoms and disorders of primary family caregivers of patients with dementia: design of a randomized controlled trial. BMC Geriatr. 2008;8:2. KQ4E5, KQ5E5. [pmid: 18208607].
481 Joling KJ, van Marwijk HW, Smit F, et al. Does a family meetings intervention prevent depression and anxiety in family caregivers of dementia patients? A randomized trial. PLoS One. 2012;7(1):e30936. KQ5E5. [pmid: 22303473].
482 Joling KJ, van Marwijk HW, van der Horst HE, et al. Effectiveness of family meetings for family caregivers on delaying time to nursing home placement of dementia patients: a randomized trial. PLoS One. 2012;7(8):e42145. KQ5E5. [pmid: 22876304].
483 Jones RW, Soininen H, Hager K, et al. A multinational, randomised, 12-week study comparing the effects of donepezil and galantamine in patients with mild to moderate Alzheimer's disease. Int J Geriatr Psychiatry. Jan. 2004;19(1):58-67. KQ4E2b, KQ5E2e. [pmid: 14716700].
484 Jones RW, Bayer A, Inglis F, et al. Safety and tolerability of once-daily versus twice-daily memantine: a randomised, double-blind study in moderate to severe Alzheimer's disease. Int J Geriatr Psychiatry. Mar. 2007;22(3):258-62. KQ4E4c, KQ5E4c. [pmid: 17243195].
485 Jones RW. A review comparing the safety and tolerability of memantine with the acetylcholinesterase inhibitors. Int J Geriatr Psychiatry. Jun. 2010;25(6):547-53. KQ4E2a, KQ5E2a. [pmid: 20049770].
486 Jonker C, Comijs HC, Smit JH. Does aspirin or other NSAIDs reduce the risk of cognitive decline in elderly persons? Results from a population-based study. Neurobiol Aging. Jul. 2003;24(4):583-8. KQ4E1b, KQ5E1b. [pmid: 12714115].
487 Joosten-Weyn Banningh LW, Kessels RP, Olde Rikkert MG, et al. A cognitive behavioural group therapy for patients diagnosed with mild cognitive impairment and their significant others: feasibility and preliminary results. Clin Rehabil. Aug. 2008;22(8):731-40. KQ4E2a, KQ5E2a. [pmid: 18678573].
488 Joosten-Weyn Banningh LW, Prins JB, Vernooij-Dassen MJ, et al. Group therapy for patients with mild cognitive impairment and their significant others: results of a waiting-list controlled trial. Gerontology. 2011;57(5):444-54. KQ4E2a, KQ5E2a. [pmid: 20664181].
489 Jorm AF, Jacomb PA. The Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE): socio-demographic correlates, reliability, validity and some norms. Psychol Med. Nov. 1989;19(4):1015-22. KQ2E5. [pmid: 2594878].
490 Jorm AF, Scott R, Cullen JS, et al. Performance of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) as a screening test for dementia. Psychol Med. Aug. 1991;21(3):785-90. KQ2E3b, KQ3E3b. [pmid: 1946866].
491 Jorm AF. A short form of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE): development and cross-validation. Psychol Med. Feb. 1994;24(1):145-53. KQ2E7c. [pmid: 8208879].
492 Jorm AF, Broe GA, Creasy H, et al. Further data on the validity of the informant questionnaire on cognitive decline in the elderly (IQCODE). Int J Geriatr Psychiatry. 1996;11(2):131-9. PMID: None. KQ3E5.
493 Jorm AF, Christensen H, Henderson AS, et al. Informant ratings of cognitive decline of elderly people: relationship to longitudinal change on cognitive tests. Age Ageing. Mar. 1996;25(2):125-9. KQ2E5. [pmid: 8677826].
494 Judge KS, Bass DM, Snow AL, et al. Partners in dementia care: a care coordination intervention for individuals with dementia and their family caregivers. Gerontologist. Apr. 2011;51(2):261-72. KQ4E2a, KQ5E5. [pmid: 21242317].
495 Judge KS, Yarry SJ, Looman WJ, et al. Improved Strain and Psychosocial Outcomes for Caregivers of Individuals with Dementia: Findings from Project ANSWERS. Gerontologist. 2012. Aug. 16. KQ4E7c, KQ5E7c. [pmid: 22899427].
496 Jungwirth S, Zehetmayer S, Bauer P, et al. Screening for Alzheimer's dementia at age 78 with short psychometric instruments. Int Psychogeriatr. Jun. 2009;21(3):548-59. KQ2E5. [pmid: 19327204].
497 Junkkila J, Oja S, Laine M, et al. Applicability of the CANTAB-PAL computerized memory test in identifying amnestic mild cognitive impairment and Alzheimer's disease. Dement Geriatr Cogn Disord. 2012;34(2):83-9. KQ2E2d. [pmid: 22922741].
498 Justiss MD, Boustani M, Fox C, et al. Patients' attitudes of dementia screening across the Atlantic. Int J Geriatr Psychiatry. Jun. 2009;24(6):632-7. KQ3E5. [pmid: 19115255].
499 Juva K, Makela M, Erkinjuntti T, et al. Functional assessment scales in detecting dementia. Age Ageing. Sep. 1997;26(5):393-400. KQ3E5. [pmid: 9351484].
500 Kadir A, rreh-Shori T, Almkvist O, et al. PET imaging of the in vivo brain acetylcholinesterase activity and nicotine binding in galantamine-treated patients with AD. Neurobiol Aging. Aug. 2008;29(8):1204-17. KQ4E7c, KQ5E7c. [pmid: 17379359].
501 Kahan J, Kemp B, Staples FR, et al. Decreasing the burden in families caring for a relative with a dementing illness. A controlled study. J Am Geriatr Soc. Oct. 1985;33(10):664-70. KQ4E2c, KQ5E2c. [pmid: 4045083].
502 Kahle-Wrobleski K, Corrada MM, Li B, et al. Sensitivity and specificity of the mini-mental state examination for identifying dementia in the oldest-old: the 90+ study. J Am Geriatr Soc. Feb. 2007;55(2):284-9. KQ3E5. [pmid: 17302668].
503 Kaisey M, Mittman B, Pearson M, et al. Predictors of acceptance of offered care management intervention services in a quality improvement trial for dementia. Int J Geriatr Psychiatry. Oct. 2012;27(10):1078-85. KQ4E2a, KQ5E2a. [pmid: 22190354].
504 Kalbe E, Calabrese P, Schwalen S, et al. The Rapid Dementia Screening Test (RDST): a new economical tool for detecting possible patients with dementia. Dement Geriatr Cogn Disord. 2003;16(4):193-9. KQ2E2d. [pmid: 14512713].
505 Kalbe E, Kessler J, Calabrese P, et al. DemTect: a new, sensitive cognitive screening test to support the diagnosis of mild cognitive impairment and early dementia. Int J Geriatr Psychiatry. Feb. 2004;19(2):136-43. KQ2E2d. [pmid: 14758579].
506 Kalmijn S, Launer LJ, Ott A, et al. Dietary fat intake and the risk of incident dementia in the Rotterdam Study. Ann Neurol. Nov. 1997;42(5):776-82. KQ4E6b, KQ5E6b. [pmid: 9392577].
507 Kalmijn S, Feskens EJ, Launer LJ, et al. Polyunsaturated fatty acids, antioxidants, and cognitive function in very old men. Am J Epidemiol. Jan. 1. 1997;145(1):33-41. KQ4E1, KQ5E1. [pmid: 8982020].
508 Kamenski G, Dorner T, Lawrence K, et al. Detection of dementia in primary care: comparison of the original and a modified Mini-Cog Assessment with the Mini-Mental State Examination. Ment Health Fam Med. Dec. 2009;6(4):209-17. KQ2E7b. [pmid: 22477912].
509 Kang HY, Bae YS, Kim EH, et al. An integrated dementia intervention for Korean older adults. J Psychosoc Nurs Ment Health Serv. Dec. 2010;48(12):42-50. KQ4E2a, KQ5E2a. [pmid: 21053789].
510 Kang JH, Cook N, Manson J, et al. Low dose aspirin and cognitive function in the women's health study cognitive cohort. BMJ. May. 12. 2007;334(7601):987. KQ4E1b, KQ5E1b. [pmid: 17468120].
511 Kang JH, Cook NR, Manson JE, et al. Vitamin E, vitamin C, beta carotene, and cognitive function among women with or at risk of cardiovascular disease: The Women's Antioxidant and Cardiovascular Study. Circulation. Jun. 2. 2009;119(21):2772-80. KQ4E1b, KQ5E1b. [pmid: 19451353].
512 Kapaki E, Ilias I, Paraskevas GP, et al. Thyroid function in patients with Alzheimer's disease treated with cholinesterase inhibitors. Acta Biol Exp. 2003;63(4):389-92. KQ5E1. [pmid: 15053263].
513 Katzman R, Brown T, Fuld P, et al. Validation of a short Orientation-Memory-Concentration Test of cognitive impairment. Am J Psychiatry. Jun. 1983;140(6):734-9. KQ2E3b. [pmid: 6846631].
514 Kaufer DI, Williams CS, Braaten AJ, et al. Cognitive screening for dementia and mild cognitive impairment in assisted living: comparison of 3 tests. J Am Med Dir Assoc. Oct. 2008;9(8):586-93. KQ3E5. [pmid: 19083293].
515 Kavanagh S, Howe I, Brashear HR, et al. Long-term response to galantamine in relation to short-term efficacy data: pooled analysis in patients with mild to moderate Alzheimer's disease. Curr Alzheimer Res. Mar. 2011;8(2):175-86. KQ5E5. [pmid: 21222607].
516 Kavanagh S, Van BB, Schauble B. Long-term effects of galantamine on cognitive function in Alzheimer's disease: a large-scale international retrospective study. J Alzheimers Dis. 2011;27(3):521-30. KQ4E8, KQ5E8. [pmid: 21891871].
517 Kavanagh S, Gaudig M, Van BB, et al. Galantamine and behavior in Alzheimer disease: analysis of four trials. Acta Neurol Scand. Nov. 2011;124(5):302-8. KQ4E8, KQ5E8. [pmid: 21615354].
518 Kawas C, Segal J, Stewart WF, et al. A validation study of the Dementia Questionnaire. Arch Neurol. Sep. 1994;51(9):901-6. KQ2E6a. [pmid: 8080390].
519 Kay DW, Henderson AS, Scott R, et al. Dementia and depression among the elderly living in the Hobart community: the effect of the diagnostic criteria on the prevalence rates. Psychol Med. Nov. 1985;15(4):771-88. KQ3E5. [pmid: 4080881].
520 Keller C, Kadir A, Forsberg A, et al. Long-term effects of galantamine treatment on brain functional activities as measured by PET in Alzheimer's disease patients. J Alzheimers Dis. 2011;24(1):109-23. KQ4E7c, KQ5E7c. [pmid: 21157026].
521 Kemoun G, Thibaud M, Roumagne N, et al. Effects of a physical training programme on cognitive function and walking efficiency in elderly persons with dementia. Dement Geriatr Cogn Disord. 2010;29(2):109-14. KQ4E3b, KQ5E3b. [pmid: 20150731].
522 Kempenaar L, Creaney W. An investigation into a short-term group carer education programme for the informal carers of people with dementia. J Dement Care. 2002;10(5):32. PMID: None. KQ4E7c, KQ5E7c.
523 Kenny AM, Fabregas G, Song C, et al. Effects of testosterone on behavior, depression, and cognitive function in older men with mild cognitive loss. J Gerontol A Biol Sci Med Sci. Jan. 2004;59(1):75-8. KQ4E2c, KQ5E5. [pmid: 14718489].
524 Kerwin DR, Gaussoin SA, Chlebowski RT, et al. Interaction between body mass index and central adiposity and risk of incident cognitive impairment and dementia: results from the Women's Health Initiative Memory Study. J Am Geriatr Soc. 2011;59(1):107-12. KQ4E1b, KQ5E1b. [pmid: 21226681].
525 Khachaturian AS, Gallo JJ, Breitner JC. Performance characteristics of a two-stage dementia screen in a population sample. J Clin Epidemiol. May. 2000;53(5):531-40. KQ2E7c. [pmid: 10812327].
526 Kiddoe JM, Whitfield KE, Andel R, et al. Evaluating brief cognitive impairment screening instruments among African Americans. Aging Ment Health. Jul. 2008;12(4):488-93. KQ2E7b. [pmid: 18791896].
527 Kilada S, Gamaldo A, Grant EA, et al. Brief screening tests for the diagnosis of dementia: comparison with the Mini-Mental State Exam. Alzheimer Dis Assoc Disord. 2005;19(1):8-16. KQ2E2d. [pmid: 15764865].
528 Kim JM, Shin IS, Yoon JS. Correlates of dropout, efficacy, and adverse events in treatment with acetylcholinesterase inhibitors in Korean patients with Alzheimer's disease. Int Psychogeriatr. Jun. 2002;14(2):187-95. KQ4E3c, KQ5E3c. [pmid: 12243209].
529 Kim TH, Jhoo JH, Park JH, et al. Korean version of mini mental status examination for dementia screening and its' short form. Psychiatry Investig. Jun. 2010;7(2):102-8. KQ2E2d. [pmid: 20577618].
530 King AC, Baumann K, O'Sullivan P, et al. Effects of Moderate-Intensity Exercise on Physiological, Behavioral, and Emotional Responses to Family Caregiving. J Gerontol A Biol Sci Med Sci. Jan. 1. 2002;57(1):M26-M36. KQ5E5. [pmid: 11773209].
531 Kinnair D, Machili C, Prettyman R, et al. Cardio-vascular safety of acetyl cholinesterase inhibitors in patients suffering from Alzheimer's disease; factors that predict poor tolerability. Int J Geriatr Psychiatry. Mar. 2011;26(3):328-9. KQ5E2e. [pmid: 21319335].
532 Kinsella GJ, Mullaly E, Rand E, et al. Early intervention for mild cognitive impairment: a randomised controlled trial. J Neurol Neurosurg Psychiatry. Jul. 2009;80(7):730-6. KQ5E5. [pmid: 19332424].
533 Kirby M, Denihan A, Bruce I, et al. The clock drawing test in primary care: sensitivity in dementia detection and specificity against normal and depressed elderly. Int J Geriatr Psychiatry. Oct. 2001;16(10):935-40. KQ3E5. [pmid: 11607936].
534 Klinger T, Ibach B, Schoenknecht P, et al. Effect of donepezil in patients with Alzheimer's disease previously untreated or treated with memantine or nootropic agents in Germany: an observational study. Curr Med Res Opin. May. 2005;21(5):723-32. KQ4E2a, KQ5E2e. [pmid: 15969871].
535 Klusmann V, Evers A, Schwarzer R, et al. Complex mental and physical activity in older women and cognitive performance: A 6-month randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2010;65A(6):680-8. KQ4E1b, KQ5E1b. [pmid: 20418350].
536 Knafelc R, Lo GD, Harrigan S, et al. The combination of cognitive testing and an informant questionnaire in screening for dementia. Age Ageing. Sep. 2003;32(5):541-7. KQ2E3c. [pmid: 12958005].
537 Kokmen E, Smith GE, Petersen RC, et al. The short test of mental status. Correlations with standardized psychometric testing. Arch Neurol. Jul. 1991;48(7):725-8. KQ2E2d. [pmid: 1859300].
538 Kolanowski AM, Hill NL. Community-based non-pharmacological interventions delivered by family caregivers reduce behavioural and psychological symptoms of dementia. Evid Based Nurs. 2012. Nov. 30. KQ4E2a, KQ5E2a. [pmid: 23204295].
539 Koontz J, Baskys A. Effects of galantamine on working memory and global functioning in patients with mild cognitive impairment: a double-blind placebo-controlled study. Am J Alzheimers Dis Other Demen. 2005;20(5):295-302. KQ4E8, KQ5E8. [pmid: 16273995].
540 Korner EA, Lauritzen L, Nilsson FM, et al. Simple scoring of the Clock-Drawing test for dementia screening. Dan Med J. Jan. 2012;59(1):A4365. KQ2E2d. [pmid: 22239841].
541 Kosloski K, Montgomery RJV. The effects of respite on caregivers of Alzheimer's patients: One year evaluation of the Michigan Model Respite Programs. J Appl Gerontol. 1993;12(1):4-17. PMID: None. KQ4E6b, KQ5E6b.
542 Kosloski K, Montgomery RJ. The impact of respite use on nursing home placement. Gerontologist. Feb. 1995;35(1):67-74. KQ4E2a, KQ5E5. [pmid: 7890206].
543 Kral VA, Solyom L, Enesco H, et al. Relationship of vitamin B12 and folic acid to memory function. Biol Psychiatry. Jan. 1970;2(1):19-26. KQ4E3b, KQ5E3b. [pmid: 5414901].
544 Kroger E, van MR, Souverein P, et al. Discontinuation of cholinesterase inhibitor treatment and determinants thereof in the Netherlands: A retrospective cohort study. Drugs Aging. Aug. 1. 2010;27(8):663-75. KQ5E5. [pmid: 20658794].
545 Kruglov LS. The early stage of vascular dementia: significance of a complete therapeutic program. Int J Geriatr Psychiatry. May. 2003;18(5):402-6. KQ4E3a, KQ5E3a. [pmid: 12766915].
546 Kurz A. Non-cognitive benefits of galantamine (Reminyl-®) treatment in vascular dementia. Acta Neurol Scand. 2002;106(Suppl178):19-24. KQ4E8, KQ5E8. [pmid: 12067323].
547 Kurz A, Lilienfeld S, Brashear HR. Galantamine delays the onset of behavioral disturbances over 1 year in vascular dementia and Alzheimer's disease with cerebrovascular disease. Eur Neuropsychopharmacol. 2002;12(Suppl 3):S380. PMID: None. KQ4E2a, KQ5E5.
548 Kurz A, Wagenpfeil S, Hallauer J, et al. Evaluation of a brief educational program for dementia carers: the AENEAS study. Int J Geriatr Psychiatry. Aug. 2010;25(8):861-9. KQ5E5. [pmid: 19946869].
549 Kurz A, Thone-Otto A, Cramer B, et al. CORDIAL: cognitive rehabilitation and cognitive-behavioral treatment for early dementia in Alzheimer disease: a multicenter, randomized, controlled trial. Alzheimer Dis Assoc Disord. Jul. 2012;26(3):246-53. KQ5E5. [pmid: 21986341].
550 Kurz AF, Erkinjuntti T, Small GW, et al. Long-term safety and cognitive effects of galantamine in the treatment of probable vascular dementia or Alzheimer's disease with cerebrovascular disease. Eur J Neurol. 2003;10(6):633-40. KQ4E2a, KQ5E8. [pmid: 14641507].
551 Kuslansky G, Buschke H, Katz M, et al. Screening for Alzheimer's disease: the memory impairment screen versus the conventional three-word memory test. J Am Geriatr Soc. Jun. 2002;50(6):1086-91. KQ3E5. [pmid: 12110070].
552 Kuslansky G, Katz M, Verghese J, et al. Detecting dementia with the Hopkins Verbal Learning Test and the Mini-Mental State Examination. Arch Clin Neuropsychol. Jan. 2004;19(1):89-104. KQ2E2d. [pmid: 14670382].
553 Kwak J, Montgomery RJ, Kosloski K, et al. The impact of TCARE[REGISTERED] on service recommendation, use, and caregiver well-being. Gerontologist. Oct. 2011;51(5):704-13. KQ4E7c, KQ5E7c. [pmid: 21593010].
554 Kwak YS, Um SY, Son TG, et al. Effect of regular exercise on senile dementia patients. Int J Sports Med. Jun. 2008;29(6):471-4. KQ4E7c, KQ5E7c. [pmid: 18050054].
555 Kwok T, Tang C, Woo J, et al. Randomized trial of the effect of supplementation on the cognitive function of older people with subnormal cobalamin levels. Int J Geriatr Psychiatry. Sep. 1998;13(9):611-6. KQ4E1, KQ5E1. [pmid: 9777425].
556 Kwok T, Lee J, Law CB, et al. A randomized placebo controlled trial of homocysteine lowering to reduce cognitive decline in older demented people. Clin Nutr. Jun. 2011;30(3):297-302. KQ5E5. [pmid: 21216507].
557 Kwon JC, Kim EG, Kim JW, et al. A multicenter, open-label, 24-week follow-up study for efficacy on cognitive function of donepezil in Binswanger-type subcortical vascular dementia. Am J Alzheimers Dis Other Demen. Aug. 2009;24(4):293-301. KQ4E2b, KQ5E2e. [pmid: 19383979].
558 Lam LC, Tam CW, Lui VW, et al. Screening of mild cognitive impairment in Chinese older adults--a multistage validation of the Chinese abbreviated mild cognitive impairment test. Neuroepidemiology. 2008;30(1):6-12. KQ3E5. [pmid: 18204291].
559 Lam LC, Lee JS, Chung JC, et al. A randomized controlled trial to examine the effectiveness of case management model for community dwelling older persons with mild dementia in Hong Kong. Int J Geriatr Psychiatry. Apr. 2010;25(4):395-402. KQ5E5. [pmid: 19606455].
560 Lam LC, Lui VW, Luk DN, et al. Effectiveness of an individualized functional training program on affective disturbances and functional skills in mild and moderate dementia--a randomized control trial. Int J Geriatr Psychiatry. Feb. 2010;25(2):133-41. KQ4E2b, KQ5E2b. [pmid: 19582757].
561 Lam LC, Chau RC, Wong BM, et al. Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. Int J Geriatr Psychiatry. Jul. 2011;26(7):733-40. KQ5E5. [pmid: 21495078].
562 Lam LC, Chau RC, Wong BM, et al. A 1-year randomized controlled trial comparing mind body exercise (Tai Chi) with stretching and toning exercise on cognitive function in older Chinese adults at risk of cognitive decline. J Am Med Dir Assoc. Jul. 2012;13(6):568-20. KQ4E7a, KQ5E7a. [pmid: 22579072].
563 Lancer KM. Immune function and psychological distress in familial dementia caregivers: A controlled trial of a cognitive-behavioral intervention. 68 ed. US. ProQuest Information & Learning. 2007. PMID: None. KQ4E2c, KQ5E5.
564 Lane GW. Coping as a mediator of caregiver distress. 64 ed. US. ProQuest Information & Learning. 2004. PMID: None. KQ4E7c, KQ5E7c.
565 Larkin M. Detection of cognitive impairment: the final frontier. Lancet Neurol. Oct. 2003;2(10):590-1. KQ4E2a, KQ5E2a. [pmid: 14526798].
566 Larner AJ. An audit of the Addenbrooke's Cognitive Examination (ACE) in clinical practice. Int J Geriatr Psychiatry. 2005;20(6):593-4. KQ2E6a, KQ3E6a. [pmid: 15962353].
567 Larner AJ. DemTect: 1-year experience of a neuropsychological screening test for dementia. Age Ageing. May. 2007;36(3):326-7. KQ2E3c, KQ3E3c. [pmid: 17296602].
568 Larner AJ. Addenbrooke's Cognitive Examination (ACE) for the diagnosis and differential diagnosis of dementia. Clin Neurol Neurosurg. Jul. 2007;109(6):491-4. KQ2E6a, KQ3E6a. [pmid: 17509752].
569 Larner AJ, Hancock P. Does combining cognitive and functional scales facilitate the diagnosis of dementia?. Int J Geriatr Psychiatry. May. 2012;27(5):547-8. KQ2E3c. [pmid: 22508475].
570 Larsson V, Engedal K, Aarsland D, et al. Quality of life and the effect of memantine in dementia with lewy bodies and Parkinson's disease dementia. Dement Geriatr Cogn Disord. 2011;32(4):227-34. KQ4E4b, KQ5E4b. [pmid: 22122992].
571 Lavery LL, Lu SY, Chang CC, et al. Cognitive assessment of older primary care patients with and without memory complaints. J Gen Intern Med. Jul. 2007;22(7):949-54. KQ3E5. [pmid: 17453265].
572 Law E, Connelly PJ, Randall E, et al. Does the Addenbrooke's Cognitive Examination-revised add to the Mini-Mental State Examination in established Alzheimer disease? Results from a national dementia research register. Int J Geriatr Psychiatry. 2012. May. 4. KQ2E3c. [pmid: 22556006].
573 Lawton MP, Brody EM, Saperstein A, et al. Respite services for caregivers: research findings for service planning. Home Health Care Serv Q. 1989;10(1-2):5-32. KQ4E6b, KQ5E6b. [pmid: 10318337].
574 Lawton MP, Brody EM, Saperstein AR. A controlled study of respite service for caregivers of Alzheimer's patients. Gerontologist. Feb. 1989;29(1):8-16. KQ4E6b, KQ5E6b. [pmid: 2753374].
575 Lazowski DA, Ecclestone NA, Myers AM, et al. A randomized outcome evaluation of group exercise programs in long-term care institutions. J Gerontol A Biol Sci Med Sci. Dec. 1999;54(12):M621-M628. KQ4E3b, KQ5E3b. [pmid: 10647968].
576 Le Couteur DG, Robinson M, Leverton A, et al. Adherence, persistence and continuation with cholinesterase inhibitors in Alzheimer's disease. Australas J Ageing. Sep. 2012;31(3):164-9. KQ5E5. [pmid: 22950587].
577 Lee D, Morgan K, Lindesay J. Effect of institutional respite care on the sleep of people with dementia and their primary caregivers. J Am Geriatr Soc. Feb. 2007;55(2):252-8. KQ4E2a, KQ5E5. [pmid: 17302663].
578 Lee JY, Dong WL, Cho SJ, et al. Brief screening for mild cognitive impairment in elderly outpatient clinic: validation of the Korean version of the Montreal Cognitive Assessment. J Geriatr Psychiatry Neurol. Jun. 2008;21(2):104-10. KQ3E5. [pmid: 18474719].
579 Lee KS, Kim EA, Hong CH, et al. Clock drawing test in mild cognitive impairment: quantitative analysis of four scoring methods and qualitative analysis. Dement Geriatr Cogn Disord. 2008;26(6):483-9. KQ3E5. [pmid: 18987468].
580 Lee LK, Shahar S, Chin AV, et al. Docosahexaenoic acid-concentrated fish oil supplementation in subjects with mild cognitive impairment (MCI): a 12-month randomised, double-blind, placebo-controlled trial. Psychopharmacology (Berl). 2012. Aug. 30. KQ4E3a, KQ5E3a. [pmid: 22932777].
581 Lehmann M, Regland B, Blennow K, et al. Vitamin B12-B6-folate treatment improves blood-brain barrier function in patients with hyperhomocysteinaemia and mild cognitive impairment. Dement Geriatr Cogn Disord. 2003;16(3):145-50. KQ4E2a, KQ5E5. [pmid: 12826740].
582 Leopold NA, Borson AJ. An alphabetical 'WORLD'. A new version of an old test. Neurology. Dec. 1997;49(6):1521-4. KQ2E2d. [pmid: 9409339].
583 Leoutsakos JM, Muthen BO, Breitner JC, et al. Effects of non-steroidal anti-inflammatory drug treatments on cognitive decline vary by phase of pre-clinical Alzheimer disease: findings from the randomized controlled Alzheimer's Disease Anti-inflammatory Prevention Trial. Int J Geriatr Psychiatry. Apr. 2012;27(4):364-74. KQ5E1b. [pmid: 21560159].
584 Lessig MC, Scanlan JM, Nazemi H, et al. Time that tells: critical clock-drawing errors for dementia screening. Int Psychogeriatr. Jun. 2008;20(3):459-70. KQ2E3c. [pmid: 17908348].
585 Leszcz M. Review of “Multisensory stimulation for elderly with dementia: A 24-week single-blind randomized controlled pilot study” and “A cognitive behavioral group therapy for patients diagnosed with mild cognitive impairment and their significant others: Feasibility and preliminary results”. Int J Group Psychother. 2011;61(1):153-8. KQ4E2a, KQ5E2a. [pmid: 21244210].
586 Levin OS, Batukaeva LA, Smolentseva IG, et al. Efficacy and safety of memantine in Lewy body dementia. Neurosci Behav Physiol. Jul. 2009;39(6):597-604. KQ4E2a, KQ5E2e. [pmid: 19517247].
587 Lewerin C, Matousek M, Steen G, et al. Significant correlations of plasma homocysteine and serum methylmalonic acid with movement and cognitive performance in elderly subjects but no improvement from short-term vitamin therapy: a placebo-controlled randomized study. Am J Clin Nutr. May. 2005;81(5):1155-62. KQ4E1b, KQ5E1b. [pmid: 15883442].
588 Li F, Jia XF, Jia J. The Informant Questionnaire on Cognitive Decline in the Elderly Individuals in Screening Mild Cognitive Impairment With or Without Functional Impairment. J Geriatr Psychiatry Neurol. 2012. Nov. 21. KQ2E3a. [pmid: 21560159].
589 Li M, Ng TP, Kua EH, et al. Brief informant screening test for mild cognitive impairment and early Alzheimer's disease. Dement Geriatr Cogn Disord. 2006;21(5-6):392-402. KQ3E5. [pmid: 16645272].
590 Liddle J, Smith-Conway ER, Baker R, et al. Memory and communication support strategies in dementia: Effect of a training program for informal caregivers. Int Psychogeriatr. Dec. 2012;24(12):1927-42. KQ4E7c, KQ5E7c. [pmid: 23092595].
591 Lifshitz M, Dwolatzky T, Press Y. Validation of the Hebrew Version of the MoCA Test as a Screening Instrument for the Early Detection of Mild Cognitive Impairment in Elderly Individuals. J Geriatr Psychiatry Neurol. Sep. 2012;25(3):155-61. KQ2E3c. [pmid: 23124009].
592 Lilly ML, Richards BS, Buckwalter KC. Friends and social support in dementia caregiving. Assessment and intervention. J Gerontol Nurs. Jan. 2003;29(1):29-36. KQ4E2a, KQ5E2a. [pmid: 12596335].
593 Lin KN, Wang PN, Liu CY, et al. Cutoff scores of the cognitive abilities screening instrument, Chinese version in screening of dementia. Dement Geriatr Cogn Disord. 2002;14(4):176-82. KQ2E6a. [pmid: 12411759].
594 Lin KN, Wang PN, Chen C, et al. The three-item clock-drawing test: a simplified screening test for Alzheimer's disease. Eur Neurol. 2003;49(1):53-8. KQ2E3c. [pmid: 12464719].
595 Lipton RB, Katz MJ, Kuslansky G, et al. Screening for dementia by telephone using the memory impairment screen. J Am Geriatr Soc. Oct. 2003;51(10):1382-90. KQ3E5. [pmid: 14511157].
596 Lithell H, Hansson L, Skoog I, et al. The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens. May. 2003;21(5):875-86. KQ4E1b, KQ5E1b. [pmid: 12714861].
597 Littbrand H, Rosendahl E, Lindelof N, et al. A high-intensity functional weight-bearing exercise program for older people dependent in activities of daily living and living in residential care facilities: evaluation of the applicability with focus on cognitive function. Phys Ther. Apr. 2006;86(4):489-98. KQ4E1b, KQ5E1b. [pmid: 16579666].
598 Littbrand H, Lundin-Olsson L, Gustafson Y, et al. The effect of a high-intensity functional exercise program on activities of daily living: a randomized controlled trial in residential care facilities. J Am Geriatr Soc. Oct. 2009;57(10):1741-9. KQ4E5, KQ5E5. [pmid: 19702617].
599 Littbrand H, Carlsson M, Lundin-Olsson L, et al. Effect of a high-intensity functional exercise program on functional balance: preplanned subgroup analyses of a randomized controlled trial in residential care facilities. J Am Geriatr Soc. Jul. 2011;59(7):1274-82. KQ4E5, KQ5E5. [pmid: 21718270].
600 Liu HC, Chou P, Lin KN, et al. Assessing cognitive abilities and dementia in a predominantly illiterate population of older individuals in Kinmen. Psychol Med. Aug. 1994;24(3):763-70. KQ2E6a. [pmid: 7991758].
601 Loewenstein DA, Acevedo A, Czaja SJ, et al. Cognitive rehabilitation of mildly impaired Alzheimer disease patients on cholinesterase inhibitors. Am J Geriatr Psychiatry. Jul. 2004;12(4):395-402. KQ4E2b, KQ5E2b. [pmid: 15249277].
602 LoGiudice D, Waltrowicz W, Brown K, et al. Do memory clinics improve the quality of life of carers? A randomized pilot trial. Int J Geriatr Psychiatry. Aug. 1999;14(8):626-32. KQ5E5. [pmid: 10489653].
603 LoGiudice D, Strivens E, Smith K, et al. The KICA Screen: the psychometric properties of a shortened version of the KICA (Kimberley Indigenous Cognitive Assessment). Australas J Ageing. Dec. 2011;30(4):215-9. KQ2E1. [pmid: 22176567].
604 Logsdon RG, McCurry SM, Teri L. Time-limited support groups for individuals with early stage dementia and their care partners: preliminary outcomes from a controlled clinical trial. Clin Gerontol. 2007;30(2):5-19. PMID: None. KQ4E2c, KQ5E2c.
605 Logsdon RG, Pike KC, McCurry SM, et al. Early-stage memory loss support groups: Outcomes from a randomized controlled clinical trial. J Gerontol B Psychol Sci Soc Sci. 2010;65B(6):691-7. KQ4E2c, KQ5E2c. [pmid: 20693265].
606 Loh PK, Maher S, Goldswain P, et al. Diagnostic accuracy of telehealth community dementia assessments. J Am Geriatr Soc. Nov. 2005;53(11):2043-4. KQ2E3c. [pmid: 16274402].
607 Lolk A, Nielsen H, Andersen K, et al. CAMCOG as a screening instrument for dementia: the Odense study. Cambridge Cognitive Examination. Acta Psychiatr Scand. Nov. 2000;102(5):331-5. KQ2E6a. [pmid: 11098803].
608 Lonie JA, Tierney KM, Herrmann LL, et al. Dual task performance in early Alzheimer's disease, amnestic mild cognitive impairment and depression. Psychol Med. Jan. 2009;39(1):23-31. KQ2E2d. [pmid: 18410701].
609 Lopez OL, Mackell JA, Sun Y, et al. Effectiveness and safety of donepezil in Hispanic patients with Alzheimer's disease: a 12-week open-label study. J Natl Med Assoc. Nov. 2008;100(11):1350-8. KQ5E2e. [pmid: 19024233].
610 Lopez OL, Becker JT, Wahed AS, et al. Long-term effects of the concomitant use of memantine with cholinesterase inhibition in Alzheimer disease. [Erratum appears in J Neurol Neurosurg Psychiatry. 2009 Sep 1;80(9):1056]. J Neurol Neurosurg Psychiatry. Jun. 2009;80(6):600-7. KQ4E2a, KQ5E5. [pmid: 19204022].
611 Lorentz WJ, Scanlan JM, Borson S. Brief screening tests for dementia. Can J Psychiatry. Oct. 2002;47(8):723-33. KQ2E2a. [pmid: 12420650].
612 Losada A, Marquez-Gonzalez M, Romero-Moreno R. Mechanisms of action of a psychological intervention for dementia caregivers: effects of behavioral activation and modification of dysfunctional thoughts. Int J Geriatr Psychiatry. 2010. Nov. 9. KQ5E5. [pmid: 21061414].
613 Lourenco RA, Filho Ribeiro ST. The accuracy of the Mini-Cog in screening low-educated elderly for dementia. J Am Geriatr Soc. 2006;54(2):376-7. KQ2E2a. [pmid: 16460402].
614 Lu CJ, Tune LE. Chronic exposure to anticholinergic medications adversely affects the course of Alzheimer disease. Am J Geriatr Psychiatry. Jul. 2003;11(4):458-61. KQ4E1, KQ5E1. [pmid: 12837675].
615 Lu PH, Edland SD, Teng E, et al. Donepezil delays progression to AD in MCI subjects with depressive symptoms. Neurology. Jun. 16. 2009;72(24):2115-21. KQ4E8, KQ5E8. [pmid: 19528519].
616 Luchsinger JA, Tang MX, Miller J, et al. Relation of higher folate intake to lower risk of Alzheimer disease in the elderly. Arch Neurol. Jan. 2007;64(1):86-92. KQ4E1b, KQ5E1b. [pmid: 17210813].
617 Luis CA, Keegan AP, Mullan M. Cross validation of the Montreal Cognitive Assessment in community dwelling older adults residing in the Southeastern US. Int J Geriatr Psychiatry. Feb. 2009;24(2):197-201. KQ2E3c. [pmid: 18850670].
618 Maci T, Pira FL, Quattrocchi G, et al. Physical and cognitive stimulation in Alzheimer Disease. the GAIA Project: a pilot study. Am J Alzheimers Dis Other Demen. Mar. 2012;27(2):107-13. KQ4E3c, KQ5E3c. [pmid: 22495338].
619 Mackinnon A, Mulligan R. Combining cognitive testing and informant report to increase accuracy in screening for dementia. Am J Psychiatry. Nov. 1998;155(11):1529-35. KQ2E3c. [pmid: 9812113].
620 Mackinnon A, Mulligan R. The Psychogeriatric Assessment Scales (PAS): psychometric properties in French and German speaking populations. Int J Geriatr Psychiatry. Sep. 2001;16(9):892-9. KQ2E6a. [pmid: 11571770].
621 Maclean LE, Collins CC, Byrne EJ. Dementia with Lewy bodies treated with rivastigmine: Effects on cognition, neuropsychiatric symptoms, and sleep. Int Psychogeriatr. 2001;13(3):277-88. KQ4E2a, KQ5E2a. [pmid: 11768375].
622 MacRae PG, Asplund LA, Schnelle JF, et al. A walking program for nursing home residents: effects on walk endurance, physical activity, mobility, and quality of life. J Am Geriatr Soc. Feb. 1996;44(2):175-80. KQ4E3b, KQ5E3b. [pmid: 8576508].
623 Magierska J, Magierski R, Fendler W, et al. Clinical application of the Polish adaptation of the Montreal Cognitive Assessment (MoCA) test in screening for cognitive impairment. Neurol Neurochir Psychiatr Pol. Mar. 2012;46(2):130-9. KQ2E2d. [pmid: 22581594].
624 Magnus RV, Cooper AJ. A controlled study of reactivan in geriatrics. Modern Geriatrics. June. 1974:270-6. PMID: None. KQ4E6b, KQ5E6b.
625 Mahoney DF, Tarlow BJ, Jones RN. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. Aug. 2003;43(4):556-67. KQ5E5. [pmid: 12937334].
626 Mahoney DM, Tarlow B, Jones RN, et al. Factors affecting the use of a telephone-based intervention for caregivers of people with Alzheimer's disease. J Telemed Telecare. 2001;7(3):139-48. KQ4E5, KQ5E5. [pmid: 11346473].
627 Malmstrom TK, Miller DK, Coats MA, et al. Informant-based dementia screening in a population-based sample of African Americans. Alzheimer Dis Assoc Disord. Apr. 2009;23(2):117-23. KQ2E4a. [pmid: 19484913].
628 Manly JJ, Schupf N, Stern Y, et al. Telephone-based identification of mild cognitive impairment and dementia in a multicultural cohort. Arch Neurol. May. 2011;68(5):607-14. KQ3E5. [pmid: 21555635].
629 Manos PJ. Ten-point clock test sensitivity for Alzheimer's disease in patients with MMSE scores greater than 23. Int J Geriatr Psychiatry. Jun. 1999;14(6):454-8. KQ2E2d. [pmid: 10398355].
630 Mansbach WE, MacDougall EE, Rosenzweig AS. The Brief Cognitive Assessment Tool (BCAT): a new test emphasizing contextual memory, executive functions, attentional capacity, and the prediction of instrumental activities of daily living. J Clin Exp Neuropsychol. 2012;34(2):183-94. KQ2E3c. [pmid: 22149477].
631 Mansbach WE, MacDougall EE. Development and validation of the short form of the Brief Cognitive Assessment Tool (BCAT-SF). Aging Ment Health. 2012;16(8):1065-71. KQ2E3c. [pmid: 22852748].
632 Marder K. Vitamin E and donepezil for the treatment of mild cognitive impairment. Curr Neurol Neurosci Rep. Sep. 2005;5(5):337-8. KQ4E2a, KQ5E2a. [pmid: 16131415].
633 Marin D, Amaya K, Casciano R, et al. Impact of rivastigmine on costs and on time spent in caregiving for families of patients with Alzheimer's disease. Int Psychogeriatr. Dec. 2003;15(4):385-98. KQ4E2a, KQ5E2a. [pmid: 15000418].
634 Markowitz JS, Gutterman EM, Lilienfeld S, et al. Sleep-related outcomes in persons with mild to moderate Alzheimer disease in a placebo-controlled trial of galantamine. Sleep. Aug. 1. 2003;26(5):602-6. KQ4E8, KQ5E8. [pmid: 12938815].
635 Marmeleira JF, Godinho MB, Fernandes OM. The effects of an exercise program on several abilities associated with driving performance in older adults. Accid Anal Prev. Jan. 2009;41(1):90-7. KQ4E1b, KQ5E1b. [pmid: 19114142].
636 Marquez-Gonzalez M, Losada A, Izal M, et al. Modification of dysfunctional thoughts about caregiving in dementia family caregivers: description and outcomes of an intervention programme. Aging Ment Health. Nov. 2007;11(6):616-25. KQ4E2c, KQ5E2c. [pmid: 18074249].
637 Marquez de la Plata C, Vicioso B, Hynan L, et al. Development of the Texas Spanish Naming Test: A test For Spanish speakers. Clin Neuropsychol. 2008;22(2):288-304. KQ2E7c. [pmid: 17853138].
638 Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. Jun. 2000;176:557-62. KQ5E5. [pmid: 10974962].
639 Martin-Carrasco M, Martin MF, Valero CP, et al. Effectiveness of a psychoeducational intervention program in the reduction of caregiver burden in Alzheimer's disease patients' caregivers. Int J Geriatr Psychiatry. May. 2009;24(5):489-99. KQ5E5. [pmid: 18949763].
640 Martin-Cook K, Davis BA, Hynan LS, et al. A randomized, controlled study of an Alzheimer's caregiver skills training program. Am J Alzheimers Dis Other Demen. Jul. 2005;20(4):204-10. KQ5E5. [pmid: 16136843].
641 Martin DC, Francis J, Protetch J, et al. Time dependency of cognitive recovery with cobalamin replacement: report of a pilot study. J Am Geriatr Soc. Feb. 1992;40(2):168-72. KQ4E4b, KQ5E4b. [pmid: 1740602].
642 Martins SP, Damasceno BP. Accuracy of prospective memory tests in mild Alzheimer's disease. Arq Neuropsiquiatr. 2012;70(1):17-21. KQ2E2d. [pmid: 22218468].
643 Matsuda O. Cognitive stimulation therapy for Alzheimer's disease: The effect of cognitive stimulation therapy on the progression of mild Alzheimer's disease in patients treated with donepezil. Int Psychogeriatr. 2007;19(2):241-52. KQ4E2a, KQ5E2a. [pmid: 17005066].
644 Matthews HP, Korbey J, Wilkinson DG, et al. Donepezil in Alzheimer's disease: eighteen month results from Southampton Memory Clinic. Int J Geriatr Psychiatry. Aug. 2000;15(8):713-20. KQ4E2a, KQ5E2e. [pmid: 10960883].
645 Maury S, Fondarai J, Baudu C, et al. Study of naftidrofuryl versus placebo in the age associated cognitive impairment on an outpatient basis. Rev Geriatr. 1993;18(4):239-46. PMID: None. KQ4E6b, KQ5E6b.
646 Mavall L, Malmberg B. Day care for persons with dementia. Dementia. Feb. 1. 2007;6(1):27-43. PMID: None. KQ4E6c, KQ5E6c.
647 Maxfield M. The death of the self: Older adults' anxiety concerning cognitive decline. Diss Abstr Int. 2010;70(8-B):5173. PMID: None. KQ3E1.
648 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. KQ4E3b, KQ5E3b. [pmid: 9988292].
649 McCarten JR, Anderson P, Kuskowski MA, et al. Screening for cognitive impairment in an elderly veteran population: acceptability and results using different versions of the Mini-Cog. J Am Geriatr Soc. Feb. 2011;59(2):309-13. KQ2E7b. [pmid: 21314650].
650 McCurry SM, Logsdon RG, Vitiello MV, et al. Successful behavioral treatment for reported sleep problems in elderly caregivers of dementia patients: a controlled study. J Gerontol B Psychol Sci Soc Sci. Mar. 1998;53(2):122-9. KQ4E7c, KQ5E7c. [pmid: 9520929].
651 McCurry SM, Pike KC, Vitiello MV, et al. Increasing Walking and Bright Light Exposure to Improve Sleep in Community-Dwelling Persons with Alzheimer's Disease: Results of a Randomized, Controlled Trial. J Am Geriatr Soc. 2011;59(8):1393-402. KQ4E6c, KQ5E6c. [pmid: 21797835].
652 McDowell I, Kristjansson B, Hill GB, et al. Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini-Mental State Exam (3MS) compared. J Clin Epidemiol. Apr. 1997;50(4):377-83. KQ3E5. [pmid: 9179095].
653 McGeer PL, Zeldowicz L, McGeer EG. A clinical trial of folic acid in Parkinson's disease. Can Med Assoc J. Jan. 22. 1972;106(2):145-6. KQ4E4b, KQ5E4b. [pmid: 4400558].
654 McGinnis KA, Schulz R, Stone RA, et al. Concordance of race or ethnicity of interventionists and caregivers of dementia patients: relationship to attrition and treatment outcomes in the REACH study. Gerontologist. Aug. 2006;46(4):449-55. KQ4E5, KQ5E5. [pmid: 16920998].
655 McMahon JA, Green TJ, Skeaff CM, et al. A controlled trial of homocysteine lowering and cognitive performance. N Engl J Med. Jun. 29. 2006;354(26):2764-72. KQ4E1b, KQ5E1b. [pmid: 16807413].
656 McMurdo ME, Rennie L. A controlled trial of exercise by residents of old people's homes. Age Ageing. Jan. 1993;22(1):11-5. KQ4E2b, KQ5E2b. [pmid: 8438659].
657 McMurdo ME, Rennie LM. Improvements in quadriceps strength with regular seated exercise in the institutionalized elderly. Arch Phys Med Rehabil. May. 1994;75(5):600-3. KQ4E3b, KQ5E3b. [pmid: 8185457].
658 McMurdo ME, Millar AM, Daly F. A randomized controlled trial of fall prevention strategies in old peoples' homes. Gerontology. Mar. 2000;46(2):83-7. KQ4E2b, KQ5E2b. [pmid: 10671804].
659 McNeill G, Avenell A, Campbell MK, et al. Effect of multivitamin and multimineral supplementation on cognitive function in men and women aged 65 years and over: a randomised controlled trial. Nutr J. 2007;6:10. KQ4E1b, KQ5E1b. [pmid: 17474991].
660 McSweeney K, Jeffreys A, Griffith J, et al. Specialist mental health consultation for depression in Australian aged care residents with dementia: a cluster randomized trial. Int J Geriatr Psychiatry. Nov. 2012;27(11):1163-71. KQ4E3b, KQ5E3b. [pmid: 22344753].
661 Meador K, Loring D, Nichols M, et al. Preliminary findings of high-dose thiamine in dementia of Alzheimer's type. J Geriatr Psychiatry Neurol. Oct. 1993;6(4):222-9. KQ4E2c, KQ5E2e. [pmid: 8251051].
662 Meeuwsen EJ, Melis RJ, Van Der Aa GC, et al. Effectiveness of dementia follow-up care by memory clinics or general practitioners: randomised controlled trial. BMJ. 2012;344:e3086. KQ5E5. [pmid: 22589500].
663 Meguro M, Kasai M, Akanuma K, et al. Comprehensive approach of donepezil and psychosocial interventions on cognitive function and quality of life for Alzheimer's disease: the Osaki-Tajiri Project. Age Ageing. Jul. 2008;37(4):469-73. KQ4E3b, KQ5E3b. [pmid: 18515851].
664 Melis RJ, van Eijken MI, Borm GF, et al. The design of the Dutch EASYcare study: a randomised controlled trial on the effectiveness of a problem-based community intervention model for frail elderly people [NCT00105378]. BMC Health Serv Res. 2005;5:65. KQ4E6c, KQ5E6c. [pmid: 16207382].
665 Melis RJ, van Eijken MI, Teerenstra S, et al. A randomized study of a multidisciplinary program to intervene on geriatric syndromes in vulnerable older people who live at home (Dutch EASYcare Study). J Gerontol A Biol Sci Med Sci. Mar. 2008;63(3):283-90. KQ4E6c, KQ5E6c. [pmid: 18375877].
666 Mendez MF, Shapira JS, McMurtray A, et al. Preliminary findings: behavioral worsening on donepezil in patients with frontotemporal dementia. Am J Geriatr Psychiatry. Jan. 2007;15(1):84-7. KQ4E2a, KQ5E5. [pmid: 17194818].
667 Mendiondo MS, Ashford JW, Kryscio RJ, et al. Designing a Brief Alzheimer Screen (BAS). J Alzheimers Dis. Oct. 2003;5(5):391-8. KQ2E2d. [pmid: 14646030].
668 Menn P, Holle R, Kunz S, et al. Dementia care in the general practice setting: a cluster randomized trial on the effectiveness and cost impact of three management strategies. Value Health. Sep. 2012;15(6):851-9. KQ5E5. [pmid: 22999135].
669 Mets T, Vandewoude M, Jacquy J, et al. Patient and caregiver outcomes after 6 +/- 1.5-months of rivastigmine therapy for mild-to-moderate Alzheimer's disease: the Belgian FExT study. Curr Med Res Opin. Oct. 2007;23(10):2485-501. KQ4E2a, KQ5E5. [pmid: 17784995].
670 Meuleman JR, Brechue WF, Kubilis PS, et al. Exercise training in the debilitated aged: strength and functional outcomes. Arch Phys Med Rehabil. Mar. 2000;81(3):312-8. KQ4E3b, KQ5E3b. [pmid: 10724076].
671 Meulen EF, Schmand B, van Campen JP, et al. The seven minute screen: a neurocognitive screening test highly sensitive to various types of dementia. J Neurol Neurosurg Psychiatry. May. 2004;75(5):700-5. KQ2E2d. [pmid: 15090563].
672 Meyer JS, Rogers RL, McClintic K, et al. Controlled clinical trial of daily aspirin therapy in multi-infarct dementia. Stroke. 1988;19(1):148. PMID: None. KQ4E7c, KQ5E7c.
673 Milian M, Leiherr AM, Straten G, et al. The Mini-Cog versus the Mini-Mental State Examination and the Clock Drawing Test in daily clinical practice: screening value in a German Memory Clinic. Int Psychogeriatr. May. 2012;24(5):766-74. KQ2E3c. [pmid: 22172089].
674 Mimori Y, Katsuoka H, Nakamura S. Thiamine therapy in Alzheimer's disease. Metab Brain Dis. Mar. 1996;11(1):89-94. KQ4E2a, KQ5E5. [pmid: 8815393].
675 Minthon L, Wallin AK, Eriksson S, et al. Long-term rivastigmine treatment in a routine clinical setting. Acta Neurol Scand. Mar. 2009;119(3):180-5. KQ4E2a, KQ5E5. [pmid: 18759798].
676 Mioshi E, Dawson K, Mitchell J, et al. The Addenbrooke's Cognitive Examination Revised (ACE-R): a brief cognitive test battery for dementia screening. Int J Geriatr Psychiatry. Nov. 2006;21(11):1078-85. KQ2E6a. [pmid: 16977673].
677 Mioshi E, McKinnon C, Savage S, et al. Improving Burden and Coping Skills in Frontotemporal Dementia Caregivers : A Pilot Study. Alzheimer Dis Assoc Disord. 2012. Feb. 17. KQ4E7c, KQ5E7c. [pmid: 22354158].
678 Mitsuyama Y, Kogoh H. Serum and cerebrospinal fluid vitamin B12 levels in demented patients with CH3-B12 treatment--preliminary study. Jpn J Psychiatry Neurol. Mar. 1988;42(1):65-71. KQ4E4, KQ5E4. [pmid: 3398357].
679 Mittelman MS, Ferris SH, Steinberg G, et al. An intervention that delays institutionalization of Alzheimer's disease patients: treatment of spouse-caregivers. Gerontologist. Dec. 1993;33(6):730-40. KQ4E2b, KQ5E2b. [pmid: 8314099].
680 Mittelman MS, Ferris SH, Shulman E, et al. A comprehensive support program: effect on depression in spouse-caregivers of AD patients. Gerontologist. Dec. 1995;35(6):792-802. KQ4E2b, KQ5E2b. [pmid: 8557206].
681 Mittelman MS, Ferris SH, Shulman E, et al. A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. JAMA. Dec. 4. 1996;276(21):1725-31. KQ4E2b, KQ5E2b. [pmid: 8940320].
682 Mittelman MS. Psychosocial intervention for dementia caregivers: what can it accomplish?. Int Psychogeriatr. 2003;15(Suppl 1):247-9. KQ4E2a, KQ5E2a. [pmid: 16191248].
683 Mittelman MS. Long Term Effects of a Psychosocial Intervention on People With Dementia and Their Spouse Caregivers: Results of a Randomized Controlled Trial. Neurobiol Aging. 2004;25(2):S22-S23. PMID: None. KQ4E2b, KQ5E2b.
684 Mittelman MS, Roth DL, Haley WE, et al. Effects of a caregiver intervention on negative caregiver appraisals of behavior problems in patients with Alzheimer's disease: results of a randomized trial. J Gerontol B Psychol Sci Soc Sci. Jan. 2004;59(1):27-34. KQ4E2b, KQ5E2b. [pmid: 14722336].
685 Mittelman MS, Roth DL, Coon DW, et al. Sustained benefit of supportive intervention for depressive symptoms in caregivers of patients with Alzheimer's disease. Am J Psychiatry. May. 2004;161(5):850-6. KQ4E2b, KQ5E2b. [pmid: 15121650].
686 Mittelman MS, Haley WE, Clay OJ, et al. Improving caregiver well-being delays nursing home placement of patients with Alzheimer disease. Neurology. Nov. 14. 2006;67(9):1592-9. KQ4E4c, KQ5E4c. [pmid: 17101889].
687 Mittelman MS, Roth DL, Clay OJ, et al. Preserving health of Alzheimer caregivers: impact of a spouse caregiver intervention. Am J Geriatr Psychiatry. Sep. 2007;15(9):780-9. KQ4E2b, KQ5E2b. [pmid: 17804831].
688 Mittelman MS, Brodaty H, Wallen AS, et al. A three-country randomized controlled trial of a psychosocial intervention for caregivers combined with pharmacological treatment for patients with Alzheimer disease: effects on caregiver depression. Am J Geriatr Psychiatry. Nov. 2008;16(11):893-904. KQ5E5. [pmid: 18978250].
689 Mittelman MS. Effect of support and counseling on caregivers of patients with Alzheimer's disease. Int Psychogeriatr. 2000;12(Suppl 1):341-6. PMID: None. KQ4E2a, KQ5E2a.
690 Miu DKY, Szeto SL, Mak YF. Asian J Gerontol Geriatr. 2008;3. PMID: None. KQ4E7c, KQ5E7c.
691 Modrego PJ, Pina MA, Fayed N, et al. Changes in metabolite ratios after treatment with rivastigmine in Alzheimer's disease: a nonrandomised controlled trial with magnetic resonance spectroscopy. CNS Drugs. 2006;20(10):867-77. KQ4E5, KQ5E5. [pmid: 16999455].
692 Mohide EA, Pringle DM, Streiner DL, et al. A randomized trial of family caregiver support in the home management of dementia. J Am Geriatr Soc. Apr. 1990;38(4):446-54. KQ4E4c, KQ5E4c. [pmid: 2184186].
693 Molinuevo JL, Berthier ML, Rami L. Donepezil provides greater benefits in mild compared to moderate Alzheimer's disease: implications for early diagnosis and treatment. Arch Gerontol Geriatr. Jan. 2011;52(1):18-22. KQ4E2a, KQ5E2e. [pmid: 19948364].
694 Moller HJ, Hartmann A, Kessler C, et al. Naftidrofuryl in the treatment of vascular dementia. Eur Arch Psychiatry Clin Neurosci. Dec. 2001;251(6):247-54. KQ4E6c, KQ5E6c. [pmid: 11881837].
695 Moniz-Cook E, Agar S, Gibson GD, et al. A preliminary study of the effects of early intervention with people with dementia and their families in a memory clinic. Aging Ment Health. 1998;2(3):199-211. PMID: None. KQ4E7c, KQ5E7c.
696 Moniz-Cook E, Elston C, Gardiner E, et al. Can training community mental health nurses to support family carers reduce behavioural problems in dementia? An exploratory pragmatic randomised controlled trial. Int J Geriatr Psychiatry. Feb. 2008;23(2):185-91. KQ4E7a, KQ5E7a. [pmid: 17621379].
697 Monsch AU, Giannakopoulos P, GAL-SUI Study Group. Effects of galantamine on behavioural and psychological disturbances and caregiver burden in patients with Alzheimer's disease. Curr Med Res Opin. Jun. 2004;20(6):931-8. KQ4E2a, KQ5E2e. [pmid: 15200752].
698 Montgomery RJ, Borgatta EF. The effects of alternative support strategies on family caregiving. Gerontologist. Aug. 1989;29(4):457-64. KQ4E6b, KQ5E6b. [pmid: 2521103].
699 Montgomery RJ, Kwak J, Kosloski K, et al. Effects of the TCARE[REGISTERED] intervention on caregiver burden and depressive symptoms: preliminary findings from a randomized controlled study. J Gerontol B Psychol Sci Soc Sci. Sep. 2011;66(5):640-7. KQ4E2b, KQ5E2b. [pmid: 21840840].
700 Moore AA, Siu AL. Screening for common problems in ambulatory elderly: clinical confirmation of a screening instrument. Am J Med. Apr. 1996;100(4):438-43. KQ2E5, KQ3E5. [pmid: 8610731].
701 Moore S, Sandman CA, McGrady K, et al. Memory training improves cognitive ability in patients with dementia. Neuropsychol Rehabil. 2001;11(3-4):245-61. PMID: None. KQ4E2c, KQ5E2c.
702 Morales JM, Gonzalez-Montalvo JI, Bermejo F, et al. The screening of mild dementia with a shortened Spanish version of the “Informant Questionnaire on Cognitive Decline in the Elderly”. Alzheimer Dis Assoc Disord. 1995;9(2):105-11. KQ2E7c. [pmid: 7662322].
703 Morales JM, Bermejo F, Romero M, et al. Screening of dementia in community-dwelling elderly through informant report. Int J Geriatr Psychiatry. Aug. 1997;12(8):808-16. KQ3E5. [pmid: 9283925].
704 Moretti R, Torre P, Antonello RM, et al. An open-label pilot study comparing rivastigmine and low-dose aspirin for the treatment of symptoms specific to patients with subcortical vascular dementia. Curr Ther Res Clin Exp. 2002;63(7):443-58. PMID: None. KQ4E2a, KQ5E2e.
705 Moretti R, Torre P, Antonello RM, et al. Rivastigmine in subcortical vascular dementia: an open 22-month study. J Neurol Sci. Nov. 15. 2002;203-204:141-6. KQ4E2a, KQ5E2e. [pmid: 12417373].
706 Moretti R, Torre P, Antonello RM, et al. Frontotemporal dementia: paroxetine as a possible treatment of behavior symptoms. A randomized, controlled, open 14-month study. Eur Neurol. 2003;49(1):13-9. KQ4E6c, KQ5E6c. [pmid: 12464713].
707 Moretti R, Torre P, Antonello RM, et al. Rivastigmine in subcortical vascular dementia: a randomized, controlled, open 12-month study in 208 patients. Am J Alzheimers Dis Other Demen. Sep. 2003;18(5):265-72. KQ4E2b, KQ5E2b. [pmid: 14569643].
708 Moretti R, Torre P, Antonello RM, et al. Rivastigmine superior to aspirin plus nimodipine in subcortical vascular dementia: an open, 16-month, comparative study. Int J Clin Pract. Apr. 2004;58(4):346-53. KQ4E2b, KQ5E2b. [pmid: 15161118].
709 Moretti R, Torre P, Antonello RM, et al. Rivastigmine in frontotemporal dementia: an open-label study. Drugs Aging. 2004;21(14):931-7. KQ4E2b, KQ5E2e. [pmid: 15554751].
710 Moretti R, Torre P, Antonello RM, et al. Different responses to rivastigmine in subcortical vascular dementia and multi-infarct dementia. Am J Alzheimers Dis Other Demen. Apr. 2008;23(2):167-76. KQ4E2a, KQ5E2e. [pmid: 18184948].
711 Morris JC, Cyrus PA, Orazem J, et al. Metrifonate benefits cognitive, behavioral, and global function in patients with Alzheimer's disease. Neurology. May. 1998;50(5):1222-30. KQ4E6b, KQ5E6b. [pmid: 9595967].
712 Morris JN, Fiatarone M, Kiely DK, et al. Nursing rehabilitation and exercise strategies in the nursing home. J Gerontol A Biol Sci Med Sci. Oct. 1999;54(10):M494-M500. KQ4E3b, KQ5E3b. [pmid: 10568531].
713 Morris MC, Evans DA, Bienias JL, et al. Consumption of fish and n-3 fatty acids and risk of incident Alzheimer disease. Arch Neurol. Jul. 2003;60(7):940-6. KQ4E1, KQ5E1. [pmid: 12873849].
714 Morris RG, Woods RT, Davies KS, et al. The use of a coping strategy focused support group for carers of dementia sufferers. Couns Psychol Q. 1992;5(4):337-48. PMID: None. KQ4E2b, KQ5E2b.
715 Mossello E, Tonon E, Caleri V, et al. Effectiveness and safety of cholinesterase inhibitors in elderly subjects with Alzheimer's disease: a “real world” study. Arch Gerontol Geriatr. 2004;(9):297-307. KQ4E2a, KQ5E2e. [pmid: 15066316].
716 Mowla A, Zandi T. Mini-mental status examination: a screening instrument for cognitive and mood disorders of elderly. Alzheimer Dis Assoc Disord. 2006;20(2):124. Jun. KQ2E2a, KQ3E2a. [pmid: 16772749].
717 Mowla A, Mosavinasab M, Haghshenas H, et al. Does serotonin augmentation have any effect on cognition and activities of daily living in Alzheimer's dementia? A double-blind, placebo-controlled clinical trial. J Clin Psychopharmacol. Oct. 2007;27(5):484-7. KQ4E7c, KQ5E7c. [pmid: 17873681].
718 Muhlack S, Przuntek H, Muller T. Transdermal rivastigmine treatment does not worsen impaired performance of complex motions in patients with Alzheimer's disease. Pharmacopsychiatry. Jan. 2006;39(1):16-9. KQ4E2a, KQ5E2e. [pmid: 16453249].
719 Mundt JC, Ferber KL, Rizzo M, et al. Computer-automated dementia screening using a touch-tone telephone. Arch Intern Med. Nov. 12. 2001;161(20):2481-7. KQ2E3c. [pmid: 11700161].
720 Mungas D, Marshall SC, Weldon M, et al. Age and education correction of Mini-Mental State Examination for English and Spanish-speaking elderly. Neurology. Mar. 1996;46(3):700-6. KQ2E7b. [pmid: 8618670].
721 Murden RA, McRae TD, Kaner S, et al. Mini-Mental State exam scores vary with education in blacks and whites. J Am Geriatr Soc. Feb. 1991;39(2):149-55. KQ2E7c. [pmid: 1991947].
722 Muscari A, Giannoni C, Pierpaoli L, et al. Chronic endurance exercise training prevents aging-related cognitive decline in healthy older adults: a randomized controlled trial. Int J Geriatr Psychiatry. Oct. 2010;25(10):1055-64. KQ4E1b, KQ5E1b. [pmid: 20033904].
723 Mussi C, Foroni M, Valli A, et al. The “time and change” test: an appropriate method to detect cognitive decline in the elderly. J Geriatr Psychiatry Neurol. 2002;15(1):12-5. KQ2E3b. [pmid: 11936237].
724 Na HR, Kim S, Choi SH, et al. Donepezil treatment in Alzheimer's disease patients with and without cerebrovascular lesions: a preliminary report. Geriatr Gerontol Int. Jan. 2011;11(1):90-7. KQ4E2a, KQ5E2e. [pmid: 20825496].
725 Nair BR, Browne WL, Chua LE, et al. Validating an Australian version of the Time and Change Test: A screening test for cognitive impairment. Australas J Ageing. 2007;26(2):87-90. PMID: None. KQ2E3c, KQ3E3c.
726 Narasimhalu K, Lee J, Auchus AP, et al. Improving detection of dementia in Asian patients with low education: combining the Mini-Mental State Examination and the Informant Questionnaire on Cognitive Decline in the Elderly. Dement Geriatr Cogn Disord. 2008;25(1):17-22. KQ2E4b. [pmid: 18025825].
727 Narasimhalu K, Effendy S, Sim CH, et al. A randomized controlled trial of rivastigmine in patients with cognitive impairment no dementia because of cerebrovascular disease. Acta Neurol Scand. Apr. 2010;121(4):217-24. KQ4E4b, KQ5E4b. [pmid: 19951274].
728 Nasreddine ZS, Phillips NA, Bedirian V, et al. The Montreal Cognitive Assessment, MoCA: a brief screening tool for mild cognitive impairment. J Am Geriatr Soc. Apr. 2005;53(4):695-9. KQ2E2d. [pmid: 15817019].
729 National Institutes of Health. Use of non-steroidal anti-inflammatory drugs suspended in large Alzheimer's disease prevention trial. NIH News. 2004. PMID: None. KQ4E2a, KQ5E2a.
730 Nebreda MC, Garcia-Caballero A, Asensio E, et al. A short-form version of the Boston Naming Test for language screening in dementia in a bilingual rural community in Galicia (Spain). Int Psychogeriatr. Apr. 2011;23(3):435-41. KQ2E3c. [pmid: 20813075].
731 Neri M, Iacono S, Renzetti C, et al. Cognitive training in aging and disease (COTRAD): Does it work in Italy?. Arch Gerontol Geriatr. Suppl 7. 2001:285-93. KQ4E2a, KQ5E2a. [pmid: 11431076].
732 Netz Y, Yaretzki A, Salganik I, et al. The effect of supervised physical activity on cognitive and affective state of geriatric and psycholgeriatric in-patients. Clin Gerontol. 1994;15(1):47-56. PMID: None. KQ4E3c, KQ5E3c.
733 Netz Y, Axelrad S, Argov E. Group physical activity for demented older adults feasibility and effectiveness. Clin Rehabil. Nov. 2007;21(11):977-86. KQ4E7c, KQ5E7c. [pmid: 17984150].
734 Neville CC, Byrne GJ. The impact of residential respite care on the behavior of older people. Int Psychogeriatr. Mar. 2006;18(1):163-70. KQ4E2a, KQ5E5. [pmid: 16255840].
735 Neville CC, Byrne GJ. Prevalence of disruptive behaviour displayed by older people in community and residential respite care settings. Int J Ment Health Nurs. Apr. 2007;16(2):81-5. KQ4E1, KQ5E1. [pmid: 17348958].
736 Newcomer R, Spitalny M, Fox P, et al. Effects of the Medicare Alzheimer's Disease Demonstration on the use of community-based services. Health Serv Res. Aug. 1999;34(3):645-67. KQ4E7a, KQ5E7a. [pmid: 10445896].
737 Newcomer R, Yordi C, DuNah R, et al. Effects of the Medicare Alzheimer's Disease Demonstration on caregiver burden and depression. Health Serv Res. Aug. 1999;34(3):669-89. KQ4E7a, KQ5E7a. [pmid: 10445897].
738 Nichols LO, Chang C, Lummus A, et al. The cost-effectiveness of a behavior intervention with caregivers of patients with Alzheimer's disease. J Am Geriatr Soc. Mar. 2008;56(3):413-20. KQ4E5, KQ5E5. [pmid: 18179480].
739 Nichols LO, Martindale-Adams J, Burns R, et al. Translation of a dementia caregiver support program in a health care system--REACH VA. Arch Intern Med. Feb. 28. 2011;171(4):353-9. KQ4E2a, KQ5E2a. [pmid: 21357811].
740 Nilsson K, Gustafson L, Hultberg B. Improvement of cognitive functions after cobalamin/folate supplementation in elderly patients with dementia and elevated plasma homocysteine. Int J Geriatr Psychiatry. Jun. 2001;16(6):609-14. KQ4E2a, KQ5E5. [pmid: 11424170].
741 Nishiwaki Y, Breeze E, Smeeth L, et al. Validity of the Clock-Drawing Test as a screening tool for cognitive impairment in the elderly. Am J Epidemiol. Oct. 15. 2004;160(8):797-807. KQ2E7b. [pmid: 15466502].
742 Nobili A, Riva E, Tettamanti M, et al. The effect of a structured intervention on caregivers of patients with dementia and problem behaviors: a randomized controlled pilot study. Alzheimer Dis Assoc Disord. Apr. 2004;18(2):75-82. KQ4E7a, KQ5E7a. [pmid: 15249851].
743 Nolan KA, Black RS, Sheu KF, et al. A trial of thiamine in Alzheimer's disease. Arch Neurol. Jan. 1991;48(1):81-3. KQ4E7c, KQ5E7c. [pmid: 1986730].
744 Nourhashemi F, Andrieu S, Gillette-Guyonnet S, et al. Effectiveness of a specific care plan in patients with Alzheimer's disease: cluster randomised trial (PLASA study). BMJ. 2010;340:c2466. KQ5E5. [pmid: 20522656].
745 Nozawa M, Ichimiya Y, Nozawa E, et al. Clinical effects of high oral dose of donepezil for patients with Alzheimer's disease in Japan. Psychogeriatrics. Jun. 2009;9(2):50-5. KQ4E2a, KQ5E5. [pmid: 19604325].
746 O'Caoimh R, Gao Y, McGlade C, et al. Resistance Training Promotes Cognitive and Functional Brain Plasticity in Seniors With Probable Mild Cognitive Impairment. Age Ageing. Sep. 2012;41(5):624-9. KQ2E3c. [pmid: 22610464].
747 O'Connor DW, Pollitt PA, Hyde JB, et al. The reliability and validity of the Mini-Mental State in a British community survey. J Psychiatr Res. 1989;23(1):87-96. KQ2E7c. [pmid: 2666647].
748 O'Neill D. The Mini-Mental Status Examination. J Am Geriatr Soc. Jul. 1991;39(7):733. KQ2E2a, KQ3E2a. [pmid: 2061545].
749 Olazaran J, Muniz R. Cognitive intervention in the initial stages of Alzheimer's disease. Res Pract Alzheimers Dis. 2006;11:376-80. PMID: None. KQ4E5, KQ5E5.
750 Olin JT, Bhatnagar V, Reyes P, et al. Safety and tolerability of rivastigmine capsule with memantine in patients with probable Alzheimer's disease: a 26-week, open-label, prospective trial (Study ENA713B US32). Int J Geriatr Psychiatry. Apr. 2010;25(4):419-26. KQ5E2e. [pmid: 19670390].
751 Onder G, Zanetti O, Giacobini E, et al. Reality orientation therapy combined with cholinesterase inhibitors in Alzheimer's disease: randomised controlled trial. Br J Psychiatry. Nov. 2005;187:450-5. KQ4E6b, KQ5E6b. [pmid: 16260821].
752 Onor ML, Trevisiol M, Negro C, et al. Impact of a multimodal rehabilitative intervention on demented patients and their caregivers. Am J Alzheimers Dis Other Demen. Aug. 2007;22(4):261-72. KQ4E7c, KQ5E7c. [pmid: 17712157].
753 Oresnik M. The influence of cognitive rehabilitation on cognitive competence in patients with Alzheimer's disease. Psychiatria Danub. 2008;20(2):174-8. KQ4E7c, KQ5E7c. [pmid: 18587287].
754 Orgogozo JM, Rigaud AS, Stoffler A, et al. Efficacy and safety of memantine in patients with mild to moderate vascular dementia: a randomized, placebo-controlled trial (MMM 300). Stroke. Jul. 2002;33(7):1834-9. KQ4E8, KQ5E8. [pmid: 12105362].
755 Orrell M, Spector A, Thorgrimsen L, et al. A pilot study examining the effectiveness of maintenance Cognitive Stimulation Therapy (MCST) for people with dementia. Int J Geriatr Psychiatry. May. 2005;20(5):446-51. KQ4E2c, KQ5E2c. [pmid: 15852436].
756 Ostrosky-Solis F, Davila G, Ortiz X, et al. Determination of normative criteria and validation of the SKT for use in Spanish-speaking populations. Int Psychogeriatr. Jun. 1999;11(2):171-80. KQ2E3a. [pmid: 11475431].
757 Ostwald SK, Hepburn KW, Caron W, et al. Reducing caregiver burden: a randomized psychoeducational intervention for caregivers of persons with dementia. Gerontologist. Jun. 1999;39(3):299-309. KQ5E5. [pmid: 10396888].
758 Ott BR, Blake LM, Kagan E, et al. Open label, multicenter, 28-week extension study of the safety and tolerability of memantine in patients with mild to moderate Alzheimer's disease. J Neurol. Mar. 2007;254(3):351-8. KQ4E5. [pmid: 17345042].
759 Ott CH, Kelber ST, Blaylock M. “Easing the way” for spouse caregivers of individuals with dementia: a pilot feasibility study of a grief intervention. Res Gerontol Nurs. Apr. 2010;3(2):89-99. KQ4E2a, KQ5E2a. [pmid: 20415358].
760 Ownby RL. Donepezil and vitamin E for mild cognitive impairment. Curr Psychiatry Rep. Feb. 2006;8(1):9. KQ4E2a, KQ5E2a. [pmid: 16513036].
761 Ownby RL. Rofecoxib in mild cognitive impairment. Curr Psychiatry Rep. Feb. 2006;8(1):9-10. KQ4E2a, KQ5E2a. [pmid: 16513035].
762 Ozenli Y, Yagci D, Karaca S. Efficacy of donepezil on cognitive functions in mild cognitive impairment. Klinik Psikofarmakoloji Bulteni. 2007;17(2):62-7. PMID: None. KQ4E3a, KQ5E3a.
763 Padala KP, Padala PR, Potter JF. Statins: a case for drug withdrawal in patients with dementia. J Am Geriatr Soc. Jun. 2010;58(6):1214-6. KQ4E1, KQ5E1. [pmid: 20722868].
764 Paleacu D, Mazeh D, Mirecki I, et al. Donepezil for the treatment of behavioral symptoms in patients with Alzheimer's disease. Clin Neuropharmacol. Nov. 2002;25(6):313-7. KQ4E2a, KQ5E2e. [pmid: 12469005].
765 Panisset M, Gauthier S, Moessler H, et al. Cerebrolysin in Alzheimer's disease: a randomized, double-blind, placebo-controlled trial with a neurotrophic agent. J Neural Trans. Jul. 2002;109(7-8):1089-104. KQ4E6c, KQ5E6c. [pmid: 12111446].
766 Pantoni L, Carosi M, Amigoni S, et al. A preliminary open trial with nimodipine in patients with cognitive impairment and leukoaraiosis. Clin Neuropharmacol. Dec. 1996;19(6):497-506. KQ4E6c, KQ5E6c. [pmid: 8937788].
767 Pantoni L, Bianchi C, Beneke M, et al. The Scandinavian Multi-Infarct Dementia Trial: a double-blind, placebo-controlled trial on nimodipine in multi-infarct dementia. J Neurol Sci. Apr. 15. 2000;175(2):116-23. KQ4E6c, KQ5E6c. [pmid: 10831772].
768 Pantoni L, Rossi R, Inzitari D, et al. Efficacy and safety of nimodipine in subcortical vascular dementia: a subgroup analysis of the Scandinavian Multi-Infarct Dementia Trial. J Neurol Sci. Apr. 15. 2000;175(2):124-34. KQ4E6c, KQ5E6c. [pmid: 10831773].
769 Panza F, Capurso C, D'Introno A, et al. Dietary polyunsaturated fatty acid supplementation, pre-dementia syndromes, and Alzheimer's disease. J Am Geriatr Soc. Mar. 2007;55(3):469-70. KQ4E2a, KQ5E2a. [pmid: 17341255].
770 Park MH, Kwon DY, Seo WK, et al. The effects of cognitive training on community-dwelling elderly Koreans. J Psychiatr Ment Health Nurs. Dec. 2009;16(10):904-9. KQ4E2c, KQ5E2c. [pmid: 19930364].
771 Pasquier F, Leys D, Scheltens P. The influence of coincidental vascular pathology on symptomatology and course of Alzheimer's disease. J Neural Transm Suppl. 1998;54:117-27. KQ4E1, KQ5E1. [pmid: 9850920].
772 Passeri M, Cucinotta D, Abate G, et al. Oral 5'-methyltetrahydrofolic acid in senile organic mental disorders with depression: results of a double-blind multicenter study. Aging (Milano ). Feb. 1993;5(1):63-71. KQ4E2b, KQ5E5. [pmid: 8257478].
773 Pathansali R, Mangoni AA, Creagh-Brown B, et al. Effects of folic acid supplementation on psychomotor performance and hemorheology in healthy elderly subjects. Arch Gerontol Geriatr. Jul. 2006;43(1):127-37. KQ4E1b, KQ5E1b. [pmid: 16359741].
774 Patterson CE, Passmore AP, Crawford VL. A 6-month open-label study of the effectiveness and tolerability of galantamine in patients with Alzheimer's disease. Int J Clin Pract. Feb. 2004;58(2):144-8. KQ4E2a, KQ5E2e. [pmid: 15055862].
775 Pavlik VN, Doody RS, Rountree SD, et al. Vitamin E use is associated with improved survival in an Alzheimer's disease cohort. Dement Geriatr Cogn Disord. 2009;28(6):536-40. KQ4E2a, KQ5E5. [pmid: 20016184].
776 Pedroso RV, Coelho FG, Santos-Galduroz RF, et al. Balance, executive functions and falls in elderly with Alzheimer's disease (AD): a longitudinal study. Arch Gerontol Geriatr. Mar. 2012;54(2):348-51. KQ4E7c, KQ5E7c. [pmid: 21774999].
777 Perry M, Melis RJ, Teerenstra S, et al. An in-home geriatric programme for vulnerable community-dwelling older people improves the detection of dementia in primary care. Int J Geriatr Psychiatry. Dec. 2008;23(12):1312-9. KQ4E6c, KQ5E6c. [pmid: 18853470].
778 Peskind ER, Potkin SG, Pomara N, et al. Memantine treatment in mild to moderate Alzheimer disease: a 24-week randomized, controlled trial. Am J Geriatr Psychiatry. Aug. 2006;14(8):704-15. KQ4E8, KQ5E8. [pmid: 16861375].
779 Peters O, Lorenz D, Fesche A, et al. A combination of galantamine and memantine modifies cognitive function in subjects with amnestic MCI. J Nutr Health Aging. 2012;16(6):544-8. KQ4E7a, KQ5E2e. [pmid: 22659994].
780 Peters R, Beckett N, Forette F, et al. Incident dementia and blood pressure lowering in the Hypertension in the Very Elderly Trial cognitive function assessment (HYVET-COG): a double-blind, placebo controlled trial. Lancet Neurol. Aug. 2008;7(8):683-9. KQ4E1b, KQ5E1b. [pmid: 18614402].
781 Peters R, Beckett N, Geneva M, et al. Sociodemographic and lifestyle risk factors for incident dementia and cognitive decline in the HYVET. Age Ageing. Sep. 2009;38(5):521-7. KQ4E1b, KQ5E1b. [pmid: 19553357].
782 Peters R, Beckett N, Beardmore R, et al. Modelling cognitive decline in the Hypertension in the Very Elderly Trial [HYVET] and proposed risk tables for population use. PLoS One. 2010;5(7):e11775. KQ4E1b, KQ5E1b. [pmid: 20668673].
783 Petersen RC, Thomas RG, Grundman M, et al. Vitamin E and donepezil for the treatment of mild cognitive impairment. N Engl J Med. Jun. 9. 2005;352(23):2379-88. KQ4E8, KQ5E8. [pmid: 15829527].
784 Pezzotti P, Scalmana S, Mastromattei A, et al. The accuracy of the MMSE in detecting cognitive impairment when administered by general practitioners: a prospective observational study. BMC Fam Pract. 2008;9:29. KQ2E7c. [pmid: 18477390].
785 Pigliautile M, Ricci M, Mioshi E, et al. Validation study of the Italian Addenbrooke's Cognitive Examination Revised in a young-old and old-old population. Dement Geriatr Cogn Disord. 2011;32(5):301-7. KQ2E2d. [pmid: 22262124].
786 Pillemer K, Jill SJ. Peer support for Alzheimer's caregivers: Is it enough to make a difference?. Res Aging. 2002;24(2):171-92. PMID: None. KQ5E5.
787 Pirani A, Brodaty H, Martini E, et al. The validation of the Italian version of the GPCOG (GPCOG-It): a contribution to cross-national implementation of a screening test for dementia in general practice. Int Psychogeriatr. Feb. 2010;22(1):82-90. KQ2E2d. [pmid: 19891815].
788 Pirttila T, Wilcock G, Truyen L, et al. Long-term efficacy and safety of galantamine in patients with mild-to-moderate Alzheimer's disease: multicenter trial. Eur J Neurol. Nov. 2004;11(11):734-41. KQ4E2a, KQ5E8. [pmid: 15525294].
789 Pitrou I. Well-being of patients with dementia and their caregivers after a biobehavioral home-based intervention. JAMA. 2010;304(22):2482-3. KQ4E2a, KQ5E2a. [pmid: 21139108].
790 Poitrenaud J, Piette F, Malbezin M, et al. Almitrine-raubasine and cognitive impairment in the elderly: results of a 6-month controlled multicenter study. Clin Neuropharmacol. 1990;13(Suppl 3):S100-S108. KQ4E6c, KQ5E6c. [pmid: 2093414].
791 Pomara N, Ott BR, Peskind E, et al. Memantine treatment of cognitive symptoms in mild to moderate Alzheimer disease: secondary analyses from a placebo-controlled randomized trial. Alzheimer Dis Assoc Disord. Jan. 2007;21(1):60-4. KQ4E8, KQ5E8. [pmid: 17334274].
792 Pomeroy VM, Warren CM, Honeycombe C, et al. Mobility and dementia: is physiotherapy treatment during respite care effective?. Int J Geriatr Psychiatry. May. 1999;14(5):389-97. KQ4E2b, KQ5E2b. [pmid: 10389044].
793 Potkin SG, Alva G, Gunay I, et al. A pilot study evaluating the efficacy and safety of rivastigmine in patients with mixed dementia. Drugs Aging. 2006;23(3):241-9. KQ4E2a, KQ5E2e. [pmid: 16608379].
794 Powell RR. Psychological effects of exercise therapy upon institutionalized geriatric mental patients. J Gerontol. Mar. 1974;29(2):157-61. KQ4E3c, KQ5E3c. [pmid: 4811950].
795 Powlishta KK, Von Dras DD, Stanford A, et al. The clock drawing test is a poor screen for very mild dementia. Neurology. Sep. 24. 2002;59(6):898-903. KQ2E4c. [pmid: 12297574].
796 Pratico D. High-dose B vitamin supplements and Alzheimer disease. JAMA. Mar. 2009;301(10):1020-1. KQ4E2a, KQ5E2a. [pmid: 19278942].
797 Pregelj P. Safety and tolerability of rivastigmine transdermal patch formulation in newly diagnosed patients with Alzheimer's dementia in naturalistic conditions. Psychogeriatrics. Sep. 2012;12(3):165-71. KQ5E2e. [pmid: 22994614].
798 Pressman P, Gottfried JA. Journal Club: a randomized, double-blind, placebo-controlled trial of simvastatin to treat Alzheimer disease. Neurology. Jul. 24. 2012;79(4):e33-e36. KQ4e2A, KQ5E2a. [pmid: 22826548].
799 Price JF, Stewart MC, Deary IJ, et al. Low dose aspirin and cognitive function in middle aged to elderly adults: randomised controlled trial. BMJ. 2008;337:a1198. KQ4E1b, KQ5E1b. [pmid: 18762476].
800 Prieto G, Contador I, Tapias-Merino E, et al. The Mini-Mental-37 Test for dementia screening in the Spanish population: An analysis using the Rasch model. Clin Neuropsychol. 2012;26(6):1003-18. KQ2E5. [pmid: 22809084].
801 Purdon SE, Waldie B. A short form of the Wisconsin Card Sorting Test. J Psychiatry Neurosci. May. 2001;26(3):253-6. KQ2E1. [pmid: 11394197].
802 Quayhagen MP, Quayhagen M. Differential effects of family-based strategies on Alzheimer's disease. Gerontologist. Apr. 1989;29(2):150-5. KQ4E2b, KQ5E2b. [pmid: 2666277].
803 Quayhagen MP, Quayhagen M, Corbeil RR, et al. A dyadic remediation program for care recipients with dementia. Nurs Res. May. 1995;44(3):153-9. KQ5E5. [pmid: 7761291].
804 Quayhagen MP, Quayhagen M, Corbeil RR, et al. Coping with dementia: evaluation of four nonpharmacologic interventions. Int Psychogeriatr. Jun. 2000;12(2):249-65. KQ4E7c, KQ5E7c. [pmid: 10937544].
805 Quayhagen MP, Quayhagen M. Testing of a cognitive stimulation intervention for dementia caregiving dyads. Neuropsychol Rehabil. 2001;11(3-4):319-32. PMID: None. KQ4E5, KQ5E5.
806 Querfurth HW, Allam GJ, Geffroy MA, et al. Acetylcholinesterase inhibition in dementia with Lewy bodies: Results of a prospective pilot trial. Dement Geriatr Cogn Disord. 2000;11(6):314-21. KQ4E2a, KQ5E5. [pmid: 11044776].
807 Qureshi N, Babbar R. Effect of ramipril therapy on cognitive functions in cases of mild to moderate essential hypertension. Indian J Physiol Pharmacol. Jan. 2007;51(1):40-8. KQ4E1b, KQ5E1b. [pmid: 17877291].
808 Raab MF, Anstadt SP. Improving office detection of asymptomatic dementia. J Am Geriatr Soc. Oct. 2011;59(10):1975-6. KQ2E7c. [pmid: 22091518].
809 Rainer M, Mucke HA, Kruger-Rainer C, et al. Cognitive relapse after discontinuation of drug therapy in Alzheimer's disease: cholinesterase inhibitors versus nootropics. J Neural Trans. 2001;108(11):1327-33. KQ4E1, KQ5E1. [pmid: 11768631].
810 Rait G, Morley M, Burns A, et al. Screening for cognitive impairment in older African-Caribbeans. Psychol Med. Jul. 2000;30(4):957-63. KQ3E5. [pmid: 11037103].
811 Rait G, Burns A, Baldwin R, et al. Validating screening instruments for cognitive impairment in older South Asians in the United Kingdom. Int J Geriatr Psychiatry. Jan. 2000;15(1):54-62. KQ3E5. [pmid: 10637405].
812 Rami L, Molinuevo JL, Sanchez-Valle R, et al. Screening for amnestic mild cognitive impairment and early Alzheimer's disease with M@T (Memory Alteration Test) in the primary care population. Int J Geriatr Psychiatry. Apr. 2007;22(4):294-304. KQ2E3c. [pmid: 16998781].
813 Randhawa S, Walterfang M, Miller K, et al. The development and validation of a carer questionnaire to assess cognitive function in neuropsychiatric patients. J Psychosom Res. Jul. 2007;63(1):93-8. KQ2E3c. [pmid: 17586342].
814 Rapp S, Brenes G, Marsh AP. Memory enhancement training for older adults with mild cognitive impairment: a preliminary study. Aging Ment Health. Feb. 2002;6(1):5-11. KQ5E5. [pmid: 11827617].
815 Rapp SR, Espeland MA, Shumaker SA, et al. Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women's Health Initiative Memory Study: a randomized controlled trial. JAMA. May. 28. 2003;289(20):2663-72. KQ4E1b, KQ5E1b. [pmid: 12771113].
816 Raschetti R, Maggini M, Sorrentino GC, et al. A cohort study of effectiveness of acetylcholinesterase inhibitors in Alzheimer's disease. Eur J Clin Pharmacol. Jul. 2005;61(5-6):361-8. KQ4E2a. [pmid: 15912389].
817 Raskind MA, Cyrus PA, Ruzicka BB, et al. The effects of metrifonate on the cognitive, behavioral, and functional performance of Alzheimer's disease patients. Metrifonate Study Group. J Clin Psychiatry. May. 1999;60(5):318-25. KQ4E6c, KQ5E6c. [pmid: 10362441].
818 Raskind MA, Peskind ER, Wessel T, et al. Galantamine in AD: A 6-month randomized, placebo-controlled trial with a 6-month extension. The Galantamine USA-1 Study Group. Neurology. Jun. 27. 2000;54(12):2261-8. KQ4E8, KQ5E8. [pmid: 10881250].
819 Raskind MA, Peskind ER. Alzheimer's disease and related disorders. Med Clin North Am. May. 2001;85(3):803-17. KQ4E2a, KQ5E2a. [pmid: 11349485].
820 Raskind MA, Peskind ER, Truyen L, et al. The cognitive benefits of galantamine are sustained for at least 36 months: a long-term extension trial. Arch Neurol. 2004;61(2):252-6. KQ4E2a, KQ5E8. [pmid: 14967774].
821 Ravaglia G, Forti P, Maioli F, et al. Screening for mild cognitive impairment in elderly ambulatory patients with cognitive complaints. Aging Clin Exp Res. Oct. 2005;17(5):374-9. KQ2E3c. [pmid: 16392411].
822 Reines SA, Block GA, Morris JC, et al. Rofecoxib: no effect on Alzheimer's disease in a 1-year, randomized, blinded, controlled study. Neurology. Jan. 13. 2004;62(1):66-71. KQ4E6c, KQ5E6c. [pmid: 14718699].
823 Reischies FM, Geiselmann B. Age-related cognitive decline and vision impairment affecting the detection of dementia syndrome in old age. Br J Psychiatry. Nov. 1997;171:449-51. KQ3E5. [pmid: 9463604].
824 Relkin NR, Reichman WE, Orazem J, et al. A large, community-based, open-label trial of donepezil in the treatment of Alzheimer's disease. Dement Geriatr Cogn Disord. 2003;16(1):15-24. KQ4E2a. [pmid: 12714795].
825 Requena C, Lopez Ibor MI, Maestu F, et al. Effects of cholinergic drugs and cognitive training on dementia. Dement Geriatr Cogn Disord. 2004;18(1):50-4. KQ5E5. [pmid: 15084794].
826 Requena C, Maestu F, Campo P, et al. Effects of cholinergic drugs and cognitive training on dementia: 2-year follow-up. Dement Geriatr Cogn Disord. 2006;22(4):339-45. KQ5E5. [pmid: 16954689].
827 Requena H, Zubiaur G, ¡ndez Lucas A, et al. The effect of motor activity on improved memory and emotional well-being in elderly women. Rev Int Cienc Deporte. 2008;4(13):20-32. PMID: None. KQ4E7c, KQ5E7c.
828 Resnick SM, Coker LH, Maki PM, et al. The Women's Health Initiative Study of Cognitive Aging (WHISCA): a randomized clinical trial of the effects of hormone therapy on age-associated cognitive decline. Clinical Trials. 2004;1(5):440-50. KQ4E1b, KQ5E1b. [pmid: 16279282].
829 Richard E, Kuiper R, Dijkgraaf MG, et al. Vascular care in patients with Alzheimer's disease with cerebrovascular lesions-a randomized clinical trial. J Am Geriatr Soc. May. 2009;57(5):797-805. KQ4E1b, KQ5E1b. [pmid: 19484836].
830 Riepe MW, Adler G, Ibach B, et al. Domain-specific improvement of cognition on memantine in patients with Alzheimer's disease treated with rivastigmine. Dement Geriatr Cogn Disord. 2007;23(5):301-6. KQ4E2a, KQ5E5. [pmid: 17356273].
831 Rigaud AS, Andre G, Vellas B, et al. No additional benefit of HRT on response to rivastigmine in menopausal women with AD. Neurology. Jan. 14. 2003;60(1):148-9. KQ4E2b, KQ5E2e. [pmid: 12525745].
832 Riley McCarten J, Anderson P, Kuskowski MA, et al. Finding Dementia in Primary Care: The Results of a Clinical Demonstration Project. J Am Geriatr Soc. 2012;60(2):210-7. KQ2E7c, KQ3E7c. [pmid: 22332672].
833 Riordan J, Bennett A. An evaluation of an augmented domiciliary service to older people with dementia and their carers. Aging Ment Health. 1998;2:137-43. PMID: None. KQ4E4c, KQ5E4c.
834 Ripich DN, Ziol E, Lee MM. Longitudinal effects of communication training on caregivers of persons with Alzheimer's disease. Clin Gerontol. 1998;19(2):37-53. PMID: None. KQ4E2a, KQ5E2a.
835 Risner ME, Saunders AM, Altman JF, et al. Efficacy of rosiglitazone in a genetically defined population with mild-to-moderate Alzheimer's disease. Pharmacogenomics J. Jul. 2006;6(4):246-54. KQ4E6c, KQ5E6c. [pmid: 16446752].
836 Ritchie K, Fuhrer R. The validation of an informant screening test for irreversible cognitive decline in the elderly: performance characteristics within a general population sample. Int J Geriatr Psychiatry. 1996;11(2):149-56. PMID: None. KQ2E6a.
837 Rivera PA. Effectiveness of a psychoeducational intervention for the reduction of distress in mexican-american caregivers of dementia patients. Diss Abstr Int. 2000;60(8-B):4248. PMID: None. KQ4E2c, KQ5E5.
838 Robert PH, Schuck S, Dubois B, et al. Screening for Alzheimer's disease with the short cognitive evaluation battery. Dement Geriatr Cogn Disord. 2003;15(2):92-8. KQ2E3c. [pmid: 12566598].
839 Roberts J, Browne G, Milne C, et al. Problem-solving counseling for caregivers of the cognitively impaired: effective for whom?. Nurs Res. May. 1999;48(3):162-72. KQ5E5. [pmid: 10337847].
840 Robinson K, Yates K. Effects of two caregiver-training programs on burden and attitude toward help. Arch Psychiatr Nurs. Oct. 1994;8(5):312-9. KQ4E7c, KQ5E7c. [pmid: 7993133].
841 Robinson KM. A social skills training program for adult caregivers. ANS Adv Nurs Sci. Jan. 1988;10(2):59-72. KQ4E2c, KQ5E2c. [pmid: 3124721].
842 Roccaforte WH, Burke WJ, Bayer BL, et al. Reliability and validity of the Short Portable Mental Status Questionnaire administered by telephone. J Geriatr Psychiatry Neurol. Jan. 1994;7(1):33-8. KQ2E3c. [pmid: 8192828].
843 Rockwood K, Mintzer J, Truyen L, et al. Effects of a flexible galantamine dose in Alzheimer's disease: a randomised, controlled trial. J Neurol Neurosurg Psychiatry. Nov. 2001;71(5):589-95. KQ4E8, KQ5E8. [pmid: 11606667].
844 Rockwood K, Graham JE, Fay S, et al. Goal setting and attainment in Alzheimer's disease patients treated with donepezil. J Neurol Neurosurg Psychiatry. Nov. 2002;73(5):500-7. KQ4E2a, KQ5E2e. [pmid: 12397141].
845 Rockwood K, Black S, Bedard MA, et al. Specific symptomatic changes following donepezil treatment of Alzheimer's disease: a multi-centre, primary care, open-label study. Int J Geriatr Psychiatry. Apr. 2007;22(4):312-9. KQ4E2a, KQ5E2e. [pmid: 17006874].
846 Rockwood K, Dai D, Mitnitski A. Patterns of decline and evidence of subgroups in patients with Alzheimer's disease taking galantamine for up to 48 months. Int J Geriatr Psychiatry. Feb. 2008;23(2):207-14. KQ4E2a, KQ5E7a. [pmid: 17621382].
847 Rogers J, Kirby LC, Hempelman SR, et al. Clinical trial of indomethacin in Alzheimer's disease. Neurology. Aug. 1993;43(8):1609-11. KQ4E7c, KQ5E7c. [pmid: 8351023].
848 Rogers SL, Friedhoff LT. The efficacy and safety of donepezil in patients with Alzheimer's disease: results of a US Multicentre, Randomized, Double-Blind, Placebo-Controlled Trial. The Donepezil Study Group. Dementia. Nov. 1996;7(6):293-303. KQ4E8, KQ5E8. [pmid: 8915035].
849 Rogers SL, Doody RS, Mohs RC, et al. Donepezil improves cognition and global function in Alzheimer disease: a 15-week, double-blind, placebo-controlled study. Donepezil Study Group. Arch Intern Med. May. 11. 1998;158(9):1021-31. KQ4E8, KQ5E8. [pmid: 9588436].
850 Rogers SL, Farlow MR, Doody RS, et al. A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Alzheimer's disease. Donepezil Study Group. Neurology. Jan. 1998;50(1):136-45. KQ4E8, KQ5E8. [pmid: 9443470].
851 Rogers SL, Doody RS, Pratt RD, et al. Long-term efficacy and safety of donepezil in the treatment of Alzheimer's disease: final analysis of a US multicentre open-label study. Eur Neuropsychopharmacol. May. 2000;10(3):195-203. KQ4E8, KQ5E8. [pmid: 10793322].
852 Rolland Y, Pillard F, Klapouszczak A, et al. Exercise program for nursing home residents with Alzheimer's disease: a 1-year randomized, controlled trial. J Am Geriatr Soc. Feb. 2007;55(2):158-65. KQ4E3b, KQ5E3b. [pmid: 17302650].
853 Roman GC, Salloway S, Black SE, et al. Randomized, placebo-controlled, clinical trial of donepezil in vascular dementia: differential effects by hippocampal size. Stroke. Jun. 2010;41(6):1213-21. KQ4E4b, KQ5E4b. [pmid: 20395618].
854 Rondanelli M, Opizzi A, Faliva M, et al. Effects of a diet integration with an oily emulsion of DHA-phospholipids containing melatonin and tryptophan in elderly patients suffering from mild cognitive impairment. Nutr Neurosci. Mar. 2012;15(2):46-54. KQ4E3b, KQ5E3b. [pmid: 22334085].
855 Rosenblatt A, Gao J, Mackell J, et al. Efficacy and safety of donepezil in patients with Alzheimer's disease in assisted living facilities. Am J Alzheimers Dis Other Demen. Sep. 2010;25(6):483-9. KQ5E2e. [pmid: 20558849].
856 Rosler M, Anand R, Cicin-Sain A, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease: international randomised controlled trial. [Erratum appears in BMJ 2001 Jun 16;322(7300):1456]. BMJ. Mar. 6. 1999;318(7184):633-8. KQ4E8, KQ5E8. [pmid: 10066203].
857 Roth DL, Mittelman MS, Clay OJ, et al. Changes in social support as mediators of the impact of a psychosocial intervention for spouse caregivers of persons with Alzheimer's disease. Psychol Aging. Dec. 2005;20(4):634-44. KQ4E2b, KQ5E2b. [pmid: 16420138].
858 Rothman ML, Hedrick SC, Bulcroft KA, et al. Effects of VA adult day health care on health outcomes and satisfaction with care. Med Care. Sep. 1993;31(9 Suppl):SS38-SS49. KQ4E6c, KQ5E6c. [pmid: 8361247].
859 Rowland JT, Basic D, Storey JE, et al. The Rowland Universal Dementia Assessment Scale (RUDAS) and the Folstein MMSE in a multicultural cohort of elderly persons. Int Psychogeriatr. Mar. 2006;18(1):111-20. KQ2E3c. [pmid: 16466591].
860 Royall DR, Mahurin RK, Gray KF. Bedside assessment of executive cognitive impairment: the executive interview. J Am Geriatr Soc. Dec. 1992;40(12):1221-6. KQ2E5, KQ3E5. [pmid: 1447438].
861 Royall DR. Re: De Jager, CA, et al. Sensitivity and specificity of neuropsychological tests for mild cognitive impairment, vascular cognitive impairment and Alzheimer's disease. Psychol Med. May. 2004;34(4):761-2. KQ2E2a. [pmid: 15099434].
862 Rozzini L, Vicini CB, Bellelli G, et al. Effects of cholinesterase inhibitors appear greater in patients on established antihypertensive therapy. Int J Geriatr Psychiatry. Jun. 2005;20(6):547-51. KQ4E2a, KQ5E5. [pmid: 15920713].
863 Rozzini L, Costardi D, Chilovi BV, et al. Efficacy of cognitive rehabilitation in patients with mild cognitive impairment treated with cholinesterase inhibitors. Int J Geriatr Psychiatry. Apr. 2007;22(4):356-60. KQ4E7c, KQ5E7c. [pmid: 17117398].
864 Rozzini R, Ferrucci L, Losonczy K, et al. Protective effect of chronic NSAID use on cognitive decline in older persons. J Am Geriatr Soc. Sep. 1996;44(9):1025-9. KQ4E2a, KQ5E5. [pmid: 8790225].
865 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. KQ1E6b. [pmid: 17302651].
866 Rusted J, Sheppard L, Waller D. A multi-centre randomized control group trial on the use of art therapy for older people with dementia. Group Analysis. 2006;39(4):517-36. PMID: None. KQ4E6c, KQ5E6c.
867 Ryu HJ, Kim HJ, Han SH. Validity and reliability of the Korean version of the AD8 informant interview (K-AD8) in dementia. Alzheimer Dis Assoc Disord. Oct. 2009;23(4):371-6. KQ2E2d. [pmid: 19561437].
868 Sabbagh MN, Hake AM, Ahmed S, et al. The use of memantine in dementia with Lewy bodies. J Alzheimers Dis. Aug. 2005;7(4):285-9. KQ4E2a, KQ5E2e. [pmid: 16131729].
869 Sadowsky CH, Farlow MR, Atkinson L, et al. Switching from donepezil to rivastigmine is well tolerated: results of an open-label safety and tolerability study. Prim Care Companion J Clin Psychiatry. 2005;7(2):43-8. KQ5E2e. [pmid: 15841194].
870 Sadowsky CH, Dengiz A, Olin JT, et al. Switching from donepezil tablets to rivastigmine transdermal patch in Alzheimer's disease. Am J Alzheimers Dis Other Demen. Jun. 2009;24(3):267-75. KQ4E2b, KQ5E2e. [pmid: 19293130].
871 Sadowsky CH, Farlow MR, Meng X, et al. Safety and tolerability of rivastigmine transdermal patch compared with rivastigmine capsules in patients switched from donepezil: data from three clinical trials. Int J Clin Pract. Jan. 2010;64(2):188-93. KQ5E2e. [pmid: 20089009].
872 Sakka P, Tsolaki M, Hort J, et al. Effectiveness of open-label donepezil treatment in patients with Alzheimer's disease discontinuing memantine monotherapy. Curr Med Res Opin. Dec. 2007;23(12):3153-65. KQ4E4c, KQ5E4c. [pmid: 17988434].
873 Salloway S, Ferris S, Kluger A, et al. Efficacy of donepezil in mild cognitive impairment: a randomized placebo-controlled trial. Neurology. Aug. 24. 2004;63(4):651-7. KQ4E8, KQ5E8. [pmid: 15326237].
874 Salloway S, Correia S, Richardson S. Key lessons learned from short-term treatment trials of cholinesterase inhibitors for amnestic MCI. Int Psychogeriatr. Feb. 2008;20(1):40-6. KQ4E8, KQ5E8. [pmid: 17597552].
875 Salmon DP, Cummings JL, Jin S, et al. ADCS Prevention Instrument Project: development of a brief verbal memory test for primary prevention clinical trials. Alzheimer Dis Assoc Disord. Oct. 2006;20(4:Suppl 3):S139-S146. KQ4E1, KQ5E1. [pmid: 17135807].
876 Salmon N. Cognitive Stimulation Therapy versus Acetyl Cholinesterase Inhibitors for Mild to Moderate Dementia: A latter-day David and Goliath?. Br J Occup Ther. 2006;69(11):528-30. PMID: None. KQ4E7c, KQ5E7c.
877 Salva A, Andrieu S, Fernandez E, et al. Health and nutrition promotion program for patients with dementia (NutriAlz): cluster randomized trial. J Nutr Health Aging. Dec. 2011;15(10):822-30. KQ4E6b, KQ5E6b. [pmid: 22159768].
878 Samuel W, Caligiuri M, Galasko D, et al. Better cognitive and psychopathologic response to donepezil in patients prospectively diagnosed as dementia with Lewy bodies: a preliminary study. Int J Geriatr Psychiatry. Sep. 2000;15(9):794-802. KQ4E2a, KQ5E5. [pmid: 10984725].
879 Sano M, Wilcock GK, Van BB, et al. The effects of galantamine treatment on caregiver time in Alzheimer's disease. Int J Geriatr Psychiatry. Oct. 2003;18(10):942-50. KQ4E8, KQ5E8. [pmid: 14533127].
880 Santana-Sosa E, Barriopedro MI, Lopez-Mojares LM, et al. Exercise training is beneficial for Alzheimer's patients. Int J Sports Med. Oct. 2008;29(10):845-50. KQ4E3b, KQ5E3b. [pmid: 18401810].
881 Santoro A, Siviero P, Minicuci N, et al. Effects of donepezil, galantamine and rivastigmine in 938 Italian patients with Alzheimer's disease: a prospective, observational study. CNS Drugs. Feb. 1. 2010;24(2):163-76. KQ4E2a, KQ5E2e. [pmid: 20088621].
882 Santos MT, Sougey EB, Alchieri JC. Validity and reliability of the screening test for Alzheimer's disease with proverbs (STADP) for the elderly. Arq Neuropsiquiatr. Sep. 2009;67(3B):836-42. KQ2E3c. [pmid: 19838514].
883 Sarasqueta C, Bergareche A, Arce A, et al. The validity of Hodkinson's Abbreviated Mental Test for dementia screening in Guipuzcoa, Spain. Eur J Neurol. Sep. 2001;8(5):435-40. KQ2E2d. [pmid: 11554906].
884 Saxby BK, Harrington F, Wesnes KA, et al. Candesartan and cognitive decline in older patients with hypertension: a substudy of the SCOPE trial. Neurology. May. 6. 2008;70(19 Pt 2):1858-66. KQ4E1b, KQ5E1b. [pmid: 18458219].
885 Saxton J, Morrow L, Eschman A, et al. Computer assessment of mild cognitive impairment. Postgrad Med. Mar. 2009;121(2):177-85. KQ3E5. [pmid: 19332976].
886 Scanlan J, Borson S. The Mini-Cog: receiver operating characteristics with expert and naive raters. Int J Geriatr Psychiatry. Feb. 2001;16(2):216-22. KQ2E3c. [pmid: 11241728].
887 Scarpini E, Bruno G, Zappala G, et al. Cessation versus continuation of galantamine treatment after 12 months of therapy in patients with Alzheimer's disease: a randomized, double blind, placebo controlled withdrawal trial. J Alzheimers Dis. 2011;26(2):211-20. KQ4E7a, KQ5E2e. [pmid: 21606568].
888 Scharf S, Mander A, Ugoni A, et al. A double-blind, placebo-controlled trial of diclofenac/misoprostol in Alzheimer's disease. Neurology. Jul. 13. 1999;53(1):197-201. KQ4E7c, KQ5E7c. [pmid: 10408559].
889 Scharre DW, Shiovitz T, Zhu Y, et al. One-week dose titration of extended release galantamine in patients with Alzheimer's disease. Alzheimers Dement. Jan. 2008;4(1):30-7. KQ4E2a, KQ5E2e. [pmid: 18631948].
890 Scharre DW, Chang SI, Murden RA, et al. Self-administered Gerocognitive Examination (SAGE): a brief cognitive assessment Instrument for mild cognitive impairment (MCI) and early dementia. Alzheimer Dis Assoc Disord. Jan. 2010;24(1):64-71. KQ3E5. [pmid: 20220323].
891 Scherder EJ, van PJ, Deijen JB, et al. Physical activity and executive functions in the elderly with mild cognitive impairment. Aging Ment Health. May. 2005;9(3):272-80. KQ4E3b, KQ5E3b. [pmid: 16019281].
892 Schmand B, Walstra G, Lindeboom J, et al. Early detection of Alzheimer's disease using the Cambridge Cognitive Examination (CAMCOG). Psychol Med. May. 2000;30(3):619-27. KQ2E2d. [pmid: 10883717].
893 Schmidtke K, Olbrich S. The Clock Reading Test: validation of an instrument for the diagnosis of dementia and disorders of visuo-spatial cognition. Int Psychogeriatr. Apr. 2007;19(2):307-21. KQ2E2d. [pmid: 17147844].
894 Schneider LS, Anand R, Farlow MR. Systematic review of the efficacy of rivastigmine for patients with Alzheimer's disease. Int J Geriatr Psychopharmacol. 1998;1(Suppl 1):S26-S34. PMID: None. KQ4E2a, KQ5E2a.
895 Schneider LS, Insel PS, Weiner MW, et al. Treatment with cholinesterase inhibitors and memantine of patients in the Alzheimer's Disease Neuroimaging Initiative. Arch Neurol. Jan. 2011;68(1):58-66. KQ4E2a, KQ5E2e. [pmid: 21220675].
896 Schneider LS. Could cholinesterase inhibitors be harmful over the long term?. Int Psychogeriatr. Feb. 2012;24(2):171-4. KQ5E2a. [pmid: 22189623].
897 Schnelle JF, MacRae PG, Ouslander JG, et al. Functional Incidental Training, mobility performance, and incontinence care with nursing home residents. J Am Geriatr Soc. Dec. 1995;43(12):1356-62. KQ4E3b, KQ5E3b. [pmid: 7490386].
898 Schnelle JF, MacRae PG, Giacobassi K, et al. Exercise with physically restrained nursing home residents: maximizing benefits of restraint reduction. J Am Geriatr Soc. May. 1996;44(5):507-12. KQ4E3b, KQ5E3b. [pmid: 8617897].
899 Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. Sep. 2002;50(9):1476-83. KQ4E3b, KQ5E3b. [pmid: 12383143].
900 Schoenmakers B, Buntinx F, DeLepeleire J. Supporting family carers of community-dwelling elder with cognitive decline: a randomized controlled trial. Int J Family Med. 2010;2010:184152. KQ5E5. [pmid: 22332005].
901 Schofield I, Stott DJ, Tolson D, et al. Screening for cognitive impairment in older people attending accident and emergency using the 4-item Abbreviated Mental Test. Eur J Emerg Med. Dec. 2010;17(6):340-2. KQ2E7b. [pmid: 20164778].
902 Schrijnemaekers V, van RE, Candel M, et al. Effects of emotion-oriented care on elderly people with cognitive impairment and behavioral problems. Int J Geriatr Psychiatry. Oct. 2002;17(10):926-37. KQ4E4c, KQ5E4c. [pmid: 12325052].
903 Schroecksandel K, Gruber B, Frick B, et al. Long-term supplementation with B vitamins does not change plasma neopterin concentrations in demented patients. Pteridines. 2006;17(4):135-44. PMID: None. KQ4E2a, KQ5E5.
904 Schuff N, Suhy J, Goldman R, et al. An MRI substudy of a donepezil clinical trial in mild cognitive impairment. Neurobiol Aging. Dec. 2011;32(12):2318-41. KQ4E5, KQ5E5. [pmid: 20541841].
905 Schultz-Larsen K, Kreiner S, Lomholt RK. Mini-Mental Status Examination: mixed Rasch model item analysis derived two different cognitive dimensions of the MMSE. J Clin Epidemiol. Mar. 2007;60(3):268-79. KQ2E7c. [pmid: 17292021].
906 Schultz-Larsen K, Lomholt RK, Kreiner S. Mini-Mental Status Examination: a short form of MMSE was as accurate as the original MMSE in predicting dementia. J Clin Epidemiol. Mar. 2007;60(3):260-7. KQ2E7c. [pmid: 17292020].
907 Schwenk M, Zieschang T, Oster P, et al. Dual-task performances can be improved in patients with dementia: a randomized controlled trial. Neurology. Jun. 15. 2010;74(24):1961-8. KQ5E5. [pmid: 20445152].
908 Seal EC, Metz J, Flicker L, et al. A randomized, double-blind, placebo-controlled study of oral vitamin B12 supplementation in older patients with subnormal or borderline serum vitamin B12 concentrations. J Am Geriatr Soc. Jan. 2002;50(1):146-51. KQ4E1, KQ5E1. [pmid: 12028259].
909 Sebaldt R, Dalziel W, Massoud F, et al. Detection of cognitive impairment and dementia using the animal fluency test: the DECIDE study. Can J Neurol Sci. Sep. 2009;36(5):599-604. KQ2E7b. [pmid: 19831129].
910 Segers K, Cytryn E, Surquin M. Do local meteorological conditions influence skin irritation caused by transdermal rivastigmine? A retroprospective, pilot study. J Clin Psychopharmacol. Jun. 2012;32(3):412-5. KQ5E2e. [pmid: 22544007].
911 Seltzer B, Zolnouni P, Nunez M, et al. Efficacy of donepezil in early-stage Alzheimer disease: a randomized placebo-controlled trial. Arch Neurol. Dec. 2004;61(12):1852-6. KQ4E8, KQ5E8. [pmid: 15596605].
912 Senanarong V, Poungvarin N, Phanthumchinda K, et al. Safety and tolerability of galantamine in possible Alzheimer's disease with or without cerebrovascular disease and vascular dementia in Thai patients. J Med Assoc Thai. Mar. 2009;92:Suppl-8. KQ4E3a, KQ5E3a. [pmid: 19562980].
913 Sever P. The SCOPE trial. Study on Cognition and Prognosis in the Elderly. J Renin Angiotensin Aldosterone Syst. Jun. 2002;3(2):61-2. KQ4E2a, KQ5E2a. [pmid: 12228843].
914 Shaw DM, Macsweeney DA, Johnson AL, et al. Folate and amine metabolites in senile dementia: a combined trial and biochemical study. Psychol Med. Feb. 1971;1(2):166-71. KQ4E3c, KQ5E3c. [pmid: 5148767].
915 Shelton P, Schraeder C, Dworak D, et al. Caregivers' utilization of health services: results from the Medicare Alzheimer's Disease Demonstration, Illinois site. J Am Geriatr Soc. Dec. 2001;49(12):1600-5. KQ4E7a, KQ5E7a. [pmid: 11843991].
916 Sherwin BB, Chertkow H, Schipper H, et al. A randomized controlled trial of estrogen treatment in men with mild cognitive impairment. Neurobiol Aging. Oct. 2011;32(10):1808-17. KQ4E7c, KQ5E7c. [pmid: 20004499].
917 Shikiar R, Shakespeare A, Sagnier PP, et al. The impact of metrifonate therapy on caregivers of patients with Alzheimer's disease: results from the MALT clinical trial. Metrifonate in Alzheimer's Disease Trial. J Am Geriatr Soc. Mar. 2000;48(3):268-74. KQ4E6b, KQ5E6b. [pmid: 10733052].
918 Shlyakhto E. Observational Study on Cognitive function And systolic blood pressure Reduction (OSCAR): preliminary analysis of 6-month data from > 10,000 patients and review of the literature. Curr Med Res Opin. Nov. 2007;23(Suppl 5):S13-S18. KQ4E1b, KQ5E1b. [pmid: 18093409].
919 Shua-Haim JR, Shua-Haim V, Comsti E, et al. Donepezil (Aricept-®) treatment of multi infarct dementia: The caregivers and clinical impression. Am J Alzheimers Dis Other Demen. 2000;15(4):201-11. PMID: None. KQ4E2a, KQ5E2e.
920 Shumaker SA, Legault C, Kuller L, et al. Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women's Health Initiative Memory Study. JAMA. Jun. 23. 2004;291(24):2947-58. KQ4E1b, KQ5E1b. [pmid: 15213206].
921 Signe A, Elmstahl S. Psychosocial intervention for family caregivers of people with dementia reduces caregiver's burden: development and effect after 6 and 12 months. Scand J Caring Sci. Mar. 2008;22(1):98-109. KQ4E7a, KQ5E7a. [pmid: 18269429].
922 Simmons SF, Schnelle JF. Effects of an exercise and scheduled-toileting intervention on appetite and constipation in nursing home residents. J Nutr Health Aging. 2004;8(2):116-21. KQ4E3b, KQ5E3b. [pmid: 14978607].
923 Simpson R, Wakefield P, Spiers N, et al. Carer-held records for dementia: a controlled trial. Int Psychogeriatr. Jun. 2006;18(2):259-68. KQ4E2a, KQ5E2a. [pmid: 16734920].
924 Sink KM, Leng X, Williamson J, et al. Angiotensin-converting enzyme inhibitors and cognitive decline in older adults with hypertension: results from the Cardiovascular Health Study. Arch Intern Med. Jul. 13. 2009;169(13):1195-202. KQ4E1b, KQ5E1b. [pmid: 19597068].
925 Small GW, Siddarth P, Silverman DH, et al. Cognitive and cerebral metabolic effects of celecoxib versus placebo in people with age-related memory loss: randomized controlled study. Am J Geriatr Psychiatry. Dec. 2008;16(12):999-1009. KQ4E1b, KQ5E1b. [pmid: 19038899].
926 Small G, Erkinjuntti T, Kurz A, et al. Galantamine in the Treatment of Cognitive Decline in Patients with Vascular Dementia or Alzheimer's Disease with Cerebrovascular Disease. CNS Drugs. 2003;17(12):905-14. KQ4E8, KQ5E8. [pmid: 12962529].
927 Smith A, Clarke R, Nutt D, et al. Anti-oxidant vitamins and mental performance f the elderly. Hum Psychopharmacol. 1999;14(7):459-71. PMID: None. KQ4E1b, KQ5E1b.
928 Smith K, Flicker L, Dwyer A, et al. Assessing cognitive impairment in indigenous Australians: Re-evaluation of the Kimberley Indigenous Cognitive Assessment in Western Australia and the Northern Territory. Aust Psychol. 2009;44(1). PMID: None. KQ2E7c.
929 Smith PJ, Blumenthal JA, Babyak MA, et al. Effects of the dietary approaches to stop hypertension diet, exercise, and caloric restriction on neurocognition in overweight adults with high blood pressure. Hypertension. Jun. 2010;55(6):1331-8. KQ4E1b, KQ5E1b. [pmid: 20305128].
930 Smith T, Gildeh N, Holmes C. The Montreal Cognitive Assessment: validity and utility in a memory clinic setting. Can J Psychiatry. May. 2007;52(5):329-32. KQ2E3c. [pmid: 17542384].
931 Sobel BP. Bingo vs. physical intervention in stimulating short-term cognition in Alzheimer's disease patients. Am J Alzheimers Dis Other Demen. Mar. 2001;16(2):115-20. KQ4E2b, KQ5E2b. [pmid: 11302072].
932 Solomon PR, Brush M, Calvo V, et al. Identifying dementia in the primary care practice. Int Psychogeriatr. Dec. 2000;12(4):483-93. KQ3E5. [pmid: 11263715].
933 Sommer BR, Hoff AL, Costa M. Folic acid supplementation in dementia: a preliminary report. J Geriatr Psychiatry Neurol. Sep. 2003;16(3):156-9. KQ4E2c, KQ5E5. [pmid: 12967058].
934 Sotaniemi M, Pulliainen V, Hokkanen L, et al. CERAD-neuropsychological battery in screening mild Alzheimer's disease. Acta Neurol Scand. Jan. 2012;125(1):16-23. KQ2E2d. [pmid: 21198445].
935 Sparks DL, Sabbagh MN, Connor DJ, et al. Atorvastatin for the treatment of mild to moderate Alzheimer disease: preliminary results. Arch Neurol. May. 2005;62(5):753-7. KQ5E5. [pmid: 15883262].
936 Sparks DL, Petanceska S, Sabbagh M, et al. Cholesterol, copper and Abeta in controls, MCI, AD and the AD cholesterol-lowering treatment trial (ADCLT). Curr Alzheimer Res. Dec. 2005;2(5):527-39. KQ4E1, KQ5E1. [pmid: 16375656].
937 Sparks DL, Sabbagh M, Connor D, et al. Statin therapy in Alzheimer's disease. Acta Neurol Scand. 2006;114(Suppl 185):78-86. KQ5E5. [pmid: 16866915].
938 Sparks DL, Connor DJ, Sabbagh MN, et al. Circulating cholesterol levels, apolipoprotein E genotype and dementia severity influence the benefit of atorvastatin treatment in Alzheimer's disease: results of the Alzheimer's Disease Cholesterol-Lowering Treatment (ADCLT) trial. Acta Neurol Scand. 2006;114(Suppl 185):3-7. KQ5E5. [pmid: 16866904].
939 Sparks DL, Kryscio RJ, Connor DJ, et al. Cholesterol and cognitive performance in normal controls and the influence of elective statin use after conversion to mild cognitive impairment: results in a clinical trial cohort. Neurodegener Dis. 2010;7(1-3):183-6. KQ4E1b. [pmid: 20224282].
940 Spector A, Thorgrimsen L, Woods B, et al. Efficacy of an evidence-based cognitive stimulation therapy programme for people with dementia: randomised controlled trial. Br J Psychiatry. Sep. 2003;183:248-54. KQ4E2c, KQ5E2c. [pmid: 12948999].
941 Spector A, Orrell M, Woods B. Cognitive Stimulation Therapy (CST): effects on different areas of cognitive function for people with dementia. Int J Geriatr Psychiatry. Dec. 2010;25(12):1253-8. KQ4E2c, KQ5E2c. [pmid: 20069533].
942 Spering CC, Hobson V, Lucas JA, et al. Diagnostic accuracy of the MMSE in detecting probable and possible Alzheimer's disease in ethnically diverse highly educated individuals: an analysis of the NACC database. J Gerontol A Biol Sci Med Sci. Aug. 2012;67(8):890-6. KQ2E3c. [pmid: 22396476].
943 Spijker A, Verhey F, Graff M, et al. Systematic care for caregivers of people with dementia in the ambulatory mental health service: designing a multicentre, cluster, randomized, controlled trial. BMC Geriatr. 2009;9:21. KQ4E5, KQ5E5. [pmid: 19500421].
944 Spijker A, Wollersheim H, Teerenstra S, et al. Systematic care for caregivers of patients with dementia: a multicenter, cluster-randomized, controlled trial. Am J Geriatr Psychiatry. 2011. Feb. 24. KQ5E5. [pmid: 21358385].
945 Spitznagel MB, Tremont G, Davis JD, et al. Psychosocial predictors of dementia caregiver desire to institutionalize: caregiver, care recipient, and family relationship factors. J Geriatr Psychiatry Neurol. Mar. 2006;19(1):16-20. KQ4E1, KQ5E1. [pmid: 16449755].
946 St.John P, Montgomery P. Is subjective memory loss correlated with MMSE scores or dementia?. J Geriatr Psychiatry Neurol. Jun. 2003;16(2):80-3. KQ2E6b. [pmid: 12801156].
947 Stahl SM, Markowitz JS, Gutterman EM, et al. Co-use of donepezil and hypnotics among Alzheimer's disease patients living in the community. J Clin Psychiatry. Apr. 2003;64(4):466-72. KQ4E1, KQ5E1. [pmid: 12716251].
948 Stamford BA, Hambacher W, Fallica A. Effects of daily physical exercise on the psychiatric state of institutionalized geriatric mental patients. Res Q. Mar. 1974;45(1):34-41. KQ4E3c, KQ5E3c. [pmid: 4522210].
949 Standish TI, Molloy DW, Cunje A, et al. Do the ABCS 135 short cognitive screen and its subtests discriminate between normal cognition, mild cognitive impairment and dementia?. Int J Geriatr Psychiatry. Mar. 2007;22(3):189-94. KQ2E2d. [pmid: 16977680].
950 Stanley MA, Calleo J, Bush AL, et al. The Peaceful Mind Program: A Pilot Test of a Cognitive-Behavioral Therapy-Based Intervention for Anxious Patients With Dementia. Am J Geriatr Psychiatry. 2012. Apr. 30. KQ4E6b, KQ5E6b.
951 Steadman PL, Tremont G, Davis JD. Premorbid relationship satisfaction and caregiver burden in dementia caregivers. J Geriatr Psychiatry Neurol. Jun. 2007;20(2):115-9. KQ4E1, KQ5E1. [pmid: 17548782].
952 Steffen AM, McKibbin C, Zeiss AM, et al. The revised scale for caregiving self-efficacy: reliability and validity studies. J Gerontol B Psychol Sci Soc Sci. Jan. 2002;57(1):74-86. KQ4E1, KQ5E1. [pmid: 11773226].
953 Stella F, Canonici AP, Gobbi S, et al. Attenuation of neuropsychiatric symptoms and caregiver burden in Alzheimer's disease by motor intervention: a controlled trial. Clinics (Sao Paulo, Brazil). 2011;66(8):1353-60. KQ4E3a, KQ5E3a. [pmid: 21915483].
954 Stevens J, Killeen M. A randomised controlled trial testing the impact of exercise on cognitive symptoms and disability of residents with dementia. Contemp Nurse. Feb. 2006;21(1):32-40. KQ4E7c, KQ5E7c. [pmid: 16594879].
955 Stolley JM, Reed D, Buckwalter KC. Caregiving appraisal and interventions based on the progressively lowered stress threshold model. Am J Alzheimers Dis Other Demen. Mar. 2002;17(2):110-20. KQ4E2b, KQ5E2b. [pmid: 11954669].
956 Storey JE, Rowland JT, Basic D, et al. A comparison of five clock scoring methods using ROC (receiver operating characteristic) curve analysis. Int J Geriatr Psychiatry. Apr. 2001;16(4):394-9. KQ2E3c. [pmid: 11333427].
957 Storey JE, Rowland JT, Basic D, et al. The Rowland Universal Dementia Assessment Scale (RUDAS): a multicultural cognitive assessment scale. Int Psychogeriatr. Mar. 2004;16(1):13-31. KQ2E3c. [pmid: 15190994].
958 Stott DJ, MacIntosh G, Lowe GD, et al. Randomized controlled trial of homocysteine-lowering vitamin treatment in elderly patients with vascular disease. Am J Clin Nutr. Dec. 2005;82(6):1320-6. KQ4E1b, KQ5E1b. [pmid: 16332666].
959 Sturmer T, Glynn RJ, Field TS, et al. Aspirin use and cognitive function in the elderly. Am J Epidemiol. Apr. 1. 1996;143(7):683-91. KQ4E2a, KQ5E1b. [pmid: 8651230].
960 Suh GH, Yeon JH, Uk LC, et al. A prospective, double-blind, community-controlled comparison of three doses of galantamine in the treatment of mild to moderate Alzheimer's disease in a Korean population. Clin Ther. Oct. 2004;26(10):1608-18. KQ4E2a, KQ5E2e. [pmid: 15598477].
961 Suh GH, Jung HY, Lee CU, et al. Effect of the apolipoprotein E epsilon4 allele on the efficacy and tolerability of galantamine in the treatment of Alzheimer's disease. Dement Geriatr Cogn Disord. 2006;21(1):33-9. KQ4E2b, KQ5E2e. [pmid: 16254428].
962 Suh GH, Jung HY, Lee CU, et al. Economic and clinical benefits of galantamine in the treatment of mild to moderate Alzheimer's disease in a Korean population: a 52-week prospective study. J Korean Med Sci. Feb. 2008;23(1):10-7. KQ4E2a, KQ5E2e. [pmid: 18303192].
963 Sun Y, Lai MS, Lu CJ, et al. How long can patients with mild or moderate Alzheimer's dementia maintain both the cognition and the therapy of cholinesterase inhibitors: a national population-based study. Eur J Neurol. Mar. 2008;15(3):278-83. KQ4E2a, KQ5E5. [pmid: 18290848].
964 Suzuki T, Shimada H, Makizako H, et al. Effects of multicomponent exercise on cognitive function in WMS-LM older adults with amnestic mild cognitive impairment: a randomized controlled trial. BMC Neurol. Oct. 31. 2012;12(1):128. KQ5E5. [pmid: 23113898].
965 Swearer JM, Drachman DA, Li L, et al. Screening for dementia in “real world” settings: the cognitive assessment screening test: CAST. Clin Neuropsychol. May. 2002;16(2):128-35. KQ3E5. [pmid: 12221476].
966 Szekely CA, Breitner JC, Fitzpatrick AL, et al. NSAID use and dementia risk in the Cardiovascular Health Study: role of APOE and NSAID type. Neurology. Jan. 1. 2008;70(1):17-24. KQ4E2a, KQ5E5. [pmid: 18003940].
967 Tadaka E, Kanagawa K. Randomized controlled trial of a group care program for community-dwelling elderly people with dementia. Jpn J Nurs Sci. 2004;1(1):19-25. PMID: None. KQ4E6c, KQ5E6c.
968 Tadaka E, Kanagawa K. Effects of reminiscence group in elderly people with Alzheimer disease and vascular dementia in a community setting. Geriatr Gerontol Int. 2007;7(2):167-73. PMID: None. KQ4E6c, KQ5E6c.
969 Takahashi F, Awata S, Sakuma N, et al. Reliability and validity of A Quick Test of Cognitive Speed for detecting early-stage dementia in elderly Japanese. Psychogeriatrics. Jun. 2012;12(2):75-82. KQ2E2d. [pmid: 22712639].
970 Takaya M, Matsusaka K, Yanagida M, et al. The effects of memantine on a patient having preclinical dementia with Lewy bodies. Gen Hosp Psychiatry. 2012. Jul. 25. KQ4E2a, KQ5E2a. [pmid: 22840564].
971 Tanaka M, Namiki C, Thuy DH, et al. Prediction of psychiatric response to donepezil in patients with mild to moderate Alzheimer's disease. J Neurol Sci. Oct. 15. 2004;225(1-2):135-41. KQ4E2a, KQ5E2e. [pmid: 15465097].
972 Tang-Wai DF, Knopman DS, Geda YE, et al. Comparison of the short test of mental status and the mini-mental state examination in mild cognitive impairment. Arch Neurol. Dec. 2003;60(12):1777-81. KQ2E2d. [pmid: 14676056].
973 Tangalos EG, Smith GE, Ivnik RJ, et al. The Mini-Mental State Examination in general medical practice: clinical utility and acceptance. Mayo Clin Proc. Sep. 1996;71(9):829-37. KQ2E2d. [pmid: 8790257].
974 Tappen RM, Roach KE, Touhy TA. Effect of a comprehensive exercise program on function in nursing home residents with Alzheimer's disease. Proceedings of the World Alzheimer Congress. 2000 Jul 9-13. Washington, DC. 2000. PMID: None. KQ4E3b, KQ5E3b.
975 Tappen RM, Roach KE, Applegate EB, et al. Effect of a combined walking and conversation intervention on functional mobility of nursing home residents with Alzheimer disease. Alzheimer Dis Assoc Disord. Oct. 2000;14(4):196-201. KQ4E3b, KQ5E3b. [pmid: 11186596].
976 Tariot PN, Solomon PR, Morris JC, et al. A 5-month, randomized, placebo-controlled trial of galantamine in AD. The Galantamine USA-10 Study Group. Neurology. Jun. 27. 2000;54(12):2269-76. KQ4E8, KQ5E8. [pmid: 10881251].
977 Tariq SH, Tumosa N, Chibnall JT, et al. Comparison of the Saint Louis University mental status examination and the mini-mental state examination for detecting dementia and mild neurocognitive disorder--a pilot study. Am J Geriatr Psychiatry. Nov. 2006;14(11):900-10. KQ3E5. [pmid: 17068312].
978 Tarraga L, Boada M, Modinos G, et al. A randomised pilot study to assess the efficacy of an interactive, multimedia tool of cognitive stimulation in Alzheimer's disease. J Neurol Neurosurg Psychiatry. Oct. 2006;77(10):1116-21. KQ4E2b, KQ5E2b. [pmid: 16820420].
979 Terano T, Fujishiro S, Ban T, et al. Docosahexaenoic acid supplementation improves the moderately severe dementia from thrombotic cerebrovascular diseases. Lipids. 1999;34(Suppl):S345-S346. KQ4E4c, KQ5E4c. [pmid: 10419198].
980 Teri L, Gibbons LE, McCurry SM, et al. Exercise plus behavioral management in patients with Alzheimer disease: a randomized controlled trial. JAMA. Oct. 15. 2003;290(15):2015-22. KQ5E5. [pmid: 14559955].
981 Teri L, McCurry SM, Logsdon R, et al. Training community consultants to help family members improve dementia care: a randomized controlled trial. Gerontologist. Dec. 2005;45(6):802-11. KQ5E5. [pmid: 16326662].
982 Tesky VA, Thiel C, Banzer W, et al. Effects of a group program to increase cognitive performance through cognitively stimulating leisure activities in healthy older subjects: The AKTIVA study. GeroPsych. 2011;24(2):83-92. PMID: None. KQ4E1b, KQ5E1b.
983 Teunisse S, Bollen AE, Van Gool WA, et al. Dementia and subnormal levels of vitamin B12: effects of replacement therapy on dementia. J Neurol. Jul. 1996;243(7):522-9. KQ4E2a, KQ5E5. [pmid: 8836942].
984 Thal LJ, Forrest M, Loft H, et al. Lu 25-109, a muscarinic agonist, fails to improve cognition in Alzheimer's disease. Neurology. 2000;54(2):421-6. KQ4E6b, KQ5E6b. [pmid: 10668706].
985 Thal LJ, Thomas RG, Mulnard R, et al. Estrogen levels do not correlate with improvement in cognition. Arch Neurol. Feb. 2003;60(2):209-12. KQ4E2a, KQ5E5. [pmid: 12580705].
986 Thal LJ, Ferris SH, Kirby L, et al. A randomized, double-blind, study of rofecoxib in patients with mild cognitive impairment. Neuropsychopharmacol. Jun. 2005;30(6):1204-15. KQ4E6c, KQ5E6c. [pmid: 15742005].
987 Thompson TA, Wilson PH, Snyder PJ, et al. Sensitivity and test-retest reliability of the international shopping list test in assessing verbal learning and memory in mild Alzheimer's disease. Arch Clin Neuropsychol. Aug. 2011;26(5):412-24. KQ2E2d. [pmid: 21613302].
988 Tinklenberg JR, Kraemer HC, Yaffe K, et al. Donepezil treatment and Alzheimer disease: can the results of randomized clinical trials be applied to Alzheimer disease patients in clinical practice?. Am J Geriatr Psychiatry. Nov. 2007;15(11):953-60. KQ4E2a, KQ5E5. [pmid: 17974866].
989 Tobiansky R, Blizard R, Livingston G, et al. The Gospel Oak Study stage IV: the clinical relevance of subjective memory impairment in older people. Psychol Med. Jul. 1995;25(4):779-86. KQ2E7c. [pmid: 7480455].
990 Tokuhara KG, Valcour VG, Masaki KH, et al. Utility of the Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) for dementia in a Japanese-American population. Hawaii Med J. Mar. 2006;65(3):72-5. KQ3E5. [pmid: 16724448].
991 Tomaszewski FS, Mungas D, Harvey DJ, et al. The measurement of everyday cognition: development and validation of a short form of the Everyday Cognition scales. Alzheimers Dement. Nov. 2011;7(6):593-601. KQ2E3c. [pmid: 22055976].
992 Tomita N, Ootsuki M, Maruyama M, et al. Long-term cognitive benefits of donepezil in Alzheimer's disease: A retrospective comparison between 1994-1999 and 2000-2004. Geriatr Gerontol Int. 2007;7(1):41-7. PMID: None. KQ4E2a, KQ5E5.
993 Tornatore JB, Hill E, Laboff JA, et al. Self-Administered Screening for Mild Cognitive Impairment: Initial Validation of a Computerized Test Battery. J Neuropsychiatry Clin Neurosci. 2005;17(1):98-105. KQ2E6a, KQ3E6a. [pmid: 15746489].
994 Touchon J, Bergman H, Bullock R, et al. Response to rivastigmine or donepezil in Alzheimer's patients with symptoms suggestive of concomitant Lewy body pathology. Curr Med Res Opin. Jan. 2006;22(1):49-59. KQ4E2b, KQ5E2e. [pmid: 16393430].
995 Tremont G, Davis JD, Bishop DS. Unique contribution of family functioning in caregivers of patients with mild to moderate dementia. Dement Geriatr Cogn Disord. 2006;21(3):170-4. KQ4E1, KQ5E1. [pmid: 16397397].
996 Tremont G, Papandonatos GD, Springate B, et al. Use of the telephone-administered Minnesota Cognitive Acuity Screen to detect mild cognitive impairment. Am J Alzheimers Dis Other Demen. Nov. 2011;26(7):555-62. KQ2E2d. [pmid: 22127023].
997 Tremont G, Davis JD, Bishop DS, et al. Telephone-delivered psychosocial intervention reduces burden in dementia caregivers. Dementia. 2008;7(4):503-20. KQ4E7a, KQ5E7a. [pmid: 20228893].
998 Trenkle DL, Shankle WR, Azen SP. Detecting cognitive impairment in primary care: performance assessment of three screening instruments. J Alzheimers Dis. Jun. 2007;11(3):323-35. KQ2E7c. [pmid: 17851183].
999 Trompet S, van VP, de Craen AJ, et al. Pravastatin and cognitive function in the elderly. Results of the PROSPER study. J Neurol. Jan. 2010;257(1):85-90. KQ4E1b, KQ5E1b. [pmid: 19653027].
1000 Troyer AK, Murphy KJ, Anderson ND, et al. Changing everyday memory behaviour in amnestic mild cognitive impairment: a randomised controlled trial. Neuropsychol Rehabil. Jan. 2008;18(1):65-88. KQ5E5. [pmid: 17943615].
1001 Tsai AY, Yang MJ, Lan CF, et al. Evaluation of effect of cognitive intervention programs for the community-dwelling elderly with subjective memory complaints. Int J Geriatr Psychiatry. Nov. 2008;23(11):1172-4. KQ4E2b, KQ5E2b. [pmid: 18496884].
1002 Tsai CF, Lee WJ, Wang SJ, et al. Psychometrics of the Montreal Cognitive Assessment (MoCA) and its subscales: Validation of the Taiwanese version of the MoCA and an item response theory analysis. Int Psychogeriatr. 2012;24(4):651-8. KQ2E3c. [pmid: 22152127].
1003 Tsai PF, Chang JY, Beck C, et al. A Pilot Cluster-Randomized Trial of a 20-Week Tai Chi Program in Elders With Cognitive Impairment and Osteoarthritic Knee: Effects on Pain and Other Health Outcomes. J Pain Symptom Manage. 2012. Sep. 24. KQ5E5. [pmid: 23017610].
1004 Tsang RS, Diamond K, Mowszowski L, et al. Using informant reports to detect cognitive decline in mild cognitive impairment. Int Psychogeriatr. Jun. 2012;24(6):967-73. KQ2E3c. [pmid: 22300542].
1005 Tsolaki M, Kounti F, Agogiatou C, et al. Effectiveness of nonpharmacological approaches in patients with mild cognitive impairment. Neurodegener Dis. 2011;8(3):138-45. KQ5E5. [pmid: 21135531].
1006 Tucker KL, Olson B, Bakun P, et al. Breakfast cereal fortified with folic acid, vitamin B-6, and vitamin B-12 increases vitamin concentrations and reduces homocysteine concentrations: a randomized trial. Am J Clin Nutr. May. 2004;79(5):805-11. KQ4E1b, KQ5E1b. [pmid: 15113718].
1007 Uemura K, Doi T, Shimada H, et al. Effects of exercise intervention on vascular risk factors in older adults with mild cognitive impairment: a randomized controlled trial. Dement Geriatr Cogn Dis Extra. Jan. 2012;2(1):445-55. KQ4E5, KQ5E5. [pmid: 23189083].
1008 Ukawa S, Satoh H, Yuasa M, et al. A randomized controlled trial of a Functioning Improvement Tool home-visit program and its effect on cognitive function in older persons. Int J Geriatr Psychiatry. Jun. 2012;27(6):557-64. KQ4E1b, KQ5E1b. [pmid: 21728184].
1009 Ulstein ID, Sandvik L, Wyller TB, et al. A one-year randomized controlled psychosocial intervention study among family carers of dementia patients--effects on patients and carers. Dement Geriatr Cogn Disord. 2007;24(6):469-75. KQ5E5. [pmid: 17986818].
1010 Umegaki H, Itoh A, Suzuki Y, et al. Discontinuation of donepezil for the treatment of Alzheimer's disease in geriatric practice. Int Psychogeriatr. Aug. 2008;20(4):800-6. KQ4E2a, KQ5E2e. [pmid: 18341753].
1011 Unverzagt FW, Smith DM, Rebok GW, et al. The Indiana Alzheimer Disease Center's Symposium on Mild Cognitive Impairment. Cognitive training in older adults: lessons from the ACTIVE Study. Curr Alzheimer Res. Aug. 2009;6(4):375-83. KQ4E1b, KQ5E1b. [pmid: 19689237].
1012 van Asselt DZ, Pasman JW, van Lier HJ, et al. Cobalamin supplementation improves cognitive and cerebral function in older, cobalamin-deficient persons. J Gerontol A Biol Sci Med Sci. Dec. 2001;56(12):M775-M779. KQ4E1b, KQ5E1b. [pmid: 11723153].
1013 van Beek AH, Sijbesma JC, Olde Rikkert MG, et al. Galantamine does not cause aggravated orthostatic hypotension in people with Alzheimer's disease. J Am Geriatr Soc. Feb. 2010;58(2):409-10. KQ5E2e. [pmid: 20370881].
1014 van de Rest O, Geleijnse JM, Kok FJ, et al. Effect of fish oil on cognitive performance in older subjects: a randomized, controlled trial. Neurology. Aug. 5. 2008;71(6):430-8. KQ4E1b, KQ5E1b. [pmid: 18678826].
1015 Van de Winckel A, Feys H, De WW, et al. Cognitive and behavioural effects of music-based exercises in patients with dementia. Clin Rehabil. May. 2004;18(3):253-60. KQ4E3b, KQ5E3b. [pmid: 15137556].
1016 van den Broek MD, Bradshaw CM, Szabadi E. Utility of the Modified Wisconsin Card Sorting Test in neuropsychological assessment. Br J Clin Psychol. Sep. 1993;32(Pt 3):333-43. KQ2E1. [pmid: 8251964].
1017 van Der Putt R, Dineen C, Janes D, et al. Effectiveness of acetylcholinesterase inhibitors: diagnosis and severity as predictors of response in routine practice. Int J Geriatr Psychiatry. Aug. 2006;21(8):755-60. KQ4E2a. [pmid: 16906631].
1018 van Dijk KR, Scheltens P, Luijpen MW, et al. Peripheral electrical stimulation in Alzheimer's disease. Dement Geriatr Cogn Disord. 2005;19(5-6):361-8. KQ4E6c, KQ5E6c. [pmid: 15802911].
1019 van Dyck CH, Newhouse P, Falk WE, et al. Extended-release physostigmine in Alzheimer disease: a multicenter, double-blind, 12-week study with dose enrichment. Physostigmine Study Group. Arch Gen Psychiatry. Feb. 2000;57(2):157-64. KQ4E6c, KQ5E6c. [pmid: 10665618].
1020 Van Puyvelde K, Mets T, RODOS Study Group. Galantamine (Reminyl) once daily outcome and satisfaction survey (RODOS) in mild to moderate Alzheimer's disease: a study in a real life population. Geriatr Gerontol Int. Jul. 2011;11(3):256-61. KQ4E2a, KQ5E2e. [pmid: 21199235].
1021 van Uffelen JG, Chinapaw MJ, Hopman-Rock M, et al. Feasibility and effectiveness of a walking program for community-dwelling older adults with mild cognitive impairment. J Aging Phys Act. Oct. 2009;17(4):398-415. KQ4E5, KQ5E5. [pmid: 19940321].
1022 Vanacore N, De CA, Sepe-Monti M, et al. Validity of the Italian telephone version of the mini-mental state examination in the elderly healthy population. Acta Neurol Belg. Sep. 2006;106(3):132-6. KQ2E1, KQ3E1. [pmid: 17091616].
1023 Varela S, Ayan C, Cancela JM, et al. Effects of two different intensities of aerobic exercise on elderly people with mild cognitive impairment: a randomized pilot study. Clin Rehabil. May. 2012;26(5):442-50. KQ4E7c, KQ5E7c. [pmid: 22116953].
1024 Vellas B, Cunha L, Gertz HJ, et al. Early onset effects of galantamine treatment on attention in patients with Alzheimer's disease. Curr Med Res Opin. Sep. 2005;21(9):1423-9. KQ4E2a, KQ5E2e. [pmid: 16197661].
1025 Vercambre MN, Cuvelier H, Gayon YA, et al. Validation study of a French version of the modified telephone interview for cognitive status (F-TICS-m) in elderly women. Int J Geriatr Psychiatry. Nov. 2010;25(11):1142-9. KQ3E5. [pmid: 20054838].
1026 Vercambre MN, Grodstein F, Kang JH. Dietary fat intake in relation to cognitive change in high-risk women with cardiovascular disease or vascular factors. Eur J Clin Nutr. Oct. 2010;64(10):1134-40. KQ4E1b, KQ5E1b. [pmid: 20648044].
1027 Vermeulen EG, Stehouwer CD, Valk J, et al. Effect of homocysteine-lowering treatment with folic acid plus vitamin B on cerebrovascular atherosclerosis and white matter abnormalities as determined by MRA and MRI: a placebo-controlled, randomized trial. Eur J Clin Invest. Apr. 2004;34(4):256-61. KQ4E1b, KQ5E1b. [pmid: 15086356].
1028 Vickers MR, Martin J, Meade TW, et al. The Women's International Study of Long-duration Oestrogen after Menopause (WISDOM): A randomised controlled trial. BMC Womens Health. 2007;7:2. PMID: None. KQ4E5, KQ5E5. [pmid: 17324282].
1029 Vickrey BG, Mittman BS, Connor KI, et al. The effect of a disease management intervention on quality and outcomes of dementia care: a randomized, controlled trial. Ann Int Med. Nov. 21. 2006;145(10):713-26. KQ5E5. [pmid: 17116916].
1030 Vidal JS, Lacombe JM, Dartigues JF, et al. Evaluation of the impact of memantine treatment initiation on psychotropics use: a study from the French national health care database. Neuroepidemiology. 2008;31(3):193-200. KQ4E2a. [pmid: 18815451].
1031 Viola LF, Nunes PV, Yassuda MS, et al. Effects of a multidisciplinary cognitive rehabilitation program for patients with mild Alzheimer's disease. Clinics (Sao Paulo, Brazil). 2011;66(8):1395-400. KQ4E3a, KQ5E3a. [pmid: 21915490].
1032 Visch Brink EG, Van Rhee TW, Rietveld T, et al. Improvement of spontaneous speech in early stage Alzheimer's with rivastigmine. J Nutr Health Aging. Jan. 2009;13(1):34-8. KQ4E2a, KQ5E5. [pmid: 19151906].
1033 Voigt-Radloff S, Graff M, Leonhart R, et al. WHEDA study: effectiveness of occupational therapy at home for older people with dementia and their caregivers--the design of a pragmatic randomised controlled trial evaluating a Dutch programme in seven German centres. BMC Geriatr. 2009;9:44. KQ5E5. [pmid: 19799779].
1034 Voigt-Radloff S, Graff M, Leonhart R, et al. Why did an effective Dutch complex psycho-social intervention for people with dementia not work in the German healthcare context? Lessons learnt from a process evaluation alongside a multicentre RCT. BMJ Open. Jan. 1. 2011;1(1):e000094. KQ4E5, KQ5E5. [pmid: 22021759].
1035 Voigt-Radloff S, Graff M, Leonhart R, et al. A multicentre RCT on community occupational therapy in Alzheimer's disease: 10 sessions are not better than one consultation. BMJ Open. Jan. 1. 2011;1(1):e000096. KQ5E5. [pmid: 22021760].
1036 Voigt-Radloff S, Leonhart R, Rikkert MO, et al. Study protocol of the multi-site randomised controlled REDALI-DEM trial--the effects of structured Relearning methods on Daily Living task performance of persons with Dementia. BMC Geriatr. 2011;11:44. KQ4E2b, KQ5E2b. [pmid: 21851594].
1037 Volandes AE, Paasche-Orlow MK, Barry MJ, et al. Video decision support tool for advance care planning in dementia: Randomised controlled trial. BMJ. 2009;338(7707):1-11. KQ4E2b, KQ5E2b. [pmid: 19477893].
1038 Vreugdenhil A, Cannell J, Davies A, et al. A community-based exercise programme to improve functional ability in people with Alzheimer's disease: a randomized controlled trial. Scand J Caring Sci. Mar. 2012;26(1):12-9. KQ5E5. [pmid: 21564154].
1039 Waelde LC, Thompson L, Gallagher-Thompson D. A Pilot Study of a Yoga and Meditation Intervention for Dementia Caregiver Stress. J Clin Psychol. 2004;60(6):677-87. KQ4E2c, KQ5E2c. [pmid: 15141399].
1040 Waite LM, Broe GA, Casey B, et al. Screening for Dementia Using an Informant Interview. Aging Neuropsychol Cogn. Sep. 1. 1998;5(3):194-202. PMID: None. KQ3E5.
1041 Waldorff FB, Buss DV, Eckermann A, et al. Efficacy of psychosocial intervention in patients with mild Alzheimer's disease: the multicentre, rater blinded, randomised Danish Alzheimer Intervention Study (DAISY). BMJ. 2012;345:e4693. KQ5E5. [pmid: 22807076].
1042 Wallin AK, Gustafson L, Sjogren M, et al. Five-year outcome of cholinergic treatment of Alzheimer's disease: early response predicts prolonged time until nursing home placement, but does not alter life expectancy. Dement Geriatr Cogn Disord. 2004;18(2):197-206. KQ4E2a, KQ5E2e. [pmid: 15211076].
1043 Walsh SP, Raman R, Jones KB, et al. ADCS Prevention Instrument Project: the Mail-In Cognitive Function Screening Instrument (MCFSI). Alzheimer Dis Assoc Disord. Oct. 2006;20(4:Suppl 3):Suppl-8. KQ2E5, KQ3E5. [pmid: 17135810].
1044 Wang LQ, Chien WT. Randomised controlled trial of a family-led mutual support programme for people with dementia. J Clin Nurs. 2011;20(15-16):2362-6. KQ4E2b, KQ5E2b. [pmid: 21752121].
1045 Watfa G, Rossignol P, Kearney-Schwartz A, et al. Use of calcium channel blockers is associated with better cognitive performance in older hypertensive patients with subjective memory complaints. J Hypertens. Dec. 2010;28(12):2485-93. KQ4E2a, KQ5E5. [pmid: 20739903].
1046 Watson GS, Cholerton BA, Reger MA, et al. Preserved cognition in patients with early Alzheimer disease and amnestic mild cognitive impairment during treatment with rosiglitazone: a preliminary study. Am J Geriatr Psychiatry. Nov. 2005;13(11):950-8. KQ4E6b, KQ5E6b. [pmid: 16286438].
1047 Wattmo C, Wallin AK, Londos E, et al. Long-term outcome and prediction models of activities of daily living in Alzheimer disease with cholinesterase inhibitor treatment. Alzheimer Dis Assoc Disord. Jan. 2011;25(1):63-72. KQ4E2a, KQ5E5. [pmid: 20847636].
1048 Wege N, Dlugaj M, Siegrist J, et al. Population-based distribution and psychometric properties of a short cognitive performance measure in the population-based Heinz Nixdorf Recall Study. Neuroepidemiology. 2011;37(1):13-20. KQ2E2d. [pmid: 21757960].
1049 Weiner MW, Sadowsky C, Saxton J, et al. Magnetic resonance imaging and neuropsychological results from a trial of memantine in Alzheimer's disease. Alzheimers Dement. Jul. 2011;7(4):425-35. KQ5E2e. [pmid: 21646051].
1050 Weintraub D, Somogyi M, Meng X. Rivastigmine in Alzheimer's disease and Parkinson's disease dementia: an ADAS-cog factor analysis. Am J Alzheimers Dis Other Demen. Sep. 2011;26(6):443-9. KQ4E1, KQ5E1. [pmid: 22009228].
1051 Wells D, Dawson P, Sidani S, et al. The benefits of abilities-focused morning care for residents with dementia and their caregivers. Perspectives (Montclair). 2000;24(1):17. KQ4E3b, KQ5E3b. [pmid: 12026330].
1052 Wells Y, Jorm AF. Evaluation of a special nursing home unit for dementia sufferers: a randomised controlled comparison with community care. Aust N Z J Psychiatry. Dec. 1987;21(4):524-31. KQ4E4c, KQ5E4c. [pmid: 3449047].
1053 Wells YD, Jorm AF, Jordan F, et al. Effects on care-givers of special day care programmes for dementia sufferers. Aust N Z J Psychiatry. Mar. 1990;24(1):82-90. KQ4E6c, KQ5E6c. [pmid: 2334391].
1054 Welsh KA, Breitner JCS, Magruder-Habib KM. Detection of dementia in the elderly using telephone screening of cognitive status. Neuropsychiatry Neuropsychol Behav Neurol. 1993;6(2):103-10. PMID: None. KQ2E7c.
1055 Wenger NS, Roth CP, Shekelle PG, et al. A practice-based intervention to improve primary care for falls, urinary incontinence, and dementia. J Am Geriatr Soc. Mar. 2009;57(3):547-55. KQ4E5, KQ5E5. [pmid: 19175441].
1056 Weyer G, Eul A, Milde K, et al. Cyclandelate in the treatment of patients with mild to moderate primary degenerative dementia of the Alzheimer type or vascular dementia: experience from a placebo controlled multi-center study. Pharmacopsychiatry. May. 2000;33(3):89-97. KQ4E6c, KQ5E6c. [pmid: 10855459].
1057 Wharton W, Baker LD, Gleason CE, et al. Short-term hormone therapy with transdermal estradiol improves cognition for postmenopausal women with Alzheimer's disease: results of a randomized controlled trial. J Alzheimers Dis. 2011;26(3):495-505. KQ4E7a, KQ5E7a. [pmid: 21694454].
1058 White LR, Ross GW, Petrovitch H, et al. Estimation of the sensitivity and specificity of a dementia screening test in a population-based survey. L.R. White, G.W. Ross, H. Petrovítch, K. Masaki, D. Chiu, E. Teng. National Institute on Aging, Honolulu Heart Program, U. of Hawaii, U.S.Calif. (347 N. Kuakini St., Honolulu, HI.). Neurobiol Aging. 1994;15(Suppl 1):S42. PMID: None. KQ2E7c.
1059 Wilber ST, Carpenter CR, Hustey FM. The Six-Item Screener to detect cognitive impairment in older emergency department patients. Acad Emerg Med. Jul. 2008;15(7):613-6. KQ2E7b. [pmid: 18691212].
1060 Wilcock G, Mobius HJ, Stoffler A. A double-blind, placebo-controlled multicentre study of memantine in mild to moderate vascular dementia (MMM500). Int Clin Psychopharmacol. Nov. 2002;17(6):297-305. KQ4E8, KQ5E8. [pmid: 12409683].
1061 Wilcock G, Howe I, Coles H, et al. A long-term comparison of galantamine and donepezil in the treatment of Alzheimer's disease. Drugs Aging. 2003;20(10):777-89. KQ4E2b, KQ5E2e. [pmid: 12875613].
1062 Wilcock GK, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer's disease: multicentre randomised controlled trial. Galantamine International-1 Study Group. [Erratum appears in BMJ 2001 Feb 17;322(7283):405]. BMJ. Dec. 9. 2000;321(7274):1445-9. KQ4E8, KQ5E8. [pmid: 11110737].
1063 Wilder D, Cross P, Chen J, et al. Operating Characteristics of Brief Screens for Dementia in a Multicultural Population. Am J Geriatr Psychiatry. 1995;3(2):96-107. PMID: None. KQ2E3c.
1064 Wilkinson D, Doody R, Helme R, et al. Donepezil in vascular dementia: A randomized, placebo-controlled study. Neurology. 2003;61(4):479-86. KQ4E8, KQ5E8. [pmid: 12939421].
1065 Wilkinson D, Schindler R, Schwam E, et al. Effectiveness of donepezil in reducing clinical worsening in patients with mild-to-moderate alzheimer's disease. Dement Geriatr Cogn Disord. 2009;28(3):244-51. KQ4E4c, KQ5E4c. [pmid: 19786776].
1066 Wilkinson D, Roman G, Salloway S, et al. The long-term efficacy and tolerability of donepezil in patients with vascular dementia. Int J Geriatr Psychiatry. Mar. 2010;25(3):305-13. KQ4E2a. [pmid: 19623601].
1067 Wilkinson DG, Passmore AP, Bullock R, et al. A multinational, randomised, 12-week, comparative study of donepezil and rivastigmine in patients with mild to moderate Alzheimer's disease. Int J Clin Pract. Jul. 2002;56(6):441-6. KQ4E2b, KQ5E2e. [pmid: 12166542].
1068 Wilkinson DG, Howe I. Switching from donepezil to galantamine: a double-blind study of two wash-out periods. Int J Geriatr Psychiatry. May. 2005;20(5):489-91. KQ4E2b, KQ5E8. [pmid: 15852437].
1069 Williams VP, Bishop-Fitzpatrick L, Lane JD, et al. Video-based coping skills to reduce health risk and improve psychological and physical well-being in Alzheimer's disease family caregivers. Psychosom Med. Nov. 2010;72(9):897-904. KQ5E5. [pmid: 20978227].
1070 Williamson JD, Espeland M, Kritchevsky SB, et al. Changes in cognitive function in a randomized trial of physical activity: results of the lifestyle interventions and independence for elders pilot study. J Gerontol A Biol Sci Med Sci. Jun. 2009;64(6):688-94. KQ4E1b, KQ5E1b. [pmid: 19244157].
1071 Willis SL, Tennstedt SL, Marsiske M, et al. Long-term effects of cognitive training on everyday functional outcomes in older adults. JAMA. Dec. 20. 2006;296(23):2805-14. KQ4E1b, KQ5E1b. [pmid: 17179457].
1072 Wilz G, Ýthe D, Soellner R. Goal attainment and treatment compliance in a cognitive-behavioral telephone intervention for family caregivers of persons with dementia. GeroPsych. 2011;24(3):115-25. PMID: None. KQ4E5, KQ5E5.
1073 Wimo A, Mattsson B, Adolfsson R, et al. Dementia day care and its effects on symptoms and institutionalization--a controlled Swedish study. Scand J Prim Health Care. Jun. 1993;11(2):117-23. KQ4E6c, KQ5E6c. [pmid: 8356361].
1074 Wimo A, Winblad B, Shah SN, et al. Impact of donepezil treatment for Alzheimer's disease on caregiver time. Curr Med Res Opin. Aug. 2004;20(8):1221-5. KQ4E8, KQ5E8. [pmid: 15324524].
1075 Winblad B, Engedal K, Soininen H, et al. A 1-year, randomized, placebo-controlled study of donepezil in patients with mild to moderate AD. Neurology. Aug. 14. 2001;57(3):489-95. KQ4E8, KQ5E8. [pmid: 11502918].
1076 Winblad B, Wimo A, Engedal K, et al. 3-year study of donepezil therapy in Alzheimer's disease: effects of early and continuous therapy. Dement Geriatr Cogn Disord. 2006;21(5-6):353-63. KQ4E8, KQ5E8. [pmid: 16508298].
1077 Winblad B, Kawata AK, Beusterien KM, et al. Caregiver preference for rivastigmine patch relative to capsules for treatment of probable Alzheimer's disease. Int J Geriatr Psychiatry. May. 2007;22(5):485-91. KQ4E5, KQ5E5. [pmid: 17407176].
1078 Winblad B, Jelic V, Kershaw P, et al. Effects of statins on cognitive function in patients with Alzheimer's disease in galantamine clinical trials. Drugs Aging. 2007;24(1):57-61. KQ5E2e. [pmid: 17233547].
1079 Winblad B, Grossberg G, Frolich L, et al. IDEAL: a 6-month, double-blind, placebo-controlled study of the first skin patch for Alzheimer disease. Neurology. Jul. 24. 2007;69(4:Suppl 1):S14-S22. KQ4E5, KQ5E5. [pmid: 17646619].
1080 Winblad B, Gauthier S, Scinto L, et al. Safety and efficacy of galantamine in subjects with mild cognitive impairment. Neurology. May. 27. 2008;70(22):2024-35. KQ4E7c, KQ5E7c. [pmid: 18322263].
1081 Winter L, Gitlin LN. Evaluation of a telephone-based support group intervention for female caregivers of community-dwelling individuals with dementia. Am J Alzheimers Dis Other Demen. Dec. 20. 2006;21(6):391-7. KQ5E5. [pmid: 17267370].
1082 Wishart L, Macerollo J, Loney P, et al. “Special steps”: an effective visiting/walking program for persons with cognitive impairment. Can J Nurs Res. Mar. 2000;31(4):57-71. KQ4E2c, KQ5E2c. [pmid: 11189671].
1083 Wisniewski SR, Belle SH, Coon DW, et al. The Resources for Enhancing Alzheimer's Caregiver Health (REACH): project design and baseline characteristics. Psychol Aging. Sep. 2003;18(3):375-84. KQ5E5. [pmid: 14518801].
1084 Wolf-Klein GP, Silverstone FA, Levy AP, et al. Screening for Alzheimer's disease by clock drawing. J Am Geriatr Soc. Aug. 1989;37(8):730-4. KQ3E5. [pmid: 2754158].
1085 Wolfs CAG, Kessels A, Dirksen CD, et al. Integrated multidisciplinary diagnostic approach for dementia care: Randomised controlled trial. Br J Psychiatry. 2008;192(4):300-5. KQ5E5. [pmid: 18378994].
1086 Wolinsky FD, Unverzagt FW, Smith DM, et al. The effects of the ACTIVE cognitive training trial on clinically relevant declines in health-related quality of life. J Gerontol B Psychol Sci Soc Sci. Sep. 2006;61(5):S281-S287. KQ4E1b, KQ5E1b. [pmid: 16960242].
1087 Wolinsky FD, Mahncke HW, Kosinski M, et al. The ACTIVE cognitive training trial and predicted medical expenditures. BMC Health Serv Res. 2009;9:109. KQ4E1b, KQ5E1b. [pmid: 19558724].
1088 Wolters M, Hickstein M, Flintermann A, et al. Cognitive performance in relation to vitamin status in healthy elderly German women-the effect of 6-month multivitamin supplementation. Prev Med. Jul. 2005;41(1):253-9. KQ4E1b, KQ5E1b. [pmid: 15917019].
1089 Wong VS. Effect of galantamine on verbal repetition in AD: a secondary analysis of the VISTA trial. Neurology. Aug. 21. 2007;69(8):809-10. KQ4E5, KQ5E5. [pmid: 17709718].
1090 Woods B, Thorgrimsen L, Spector A, et al. Improved quality of life and cognitive stimulation therapy in dementia. Aging Ment Health. May. 2006;10(3):219-26. KQ4E2c, KQ5E2c. [pmid: 16777649].
1091 Worm CH, Vad E, Puggard L, et al. Effects of a multicomponent exercise program on functional ability in community-dwelling, frail older adults. J Aging Phys Act. 2001;9(4):414-24. PMID: None. KQ4E1a, KQ5E1a.
1092 Wouters-Wesseling W, Wouters AE, Kleijer CN, et al. Study of the effect of a liquid nutrition supplement on the nutritional status of psycho-geriatric nursing home patients. Eur J Clin Nutr. Mar. 2002;56(3):245-51. KQ4E6c, KQ5E6c. [pmid: 11960300].
1093 Wright DW, Nevarez H, Kilgo P, et al. A novel technology to screen for cognitive impairment in the elderly. Am J Alzheimers Dis Other Demen. Sep. 2011;26(6):484-91. KQ2E5. [pmid: 22110158].
1094 Wright LK, Litaker M, Laraia MT, et al. Continuum of care for Alzheimer's disease: a nurse education and counseling program. Issues Ment Health Nurs. Apr. 2001;22(3):231-52. KQ5E5. [pmid: 11885210].
1095 Xu G, Meyer JS, Thornby J, et al. Screening for mild cognitive impairment (MCI) utilizing combined mini-mental-cognitive capacity examinations for identifying dementia prodromes. Int J Geriatr Psychiatry. Nov. 2002;17(11):1027-33. KQ2E7c. [pmid: 12404652].
1096 Yaffe K, Krueger K, Sarkar S, et al. Cognitive function in postmenopausal women treated with raloxifene. N Engl J Med. Apr. 19. 2001;344(16):1207-13. KQ4E1b, KQ5E1b. [pmid: 11309635].
1097 Yaffe K, Krueger K, Cummings SR, et al. Effect of raloxifene on prevention of dementia and cognitive impairment in older women: the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. Am J Psychiatry. Apr. 2005;162(4):683-90. KQ4E1b, KQ5E1b. [pmid: 15800139].
1098 Yang YH, Galvin JE, Morris JC, et al. Application of AD8 questionnaire to screen very mild dementia in Taiwanese. Am J Alzheimers Dis Other Demen. Mar. 2011;26(2):134-8. KQ2E3c. [pmid: 21415088].
1099 Yasar S, Corrada M, Brookmeyer R, et al. Calcium channel blockers and risk of AD: the Baltimore Longitudinal Study of Aging. Neurobiol Aging. Feb. 2005;26(2Neurobiology of Aging):157-63. KQ4E1b, KQ5E1b. [pmid: 15582745].
1100 Yoon BK, Kim DK, Kang Y, et al. Hormone replacement therapy in postmenopausal women with Alzheimer's disease: a randomized, prospective study. Fertil Steril. Feb. 2003;79(2):274-80. KQ4E2b, KQ5E2e. [pmid: 12568834].
1101 Yoshida H, Terada S, Honda H, et al. Validation of the revised Addenbrooke's Cognitive Examination (ACE-R) for detecting mild cognitive impairment and dementia in a Japanese population. Int Psychogeriatr. Jan. 2012;24(1):28-37. KQ2E3c. [pmid: 21843399].
1102 Yukawa M, Naka H, Murata Y, et al. Folic acid-responsive neurological diseases in Japan. J Nutr Sci Vitaminol (Tokyo). Jun. 2001;47(3):181-7. KQ4E4b, KQ5E4b. [pmid: 11575572].
1103 Zank S, Schacke C. Evaluation of geriatric day care units: effects on patients and caregivers. J Gerontol B Psychol Sci Soc Sci. Jul. 2002;57(4):348-57. KQ4E2a, KQ5E2a. [pmid: 12084785].
1104 Zarit SH, Stephens MA, Townsend A, et al. Stress reduction for family caregivers: effects of adult day care use. J Gerontol B Psychol Sci Soc Sci. Sep. 1998;53(5):S267-S277. KQ4E2a, KQ5E5. [pmid: 9750575].
1105 Zaudig M. A new systematic method of measurement and diagnosis of “mild cognitive impairment” and dementia according to ICD-10 and DSM-III-R criteria. International Psychogeriatrics. 1992;4:Suppl-19. KQ2E1, KQ3E1. [pmid: 1288663].
1106 Zemlan FP. Velnacrine for the treatment of Alzheimer's disease: a double-blind, placebo-controlled trial. The Mentane Study Group. J Neural Trans. 1996;103(8-9):1105-16. KQ4E6b, KQ5E6b. [pmid: 9013398].
1107 Zhou A, Jia J. The value of the clock drawing test and the mini-mental state examination for identifying vascular cognitive impairment no dementia. Int J Geriatr Psychiatry. Apr. 2008;23(4):422-6. KQ2E2d. [pmid: 17879252].
1108 Zhou J, Zhang X, Mundt JC, et al. A comparison of three dementia screening instruments administered by telephone in China. Dementia. 2004;3(1):69-81. PMID: None. KQ2E3a, KQ3E3a.
1109 Zieschang T, Schwenk M, Oster P, et al. Sustainability of Motor Training Effects in Older People with Dementia. J Alzheimers Dis. 2012. Nov. 30. KQ4E7a, KQ5E7a. [pmid: 23202438].
1110 Zimmerman S, Sloane PD, Williams CS, et al. Residential care/assisted living staff may detect undiagnosed dementia using the minimum data set cognition scale. J Am Geriatr Soc. Sep. 2007;55(9):1349-55. KQ3E5. [pmid: 17767676].