# Detailed Methods

Systematic Review Search Strategy

### PubMed (3/18/2011)

1 “Dementia/diagnosis”[Majr:NoExp] OR “Dementia/diet therapy”[Majr:NoExp] OR “Dementia/drug therapy”[Majr:NoExp] OR “Dementia/epidemiology”[Majr:NoExp] OR “Dementia/prevention and control”[Majr:NoExp] OR “Dementia/psychology”[Majr:NoExp] OR “Dementia/therapy”[Majr:NoExp] OR “Alzheimer Disease/diet therapy”[Majr] OR “Alzheimer Disease/drug therapy”[Majr] OR “Alzheimer Disease/epidemiology”[Majr] OR “Alzheimer Disease/prevention and control”[Majr] OR “Alzheimer Disease/psychology”[Majr] OR “Alzheimer Disease/therapy”[Majr] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/diagnosis”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/diet therapy”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/drug therapy”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/epidemiology”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/prevention and control”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/psychology”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/rehabilitation”[Majr:NoExp] OR “Delirium, Dementia, Amnestic, Cognitive Disorders/therapy”[Majr:NoExp] OR “Cognition Disorders/diagnosis”[Majr:NoExp] OR “Cognition Disorders/diet therapy”[Majr:NoExp] OR “Cognition Disorders/drug therapy”[Majr:NoExp] OR “Cognition Disorders/epidemiology”[Majr:NoExp] OR “Cognition Disorders/prevention and control”[Majr:NoExp] OR “Cognition Disorders/psychology”[Majr:NoExp] OR “Cognition Disorders/rehabilitation”[Majr:NoExp] OR “Cognition Disorders/therapy”[Majr:NoExp]
2 systematic[sb]
3 1 AND 2
4 “Cochrane Database Syst Rev”[Journal] OR“Evid Rep Technol Assess (Full Rep)”[Journal] OR “Evid Rep Technol Assess (Summ)”[Journal]
5 “Consensus Development Conference” [Publication Type] OR “Meta-Analysis” [Publication Type]
6 systematic*[tiab] OR meta analy*[tiab] OR literature[tiab] OR published[tiab] OR publication*[tiab] OR medline[tiab]
7 “Mass Screening”[Mesh:NoExp] OR screen*[ti]
8 4 OR 5 OR 6 OR 7
9 3 AND 8
10 (dementia[ti] OR alzheimer*[ti])
11 10 AND 2
12 (in process[sb] OR publisher[sb] OR pubmednotmedline[sb])
13 11 AND 12
14 mild cognitive impairment [ti] OR cognitive decline [ti]
15 14 AND 2
16 9 OR 13 OR 15
17 9 OR 13 OR 15 Limits: English, Publication Date from 2001 to 2012

Screening Literature Search Strategies, 12/8/2012

### Dementia screening trials

Date limit: 2000-present (bridging from previous Task Force review)

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. Dementia/
2. Alzheimer Disease/
3. Aphasia, Primary Progressive/
4. Dementia, Vascular/
5. Dementia, Multi-Infarct/
6. Frontotemporal Dementia/
7. Delirium, Dementia, Amnestic, Cognitive Disorders/
8. dementia.ti.
9. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10. screen$.ti,ab.
11. mass screening/
12. 10 or 11
13. 9 and 12
14. *Dementia/di [Diagnosis]
15. *Alzheimer Disease/di [Diagnosis]
16. *Delirium, Dementia, Amnestic, Cognitive Disorders/di [Diagnosis]
17. 13 or 14 or 15 or 16
18. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
19. random$.ti,ab.
20. Clinical Trials as Topic/
21. Randomized Controlled Trials as Topic/
22. clinical trial$.ti,ab.
23. controlled trial$.ti,ab.
24. 18 or 19 or 20 or 21 or 22 or 23
25. 17 and 24
26. limit 25 to english language
27. limit 26 to yr=“2000 -Current”

______________________________________________________________________________

### Mild cognitive impairment screening trials

Date limit: 1990-present

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. Cognition Disorders/
2. cognitive impairment$.ti.
3. cognitive decline.ti.
4. cognitive loss.ti.
5. cognitive disorder$.ti.
6. 1 or 2 or 3 or 4 or 5
7. screen$.ti,ab.
8. mass screening/
9. 7 or 8
10. 6 and 9
11. *Cognition Disorders/di [Diagnosis]
12. 10 or 11
13. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
14. random$.ti,ab.
15. Clinical Trials as Topic/
16. Randomized Controlled Trials as Topic/
17. clinical trial$.ti,ab.
18. controlled trial$.ti,ab.
19. 13 or 14 or 15 or 16 or 17 or 18
20. 12 and 19
21. limit 20 to english language
22. limit 21 to yr=“1990 -Current”

______________________________________________________________________________

### Test performance of screening instruments for dementia

Date limit: 2006-present (bridging from Holsinger review)

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. Dementia/
2. Alzheimer Disease/
3. Aphasia, Primary Progressive/
4. Dementia, Vascular/
5. Dementia, Multi-Infarct/
6. Frontotemporal Dementia/
7. Delirium, Dementia, Amnestic, Cognitive Disorders/
8. dementia.ti.
9. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10. “Sensitivity and Specificity”/
11. “Predictive Value of Tests”/
12. ROC Curve/
13. sensitivit$.ti,ab.
14. predictive value.ti,ab.
15. accuracy.ti,ab.
16. False Negative Reactions/
17. False Positive Reactions/
18. Diagnostic Errors/
19. “Reproducibility of Results”/
20. Reference Values/
21. Reference Standards/
22. Observer Variation/
23. 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22
24. 9 and 23
25. limit 24 to english language
26. limit 25 to yr=“2006 -Current”

______________________________________________________________________________

### Test performance of screening instruments for mild cognitive impairment

Date limit: 1990-present

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. *Cognition Disorders/di [Diagnosis]
2. cognitive impairment$.ti.
3. cognitive decline.ti.
4. cognitive loss.ti.
5. cognitive disorder$.ti.
6. 1 or 2 or 3 or 4 or 5
7. “Sensitivity and Specificity”/
8. “Predictive Value of Tests”/
9. ROC Curve/
10. sensitivit$.ti,ab.
11. predictive value.ti,ab.
12. accuracy.ti,ab.
13. False Negative Reactions/
14. False Positive Reactions/
15. Diagnostic Errors/
16. “Reproducibility of Results”/
17. Reference Values/
18. Reference Standards/
19. Observer Variation/
20. 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21. 6 and 20
22. limit 21 to english language
23. limit 22 to yr=“1990 -Current”

______________________________________________________________________________

### Dementia Screening harms

Date limit: 2000-present (bridging from previous Task Force review)

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. Dementia/
2. Alzheimer Disease/
3. Aphasia, Primary Progressive/
4. Dementia, Vascular/
5. Dementia, Multi-Infarct/
6. Frontotemporal Dementia/
7. Delirium, Dementia, Amnestic, Cognitive Disorders/
8. dementia.ti.
9. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10. screen$.ti,ab.
11. mass screening/
12. 10 or 11
13. 9 and 12
14. *Dementia/di [Diagnosis]
15. *Alzheimer Disease/di [Diagnosis]
16. *Delirium, Dementia, Amnestic, Cognitive Disorders/di [Diagnosis]
17. 13 or 14 or 15 or 16
18. adverse effects.fs.
19. adverse$.ti,ab.
20. harm$.ti,ab.
21. Anxiety/
22. anxiety.ti,ab.
23. Depression/
24. depression.ti,ab.
25. Depressive Disorder/
26. labeling.ti,ab.
27. labelling.ti,ab.
28. labeled.ti,ab.
29. labelled.ti,ab.
30. Stress, Psychological/
31. 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30
32. 17 and 31
33. limit 32 to english language
34. limit 33 to yr=“2000 -Current”

______________________________________________________________________________

### Mild cognitive impairment Screening harms

Date limit: 1990-present

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. Cognition Disorders/
2. cognitive impairment$.ti.
3. cognitive decline.ti.
4. cognitive loss.ti.
5. cognitive disorder$.ti.
6. 1 or 2 or 3 or 4 or 5
7. screen$.ti,ab.
8. mass screening/
9. 7 or 8
10. 6 and 9
11. *Cognition Disorders/di [Diagnosis]
12. 10 or 11
13. adverse effects.fs.
14. adverse$.ti,ab.
15. harm$.ti,ab.
16. Anxiety/
17. anxiety.ti,ab.
18. Depression/
19. depression.ti,ab.
20. Depressive Disorder/
21. labeling.ti,ab.
22. labelling.ti,ab.
23. labeled.ti,ab.
24. labelled.ti,ab.
25. Stress, Psychological/
26. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25
27. 12 and 26
28. limit 27 to english language
29. limit 28 to yr=“1990 -Current”

______________________________________________________________________________

### All screening questions

Cochrane Central Register of Controlled Trials (Central)

Issue 3 of 4, Jul 2011

#1 Dementia:ti,kw OR Alzheimer*:kw, from 2000 to 2012 in Clinical Trials
#2 screen*:ti,ab,kw, from 2000 to 2012 in Clinical Trials
#3 (#1 AND #2), from 2000 to 2012
#4 (cognitive next impairment*):ti,kw, from 1990 to 2012 in Clinical Trials
#5 (cognitive next decline):ti,kw, from 1990 to 2012 in Clinical Trials
#6 (cognitive next loss):ti,kw, from 1990 to 2012 in Clinical Trials
#7 (cognitive next disorder*):ti,kw, from 1990 to 2012 in Clinical Trials
#8 (Cognition next Disorders):kw, from 1990 to 2012 in Clinical Trials
#9 (#4 OR #5 OR #6 OR #7 OR #8), from 1990 to 2012
#10 screen*:ti,ab,kw, from 1990 to 2012 in Clinical Trials
#11 (#9 AND #10), from 1990 to 2012
#12 sensitivit*:ti,ab,kw, from 2006 to 2012 in Clinical Trials
#13 (ROC next Curve):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#14 (predictive next value):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#15 accuracy:ti,ab,kw, from 2006 to 2012 in Clinical Trials
#16 (False next Negative*):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#17 (False next positive*):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#18 (Diagnostic next Error*):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#19 Reproducibility:ti,ab,kw, from 2006 to 2012 in Clinical Trials
#20 (Reference next Value*):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#21 (Reference next standard*):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#22 (Observer next Variation*):ti,ab,kw, from 2006 to 2012 in Clinical Trials
#23 (#12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22), from 2006 to 2012
#24 (#1 AND #23), from 2006 to 2012
#25 sensitivit*:ti,ab,kw,, from 1990 to 2012 in Clinical Trials
#26 (ROC next Curve):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#27 (predictive next value):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#28 accuracy:ti,ab,kw, from 1990 to 2012 in Clinical Trials
#29 (False next Negative*):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#30 (False next positive*):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#31 (Diagnostic next Error*):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#32 Reproducibility:ti,ab,kw, from 1990 to 2012 in Clinical Trials
#33 (Reference next Value*):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#34 (Reference next standard*):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#35 (Observer next Variation*):ti,ab,kw, from 1990 to 2012 in Clinical Trials
#36 (#25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35), from 1990 to 2012
#37 (#9 AND #36), from 1990 to 2012
#38 (#3 OR #11 OR #24 OR #37)

PsycINFO 1987 to December Week 1 2012

# Searches
1. Dementia/
2. Senile Dementia/
3. Vascular Dementia/
4. Alzheimer's Disease/
5. 1 or 2 or 3 or 4
6. Screening/
7. Health Screening/
8. Screening Tests/
9. screen$.ti,ab.
10. 6 or 7 or 8 or 9
11. 5 and 10
12. treatment outcome clinical trial.md.
13. experiment controls/
14. controlled trial$.ti,ab,id,hw.
15. clinical trial$.ti,ab,id,hw.
16. random$.ti,ab,id,hw.
17. Anxiety/
18. Anxiety Disorders/
19. “Depression (Emotion)”/
20. Labeling/
21. Psychological Stress/
22. adverse$.ti,ab.
23. harm$.ti,ab.
24. anxiety.ti,ab.
25. depression.ti,ab.
26. labeling.ti,ab.
27. labelling.ti,ab.
28. labeled.ti,ab.
29. labelled.ti,ab.
30. or/12-29
31. 11 and 30
32. limit 31 to english language
33. limit 32 to yr=“2000 -Current”
34. Cognitive Impairment/
35. cognitive impairment$.ti.
36. cognitive decline.ti.
37. cognitive loss.ti.
38. cognitive disorder$.ti.
39. or/34-38
40. 39 and 10 and 30
41. limit 40 to english language
42. limit 41 to yr=“1990 -Current”
43. Test Reliability/
44. Test Validity/
45. sensitivit$.ti,ab.
46. predictive value.ti,ab.
47. accuracy.ti,ab.
48. or/43-47
49. 5 and 48
50. limit 49 to english language
51. limit 50 to yr=“2006 -Current”
52. 39 and 48
53. limit 52 to english language
54. limit 53 to yr=“1990 -Current”
55. 33 or 42 or 51 or 54

Treatment Literature Search Strategies

Database(s): Ovid MEDLINE(R) without Revisions 1996 to December Week 1 2012, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update December 8, 2012 Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 8, 2012

# Searches
1. Dementia/
2. Alzheimer Disease/
3. Aphasia, Primary Progressive/
4. Dementia, Vascular/
5. Dementia, Multi-Infarct/
6. Frontotemporal Dementia/
7. Delirium, Dementia, Amnestic, Cognitive Disorders/
8. dementia.ti.
9. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10. Cognition Disorders/
11. cognitive impairment$.ti.
12. cognitive decline.ti.
13. cognitive loss.ti.
14. cognitive disorder$.ti.
15. 10 or 11 or 12 or 13 or 14
16. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
17. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
18. control groups/ or double-blind method/ or single-blind method/
19. random$.ti,ab.
20. placebo*.ti,ab.
21. clinical trial$.ti,ab.
22. controlled trial$.ti,ab.
23. 16 or 17 or 18 or 19 or 20 or 21 or 22
24. 9 and 23
25. 15 and 23
26. statin$.mp.
27. Hydroxymethylglutaryl-CoA Reductase Inhibitors/
28. lovastatin.mp.
29. simvastatin.mp.
30. cerivastatin.mp.
31. atorvastatin.mp.
32. rosuvastatin.mp.
33. pravastatin.mp.
34. fluvastatin.mp.
35. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. 24 and 35
37. limit 36 to yr=“2008 -Current”
38. 25 and 35
39. limit 38 to yr=“1990 -Current”
40. Antihypertensive Agents/
41. Antihypertensive*.ti,ab.
42. Diuretics/
43. Diuretic*.ti,ab.
44. exp Adrenergic beta-Antagonists/
45. Adrenergic beta Antagonist*.ti,ab.
46. beta blocker*.ti,ab.
47. exp Adrenergic alpha-Antagonists/
48. Adrenergic alpha Antagonist*.ti,ab.
49. alpha blocker*.ti,ab.
50. Angiotensin-Converting Enzyme Inhibitors/
51. ace inhibitor*.ti,ab.
52. Angiotensin Converting Enzyme Inhibitor*.ti,ab.
53. Calcium Channel Blockers/
54. Calcium Channel Blocker*.ti,ab.
55. Vasodilator Agents/
56. Vasodilator*.ti,ab.
57. 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or
58. 24 and 57
59. limit 58 to yr=“2000 -Current”
60. 25 and 57
61. limit 60 to yr=“1990 -Current”
62. Aspirin/
63. aspirin*.ti,ab.
64. 62 or 63
65. 24 and 64
66. limit 65 to yr=“2007 -Current”
67. 25 and 64
68. limit 67 to yr=“1990 -Current”
69. Anti-Inflammatory Agents, Non-Steroidal/
70. Nonsteroidal Anti Inflammatory Agent*.ti,ab.
71. Non steroidal Anti Inflammatory Agent*.ti,ab.
72. Nonsteroidal Antiinflammatory Agent*.ti,ab.
73. Non steroidal Antiinflammatory Agent*.ti,ab.
74. NSAID*.ti,ab.
75. Diclofenac/
76. Diclofenac.ti,ab.
77. Ibuprofen/
78. Ibuprofen.ti,ab.
79. Indomethacin/
80. Indomethacin.ti,ab.
81. Ketoprofen/
82. Ketoprofen.ti,ab.
83. Ketorolac/
84. Ketorolac.ti,ab.
85. Naproxen/
86. Naproxen.ti,ab.
87. Piroxicam/
88. Piroxicam.ti,ab.
89. Salicylates/
90. Salicylate*.ti,ab.
91. Sulindac/
92. Sulindac.ti,ab.
93. Cyclooxygenase Inhibitors/
94. Cyclooxygenase Inhibitor*.ti,ab.
95. Cyclooxygenase 2 Inhibitors/
96. Cyclooxygenase 2 Inhibitor*.ti,ab.
97. COX 2 Inhibitor*.ti,ab.
98. 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97
99. 24 and 98
100. limit 99 to yr=“2000 -Current”
101. 25 and 98
102. limit 101 to yr=“1990 -Current”
103. Gonadal Steroid Hormones/
104. Hormone Replacement Therapy/
105. Estrogen Replacement Therapy/
106. Estradiol/
107. Estrogens/
108. “Estrogens, Conjugated (USP)”/
109. Medroxyprogesterone Acetate/
110. Progesterone/
111. Progesterone Congeners/
112. Androgens/
113. Testosterone/
114. Dehydroepiandrosterone/
115. Dehydroepiandrosterone Sulfate/
116. Norethindrone/
117. Hormone Replacement Therapy.ti,ab.
118. estrogen*.ti,ab.
119. Estradiol.ti,ab.
120. Medroxyprogesterone.ti,ab.
121. Progesterone.ti,ab.
122. Androgens.ti,ab.
123. Testosterone.ti,ab.
124. Dehydroepiandrosterone.ti,ab.
125. Norethindrone.ti,ab.
126. 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125
127. 24 and 126
128. limit 127 to yr=“2000 -Current”
129. 25 and 126
130. limit 129 to yr=“1990 -Current”
131. Cholinesterase inhibitors/
132. Cholinesterase Inhibitor*.ti,ab.
133. Anticholinesterase*.ti,ab.
134. Galantamine/
135. Galantamine.ti,ab.
136. Tacrine/
137. Tacrine.ti,ab.
138. rivastigmine.ti,ab.
139. donepezil.ti,ab.
140. 131 or 132 or 133 or 134 or 135 or 136 or 137 or 138 or 139
141. 24 and 140
142. limit 141 to yr=“2006 -Current”
143. 25 and 140
144. limit 143 to yr=“2006 -Current”
145. Memantine/
146. Memantine.ti,ab.
147. 145 or 146
148. 24 and 147
149. limit 148 to yr=“2006 -Current”
150. 25 and 147
151. limit 150 to yr=“2006 -Current”
152. folic acid/
153. folic acid.ti,ab.
154. folate.ti,ab.
155. Vitamin B Complex/
156. Thiamine/
157. Thiamine.ti,ab.
158. Thiamin.ti,ab.
159. Thiamine Monophosphate/
160. Thiamine Pyrophosphate/
161. Thiamine Triphosphate/
162. Vitamin B 1.ti,ab.
163. Vitamin B1.ti,ab.
164. Riboflavin/
165. Riboflavin.ti,ab.
166. Vitamin B 2.ti,ab.
167. Vitamin B2.ti,ab.
168. Vitamin B 6/
169. Vitamin B 6.ti,ab.
170. Vitamin B6.ti,ab.
171. Pyridoxine/
172. Pyridoxine.ti,ab.
173. Vitamin B 12/
174. Vitamin B 12.ti,ab.
175. Vitamin B12.ti,ab.
176. Cobamides/
177. Hydroxocobalamin/
178. Cobalamin.ti,ab.
179. Cyanocobalamin.ti,ab.
180. Cobamides.ti,ab.
181. Hydroxocobalamin.ti,ab.
182. 152 or 153 or 154 or 155 or 156 or 157 or 158 or 159 or 160 or 161 or 162 or 163 or 164 or 165 or 166 or 167 or 168 or 169 or 170 or 171 or 172 or 173 or 174 or 175 or 176 or 177 or 178 or 179 or 180 or 181
183. 24 and 182
184. limit 183 to yr=“2004 -Current”
185. 25 and 182
186. limit 185 to yr=“2004 -Current”
187. Antioxidants/
188. Antioxidant*.ti,ab.
189. Vitamin E/
190. Vitamin E.ti,ab.
191. alpha-Tocopherol/
192. Tocopherols/
193. Tocopherol*.ti,ab.
194. Ascorbic acid/
195. Ascorbic acid.ti,ab.
196. Vitamin C.ti,ab.
197. ascorbate.ti,ab.
198. beta carotene/
199. beta carotene.ti,ab.
200. 187 or 188 or 189 or 190 or 191 or 192 or 193 or 194 or 195 or 196 or 197 or 198 or 199
201. 24 and 200
202. limit 201 to yr=“2005 -Current”
203. 25 and 200
204. limit 203 to yr=“2005 -Current”
205. fatty acids, omega-3/ or alpha-linolenic acid/ or docosahexaenoic acids/ or neuroprostanes/ or eicosapentaenoic acid/
206. Omega 3.ti,ab.
207. n 3 Fatty Acid*.ti,ab.
208. Linolenic Acids/
209. Linolenic Acid*.ti,ab.
210. Fatty Acids, Essential/
211. Dietary Fats, Unsaturated/
212. Fish Oils/
213. fish oil*.ti,ab.
214. diet* fatty acid*.ti,ab.
215. Diet, Mediterranean/
216. Mediterranean diet*.ti,ab.
217. 205 or 206 or 207 or 208 or 209 or 210 or 211 or 212 or 213 or 214 or 215 or 216
218. 24 and 217
219. limit 218 to yr=“2005 -Current”
220. 25 and 217
221. limit 220 to yr=“2005 -Current”
222. Exercise/
223. Exercise Therapy/
224. Physical Fitness/
225. Walking/
226. exercis*.ti,ab.
227. physical activity.ti,ab.
228. physical training.ti,ab.
229. strength training.ti,ab.
230. resistance training.ti,ab.
231. Resistance Training/
232. aerobic training.ti,ab.
233. cardiovascular training.ti,ab.
234. endurance training.ti,ab.
235. flexibility training.ti,ab.
236. Relaxation/
237. relaxation.ti,ab.
238. Tai Ji/
239. Tai Chi.ti,ab.
240. walking.ti,ab.
241. Yoga/
242. yoga.ti,ab.
243. Dancing/
244. (dancing or dance).ti,ab.
245. 222 or 223 or 224 or 225 or 226 or 227 or 228 or 229 or 230 or 231 or 232 or 233 or 234 or 235 or 236 or 237 or 238 or 239 or 240 or 241 or 242 or 243 or 244
246. 24 and 245
247. limit 246 to yr=“2007 -Current”
248. 25 and 245
249. limit 248 to yr=“1990 -Current”
250. Caregivers/
251. caregiver*.ti,ab.
252. caregiving.ti,ab.
253. (carer or carers).ti,ab.
254. Self-Help Groups/
255. self help.ti,ab.
256. Respite Care/
257. care giver*.ti,ab.
258. Respite Care/
259. respite.ti,ab.
260. Family Therapy/
261. family therapy.ti,ab.
262. Social Support/
263. social support*.ti,ab.
264. Day Care/
265. (day care or daycare).ti,ab.
266. skills training.ti,ab.
267. Health Education/
268. health education.ti,ab.
269. education.fs.
270. education, continuing/ or education, medical, continuing/ or education, nursing, continuing/
271. 250 or 251 or 252 or 253 or 254 or 255 or 256 or 257 or 258 or 259 or 260 or 261 or 262 or 263 or 264 or 265 or 266 or 267 or 268 or 269 or 270
272. 24 and 271
273. limit 272 to yr=“2000 -Current”
274. Counseling/
275. Directive Counseling/
276. Cognitive Therapy/
277. cognitive therapy.ti,ab.
278. psychotherapy/ or psychotherapy, brief/
279. Behavior Therapy/
280. psychotherap*.ti,ab.
281. counsel*.ti,ab.
282. 274 or 275 or 276 or 277 or 278 or 279 or 280 or 281
283. 24 and 282
284. limit 283 to yr=“2000 -Current”
285. 25 and 282
286. limit 285 to yr=“1990 -Current”
287. (cognitive* adj3 engage*).ti,ab.
288. (creative* adj3 engage*).ti,ab.
289. (cognitive* adj3 stimulat*).ti,ab.
290. cognitive training.ti,ab.
291. cognitive intervention*.ti,ab.
292. group reminiscence.ti,ab.
293. reality orientation.ti,ab.
294. Reality Therapy/
295. reality therapy.ti,ab.
296. cognitive exercis*.ti,ab.
297. 287 or 288 or 289 or 290 or 291 or 292 or 293 or 294 or 295 or 296
298. 24 and 297
299. limit 298 to yr=“2000 -Current”
300. 25 and 297
301. limit 300 to yr=“1990 -Current”
302. Case Management/
303. Patient Care Management/
304. care manage*.ti,ab.
305. case manage*.ti,ab.
306. 302 or 303 or 304 or 305
307. 24 and 306
308. limit 307 to yr=“2000 -Current”
309. 25 and 306
310. limit 309 to yr=“1990 -Current”
311. ((multicomponent or multi component or multidisciplinary or multi disciplinary or multimodal or multi modal) adj3 (treatment* or program* or intervention*)).ti,ab.
312. 24 and 311
313. limit 312 to yr=“2000 -Current”
314. 25 and 311
315. limit 314 to yr=“1990 -Current”
316. 37 or 39 or 59 or 61 or 66 or 68 or 100 or 102 or 128 or 130 or 142 or 144 or 149 or 151 or 184 or 186 or 202 or 204 or 219 or 221 or 247 or 249 or 273 or 284 or 286 or 299 or 301 or 308 or 310 or 313 or 315
317. limit 316 to english language
318. limit 317 to humans
319. limit 317 to animals
320. 319 not 318
321. 317 not 320
322. remove duplicates from 321

Figure 1 Literature Flow Diagram

Abbreviations: SER = systematic evidence review.

Appendix A Figure 1 displays the literature search results and article flow for the review. A total of 15,684 articles were identified through database searching, 313 through selected SERs, and 182 articles were identified through other sources. 16,179 articles were screened after duplicates were removed. 1,190 full-text articles were assessed for eligibility. No articles were included for KQ1. 64 articles (55 studies) were included for KQ2. 2 articles (one study) were included for KQ3. 167 articles (131 studies) were included for KQ4. 78 articles (66 studies) were included for KQ5.

Table 1 Systematic Reviews Used for Their References and Search Dates of Literature Searches

Screening method/treatment intervention | Condition of interest | Primary existing systematic review used^*^ | Other systematic review(s) to locate primary research
KQs 1–3
Screening | MCI | None | Lonie, 2009^1^ Ehreke, 2010^2^ Mitchell, 2009^3^
Screening | Dementia | Holsinger4 | Mitchell, 2010^5^ Mitchell, 2010^6^ Kansagara, 2010^7^ Mitchell, 2009^3^ Castilla-Rilo, 2007^8^ Cherbuin, 2008^9^ Milne, 2008^10^
Screening harms | MCI/Dementia | None | Kansagara, 2010^7^
KQs 4–5: Pharmacologic
Statins | MCI | None | None
Statins | Dementia | McGuinness, 2010^11^ | Plassman12
Harms of statins | MCI/Dementia | None | None
Antihypertensives | MCI | None | None
Antihypertensives | Dementia | None | Plassman, 2010^12^ Shah, 2009^13^ Langa, 2004 14
Harms of antihypertensives | MCI/Dementia | None | None
NSAIDs (includes ASA) | MCI | None | None
NSAIDs (includes ASA) | Dementia | Rands, 2000^15^ | Plassman12 Tabet (ibuprofen)16 Tabet (indomethacin)17
Harms of NSAIDs | MCI/Dementia | None | None
Steroids (estrogen, testosterone) | MCI | None | None
Steroids (estrogen, testosterone) | Dementia | None | Plassman12 Hogervorst, 2009^18^
Harms of steroids | MCI/Dementia | None | None
Cholinesterase Inhibitors | MCI | Raina, 2008^19^ | None
Cholinesterase Inhibitors | Dementia | Raina, 2008^19^ | Plassman12 NICE 2011
Harms of cholinesterase inhibitors) | MCI/Dementia | None | None
Memantine | MCI | Raina, 2008^19^ | None
Memantine | Dementia | Raina, 2008^19^ | Plassman12
Harms of memantine | MCI/Dementia | None
Vitamin B/folate | MCI | Malouf 2003^20^ Malouf 2003^21^ Malouf 2008^22^ Balk 2006^23^ | Jia 2008^24^
Vitamin B/folate | Dementia | Malouf 2003^20^ Malouf 2003^21^ Malouf 2008^22^ Jia 2008^24^ Balk 2006^23^ | Plassman 2010^12^ Wald 2010^25^ Dangour 2010^26^
Harms of vitamin B/folate | MCI/Dementia | Balk 2006^23^ | None
Antioxidants (vitamin C, vitamin E, beta-carotene) | MCI | Jia 2008^24^ | Issac 2008 (vitamin E)27
Antioxidants (vitamin C, vitamin E, beta-carotene) | Dementia | Jia 2008^24^ | Plassman 2010^12^ Boothby 2005^28^ Issac 2008 (vitamin E)27
Harms of antioxidant vitamins | MCI/Dementia | None | None
Omega-3 | MCI | Jia 2008^24^ Issa 2006^29^ | None
Omega-3 | Dementia | Jia, 2008^24^ Issa 2006^29^ | Plassman 2010^12^ Dangour 2010^26^ MacLean 2005^30^
Harms of omega-3 | MCI/Dementia | None | None
KQs 4–5: Nonpharmacologic
Physical Activity | MCI | van Uffelen 2008^31^ | None
Physical Activity | Dementia | van Uffelen 2008^31^ Forbes 2008^32^ | Plassman 2010^12^ Olazaran 2010^33^
Harms of physical activity | MCI/Dementia | None | None
Counseling | MCI | None | None
Counseling | Dementia | None | Plassman 2010^12^ Bates 2004^34^ Olazaran 2010^33^
Harms of counseling | MCI/Dementia | None | None
Caregiver | MCI | Not applicable | Not applicable
Caregiver | Dementia | Brodaty 2003^35^ Lee 2004^36^ | Plassman 2010^12^ Chien 2011^37^ Cooper 2007^38^ Schoenmakers 2010^39^ Selwood 2007^40^ Smits 2007^41^ Thompson 2007^42^ Spijker 2008 Olazaran 2010^33^ Pinquart 2006^43^
Harms of caregiver interventions | MCI/Dementia | None | None
Cognitive engagement | MCI | None | Jean 2010^44^
Cognitive engagement | Dementia | None | Plassman 2010^12^ Frank 2005^45^ Olazaran 2010
Harms of cognitive engagement | MCI/Dementia | None | None
Multicomponent | MCI | None | None
Multicomponent | Dementia | None | Pimouguet46 Plassman12 Bates 2004^34^ Olazaran 2010^33^
Harms of multicomponent interventions | MCI/Dementia | None | None

* The start date for searches is 1 year prior to the end search date used in the primary existing systematic review. MCI literature was always searched from 1990 to present.

Abbreviations: ASA = acetylsalicyclic acid; KQ = key question; MCI = Mild Cognitive Impairment; NSAID = nonsteroidal anti-inflammatory drug.

Table 2 Inclusion/Exclusion Criteria

Populations | Include | Patient: Community-dwelling older adults, average age 65 years or older, generally asymptomatic but can have common symptoms like subjective memory complaints (SMC) Informal caregiver: Engaged in taking some kind of responsibility for the care of the patient; relationship such as spouse, de-facto partner, relative, or friend; can receive caregiver's pension
Populations | Exclude | Patient: Populations exclusively with HIV/AIDS, Down syndrome, posttraumatic brain injuries, Parkinson's disease, and stroke Professional caregiver: Formally or professionally trained, paid salary
Settings | Include | Primary care, outpatient settings (ambulatory care), home, residential care facilities, assisted living, adult foster care in developed countries (“Very High” on the Human Development Index: Norway, Australia, New Zealand, United States, Ireland, Liechtenstein, Netherlands, Canada, Sweden, Germany, Japan, Republic of Korea, Switzerland, France, Israel, Finland, Iceland, Belgium, Denmark, Spain, Hong Kong, Greece, Italy, Luxembourg, Austria, United Kingdom, Singapore, Czech Republic, Slovenia, Andorra, Slovakia, United Arab Emirates, Malta, Estonia, Cyprus, Hungary, Brunei Darussalam, Qatar, Bahrain, Portugal, Poland, Barbados)
Settings | Exclude | Hospital, long-term care facilities (e.g., skilled nursing facilities), emergency departments [underlined: Screening:] Participants recruited from memory, dementia, geropsychology, and neurology clinics
Disease/Condition | Include | [underlined: Screening:] Any cognitive impairment (MCI or dementia) [underlined: Treatment:] MCI or early (mild-moderate) dementia (Functional Assessment Screening Test [FAST] stages 2-6)
Disease/Condition | Exclude | [underlined: Screening:] None [underlined: Treatment:] Late (severe) dementia (severe dementia defined as FAST stage 7: very severe cognitive decline that includes loss of ADLs, IADLs, and verbal abilities), reversible causes of cognitive impairment
Screening | Include | Any screening instrument that can be delivered in primary care in ≤10 min for clinician administration or ≤20 min self-administration; informant instruments
Screening | Exclude | Instruments that take >10 min for clinician administration or >20 min for self- administration; biomarkers (CSF, plasma, urine) or imaging (CT, MRI, PET); proxy respondents
Treatment/management interventions | Include | Pharmacologic interventions used to treat patients with early (mild-moderate) dementia or MCI for the purpose of preventing cognitive decline; when applicable, treatments reviewed will be specific to specific types of dementia Nonpharmacologic interventions aimed at patients and/or caregivers given in early (mild-moderate) dementia or MCI; when applicable, treatments reviewed will be specific to specific types of dementia Treatments for this review will include: dietary supplements (B vitamins and folate, vitamins C, E, beta-carotene, and omega-3 fatty acids); medications (statins, antihypertensives, NSAIDs, gonadal steroids, cholinesterase inhibitors, memantine); social or behavioral interventions (physical activity, counseling, cognitive engagement, caregiver interventions, multidisciplinary or multicomponent interventions)
Treatment/management interventions | Exclude | Treatments for symptom management (e.g., agitation, psychosis, depression) in dementia (i.e., antipsychotics, antiepileptics, antidepressants, SSRIs); medications not FDA-approved for treatment of dementia; herbal supplements (e.g., ginkgo biloba, DHEA); experimental or emerging therapies (antiamyloid disease modifying treatments)
Comparisons | Include | [underlined: Diagnostic accuracy] (KQ 2): Comparator needs to be reference standard [underlined: Therapeutic or outcome efficacy] (KQs 1,3–5): No screening/treatment or usual care
Comparisons | Exclude | None
Outcomes – diagnostic accuracy | Include | Sensitivity, specificity, likelihood ratios, positive predictive value (PPV), negative predictive value (NPV)
Outcomes – diagnostic accuracy | Exclude | Cost-related outcomes
Outcomes – decision-making, planning | Include | For patients, family/caregivers: Health care, legal, and financial planning (e.g., advanced directives); safety planning; living arrangements For clinicians: Health care planning, including advanced directives; patient and caregiver education; safety planning (change, monitored medication use); screening and diagnostic decisions (e.g., cancer screening); and other treatment or management decisions (e.g., treatment of reversible causes of dementia)
Outcomes – decision-making, planning | Exclude | Cost-related outcomes
Outcomes – patient | Include | Safety (falls, other accidents), HRQL, cognitive function/decline, overall function/decline (ADL/IADL), unanticipated health care utilization (emergency use/hospitalizations), independent living (institutionalizations), medication adherence/compliance/errors, symptoms (insomnia, depression, agitation)
Outcomes – patient | Exclude | Cost-related outcomes; patient satisfaction (other than HRQL)
Outcomes – family/caregiver | Include | HRQL, caregiver burden (a priori defined primary or secondary outcome in the trial, Zarit scale, Caregiver Activity Survey [CAS], Caregiver Strain Index, general measures of illness, depression/anxiety, and self-rated health)
Outcomes – family/caregiver | Exclude | Cost-related outcomes; family/caregiver satisfaction (other than caregiver burden and HRQL)
Outcomes – society | Include | Safety (automobile accidents)
Outcomes – society | Exclude | Cost-related outcomes
Harms | Include | [underlined: Screening:] Diagnostic inaccuracy, paradoxical effects (unwanted or unexpected direction of effects of outcomes), psychological harms (depression, anxiety), harms due to labeling (psychological harms, insurance status) [underlined: Treatment:] Serious adverse events (e.g., death, serious adverse drug reactions), unexpected medical attention (e.g., emergency department visits, hospitalizations), paradoxical effects (unwanted or unexpected direction of effects of outcomes), psychological harms (depression, anxiety)
Harms | Exclude | [underlined: Screening:] Patient or family/ caregiver dissatisfaction (other than psychological harms or patient adherence) [underlined: Treatment:] Patient or family/ caregiver dissatisfaction (other than psychological harms or patient adherence)
Study Designs | Include | [underlined: Diagnostic accuracy] (KQ 2): Good-quality systematic reviews, diagnostic accuracy studies [underlined: Therapeutic or outcome efficacy] (KQs 1, 4): good-quality systematic reviews, RCT/CCT [underlined: Harms] (KQs 3,5): good-quality systematic reviews, RCT/CCT, prospective observational studies for efficacy, retrospective and case-control studies for harms
Study Designs | Exclude | [underlined: All KQs:] Poor-quality studies [underlined: Therapeutic or outcome efficacy] (KQs 1, 4): <3 month followup for efficacy trials, observational studies [underlined: Harms] (KQs 3, 5): no minimum duration for treatment harms; case series, case reports; n<1000 (KQ 5 only)
Language | Include | English only
Language | Exclude | Non-English languages

Abbreviations: ADL = activities of daily life; CAS = Caregiver Activity Survey; CCT = controlled clinical trial; CSF = cerebrospinal fluid; CT = computed tomography; DHEA = dehydroepiandrosterone; FDA = Food and Drug Administration; HRQL = health-related quality of life; IADL = instumental activities of daily life; KQ = key question; MCI = mild cognitive impaiment; NPV = negative predictive value; MRI = magnetic resonance imaging; NSAID = nonsteroidal anti-inflammatory drug; PET = positron emission tomography; PPV = positive predictive value; RCT = randomized, controlled trial; SMC = subjective memory complaints.

Table 3 Quality Rating Criteria

Design | USPSTF quality rating criteria47 | NICE methodology checklists48 | QUADAS Tool49
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable | Not applicable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - Study addresses an appropriate and clearly focused question; - Cases and controls are taken from comparable populations; - Same exclusion criteria are used for both cases and controls; - Percentage of each group (cases and controls) that participated in the study is reported; - Comparison is made between participants and non-participants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Its is clearly established that controls are non-cases; - Measures are taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid and reliable way; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided | Not applicable
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - Treatment and control groups are similar at the start of the trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - Percentage of individuals or clusters recruited into each treatment arm of the study who dropped out before the study was completed is reported; - All subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites | Not applicable
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - Study addresses an appropriate and clearly focused question; - Two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many of the people asked to take part did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each arm of the study who dropped out before the study was completed is reported; - Comparison is made between full participants and those lost to follow-up, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is made blind to exposure status; - When blinding is not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided | Not applicable
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - Nature of the test being studied is clearly specified; - Test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - Test and gold standard are measured independently (blind) of each other; - Test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported | - Spectrum of patients is representative of the patients who will receive the test in practice; - Selection criteria are clearly described; - Reference standard is likely to correctly classify the target condition; - Time period between the reference standard and the index test is short enough to be reasonably sure that the target condition did not change between the two tests; - Whole sample or a random selection of the sample receives verification using a reference standard of diagnosis; - Patients receive the same reference standard regardless of the index test result; - Reference standard is independent of the index test; - Execution of the index test is described in sufficient detail to permit replication of the test; - Execution of the reference standard is described in sufficient detail to permit its replication; - Index test results are interpreted without knowledge of the results of the reference standard; - Reference standard results are interpreted without knowledge of the results of the index test; - Same clinical data is available when test results are interpreted as would be available when the test is used in practice; - Uninterpretable/intermediate test results are reported; - Withdrawals from the study are explained