# References

1 Polen MR, Whitlock EP, Wisdom JP, Nygren P, Bougatsos C. Screening in Primary Care Settings for Illicit Drug Use: Staged Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 58.1. AHRQ Publication No. 08-05108-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
2 Lanier D, Ko S. Screening in Primary Care Settings for Illicit Drug Use: Assessment of Screening Instruments—A Supplemental Evidence Update for the U.S. Preventive Services Task Force. Evidence Synthesis No. 58.2. AHRQ Publication No. 08-05108-EF-2. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
3 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC. American Psychiatric Association. 1994.
4 Substance Abuse and Mental Health Services Administration. Results From the 2012 National Survey on Drug Misuse and Health: Summary of National Findings. NSDUH Series H-46. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2013.
5 National Institute on Drug Abuse. Drug Facts: Prescription and Over-the-Counter Medications. Washington, DC. U.S. Department of Health and Human Services, National Institutes of Health. 2012.
6 Johnston LD, O'Malley PM, Bachman JG, et al. Monitoring the Future National Results on Adolescent Drug Use: Overview of Key Findings, 2011. Ann Arbor, MI. Institute for Social Research, University of Michigan. 2012.
7 Eaton DK, Kann L, Kinchen S, et al. Youth risk behavior surveillance—United States, 2011. MMWR Surveill Summ. 2012;61(4):1-162. [pmid: 22673000].
8 Substance Abuse and Mental Health Administration. Results From the 2011 National Survey on Drug Use and Health: Summary of National Findings. NSDUH Series H-44. HHS Publication No. (SMA) 12-4713. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2012.
9 Miniño AM, Murphy SL. Death in the United States, 2010. NCHS Data Brief. 2012;(99):1-8. [pmid: 23050606].
10 Substance Abuse and Mental Health Services Administration. Drug Abuse Warning Network, 2009: National Estimates of Drug-Related Emergency Department Visits. HHS Publication No. (SMA) 11-4659. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2011.
11 Warner M, Chen LH, Makuc DM, et al. Drug poisoning deaths in the United States, 1980-2008. NCHS Data Brief. 2011;(81):1-8. [pmid: 22617462].
12 Centers for Disease Control and Prevention. Vital signs: unintentional injury deaths among persons aged 0-19 years—United States, 2000-2009. MMWR Morb Mortal Wkly Rep. 2012;61:270-6. [pmid: 22513530].
13 Townsend L, Flisher AJ, King G. A systematic review of the relationship between high school dropout and substance use. Clin Child Fam Psychol Rev. 2007;10(4):295-317. [pmid: 17636403].
14 American Academy of Pediatrics. Performing Preventive Services: A Bright Futures Handbook. Elk Grove Village, IL. American Academy of Pediatrics. 2010.
15 Fletcher A, Bonell C, Hargreaves J. School effects on young people's drug use: a systematic review of intervention and observational studies. J Adolesc Health. 2008;42(3):209-20. [pmid: 18295128].
16 Mayberry ML, Espelage DL, Koenig B. Multilevel modeling of direct effects and interactions of peers, parents, school, and community influences on adolescent substance use. J Youth Adolesc. 2009;38(8):1038-49. [pmid: 19636769].
17 Hays SP, Hays CE, Mulhall PF. Community risk and protective factors and adolescent substance use. J Prim Prev. 2003;24(4):125-42.
18 Kandel D, Yamaguchi K. From beer to crack: developmental patterns of drug involvement. Am J Public Health. 1993;83(6):851-5. [pmid: 8498623].
19 Kirby T, Barry AE. Alcohol as a gateway drug: a study of US 12th graders. J Sch Health. 2012;82(8):371-9. [pmid: 22712674].
20 Fergusson DM, Boden JM, Horwood LJ. Cannabis use and other illicit drug use: testing the cannabis gateway hypothesis. Addiction. 2006;101(4):556-69. [pmid: 16548935].
21 U.S. Department of Health and Human Services. Healthy People 2020 Summary of Objectices: Substance Abuse. Washington, DC. U.S. Department of Health and Human Services. 2012. Accessed at http://www.healthypeople.gov/2020/topicsobjectives2020/overview.aspx?topicid=40 on 26 February 2014.
22 Substance Abuse and Mental Health Administration. Screening, Brief Intervention, and Referral to Treatment (SBIRT). Rockville, MD. Substance Abuse and Mental Health Services Administration. 2012. Accessed at http://www.samhsa.gov/prevention/sbirt/ on 26 February 2014.
23 American Academy of Pediatrics Committee on Substance Abuse, Levy SJ, Kokotailo PK. Substance use screening, brief intervention, and referral to treatment for pediatricians. Pediatrics. 2011;128(5):e1330-40. [pmid: 22042818].
24 American Academy of Pediatrics Committee on Substance Abuse. Indications for management and referral of patients involved in substance abuse. Pediatrics. 2000;106(1 Pt 1):143-8. [pmid: 10878166].
25 Halpern-Felsher BL, Ozer EM, Millstein SG, et al. Preventive services in a health maintenance organization: how well do pediatricians screen and educate adolescent patients?. Arch Pediatr Adolesc Med. 2000;154(2):173-9. [pmid: 10665605].
26 Klein JD, Wilson KM. Delivering quality care: adolescents' discussion of health risks with their providers. J Adolesc Health. 2002;30(3):190-5. [pmid: 11869926].
27 Johnson TP, Booth AL, Johnson P. Physician beliefs about substance misuse and its treatment: findings from a U.S. survey of primary care practitioners. Subst Use Misuse. 2005;40(8):1071-84. [pmid: 16040369].
28 Van Hook S, Harris SK, Brooks T, et al. The “Six T's”: barriers to screening teens for substance abuse in primary care. J Adolesc Health. 2007;40(5):456-61. [pmid: 17448404].
29 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. Agency for Healthcare Quality and Research. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm on 26 February 2014.
30 Barnett E, Sussman S, Smith C, et al. Motivational interviewing for adolescent substance use: a review of the literature. Addict Behav. 2012;37(12):1325-34. [pmid: 22958865].
31 Becker SJ, Curry JF. Outpatient interventions for adolescent substance abuse: a quality of evidence review. J Consult Clin Psychol. 2008;76(4):531-43. [pmid: 18665683].
32 Carney T, Myers B. Effectiveness of early interventions for substance-using adolescents: findings from a systematic review and meta-analysis. Subst Abuse Treat Prev Policy. 2012;7(1):25. [pmid: 22697269].
33 Gates S, McCambridge J, Smith LA, et al. Interventions for prevention of drug use by young people delivered in non-school settings. Cochrane Database Syst Rev. 2006;(1):CD005030. [pmid: 16437511].
34 Jackson C, Geddes R, Haw S, et al. Interventions to prevent substance use and risky sexual behaviour in young people: a systematic review. Addiction. 2012;107(4):733-47. [pmid: 22151546].
35 Jensen CD, Cushing CC, Aylward BS, et al. Effectiveness of motivational interviewing interventions for adolescent substance use behavior change: a meta-analytic review. J Consult Clin Psychol. 2011;79(4):433-40. [pmid: 21728400].
36 Fang L, Schinke SP, Cole KC. Preventing substance use among early Asian-American adolescent girls: initial evaluation of a web-based, mother-daughter program. J Adolesc Health. 2010;47(5):529-32. [pmid: 20970090].
37 Fang L, Schinke SP. Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychol Addict Behav. 2013;27(3):788-98. [pmid: 23276322].
38 Harris SK, Csemy L, Sherritt L, et al. Computer-facilitated substance use screening and brief advice for teens in primary care: an international trial. Pediatrics. 2012;129(6):1072-82. [pmid: 22566420].
39 Rhee H, Hollen PJ, Belyea MJ, et al. Decision-making program for rural adolescents with asthma: a pilot study. J Pediatr Nurs. 2008;23(6):439-50. [pmid: 19026912].
40 Schinke SP, Fang L, Cole KC. Preventing substance use among adolescent girls: 1-year outcomes of a computerized, mother-daughter program. Addict Behav. 2009;34(12):1060-4. [pmid: 19632053].
41 Schinke SP, Fang L, Cole KC. Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Prev Med. 2009;49(5):429-35. [pmid: 19682490].
42 Walton MA, Bohnert K, Resko S, et al. Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: one year outcomes. Drug Alcohol Depend. 2013;132(3):646-53. [pmid: 23711998].
43 Knight JR, Shrier LA, Bravender TD, et al. A new brief screen for adolescent substance abuse. Arch Pediatr Adolesc Med. 1999;153(6):591-6. [pmid: 10357299].
44 Waldron HB, Slesnick N, Brody JL, et al. Treatment outcomes for adolescent substance abuse at 4- and 7-month assessments. J Consult Clin Psychol. 2001;69(5):802-13. [pmid: 11680557].
45 Levy S, Sherritt L, Harris SK, et al. Test-retest reliability of adolescents' self-report of substance use. Alcohol Clin Exp Res. 2004;28(8):1236-41. [pmid: 15318123].
46 Barnes GM, Welte JW, Hoffman JH, et al. Changes in alcohol use and alcohol-related problems among 7th to 12th grade students in New York State, 1983-1994. Alcohol Clin Exp Res. 1997;21(5):916-22. [pmid: 9267544].
47 Hollen P. Personal communication. Patnode C. 2013.
48 Barnes G. Personal communication. Patnode C. May. 28. 2013.
49 Walton M. Personal Communication. Patnode C. 2013.
50 Sieving RE, Beuhring T, Resnick MD, et al. Development of adolescent self-report measures from the National Longitudinal Study of Adolescent Health. J Adolesc Health. 2001;28(1):73-81. [pmid: 11137909].
51 Schinke S. Personal communication. Patnode C. April. 5. 2013.
52 Rocky Mountain Behavioral Institute. American Drug and Alcohol Survey. Fort Collins, CO. Rocky Mountain Behavioral Institute. 2003.
53 American Academy of Pediatrics Committee on Substance Abuse. Alcohol use by youth and adolescents: a pediatric concern. Pediatrics. 2010;125(5):1078-87. [pmid: 20385640].
54 Knight JR, Harris SK, Sherritt L, et al. Adolescents' preference for substance abuse screening in primary care practice. Subst Abus. 2007;28(4):107-17. [pmid: 18077307].
55 Knight JR, Sherritt L, Shrier LA, et al. Validity of the CRAFFT substance abuse screening test among adolescent clinic patients. Arch Pediatr Adolesc Med. 2002;156(6):607-14. [pmid: 12038895].
56 Dhalla S, Zumbo BD, Poole G. A review of the psychometric properties of the CRAFFT instrument: 1999-2010. Current Drug Abuse Reviews. 2011;4(1):57-64. [pmid: 21466499].
57 Radhert E. The Problem Oriented Screening Instrument for Teenagers: The Adolescent/Referral System Manual. Washington DC. U.S. Deparment of Health and Human Services. 1991.
58 Klitzner M, Schwartz RH, Gruenewald P, et al. Screening for risk factors for adolescent alcohol and drug use. Am J Dis Child. 1987;141(1):45-9. [pmid: 3788881].
59 Riggs SR, Alario A. Adolescent substance use instructor's guide. Dube C, Goldstein M, Lewis D, et al., editors. Project ADEPT Curriculum for Primary Care Physician Training. Providence, RI. Brown University. 1989.
60 Knight JR, Goodman E, Pulerwitz T, et al. Reliabilities of short substance abuse screening tests among adolescent medical patients. Pediatrics. 2000;105(4 Pt 2):948-53. [pmid: 10742352].
61 Pilowsky DJ, Wu LT. Screening for alcohol and drug use disorders among adults in primary care: a review. Subst Abuse Rehabil. 2012;3(1):25-34. [pmid: 22553426].
62 Dennis M, Titus JC, Diamond G, et al. The Cannabis Youth Treatment (CYT) experiment: rationale, study design and analysis plans. Addiction. 2002;97(Suppl 1):16-34. [pmid: 12460126].
63 Dennis M, Godley SH, Diamond G, et al. The Cannabis Youth Treatment (CYT) study: main findings from two randomized trials. J Subst Abuse Treat. 2004;27(3):197-213. [pmid: 15501373].
64 Diamond G, Godley SH, Liddle HA, et al. Five outpatient treatment models for adolescent marijuana use: a description of the Cannabis Youth Treatment Interventions. Addiction. 2002;97(Suppl 1):70-83. [pmid: 12460130].
65 Bernstein E, Edwards E, Dorfman D, et al. Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. 2009;16(11):1174-85. [pmid: 20053238].
66 D'Amico EJ, Miles JN, Stern SA, et al. Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. 2008;35(1):53-61. [pmid: 18037603].
67 Sarvela PD, Ford TD. An evaluation of a substance abuse education program for Mississippi Delta pregnant adolescents. J Sch Health. 1993;63(3):147-52. [pmid: 8487513].
68 Ioannidis JP. Scientific inbreeding and same-team replication: type D personality as an example. J Psychosom Res. 2012;73(6):408-10. [pmid: 23148806].
69 Centers for Disease Control and Prevention. Integrated prevention services for HIV infection, viral hepatitis, sexually transmitted diseases, and tuberculosis for persons who use drugs illicitly: summary guidance from CDC and the U.S. Department of Health and Human Services. MMWR Recomm Rep. 2012;61(RR-5):1-40.
70 Mitchell SG, Gryczynski J, O'Grady KE, et al. SBIRT for adolescent drug and alcohol use: current status and future directions. J Subst Abuse Treat. 2013;44(5):463-72. [pmid: 23352110].
71 vYOU: What Would I Do?. Boston, MA. Children's Hospital Boston. 2013. Accessed at http://www.ceasar.org/isbirt/materials/VYouWhatWouldIDo.pdf on 26 February 2014.
72 Van Hook S. Personal communication. Patnode CD. June. 14. 2013. PMID: None.
73 ClinicalTrials.gov. Medical Office Intervention for Adolescent Drug Use. NCT00229983. Boston, MA. Children's Hospital Boston. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT00229983?term=00229983&rank=1 on 26 February 2014.
74 Arnaud N, Broning S, Drechsel M, et al. Web-based screening and brief intervention for poly-drug use among teenagers: study protocol of a multicentre two-arm randomized controlled trial. BMC Public Health. 2012;12:826. [pmid: 23013141].
75 ClinicalTrials.gov. Project Chill: Tailored Youth Drug Intervention in Primary Care. NCT01329315. Ann Arbor, MI. University of Michigan. 2013. Accessed at http://clinicaltrials.gov/ct2/show/NCT01329315?term=Project+Chill%3A+Tailored+Youth+Drug+Intervention+in+Primary+Care&rank=1 on 26 February 2014.
76 ClinicalTrials.gov. Home Based Treatments for Drug Use in Early Adolescents. NCT00280228. Pittsburgh, PA. University of Pittsburgh. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT00280228?term=00280228&rank=1 on 26 February 2014.
77 Chaplin TM. Reducing Stress With Parenting-Focused Mindfulness to Prevent Youth Substance Use. New Haven, CT. Yale University. 2013. Accessed at http://clinicaltrials.gov/show/NCT02038231 on 4 March 2014.
78 NIH RePORT. Translation of Interventions for Rural Mexican-American Women. Project No. 5R01DA026776-03. Lubbock, TX. Texas Tech University Health Sciences Center. 2010. Accessed at http://projectreporter.nih.gov/project_info_description.cfm?aid=7894993&icde=16502436&ddparam=&ddvalue=&ddsub=&cr=1&csb=default&cs=ASC on 26 February 2014.
79 Epton T, Norman P, Sheeran P, et al. A theory-based online health behavior intervention for new university students: study protocol. BMC Public Health. 2013;13:107. [pmid: 23384237].
80 Australian New Zealand Clinical Trials Registry. Motivating Behaviour Change in Young Cannabis Users. Trial ID ACTRN12611000177954. Brisbane, QLD. Institute of Health and Biomedical Innovation. 2011. Accessed at http://www.anzctr.org.au/trial_view.aspx?ID=336536 on 26 February 2014.
81 ClinicalTrials.gov. Integration of (iSBIRT) for Teen Drug Use Into a Pediatric Network. NCT01454206. Boston, MA. Children's Hospital Boston. 2013. Accessed at http://clinicaltrials.gov/ct2/show/NCT01454206?term=01454206&rank=1 on 26 February 2014.
82 ClinicalTrials.gov. Dental and Medical Office iMET to Reduce Teen Tobacco, Alcohol, and Drug Use. NCT00907309. Boston, MA. Children's Hospital Boston. 2013. Accessed at http://clinicaltrials.gov/ct2/show/NCT00907309?term=00907309&rank=1 on 26 February 2014.
83 ClinicalTrials.gov. Reducing Problematic Substance Use in Youth With Chronic Medical Conditions. NCT01709201. Boston, MA. Children's Hospital Boston. 2013. Accessed at http://clinicaltrials.gov/ct2/show/NCT01709201?term=01709201&rank=1 on 26 February 2014.
84 Australian New Zealand Clinical Trials Registry. A Randomized Controlled Trial of Enhanced Cognitive Therapy and Family Education for Youth Depression, Anxiety, and Substance Abuse. Trial ID ACTRN12609000630213. Geelong, VIC. Deakin University. 2012. Accessed at http://www.anzctr.org.au/trial_view.aspx?ID=308260 on 26 February 2014.
85 NIH RePORT. Evaluating an Online Parenting Support System Disseminated by Pediatric Practices. Project No. 2R01DA021307-06A1. Eugene OR. Oregon Research Institute. 2013. Accessed at http://projectreporter.nih.gov/project_info_description.cfm?aid=8440201&icde=16502531&ddparam=&ddvalue=&ddsub=&cr=1&csb=default&cs=ASC on 26 February 2014.
86 ClinicalTrials.gov. Advancing Adolescent Screening and Brief Intervention Protocols in Primary Care Settings. NCT01523444. Philadelphia, PA. Treatment Research Institute. 2013. Accessed at http://clinicaltrials.gov/ct2/show/NCT01523444?term=01523444&rank=1 on 26 February 2014.
87 NIH RePORT. Understanding and Preventing Childhood Drug Use Risk. Project No. 5R01DA022773-05. Pittsburgh, PA. University of Pittsburgh. 2012. Accessed at http://projectreporter.nih.gov/project_info_description.cfm?aid=8265962&icde=16502589 on 26 February 2014.
88 NIH RePORT. A Brief Substance Use Preventive Intervention for Parents of Pre-Adolescents. Project No 5R34DA031337-02. Boston, MA. Tufts University. 2013. Accessed at http://projectreporter.nih.gov/project_info_description.cfm?aid=8437163&icde=16502688&ddparam=&ddvalue=&ddsub=&cr=1&csb=default&cs=ASC on 26 February 2014.
89 ClinicalTrials.gov. Substance Use Prevention in Teen Psychiatric Patients (tCheckup). NCT01170013. Providence, RI. Brown University. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01170013?term=01170013&rank=1 on 26 February 2014.
90 ClinicalTrials.gov. Teen Marijuana Check-Up. NCT01109563. Seattle, WA. University of Washington. 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT01109563?term=01109563&rank=1 on 26 February 2014.