# Results

## Literature Search

We identified six trials meeting our eligibility criteria that examined the effects of primary care–relevant interventions designed to prevent or reduce drug use in children and adolescents. These trials were reported in seven publications.36-42 Of the 143 full-text articles that were reviewed, the most common reasons for exclusion included the setting (i.e., not linked to or feasible for primary care; k=45), population (i.e., age 18 years or older, treatment seeking, or diagnosed with substance abuse or dependence; k=26), and not reporting any relevant outcomes (k=19) (Appendix A Figure 1).

We considered all of the included trials to be primary care–relevant because they were conducted in primary care or were judged to be feasible for primary care. Three of the studies were conducted in or recruited directly from primary care (i.e., “primary care–based”),38,39,42 while the other three studies all tested the same computer-based intervention that was considered potentially feasible for primary care.36,40,41 Only one of the studies exclusively targeted drug use behaviors (alcohol use was a secondary outcome).42 Among the others, three of the six studies targeted alcohol, tobacco, and drug use behaviors. The remaining two studies targeted alcohol and drug use behaviors only. None of the studies addressed long-term behavioral or health outcomes beyond 2 years. Table 3 and Table 4 present study and intervention characteristics of all of the included studies.

Table 3 Study Characteristics of Included Trials

Author, Year Quality Rating | Country, Intervention Setting | Study Design | IG N Enrolled/Randomized | CG N Enrolled/Randomized | F/U, m^*^ | % F/U | Key Eligibility Criteria | Age Range (mean), years | % Female | % Nonwhite
Primary care–based
Harris, 2012^38^ Fair | U.S., primary care practices | CCT | 1,031 | 1,075 | 12 | 72.0 | Patients ages 12–18 years arriving for routine primary care | 12–18 (15.8) | 58.2 | 35.4
Harris, 2012^38^ Fair | Czech Republic, primary care practices | CCT | 292 | 297 | 12 | 90.0 | Patients ages 12–18 years arriving for routine primary care | 13–17 (15.0) | 47.2 | 0
Rhee, 2008^39^ Fair | U.S., research center | RCT | 20 | 21 | 6 | 85.4 | Current diagnosis of asthma by health care provider | 14–20 (16.1) | 68.3 | 31.7
Walton, 2013^42^ Fair | U.S., primary care clinics | RCT | TBI: 118 CBI: 100 | 110 | 12 | 83.8 | Patients ages 12–18 years reporting past-year marijuana use | 12–18 (16.3) | 66.5 | 60.7
Computer-based
Schinke, 2009a40 Fair | U.S., computer-based intervention at home | RCT | 252^†^ | 339^†^ | 12 | 90.0 | Adolescent girls and their mothers who have private access to a personal computer | 11–13 (12.7) | 100 | 73.6
Schinke, 2009b41 Good | U.S., computer-based intervention at home | RCT | 458^†^ | 458^†^ | 12 | 94.3 | Adolescent girls and their mothers who have private access to a personal computer | 11–13 (12.8) | 100 | 76.8
Fang, 2010^36,37^ Good | U.S., computer-based intervention at home | RCT | 56^†^ | 52^†^ | 12 | 96.3 | Asian American adolescent girls and their mothers who have private access to a personal computer | 11–14 (13.1) | 100 | 100

* Longer followup times may be available; the common followup time in the included trials is reported.

† Number of mother–daughter dyads.

Abbreviations: CBI = computer-based brief intervention; CCT = clinical controlled trial; CG = control group; F/U = followup; IG = intervention group; N = sample size; NR = not reported; RCT = randomized, controlled trial; TBI = therapist-led brief intervention.

Table 4 Intervention Characteristics of Included Trials

Author, Year | Behavioral Targets | Person Targeted | Intervention Description | Role of PC | Mode of Intervention | Duration of Intervention | Estimated Time of Intervention | Control Group Description
Primary care–based
Harris, 2012^38^ | Alcohol and drugs | Child | Self-administered computer-facilitated screening asking about lifetime and past-12-month drug use followed by the CRAFFT questionnaire. Upon completion, the individual's CRAFFT score and risk level were displayed. Adolescents completed educational computer program containing information about drug use. The computer program was followed by brief provider advice informed by the adolescent's screening results. | Conducted in and recruited from PC, provider delivered part | Face, computer | 1 visit | 8 minutes (2–3 minutes with interventionist) | Usual care
Rhee, 2008^39^ | Alcohol, tobacco, and illicit drugs | Child | Brief counseling by family nurse practitioner and CD-ROM programs. The CD-ROM contained a decisionmaking module on all substance use and provided information about smoking and alcohol use. Intervention booster CD-ROMs were mailed at 2- and 4-month contacts. | Recruited from PC, no provider role | Face, computer | 1 visit + 2 booster module mailings within 4 months | 4.2 hours (10 minutes with interventionist) | Attention control
Walton, 2013^42^ | Marijuana (primary), alcohol, other illicit and prescription drug use (secondary) | Child | Therapist-led brief intervention (TBI): motivational interviewing by trained research therapist Computer-based brief intervention (CBI): stand-alone interactive animated program | Conducted in and recruited from PC | Face (TBI), computer (CBI) | 1 visit | 35–40 minutes (TBI: mean, 41 minutes; CBI: mean, 34 minutes) | Enhanced usual care
Computer-based
Schinke, 2009a40 | Alcohol, tobacco, marijuana, prescription drugs and OTC for nonmedical use | Child and parent | Mother–daughter dyads completed 9 weekly 45-minute computer-based sessions at home. Each session was delivered through voice-over narration, skills demonstration, and interactive activities for mothers and daughters to complete jointly. | No PC or provider role | Computer | 9 weeks | 6.8 hours | No intervention
Schinke, 2009b41 | Alcohol, tobacco, marijuana, prescription drugs for nonmedical use, and inhalants | Child and parent | Mothers and daughters each had private sessions addressing specific material. Joint session material covered importance of interpersonal relationships; depression from stress, pressure to succeed or look a certain way; emotional closeness; sharing difficult feelings about each other and illustrating important ways to be supportive of each other. | No PC or provider role | Computer | 9 weeks + 2 booster sessions within 2 years | 8.3 hours | No intervention
Fang, 2010^36,37^ | Alcohol, tobacco, marijuana, and prescription drugs for nonmedical use | Child and parent | | No PC or provider role | Computer | 9 weeks + 1 booster session within 12 months | 7.5 hours | No intervention

Abbreviations: NR = not reported; OTC = over-the-counter; PC = primary care.

## Key Question 1 Do Primary Care Behavioral Counseling Interventions for Drug Use, With or Without Referral, Improve Mortality, Morbidity, and Other Health, Social, and Legal Outcomes in Children and Adolescents?

## Key Question 2 Do Primary Care Behavioral Counseling Interventions, With or Without Referral, Prevent Drug Use Initiation in Children and Adolescents Who Do Not Currently Use Drugs or Reduce Drug Use in Children and Adolescents Who Currently Use Drugs?

### Study Characteristics

#### Primary Care–Based Interventions

Three studies testing four active treatment arms were conducted in or recruited from primary care; they varied greatly in terms of their study population, intervention, outcomes, and quality (Tables 3 and 4).38,39,42 A fair-quality study conducted by Harris and colleagues published in 2012 was a quasiexperimental design conducted in two sites—the United States and Czech Republic.38 The study's primary aim was to evaluate the immediate (3-month) and long-term (12-month) effects of a primary care computer-facilitated screening and brief advice system on adolescent alcohol and marijuana use. Within the United States, the study was conducted at nine primary care offices in three New England states (n=2,106). In the Czech Republic, the study included 10 pediatric generalist offices in Prague (n=589). Each site implemented an identical protocol. The study included patients ages 12 to 18 years partaking in routine primary care. At baseline, 12.8 and 14.0 percent of adolescents in the United States and Czech Republic cohorts, respectively, reported any past marijuana use. Baseline reports of ever having used alcohol were higher in the Czech Republic cohort (59.7%) than the U.S. cohort (28.5%). The intervention began with a computer-based, self-administered screening tool that asked adolescents about their lifetime and past-12-month use of substances (i.e., alcohol, marijuana, and “anything else to get high”) followed by the CRAFFT (Car, Relax, Alone, Forget, Friends, Trouble) screening questions.43 Participants were shown their individual CRAFFT score and risk level (low, medium, or high) after completing the screening questionnaire. Participants were then invited to read 10 pages of scientific information and true-life stories about substance use on the computer screen. Adolescents spent 5 minutes on average with the screening and educational computer program. Based on the adolescent's screening results, the provider was given a report that displayed their patient's risk level and six to 10 talking points designed to prompt a 2- to 3-minute brief advice discussion. This advice was tailored to advise the patient to “not start” or “stop” using substances, based on the adolescent's responses to the screening questionnaire. Providers at both sites underwent training to standardize the intervention. Control participants received treatment as usual. Substance use was assessed using a modified timeline follow-back interview that recorded frequency of use of multiple substances. The timeline follow-back interview has been found to have good convergent validity for marijuana use with other measures, including collateral reports from siblings and parents and urine testing,44 and is a reliable method of quantifying alcohol and marijuana use in adolescents in primary care.45 Because the frequency-of-use variables were highly skewed, a dichotomized use/no use variable was constructed in which any past-12-month use at the 12-month followup was the primary outcome. Rates of initiation and cessation in baseline nonusers and users, respectively, were also calculated. This study only analyzed marijuana use because of the low prevalence of use of all other drugs (≤2%). Analyses were stratified by country because the two cohorts had different demographic characteristics. The asynchronous design was this study's major threat to validity, as it precluded allocation concealment and blinding of assessors. There was also fairly high attrition among participants in the United States, with 72.4 percent of adolescents providing 12-month data (compared with a 90.4% response rate in the Czech Republic). The validity of the results were strengthened, however, by the relatively large sample sizes (United States: n=2,106; Czech Republic: n=589) and statistical methods, including controlling for demographics, peer/family substance use, visit/provider characteristics, and the multisite sampling design in logistic regression models with generalized estimating equations.

A very small fair-quality RCT conducted by Rhee and colleagues published in 2008 and based in the United States specifically recruited adolescents and young adults ages 14 to 20 years with a current diagnosis of asthma (n=41).39 This study targeted adolescents with asthma based on data showing that they have higher rates of current smoking and marijuana and inhalant use than adolescents without asthma—all behaviors which put them at high risk of asthma-related morbidity and mortality. Baseline risk of illicit drug use, alcohol use, and smoking are presented in Table 5 and Table 6. Use of illicit drugs and alcohol appeared to be generally low in participants; however, they were smoking, on average, 6.5 cigarettes per day for the past 30 days. Participants were recruited from rural outpatient clinics and one high school. While the intervention's setting was not reported, we assume it took place in a research center/clinic. The intervention was based on a computer-assisted decisionmaking program that included a brief, 10-minute counseling session conducted by a researcher (a family nurse practitioner) who educated participants about the harmful effects of tobacco, alcohol, and drug use in the context of asthma. The interventionist was able to tailor counseling to the participants' prescribed asthma medications. Additionally, each participant completed two 1-hour computer-based (CD-ROM) educational modules. Module 1 was an interactive decisionmaking module that depicted 17 different decisional situations, including smoking, alcohol, and “street” drug use. Module 2 was a noninteractive risk behavior module including information about smoking and alcohol only. Intervention boosters consisting of repeating the decisionmaking CD-ROM module and a workbook and a new interactive CD-ROM on substance use decisions were mailed at 2 and 4 months, respectively. Participants in the control group were given a sham CD-ROM program (“featuring study skills”) that ran for a comparable duration as the intervention modules. Intervention fidelity and participant adherence were also not reported. The Periodic Assessment of Drug Use was administered at baseline and 2-, 4-, and 6-month followup to assess the frequency and amount of smoking, alcohol, and illicit drug use.46 Illicit drug use risk was constructed by combining the average frequencies of seven types of illicit drugs during the past year, including marijuana; lysergic acid diethylamide (LSD) or other hallucinogens; cocaine/crack; glue or inhalants; tranquilizers; “uppers,” such as speed; or “downers,” such as sedatives or sleeping pills.47 The validity, reliability, and responsiveness to change of this surveillance instrument are unknown.48 After 6 months of followup, 85.4 percent of the sample was retained. In terms of risk-of-bias, it was unclear if allocation to condition was concealed or if outcome assessors were blinded, although several participants completed followup measures online.

Table 5 Results of Interventions in Included Trials, Drug Use Behavioral Outcomes

Author, Year Quality Rating | Setting and population (age) | Instrument | Primary Outcome Measure | F/U, m | IG N | IG Results | CG N | CG Results | Effect Size | Between-Group Difference, p-value
Primary care–based
Harris, 2012^38^ U.S. cohort Fair | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview | Any past marijuana use | BL | 765 | 12.4% | 758 | 13.3% | 0.77 (0.56, 1.05)^§^ | NSD
Harris, 2012^38^ U.S. cohort Fair | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview | Any past marijuana use | 12 | 765 | 15.6% | 757 | 17.5% | 0.85 (0.61, 1.19)^§^ | NSD
Harris, 2012^38^ U.S. cohort Fair | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview | Marijuana initiation║ | 12 | 670 | 7.8% | 656 | 8.8% | 0.81 (0.54, 1.21)^§^ | NSD
Harris, 2012^38^ U.S. cohort Fair | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview | Marijuana cessation^‡^ | 12 | 95 | 29.5% | 101 | 26.7% | 1.01 (0.57, 1.78)^§^ | NSD
Harris, 2012^38^ Czech Republic cohort Fair | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview | Any past marijuana use | BL | 264 | 14.4% | 266 | 13.6% | 1.02 (0.63, 1.64)^§^ | NSD
Harris, 2012^38^ Czech Republic cohort Fair | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview | Any past marijuana use | 12 | 264 | 17.0% | 265 | 28.7% | 0.47 (0.32, 0.71)^§^ | <0.05
Harris, 2012^38^ Czech Republic cohort Fair | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview | Marijuana initiation║ | 12 | 226 | 9.7% | 229 | 20.5% | 0.47 (0.29, 0.76)^§^ | <0.05
Harris, 2012^38^ Czech Republic cohort Fair | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview | Marijuana cessation^‡^ | 12 | 38 | 39.5% | 36 | 19.4% | 2.53 (1.06, 6.05)^§^ | <0.05
Rhee, 2008^39^ Fair | Research center Adolescents with asthma (14–20 years) | Periodic Assessment of Drug Use | Illicit drug use risk score^*^, mean (SD) | BL | 20 | 2.10 (9.16) | 21 | 4.05 (10.63) | NR | NSD
Rhee, 2008^39^ Fair | Research center Adolescents with asthma (14–20 years) | Periodic Assessment of Drug Use | Illicit drug use risk score^*^, mean (SD) | 6 | 17^¶^ | 0.63 (1.37) | 18^¶^ | 3.31 (9.4) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Marijuana use frequency, past 3 months, mean (SD)^**^ | BL | 118 | 3.1 (1.9) | 110 | 3.3 (1.9) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Marijuana use frequency, past 3 months, mean (SD)^**^ | 6 | 102 | 2.4 (2.1) | 97 | 2.0 (2.1) | 0.25 (0.14)^††^ | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Marijuana use frequency, past 3 months, mean (SD)^**^ | 12 | 104 | 2.6 (2.2) | 94 | 2.1 (2.2) | 0.15 (0.14)^††^ | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Other drug use frequency, past 3 months, mean (SD)^**^ | BL | 118 | 0.5 (1.3) | 110 | 1.2 (2.7) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Other drug use frequency, past 3 months, mean (SD)^**^ | 6 | 102 | 0.3 (0.9) | 97 | 1.2 (4.6) | -0.48 (0.42)^††^ | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Other drug use frequency, past 3 months, mean (SD)^**^ | 12 | 104 | 0.4 (1.7) | 94 | 0.6 (2.1) | 0.33 (0.51)^††^ | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Marijuana use frequency, past 3 months, mean (SD)^**^ | BL | 100 | 3.1 (1.9) | 110 | 3.3 (1.9) | NR | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Marijuana use frequency, past 3 months, mean (SD)^**^ | 6 | 79 | 2.0 (2.1) | 97 | 2.0 (2.1) | 0.08 (0.16)^††^ | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Marijuana use frequency, past 3 months, mean (SD)^**^ | 12 | 77 | 2.0 (2.2) | 94 | 2.1 (2.2) | -0.03 (0.16)^††^ | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Other drug use frequency, past 3 months, mean (SD)^**^ | BL | 100 | 0.9 (3.0) | 110 | 1.2 (2.7) | NR | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Other drug use frequency, past 3 months, mean (SD)^**^ | 6 | 79 | 0.1 (0.5) | 97 | 1.2 (4.6) | -1.41 (0.52)^††^ | <0.01^†^
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Add Health | Other drug use frequency, past 3 months, mean (SD)^**^ | 12 | 77 | 0.5 (2.1) | 94 | 0.6 (2.1) | 0.21 (0.48)^††^ | NSD
Computer-based
Schinke, 2009a40 Fair | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | BL | 252 | 0.08 (0.01) | 339 | 0.08 (0.02) | NR | NSD
Schinke, 2009a40 Fair | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | 12 | 205 | 0.10 (0.13) | 327 | 0.20 (0.65) | NR | <0.01^†^
Schinke, 2009a40 Fair | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs (for nonmedical use), use occasions in the past 30 days, mean (SD) | BL | 252 | 0.21 (0.96) | 339 | 0.10 (0.47) | NR | NSD
Schinke, 2009a40 Fair | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs (for nonmedical use), use occasions in the past 30 days, mean (SD) | 12 | 205 | 0.06 (0.46) | 327 | 0.17 (1.58) | NR | <0.0001^†^
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | BL | 458 | 0.08 (0) | 458 | 0.09 (0) | NR | NSD
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | 12 | 434^¶^ | 0.09 (0) | 430^¶^ | 0.11 (0.2) | NR | ---
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | 24 | 415^¶^ | 0.10 (0.1) | 413^¶^ | 0.20 (0.7) | NR | <0.016^†^
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs, use occasions in the past 30 days, mean (SD) | BL | 458 | 0.12 (0.2) | 458 | 0.09 (0.1) | NR | NSD
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs, use occasions in the past 30 days, mean (SD) | 12 | 434^¶^ | 0.09 (0) | 430^¶^ | 0.10 (0.1) | NR | ---
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs, use occasions in the past 30 days, mean (SD) | 24 | 415^¶^ | 0.09 (0.1) | 413^¶^ | 0.11 (0.2) | NR | <0.03^†^
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Inhalants, use occasions in the past 30 days, mean (SD) | BL | 458 | 0.04 (0.3) | 458 | 0.01 (0.1) | NR | NSD
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Inhalants, use occasions in the past 30 days, mean (SD) | 12 | 434^¶^ | 0.02 (0.2) | 430^¶^ | 0.04 (0.3) | NR | ---
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Inhalants, use occasions in the past 30 days, mean (SD) | 24 | 415^¶^ | 0.02 (0.1) | 413^¶^ | 0.03 (0.2) | NR | <0.024^†^
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | BL | 56 | 0.01 (0.12) | 52 | 0.04 (0.19) | NR | NR
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | 12 | 54 | 0 (0) | 50 | 0.12 (0.32) | NR | ---
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Marijuana, use occasions in the past 30 days, mean (SD) | 24 | 50 | 0 (0) | 43 | 0.17 (0.38) | NR | 0.043^†^
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs, use occasions in the past 30 days, mean (SD) | BL | 56 | 0.64 (2.98) | 52 | 0.46 (1.64) | NR | NR
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs, use occasions in the past 30 days, mean (SD) | 12 | 54 | 0.07 (0.32) | 50 | 1.6 (7.15) | NR | ---
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Prescription drugs, use occasions in the past 30 days, mean (SD) | 24 | 50 | 0 (0) | 43 | 3.6 (12.99) | NR | 0.047^†^

* Illicit drug use was constructed by combining the average frequencies of 7 types of illicit drugs in the past year, including marijuana; lysergic acid diethylamide (LSD) or other hallucinogens; cocaine/crack; glue or inhalants; tranquilizers; “uppers,” such as speed; or “downers,” such as sedatives or sleeping pills.

† Time × intervention group interaction effects.

‡ Cessation analyzed only participants reporting any past-12-month use at baseline.

§ Adjusted relative risk ratio (95% confidence interval). In the U.S. cohort, adjusted by multisite sampling, baseline past-12-month substance use, age, sex, parent education level, type of visit, perceived parent, sibling and peer substance use, provider sex, and connectedness to provider. In the Czech Republic cohort, adjusted by multisite sampling, baseline past-12-month substance use, age, and sex.

║ Initiation analyzed only participants reporting no past-12-month use at baseline.

¶ N is assumed.

** 7-point scale: 0 = never; 1 = 1–2 days; 2 = once a month or less; 3 = 2–3 days per month; 4 = 1–2 days per week; 5 = 3–5 days per week; 6 = every day or almost every day. Other drugs included inhalants, cocaine, and sedatives.

†† Effect estimate (SE).

Abbreviations: BL = baseline; CG = control group; F/U = followup; IG = intervention group; NR = not reported; NSD = no significant difference; SD = standard deviation; SE = standard error.

Table 6 Results of Interventions in Included Trials, Alcohol and Cigarette Behavioral Outcomes

Author, Year Quality Rating | Setting and population (age) | Instrument | Primary Outcome Measure | F/U, m | IG N | IG Results | CG N | CG Results | Effect Size | Between-Group Difference, p-value
Primary care–based
Harris, 2012^38^ U.S. cohort | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview (frequency of use) | Any past alcohol use | BL | 765 | 25.4% | 758 | 31.7% | 0.82 (0.64, 1.06)^§^ | NSD
Harris, 2012^38^ U.S. cohort | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview (frequency of use) | Any past alcohol use | 12 | 765 | 29.3% | 758 | 37.5% | 0.73 (0.57, 0.92)^§^ | <0.05
Harris, 2012^38^ U.S. cohort | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview (frequency of use) | Alcohol initiation║ | 12 | 571 | 11.9% | 518 | 17.8% | 0.66 (0.47, 0.93)^§^ | <0.05
Harris, 2012^38^ U.S. cohort | Primary care practices Adolescents (12–18 years) | 12-month timeline followback interview (frequency of use) | Alcohol cessation^‡^ | 12 | 194 | 19.6% | 240 | 20.0% | 1.50 (0.93, 2.42)^§^ | NSD
Harris, 2012^38^ Czech Republic cohort | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview (frequency of use) | Any past alcohol use | BL | 264 | 58.0% | 266 | 61.3% | 0.89 (0.76, 1.03)^§^ | NSD
Harris, 2012^38^ Czech Republic cohort | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview (frequency of use) | Any past alcohol use | 12 | 264 | 70.1% | 266 | 74.8% | 0.96 (0.86, 1.04)^§^ | NSD
Harris, 2012^38^ Czech Republic cohort | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview (frequency of use) | Alcohol initiation║ | 12 | 111 | 33.3% | 103 | 43.7% | 0.76 (0.53, 1.08)^§^ | NSD
Harris, 2012^38^ Czech Republic cohort | Primary care practices Adolescents (13–17 years) | 12-month timeline followback interview (frequency of use) | Alcohol cessation^‡^ | 12 | 153 | 3.3% | 163 | 5.5% | 1.18 (0.37, 3.73)^§^ | NSD
Rhee, 2008^39^ | Research center Adolescents with asthma (14–20 years) | Periodic Assessment of Drug Use | Smoking risk score^*^, mean (SD) | BL | 20 | 1.05 (3.06) | 21 | 1.26 (4.39) | NR | NR
Rhee, 2008^39^ | Research center Adolescents with asthma (14–20 years) | Periodic Assessment of Drug Use | Smoking risk score^*^, mean (SD) | 6 | 17^¶^ | 1.28 (4.99) | 18^¶^ | 1.69 (3.82) | NR | NSD
Rhee, 2008^39^ | Research center Adolescents with asthma (14–20 years) | Periodic Assessment of Drug Use | Alcohol risk score^**^, mean (SD) | BL | 20 | 8.40 (22.40) | 21 | 41.52 (161.54) | NR | NR
Rhee, 2008^39^ | Research center Adolescents with asthma (14–20 years) | Periodic Assessment of Drug Use | Alcohol risk score^**^, mean (SD) | 6 | 17^¶^ | 18.38 (44.98) | 18^¶^ | 7.0 (21.01) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Alcohol Use Disorder Test | Alcohol use frequency, past 3 months, mean (SD)^††^ | BL | 118 | 0.8 (0.9) | 100 | 1.0 (1.1) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Alcohol Use Disorder Test | Alcohol use frequency, past 3 months, mean (SD)^††^ | 12 | 104 | 0.9 (1.0) | 94 | 0.8 (1.0) | 0.37 (0.19)^‡‡^ | 0.05
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Alcohol Use Disorder Test | Alcohol use frequency, past 3 months, mean (SD)^††^ | BL | 100 | 0.9 (1.1) | 100 | 1.0 (1.1) | NR | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Alcohol Use Disorder Test | Alcohol use frequency, past 3 months, mean (SD)^††^ | 12 | 77 | 0.6 (0.8) | 94 | 0.8 (1.0) | -0.16 (0.20)^‡‡^ | NSD
Computer-based
Schinke, 2009a40 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | BL | 252 | 0.03 (0.24) | 339 | 0.03 (0.27) | NR | NSD
Schinke, 2009a40 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | 12 | 205 | 0.05 (0.50) | 327 | 0.11 (0.08) | NR | NSD^†^
Schinke, 2009a40 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | BL | 252 | 0.15 (0.17) | 339 | 0.16 (0.31) | NR | NSD
Schinke, 2009a40 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | 12 | 205 | 0.17 (0.32) | 327 | 0.31 (0.61) | NR | <0.05^†^
Schinke, 2009b41 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | BL | 458 | 1.02 (0.2) | 458 | 1.04 (0.3) | NR | NSD
Schinke, 2009b41 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | 12 | 434^¶^ | 1.02 (0.4) | 430^¶^ | 1.14 (1.2) | NR | ---
Schinke, 2009b41 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | 24 | 415^¶^ | 1.05 (0.5) | 413^¶^ | 1.39 (3.6) | NR | NSD^†^
Schinke, 2009b41 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | BL | 458 | 0.14 (0.2) | 458 | 0.18 (0.3) | NR | NSD
Schinke, 2009b41 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | 12 | 434^¶^ | 0.15 (0.2) | 430^¶^ | 0.25 (0.5) | NR | ---
Schinke, 2009b41 | Home Adolescent girls (11–13 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | 24 | 415^¶^ | 0.17 (0.3) | 413^¶^ | 0.33 (0.7) | NR | <0.006^†^
Fang, 2010^36,37^ | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | BL | 56 | 0.07 (0.42) | 52 | 0.17 (0.88) | NR | NR
Fang, 2010^36,37^ | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | 12 | 54 | 0.02 (0.13) | 50 | 0.44 (1.58) | NR | ---
Fang, 2010^36,37^ | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Cigarettes, use occasions in the past 30 days, mean (SD) | 24 | 50 | 0.02 (0.14) | 43 | 1.95 (9.87) | NR | NSD^†^
Fang, 2010^36,37^ | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | BL | 56 | 0.04 (0.19) | 52 | 0.29 (0.80) | NR | NR
Fang, 2010^36,37^ | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | 12 | 54 | 0.04 (0.18) | 50 | 0.54 (1.51) | NR | ---
Fang, 2010^36,37^ | Home Asian American girls (11–14 years) and their mothers | American Drug and Alcohol Survey | Alcohol, use occasions in the past 30 days, mean (SD) | 24 | 50 | 0.05 (0.30) | 43 | 0.10 (2.94) | NR | 0.038^†^

* Smoking risk based on the number of cigarettes per day in the past 30 days.

† Time × intervention group interaction effects.

‡ Cessation analyzed only participants reporting any past-12-month use at baseline.

§ Adjusted relative risk ratio (95% confidence interval). In the U.S. cohort, adjusted by multisite sampling, baseline past-12-month substance use, age, sex, parent education level, type of visit, perceived parent, sibling and peer substance use, provider sex, and connectedness to provider. In the Czech Republic cohort, adjusted by multisite sampling, baseline past-12-month substance use, age, and sex.

║ Initiation analyzed only participants reporting no past-12-month use at baseline.

¶ N is assumed.

** Alcohol use risk computed by multiplying the combined frequency of all 3 types of alcohol (beer, wine, and liquor) by the average quantity of drink per occasion in the past year.

†† 5-point scale: 0=never, 1=less than monthly, 2=monthly, 3=weekly, 4=daily.

‡‡ Generalized estimating equations analyses comparing intervention vs. control by time, estimate (SE).

Abbreviations: BL = baseline; CG = control group; F/U = followup; IG = intervention group; NR = not reported; NSD = no significant difference; SD = standard deviation; SE = standard error.

The third fair-quality study, conducted by Walton and colleagues and published in 2013, evaluated the effectiveness of two different brief interventions designed to reduce marijuana use and its consequences in adolescents ages 12 to 18 years.42 All patients visiting one of seven Federally Qualified Community Health Clinics were screened for marijuana use (n=1,146) and subsequently randomly assigned to one of the intervention arms or control if they reported any past-year marijuana use (n=328). Both intervention arms implemented a brief intervention: one was therapist-led (n=118) and the other was computer-based (n=100). The interventions incorporated motivational interviewing and included tailored, parallel content. The therapist-led intervention was facilitated by a research therapist trained in motivational interviewing. The computer-based intervention was a stand-alone interactive program that participants completed on a computer tablet at the clinic. Control group participants (n=110) received a brochure containing information on the harms of marijuana use and resources about substance abuse treatment and other leisure activities. Both interventions took approximately 35 to 40 minutes to administer (therapist-led: mean, 41 minutes; computer-based: mean, 34 minutes).49 About two thirds of the sample was female, more than 60 percent was African American, and the average age was 16 years. At baseline, 100 percent reported past-year marijuana use (required to be eligible). More than 90 percent reported having experienced some negative consequence related to their marijuana use and 21 percent reported driving while under the influence of marijuana in the past 3 months. Twenty percent of participants reported other drug use besides marijuana and about half reported alcohol use in the past 3 months. Past-3-month frequency of marijuana and other drug use (i.e., inhalants, cocaine, heroin, other hallucinogens, and the nonmedical use of painkillers/opioids, stimulants, and sedatives) was measured using items adapted from the Add Health survey.50 Response choices were on a 7-point scale and ranged from 0 = never to 6 = every day or almost every day (see Table 5 for a full description of the scale). In addition, more than 80 percent of the sample provided a urine drug screen at each time point to determine concordance with the marijuana use self-report measures. Concordance was generally high at baseline (100%), 3 months (96.1%), 6 months (96.8%), and 12 months (98.5%). Given the low rates of discordance and fairly equal distribution of discordance across groups, reported outcomes were based on self-report. Marijuana-related consequences in the past 3 months included 28 items that addressed issues such as interpersonal consequences (e.g., “got in a fight”) and symptoms of a substance use disorder (e.g., “kept smoking when you promised yourself not to”). The scale was based on the Rutgers Alcohol Problem index (23 items, 5-point scale) and Severity of Dependence Scale (5 items, 4-point scale), with a range from 0 to 107. A single item on a 5-point scale assessed the frequency of driving under the influence of marijuana in the past 3 months. This study had minimal threats to internal validity; the one concern was somewhat high attrition. At 12 months, 84 percent of the sample provided followup data, with 88, 77, and 86 percent retention in the therapist-led, computer-based, and control groups, respectively.

#### Computer-Based Interventions

We included three RCTs that evaluated the effectiveness of the same computer-based prevention program for reducing substance use in adolescent girls, reported in four publications.36,37,40,41 The same group of authors conducted all three studies (Tables 3 and 4). The primary differences between the studies were the sample characteristics.

All three studies implemented the same computer-based (i.e., Internet or CD-ROM) intervention designed for mother–daughter dyads. The intervention was based on family interaction theory and intervention objectives for the mothers were to improve communication with their daughters, monitor their daughters' behaviors and activities, build their daughters' self-image and self-esteem, establish rules and consequences for substance use, and create family rituals. For the daughters, the program focused on building skills for managing stress, conflict, and mood; refusing peer pressure; and improving body esteem and self-efficacy. Mother–daughter dyads were asked to work together to complete nine 45-minute (once per week over 9 weeks) interactive sessions in their homes. Participants could not advance to the next program session unless the mother and daughter each answered questions correctly during the prior session. Additionally, only the dyads that had completed all nine program sessions could complete followup measures. Thus, the proportion of dyads that provided followup data reflects participants who had high compliance with the intervention. Two of the studies also included one36,37 or two41 45-minute annual booster sessions that were assumed to also be computer-based and similar in content, although this was not reported. Control group participants received no intervention.

The samples within each study varied in size and demographic factors. The smaller 2009 “pilot” study conducted by Schinke et al,40 for example, randomized 591 pairs of adolescent girls ages 11 to 13 years and their mothers from three northeastern U.S. states. These pairs were recruited through advertisements posted in local newspapers, online, in subway trains and buses, and broadcast on the radio. Nearly three quarters of the girls were of nonwhite race (48.9% African American and 24.7% Latina). The larger (n=916) 2009 study by the same authors also included pairs of adolescent girls ages 11 to 13 years and their mothers recruited similarly from the same three U.S. states.41 Similarly, just over three quarters of the girls were of nonwhite race (40.6% African American, 23.1% Latina, 10.8% Asian, and 1.7% other). These two studies utilized two distinct samples within the same time frame.51 In comparison, the study lead by Fang et al exclusively recruited and randomized 108 Asian American girls ages 11 to 14 years and their mothers within 19 U.S. states.36,37 Approximately one fifth of the girls and over half of the mothers were born outside of the United States.

All three studies used the American Drug and Alcohol Survey self-report instrument to measure girls' substance use at baseline and followup (Tables 5 and 6).52 This instrument has been shown to have an internal consistency of 0.72 to 0.94,^41, 40^ although no data on its validity or sensitivity to change has been published. All measures were administered online. In terms of substance use, all three studies measured the number of “use occasions” in the past 30 days in which girls had used marijuana, prescription drugs for nonmedical purposes, alcohol, and cigarettes. One study also reported past-30-day use occasions of inhalants.41 A use occasion score of 1.0 indicates a single use occasion of the respective substance in the past 30 days. At baseline, the number of use occasions for all substances was less than 1, indicating very low use, except for one study41 that reported 1.16 mean use occasions of alcohol and 1.03 mean use occasions of cigarettes at baseline (Table 6). These studies did not report the prevalence of use in participants.

Two of the studies were rated good quality36,41 and the other was rated fair quality.40 While all three studies had more than 90 percent sample retention at 6 to 12 months, the one study rated as fair had more than 15 percentage points differential attrition between groups (i.e., retention in the intervention group at 12 months was 81.3%, whereas it was 96.5% in the control group).40 Two studies reported statistically significant differences in demographic characteristics or substance use behaviors between the groups at baseline, but both controlled for these differences in the analysis.

### Summary of Results

Four of six trials reported some type of health outcome and findings were modest, mixed, or otherwise limited. One fair-quality, primary care–based study found no effects of either a therapist-led or computer-based brief intervention on self-reported marijuana-related consequences or driving under the influence of marijuana compared with the control group at 6 or 12 months. Each of the three trials of the computer-based intervention reported depression outcomes, and only one found greater improvement in the intervention group compared with the control group at 6 months only. All six trials reported some type of substance use outcome. Four of the five studies reporting marijuana use found statistically significant differences in favor of the intervention group compared with the control group. The three computer-based trials also reported differences in nonmedical prescription drug use occasions. Individual studies reported additional substance use outcomes with mixed results. No studies reported on harms of the interventions.

### Detailed Results

#### Morbidity, Mortality, and Other Health, Social, and Legal Outcomes (KQ 1)

One primary care–based study42 and all three computer-based studies36,37,40,41 reported health outcomes from behavioral interventions to decrease substance use. In the primary care–based study by Walton and colleagues, the number of marijuana-related consequences significantly decreased in participants receiving the computer-based intervention at 3 and 6 months, while participants in the therapist-led group showed statistically significant decreases at 6 and 12 months; there were no significant decreases seen in the control group.42 No statistically significant group-by-time interactions were seen at 6 or 12 months for either the computer-based or therapist-led groups compared with the control group (Table 7).

Table 7 Results of Interventions of Included Studies, Marijuana-Related Consequences and Driving Under the Influence

Author, Year Quality Rating | Setting and population (age) | Instrument | Primary Outcome Measure | F/U, m | IG N | IG Results | CG N | CG Results | Effect Size (SE) | Between-Group Difference, p-value
Primary care–based
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Modified Rutgers Alcohol Problems Index (23 items) and Severity of Dependence Scale (5 items) | Number of marijuana-related consequences, past 3 months, mean (SD)^*^ | BL | 118 | 14.2 (15.3) | 100 | 14.0 (15.0) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Modified Rutgers Alcohol Problems Index (23 items) and Severity of Dependence Scale (5 items) | Number of marijuana-related consequences, past 3 months, mean (SD)^*^ | 6 | 102 | 11.3 (12.9) | 97 | 11.0 (13.6) | -0.08 (0.15) | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Modified Rutgers Alcohol Problems Index (23 items) and Severity of Dependence Scale (5 items) | Number of marijuana-related consequences, past 3 months, mean (SD)^*^ | 12 | 104 | 11.1 (13.0) | 94 | 11.5 (14.4) | -0.07 (0.15) | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Single item | Driving under the influence of marijuana frequency, past 3 months, mean (SD)^†^ | BL | 118 | 0.4 (0.9) | 100 | 0.3 (0.7) | NR | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Single item | Driving under the influence of marijuana frequency, past 3 months, mean (SD)^†^ | 6 | 102 | 0.3 (0.8) | 97 | 0.4 (0.9) | -0.68 (0.41) | NSD
Walton, 2013^42^ (Therapist-led brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Single item | Driving under the influence of marijuana frequency, past 3 months, mean (SD)^†^ | 12 | 104 | 0.3 (0.9) | 94 | 0.3 (0.9) | -0.32 (0.41) | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Modified Rutgers Alcohol Problems Index (23 items) and Severity of Dependence Scale (5 items) | Number of marijuana-related consequences, past 3 months, mean (SD)^*^ | BL | 100 | 14.3 (15.5) | 100 | 14.0 (15.0) | NR | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Modified Rutgers Alcohol Problems Index (23 items) and Severity of Dependence Scale (5 items) | Number of marijuana-related consequences, past 3 months, mean (SD)^*^ | 6 | 79 | 10.5 (13.6) | 97 | 11.0 (13.6) | -0.15 (0.16) | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Modified Rutgers Alcohol Problems Index (23 items) and Severity of Dependence Scale (5 items) | Number of marijuana-related consequences, past 3 months, mean (SD)^*^ | 12 | 77 | 12.7 (13.8) | 94 | 11.5 (14.4) | 0.08 (0.17) | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Single item | Driving under the influence of marijuana frequency, past 3 months, mean (SD)^†^ | BL | 100 | 0.5 (1.1) | 100 | 0.3 (0.7) | NR | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Single item | Driving under the influence of marijuana frequency, past 3 months, mean (SD)^†^ | 6 | 79 | 0.5 (1.1) | 97 | 0.4 (0.9) | -0.34 (0.37) | NSD
Walton, 2013^42^ (Computer-based brief intervention) Fair | Primary care clinics Adolescents (12–18 years) | Single item | Driving under the influence of marijuana frequency, past 3 months, mean (SD)^†^ | 12 | 77 | 0.5 (1.0) | 94 | 0.3 (0.9) | -0.17 (0.44) | NSD

* Rutgers Alcohol Problem index (23 items, 5-point scale) and Severity of Dependence Scale (5 items, 4-point scale), range: 0–107.

† 5-point scale: 0=never, 1=1–2 times, 2=3–5 times, 3=6–9 times, 4=10 or more times.

Abbreviations: BL = baseline; CG = control group; F/U = followup; IG = intervention group; NR = not reported; NSD = no significant difference; SD = standard deviation; SE = standard error.

All three computer-based studies compared differences in levels of depressed mood between the intervention and control groups at baseline and followup (Table 8).36,37,40,41 In one study, the intervention group reported less depressed mood than the control group at 6 months (p=0.045). This finding, however, did not hold true over 2 years.36,37 The other two studies did not find statistically significant differences between groups. No studies reported other health, social, or legal outcomes that might relate to drug use in children and adolescents, such as drug-related injuries or accidents, other risky behaviors (e.g., unprotected sex), educational attainment, or impaired driving.

Table 8 Results of Interventions of Included Studies, Depressed Mood Outcomes

Author, Year Quality Rating | Setting and population (age) | Instrument | Primary Outcome Measure | F/U, m | IG N | IG Results | CG N | CG Results | Time × Intervention Group Effect, p-value
Computer-based
Schinke, 2009a40 Fair | Home Adolescent girls (11–13 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | BL | 252 | 1.62 (0.77) | 339 | 1.71 (0.79) | NSD
Schinke, 2009a40 Fair | Home Adolescent girls (11–13 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | 12 | 205 | 1.52 (0.84) | 327 | 1.79 (0.80) | NSD
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | BL | 458 | 3.42 (0.7) | 458 | 3.28 (0.8) | <0.05
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | 12 | 434^†^ | 3.45 (0.8) | 430^†^ | 3.30 (0.8) | ---
Schinke, 2009b41 Good | Home Adolescent girls (11–13 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | 24 | 415^†^ | 3.48 (0.8) | 413^†^ | 3.23 (0.8) | NSD
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | BL | 56 | 1.36 (0.84) | 52 | 1.66 (0.62) | NR
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | 12 | 54 | 1.23 (0.71) | 50 | 1.71 (0.75) | ---
Fang, 2010^36,37^ Good | Home Asian American girls (11–14 years) and their mothers | Children's Depression Inventory | Depression, mean (SD)^*^ | 24 | 50 | 1.23 (0.87) | 43 | 1.67 (0.65) | NSD

* Scores are 5-item scales in which lower scores are better.

† N is assumed.

Abbreviations: BL = baseline; CG = control group; IG = intervention group; NR = not reported; NSD = no significant difference; SD = standard deviation.

#### Behavioral Outcomes (KQ 2)

Table 5 presents the results of each study according to the specific drug use outcome. The specific outcome measure varied across the studies. Four of the six studies found statistically significant differences in marijuana use at 12 to 24 months favoring the intervention group over the control group.36-38,40,41 In the cohort of U.S. adolescents in the study conducted by Harris and colleagues, there were lower rates of any marijuana use and marijuana initiation in intervention participants compared with control participants and higher rates of cessation at 12 months. These differences, however, were not statistically significant (Table 5). In contrast, in the Czech Republic cohort, 17.0 percent of participants in the intervention group reported past-12-month use of marijuana compared with 28.7 percent of control participants (risk ratio [RR], 0.47 [95% confidence interval [CI], 0.32 to 0.71]; p<0.05) at 12 months, after adjusting for multisite sampling; baseline past-12-month use; age; sex; parent education level; type of health care visit; perceived parent, sibling, and peer substance use; provider sex; and connectedness to provider.38 Similarly, statistically significantly fewer adolescents in the intervention group reported initiating marijuana use during the past 12 months compared with those in the control group who initiated marijuana use (9.7% vs. 20.5%; RR, 0.47 [95% CI, 0.29 to 0.76]; p<0.05). Likewise, more participants in the intervention group reported quitting marijuana use (39.5% vs. 19.4% in the intervention vs. control groups, respectively; RR, 2.53 [95% CI, 1.06 to 6.05]; p<0.05). The study by Rhee did not find that the intervention had a statistically significant effect on the mean illicit drug use risk score in adolescents with asthma at 6 months.39 In the Walton study, all three conditions showed significant decreases in the frequency of marijuana use over time; however, group-by-time interactions were not significant for marijuana use frequency for either the therapist-led or computer-based interventions. Regarding the frequency of other drug use, there was a significant effect of the computer-based intervention at 6 months, but not 12 months; there was no effect of the therapist-led intervention on other drug use at any time point.42

All three computer-based studies found statistically significant group-by-time effects in favor of the intervention in the number of marijuana use occasions in the past 30 days. As shown in Table 5, while marijuana use tended to increase in both the intervention and control groups over time, there was a statistically significant time-by-condition effect at 12^40^ and 24 months.37,41 Use occasions remained generally low for marijuana and inhalant use (i.e., <1.0 occasion per month) in both groups; however, instances of prescription drug use for nonmedical purposes increased at 12 months (1.6 use occasions) and 24 months (3.6 use occasions) in the control group in the study of Asian American girls.36,37

The three computer-based studies all reported statistically significant changes from baseline to 1- and 2-year followups favoring the intervention group over the control group in reduced nonmedical use of prescription drugs.37,40,41 Use occasions of prescription drugs were generally higher than marijuana for all three samples, although use was still generally low (range, 0.09 to 0.64 at baseline across groups). In all three studies, use occasions of prescription drugs decreased in the intervention group over time, whereas use increased in the control group. One of the studies41 also found that the intervention group reported fewer occasions of inhalant use than the control group (p<0.024).

Results related to alcohol use were generally consistent with the marijuana use outcomes (Table 6). All three computer-based studies found that girls receiving the intervention reported significantly fewer instances of using alcohol compared with girls in the control group.37,40,41 The study conducted by Harris and colleagues reported statistically significantly less alcohol use and initiation in adolescents in the intervention group compared with the control group in the U.S. cohort, and no significant differences among the adolescents in the Czech Republic. Interestingly, rates of any alcohol use in the Czech Republic were more than double the rates in the United States (59.6% vs. 28.5%).38 The recent study by Walton and colleagues42 found no effect of either intervention on past-3-month alcohol use frequency at any time point, and the study by Rhee also found no group differences for alcohol use outcomes after the intervention.39 None of the four studies that reported cigarette use found a statically significant positive effect of the intervention.

#### Subgroup Differences (KQs 1a, 2a)

No data were found to explore whether some subpopulations benefited more from drug use interventions than others. Three of the four studies that found positive effects for marijuana use only included younger girls (ages 11 to 14 years); one of these studies only included Asian American girls and the other two included racially diverse samples. None of the studies explored the effects of the intervention based on the participants' ages, risk level, or types or frequencies of substances used.

#### Elements of Efficacious Interventions (KQs 1b, 2b)

We qualitatively examined a number of specific intervention characteristics (e.g., computer-assisted interventions, hours of contact, role of primary care provider, individual targeted) and study design issues (e.g., measurement of drug use) to see if they were associated with effect size. All four studies that found positive effects for marijuana use included a computer-based intervention component; three of the four studies tested the same nine-session computer-based program that was completed by mother–daughter dyads. The other study utilized a computer-based screening and educational module followed by brief provider advice during one primary care visit. Given the small number and heterogeneity of included interventions, however, we do not believe there is a clear pattern that explains why some trials had beneficial effects and others did not.

#### Screening Criteria (KQs 1c, 2c)

Only one study screened participants for their history of drug use prior to enrolling them in the study. In this study, only adolescents who reported any past-year marijuana use were included. Adolescents who reported never using marijuana were enrolled in a prevention study. The three computer-based studies relied on volunteer samples recruited from the community and set no criteria for current or past drug use for eligibility to enroll in the trial.

## Key Question 3 What Are the Adverse Events of Primary Care–Relevant Behavioral Counseling Drug Use Interventions?

We identified no studies that reported adverse events related to interventions to reduce illicit drug use or nonmedical use of prescription drugs in children and adolescents.