# Methods

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an Analytic Framework (Figure 1) and three Key Questions (KQs) using the USPSTF's methods29 to guide the literature search, data abstraction, and data synthesis for this topic. The proposed Analytic Framework and KQs were posted on the USPSTF's Web site for public comment for 4 weeks. We revised the Analytic Framework and KQs based on public comment, with final approval by the USPSTF. We examined the following KQs:

1. Do primary care behavioral counseling interventions for drug use, with or without referral, improve mortality, morbidity, and other health, social, and legal outcomes in children and adolescents?
  a. Do outcomes differ in subgroups (e.g., as defined by age, risk level, sex, race, ethnicity, or types of substances used)?
  b. What are elements of efficacious interventions?
  c. What criteria are used to identify children and adolescents for primary care drug use interventions?
2. Do primary care behavioral counseling interventions for drug use, with or without referral, prevent drug use initiation in children and adolescents who do not currently use drugs or reduce drug use in children and adolescents who currently use drugs?
  a. Do outcomes differ in subgroups (e.g., as defined by age, risk level, sex, race, ethnicity, or types of substances used)?
  b. What are elements of efficacious interventions?
  c. What criteria are used to identify children and adolescents for primary care drug use interventions?
3. What are the adverse events of primary care behavioral counseling drug use interventions?

Figure 1 Analytic Framework

Figure 1 is the analytic framework that depicts the three Key Questions (KQs) addressed in the systematic review. The figure illustrates how interventions to prevent or reduce illicit drug use and the nonmedical use of prescription drugs may improve health, social, educational, and other outcomes (KQ 1) in children and adolescents (age 18 years or younger) who may or may not be currently using drugs. The figure also depicts how these interventions may also influence drug use behaviors, including reducing the frequency and/or quantity of use (KQ 2). The figure also depicts whether these interventions have any potential harms (KQ 3).

## Data Sources and Searches

In addition to reviewing the two trials specific to children and adolescents that were captured in the 2008 review,1 we searched MEDLINE, PubMed, PsycINFO, and the Cochrane Collaboration Registry of Controlled Trials for relevant publications through June 4, 2013 and MEDLINE through August 31, 2013 (Appendix A). Our searches were restricted to English-language publications published since January 1992. We chose this start date based on a 12-year decline in annual prevalence of adolescent illicit drug use from 1980 through 1992, with a sharp increase in 1993.^6^ This shift is referred to as the “relapse phase” in the drug epidemic. We also examined the reference lists of six relevant published reviews or meta-analyses30-35 and all of our included studies to identify other studies for inclusion. We also conducted grey literature searches of government agencies (e.g., AHRQ, SAMHSA), professional organizations (e.g., American Academy of Pediatrics), and other organizations (e.g., University of Washington Alcohol and Drug Abuse Institute) that sponsor or publish relevant research for synthesized evidence published outside of peer-reviewed journals. In addition, we searched for potentially relevant ongoing or recently completed studies in children and adolescents through ClinicalTrials.gov (http://www.clinicaltrials.gov/), Current Controlled Trials (http://www.controlled-trials.com), Australian New Zealand Clinical Trials Registry (http://www.anzctr.org.au), and the World Health Organization's International Clinical Trials Registry Platform (http://www.who.int/ictrp.en). We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts from sources such as ScienceDirect (Elsevier, Maryland Heights, MO), HighWire Press (Stanford University Libraries, Palo Alto, CA), and Pediatrics.

We managed our literature search results using version 12.0 of Reference Manager^®^ (Thompson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

Two investigators independently evaluated 2,253 abstracts for potential inclusion against prespecified eligibility criteria. Of these, we dually reviewed 144 full-text articles for possible inclusion in this review (Appendix A Figure 1). Full-text articles that were excluded are listed in Appendix B, including the specific reason for exclusion. We resolved reviewer discrepancies through discussion or consultation with the larger project team. Detailed inclusion and exclusion criteria are provided in Appendix A Table 1 and are discussed below.

We included randomized, controlled trials (RCTs) or controlled (nonrandomized) clinical trials designed to prevent or reduce drug use in children and adolescents (no lower age restriction to 18 years) published in English in or after 1992. We excluded studies conducted in treatment-seeking children or adolescents or those that were mandated or directly referred to substance abuse or dependence treatment via the juvenile justice system, social services, parents, or a similar referral system. We also excluded trials in which more than half of the sample was diagnosed with substance abuse or dependence or a drug use disorder. Included interventions targeted children or adolescents or their parents and were delivered individually or in small groups. We examined trials conducted in primary care or that were potentially feasible to conduct in primary care, with or without referral to specialty treatment services. This included interventions delivered exclusively through electronic media (e.g., Web-based, CD-ROMs) that were not linked to health care. We describe these trials collectively as “primary care–relevant.” We excluded trials evaluating the effects of detoxification or medically managed withdrawal, inpatient or residential treatment, and broad public health or policy interventions. Trials had to take place in a primary care setting or ED. Other settings were included, however, if the study was linked to primary care or health care (e.g., recruitment in clinics), such as research clinics/offices, community centers, or participants' homes. We excluded interventions that took place in substance abuse treatment centers, schools, worksites, and other institutions, such as juvenile detention centers, as they were seen as not generalizable to primary care. Studies had to take place in “very high” developed countries as defined by the 2011 Human Development Index of the United Nations Development Programme. Included trials had control arms that offered minimal or no intervention or an attention-control arm. Trials were only eligible if they reported a health, social, legal, or drug use outcome or a harm of the intervention at least 6 months after the baseline assessment. Given the volatile nature of behaviors in youth, outcomes reported at less than 6 months may not be truly reflective of intervention effects.

## Quality Assessment and Data Abstraction

We used predefined criteria developed by the USPSTF to assess the quality of all trials meeting our inclusion criteria.29 Two investigators independently assessed the quality, resulting in a rating of “good,” “fair,” or “poor” (see Appendix A Table 2 for quality criteria). We examined potential risks of bias, including randomization procedures and measurement procedures (including blinding and consistency between groups); comparability of the groups at baseline; overall and group-specific attrition; intervention fidelity and participant adherence; and the appropriateness of the statistical procedures, including methods for handling missing data. In general, a good-quality study employed valid randomization methods, including concealing treatment allocation, included comparable groups at baseline or appropriately adjusted for potential confounders in the analysis, had followup data on 90 percent or more of participants, and used reliable measures of drug use. Trials were rated as “poor” if attrition was greater than 40 percent; attrition in the intervention and control groups differed by more than 20 percentage points; or there were other important flaws, such as noncomparable groups at baseline. Studies that reported 10 to 20 percent differential attrition were categorized as fair. We excluded poor-quality studies from this review. We resolved differences in quality rating through discussion.

After quality rating, we abstracted data from all included studies into a standard evidence table. One reviewer abstracted data from all good- and fair-quality studies and a second reviewer checked the abstracted data for accuracy. We collected the following information for each study, where available: study characteristics (e.g., setting), recruitment methods, and eligibility criteria; study population, including the number of participants included/randomized and demographic characteristics; intervention and control descriptions; followup rates; and outcomes.

## Data Synthesis and Analysis

We summarized all included studies in narrative form and summary tables that detail the important features of the study populations, design, intervention, outcomes, and results. We reported the risk ratio and between-group differences that were reported by the included studies, where available. We identified too few trials and too much variability in a number of factors to conduct any pooled analysis. Instead, we conducted a qualitative analysis for all KQs and stratified the results into two groups based on the type of intervention: 1) primary care–based and 2) computer-based. Primary care–based studies recruited directly from or were conducted in primary care clinics. Computer-based interventions only used electronic modes of intervention delivery (e.g., Web-based or CD-ROM) and were not conducted in primary care. We discuss the outcomes for the two groups separately. Within each group, we qualitatively explored patterns of association between group differences and the following factors: the type of intervention, the mode and duration of the intervention, and the substance or substances targeted.

## Expert Review and Public Comment

A draft of the Analytic Framework, KQs, and inclusion/exclusion criteria was posted on the USPSTF's Web site for public comment from January 15 to February 11, 2013. We received comments from 14 individuals, including eight individuals providing comments on behalf of their organization. All comments were reviewed and addressed as appropriate. A final research plan was posted on the USPSTF's Web site on May 9, 2013. The full draft report was reviewed by experts and Federal partners from May 31 through June 14, 2013. We compiled and addressed (where appropriate) the comments received from invited reviewers. Additionally, a draft of the full report was posted on the USPSTF's Web site from October 1 through October 28, 2013. A few comments were received during this public comment period; there were no major changes made. All minor, editorial suggestions were addressed as appropriate.

## USPSTF Involvement

We worked with four USPSTF liaisons at key points throughout this review, particularly when developing the Analytic Framework, KQs, and scope of the review. The USPSTF liaisons approved the final Analytic Framework, KQs, and inclusion/exclusion criteria after revisions reflecting the public comment period. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.