# Introduction

## Scope and Purpose

In 2008, the U.S. Preventive Services Task Force (USPSTF) concluded that there was insufficient evidence to recommend for or against screening adolescents, adults, and pregnant women for illicit drug use. This recommendation was based on a staged evidence review1 of the literature published between 1994 and April 2006 and a 2008 supplemental assessment of screening instruments done on behalf of the USPSTF.2 The staged review only included research related to screening or treatment for marijuana, cocaine, or opioids and included evidence for children and adolescents, adults, and pregnant women. In contrast, the current systematic review focuses specifically on: 1) behavioral interventions that are considered feasible for primary care; 2) the primary prevention and reduction of all illicit drugs, including the nonmedical use of prescription drugs; and 3) children and adolescents age 18 years and younger only who do not meet criteria for substance abuse or dependence. The objective of this review is to systematically review evidence for the benefits and harms of primary care–relevant behavioral interventions designed to reduce illicit drug use or the nonmedical use of prescription drugs in children and adolescents.

## Condition Definition

Substance use typically refers to substances that affect mental processes (e.g., cognition, affect) when ingested, inhaled, injected, or taken through other administration routes. These substances have psychoactive properties and can include licit and illicit substances, such as alcohol; tobacco; marijuana; prescription drugs, including opioids and morphine derivatives; depressants; and stimulants. In this review, we focus on illicit drug use and the nonmedical use of prescription and over-the-counter drugs. We did not review the evidence related to alcohol, tobacco, and nonpsychoactive drugs (e.g., anabolic steroids or laxatives). Nonmedical use (also known as “extramedical use”) refers to using a prescription or over-the-counter drug in ways other than prescribed (i.e., more frequently or for a longer duration) or by people other than the prescribed individual. Individuals generally use these substances to “get high” or for other unapproved indications.

An individual's substance use can range from abstinence to dependency or addiction (Table 1). In this review, we are specifically interested in interventions that aim to prevent (i.e., primary prevention prior to any use) or reduce drug use in children and adolescents who have experimented with drug use, have limited drug use, or have problematic/harmful drug use. We did not review the evidence on interventions designed to reduce drug use in children and adolescents who are diagnosed with substance abuse or substance dependence according to the Diagnostic and Statistical Manual of Mental Disorders (4th edition) or similar criteria.3 The distinction between problematic use and abuse is somewhat ambiguous clinically. Problematic use is often associated with use of the substance in high-risk situations, such as driving a car, or is associated with problems such as a school suspension. Diagnosed abuse, on the other hand, reflects recurrent problems associated with use that interferes with functioning.

Table 1 Stages of Substance Use in Children and Adolescents

Stage of use | Description
No use/abstinence | The time before an individual has ever used drugs or alcohol (more than a few sips)
Experimentation | The first 1 to 2 times that a substance is used and the adolescent wants to know how intoxication from using a certain drug(s) feels (sometimes also refers to extremely infrequent or nonpersistent use)
Limited use | Use together with ≥1 friends in relatively low-risk situations and without related problems; typically, use occurs at predictable time, such as on weekends
Problematic/harmful use | Use in a high-risk situation, such as when driving or babysitting; use associated with a problem such as a fight, arrest, or school suspension; or use for emotional regulation, such as to relieve stress or depression
Substance abuse | Drug use associated with recurrent problems or that interferes with functioning, as defined in the DSM-IV-TR. A maladaptive pattern of substance use leading to clinically significant impairment or distress as manifested by one (or more) of the following, occurring within a 12-month period:; 1. Recurrent substance use resulting in a failure to fulfill major role obligations at work, school, or home (such as repeated absences or poor work performance related to substance use; substance-related absences, suspensions, or expulsions from school; or neglect of children or household); 2. Recurrent substance use in situations in which it is physically hazardous (such as driving an automobile or operating a machine when impaired by substance use); 3. Recurrent substance-related legal problems (such as arrests for substance-related disorderly conduct); 4. Continued substance use despite having persistent or recurrent social or interpersonal problems caused or exacerbated by the effects of the substance (for example, arguments with spouse about consequences of intoxication and physical fights)
Substance addiction (dependence) | Loss of control or compulsive drug use, as defined in the DSM-IV-TR as “dependence.” A maladaptive pattern of substance use leading to clinically significant impairment or distress, as manifested by three (or more) of the following, occurring any time in the same 12-month period:; 1. Tolerance, as defined by either of the following: a) A need for markedly increased amounts of the substance to achieve intoxication or the desired effect or b) Markedly diminished effect with continued use of the same amount of the substance; 2. Withdrawal, as manifested by either of the following: a) The characteristic withdrawal syndrome for the substance or b) The same (or closely related) substance is taken to relieve or avoid withdrawal symptoms; 3. The substance is often taken in larger amounts or over a longer period than intended; 4. There is a persistent desire or unsuccessful efforts to cut down or control substance use; 5. A great deal of time is spent in activities necessary to obtain the substance, use the substance, or recover from its effects; 6. Important social, occupational, or recreational activities are given up or reduced because of substance use; 7. The substance use is continued despite knowledge of having a persistent physical or psychological problem that is likely to have been caused or exacerbated by the substance (for example, current cocaine use despite recognition of cocaine-induced depression or continued drinking despite recognition that an ulcer was made worse by alcohol consumption)
Secondary abstinence | Maintenance of abstinence or re-establishing abstinence after substance relapse

Adapted from Levy SJ, Kokotailo PK. Substance use screening, brief intervention, and referral to treatment for pediatricians. Pediatrics. 2011;128(5):e1330-40. [pmid: 22042818]. 23

## Prevalence

There are three main U.S. surveillance surveys that track trends in the prevalence of alcohol, tobacco, and other drug use in children and adolescents: 1) the annual National Survey of Drug Use and Health in children age 12 years and older, 2) the annual Monitoring the Future Study of students in grades 8, 10, and 12, and 3) the biannual Youth Risk Behavior Survey of students in grades 9 through 12. Substance use is typically reported as lifetime (or ever) use, use during the past year, use during the previous 30 days (often referred to as “current” use), daily use, or use over some other defined period of time (e.g., 14 or 90 days). Rates of current substance use over the past 5 years are similar in all three surveillance systems.4

According to the 2012 National Survey of Drug Use and Health, 9.5 percent of adolescents ages 12 to 17 years reported current (past month) illicit drug use—a rate that has remained steady since 2009.^4^ Marijuana and prescription psychotherapeutics (including pain relievers) are the most commonly used drugs among children and adolescents (Table 2). Nearly 7.2 percent of 12- to 17-year-olds reported current use of marijuana and an estimated 5.0 percent used marijuana for the first time within the past year.4 Consequences of prescription drugs used for nonmedical purposes are a quickly growing epidemic in the United States. These drugs include opioid pain relievers, central nervous system depressants, and stimulants and are the number one cause of unintentional drug overdose.5 In 2012, 2.8 percent of 12- to 17-year-olds reported using a prescription drug for nonmedical reasons; 2.2 percent of those individuals reported this to be opioid pain relievers.4

Table 2 Current (Past Month) Illicit Drug, Alcohol, and Cigarette Use, 2011 National Survey on Drug Use in Health

Illicit drug | All adolescents (12–17 years) | Male adolescents (12–17 years) | Female adolescents (12–17 years) | 12–13 years | 14–15 years | 16–17 years
Any illicit drug | 10.1 | 10.8 | 9.3 | 3.3 | 9.2 | 17.2
Marijuana | 7.9 | 9.0 | 6.7 | 1.3 | 6.7 | 15.1
Nonmedical use of any psychotherapeutic (pain relievers, specifically) | 2.8 (2.3) | 2.4 (1.9) | 3.2 (2.6) | 1.3 (1.1) | 2.6 (NR) | 4.2 (NR)
Cocaine | 0.3 | NR | NR | NR | NR | 0.5
Hallucinogens | 0.9 | NR | NR | NR | 0.8 | 1.6
Inhalants | 0.9 | NR | NR | 1.0 | 0.9 | 0.7
Alcohol | 13.3 | 13.3 | 13.3 | 2.5 | 11.5 | 25.3
Cigarettes | 7.8 | 8.2 | 7.3 | 1.4 | 6.0 | 15.4

Abbreviation: NR = not reported.

To put the rates of drug use in context with the use of other substances, in 2012 the rate of current alcohol use in youths ages 12 to 17 years was 12.9 percent and current cigarette use in this group was 6.6 percent. Illicit drug use was approximately 15 times higher in young persons who smoked cigarettes and drank alcohol during the past month (61.1%) than in those who neither smoked cigarettes nor drank alcohol during the past month (4.0%).4

Drug-use patterns differ between sex and race or ethnic groups. Males, for example, are more likely than females to have ever used or be current users of all types of drugs, except for ever use of inhalants.4,6,7 Black and Hispanic students, on the other hand, have a higher rate of having ever used marijuana than white students, with lifetime prevalence reported at 43.0, 42.1, and 37.9 percent, respectively. Cocaine, inhalant, heroin, and methamphetamine use was higher in Hispanic students than white and black students. The use of prescription drugs for nonmedical purposes, on the other hand, was higher in white (22.9%) students than black (14.7%) or Hispanic (19.4%) students. More white (9.3%) and Hispanic (9.1%) students report current use of hallucinogens than black (3.3%) students.7 There are also slight differences in illicit drug use by the type of county individuals reside in (i.e., urban or rural). Drug use is more common in urban and large metropolitan settings than any other areas.4

In 2012, approximately 7,900 individuals age 12 years and older initiated drugs every day, representing an estimated 2.9 million new users per year. Most first-time illicit drug users (55.1%) were younger than age 18 years. The average age at drug use initiation in 2012 was 17 years in 12- to 49-year-olds. In 2012, the majority (65.6%) of those who used illicit drugs for the first time during the past 12 months used marijuana as their first drug. The nonmedical use of psychotherapeutics was reported by 26.0 percent of new initiates as their first drug used (includes 17.0% with pain relievers, 4.1% with tranquilizers, 3.6% with stimulants, and 1.3% with sedatives). Inhalants were reported as the first drug used by 6.3 percent of new users, and hallucinogens by 2.0 percent of new initiates in 2012.^4^

The rate of illicit drug dependence or abuse in young persons ages 12 to 17 years in 2012 was 4.0 percent, which is a 1.6 percent decline from 2002, when 5.6 percent of 12- to 17-year-olds were diagnosed with substance dependence or abuse. The rate of substance dependence and abuse (alcohol and drugs) was the same for males and females in 2012 (6.1%). Individuals who initiate marijuana use at younger ages (i.e., age 14 years or younger) are more likely to develop drug dependence or abuse as adults than those who initiate marijuana use after age 18 years.8

## Burden

Drug use is associated with multiple negative health, social, and economic consequences. In 2010, for example, 64 percent of all deaths in young persons ages 1 to 24 years in the United States resulted from three causes: unintentional injuries, including motor vehicle accidents (38%); homicide (13%); and suicide (12%).9 The use of alcohol and other drugs is the primary health risk behavior that contributes to these leading causes of morbidity and mortality in adolescents and young adults.7 While experimentation with alcohol or marijuana are often incorrectly regarded as developmentally normative behaviors in adolescents, even infrequent use increases an individual's risk of serious adverse events due to an increase in risk-taking behaviors while intoxicated or impaired. Risky behaviors often do not occur in isolation. Indeed, alcohol, tobacco, and other drug use are commonly associated with other risky behaviors, such as driving under the influence, early and unsafe sexual activity, and interpersonal violence.

In 2009, the Drug Abuse Warning Network estimated that approximately 55,306 emergency department (ED) visits by adolescents ages 12 to 17 years involved illicit drugs (alone or in combination with alcohol and/or prescription drugs).10 Marijuana (182.2 visits per 100,000 individuals), cocaine (21.4 visits), ecstasy (17.5 visits) and stimulants (15.0 visits) were the most commonly reported illicit drugs that led to an ED visit by children and adolescents. The nonmedical use of prescription drugs was involved in over 66,000 ED visits by children and adolescents, with pain relievers (e.g., opioids) being the most commonly reported substance.

National tracking systems of fatal poisonings capture deaths due to drug use. These systems report that the majority of poisoning deaths are due to illicit and licit drugs (nine out of 10 poisoning deaths for all ages are caused by drugs). From 1999 to 2008, the drug poisoning death rate for the U.S. population ages 15 to 24 years increased from 3.2 per 100,000 to 8.2 per 100,000.^11^ Unintentional poisoning deaths (due to drugs and other substances) increased by 91 percent from 2000 to 2009 for those ages 15 to 19 years and by 36 percent for those ages 10 to 14 years.12

Drug use can also have deleterious effects on educational achievement and attainment. Cross-sectional and longitudinal studies show that students who dropped out of school or were at risk for dropping out of school had higher rates of marijuana use than students who remained in school or graduated. Studies that examined the relationship between other nonmarijuana drug use and dropping out of school report mixed results, with some showing that drug use and dropping out of high school are related, while others indicate that the association varies by race/ethnicity and is confounded by other factors.13

## Risk and Protective Factors

Research has identified multiple risk and protective factors that influence adolescent substance use. Risk factors include substance use by family members (specifically parents and siblings), poor parental supervision and household disruption, low academic performance or aspirations, decreased participation in school activities, poor relationships with teachers, untreated attention deficit hyperactivity disorder, and perceived peer acceptance of substance use and actual use among peers. Protective factors include parents who set clear rules and enforce them, parents who regularly talk with their children about the dangers of substance use, having a parent in recovery, having a positive school climate and a positive sense of community, involvement in religious or other community programs, and having adequate opportunities in the community for prosocial involvement.14-17

While not everyone who uses tobacco or alcohol will progress to illicit drug use, tobacco or alcohol use often precedes marijuana and other illicit drug use and the use of one substance can be a marker for the use of others.18 A recent study found that alcohol use is the first step toward using tobacco and illicit drugs.19 Marijuana use in adolescents has been linked to illicit drug abuse and dependency and using more types of illicit drugs.20

## Behavioral Interventions in Primary Care

Preventing and reducing drug use in adolescents is a national priority. Healthy People 2020 substance abuse objectives include increasing the proportion of high school seniors who have never used illicit drugs, decreasing the proportion of young persons who use marijuana for the first time, and decreasing the proportion of adolescents who report using marijuana and nonmedical use of prescription drugs or inhalants.21

To reduce the health burden associated with substance use and substance use disorders, the Substance Abuse and Mental Health Services Administration (SAMHSA) recommends that universal screening for substance use, brief intervention, and/or referral to treatment (the SBIRT model) become a part of routine health care.22 SBIRT is an early intervention approach that targets individuals with nondependent substance use and provides strategies for intervention before the need for more extensive or specialized treatment. Brief interventions, in particular, are well-suited for use in primary care. This approach is a precursor to interventions that focus on specialized treatment of individuals with more severe substance use or those who have met the criteria for a diagnosis of a substance use disorder (i.e., abuse or dependence). Therefore, brief or early intervention is a proactive approach that is initiated by the health care provider rather than the patient.

Among children and adolescents, the term “brief intervention” includes a broad range of clinical activities intended to prevent, delay, or reduce substance use in individuals with varying experience with substances. These activities include positive feedback to nonusers as primary prevention; brief advice as a form of secondary prevention for those at low risk for abuse; or an intervention using motivational techniques directed at reducing use, associated high-risk behaviors, and/or getting a patient to accept a referral to treatment if they are at high risk for or abusing drugs. The SBIRT model for children and adolescents is slightly different than the model applied for adults, in which the focus is on brief, motivational interventions for those identified “at risk” for abuse or dependence. Because any substance use can negatively affect the health of children and adolescents, brief interventions are designed to provide positive reinforcement, brief advice, or brief motivational interventions for youth at all stages of use. According to SAMHSA, a brief intervention usually involves one to five sessions of 5 minutes to 1 hour in duration. These interventions can be delivered via face-to-face sessions, written self-help materials, a computer intervention, or telephone counseling.

The American Academy of Pediatrics has developed specific guidelines through Bright Futures for screening for and counseling about alcohol and illicit substance use. This group specifically recommends that pediatricians provide substance abuse (i.e., alcohol, tobacco, and drug) education and screening to adolescents during routine clinical care, incorporating the SBIRT guidelines designed by SAMHSA.14,23 Furthermore, it advises that brief counseling and in-office followup may be sufficient if patients report substance use without associated problems and there have been no adverse consequences of substance use. More intense intervention and referral for treatment are indicated, however, when children or adolescents are identified as having experienced adverse events related to their substance use (e.g., injuries associated with acute intoxication, trouble with the law, truancy, decline in school performance, or deterioration in physical or mental health), are regularly using drugs (including the use of more drugs and on a more frequent basis), or are using drugs to “feel normal.”24

## Current Clinical Practice in the United States

Few primary care physicians or their adolescent patients report specifically discussing substance use or drug use. Less than 50 percent of pediatricians report screening their adolescent patients for substance use or abuse in their general pediatric visits.25 In one survey of adolescent patients, only 35 percent reported discussing substance use with their physicians, although 65 percent wanted to talk about substance use.26 Difficulties with discussing the issues (e.g., parent present in the examination room), insufficient time, level of physician preparedness, and belief that treatment is not effective are reported as common barriers for not discussing substance use with children and adolescents.27,28

## Previous USPSTF Recommendation

In 2008, the USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening adolescents, adults, and pregnant women for illicit drug use (I statement).