# Trials Pending Assessment

Author | Design | Population | Intervention(s) | Comparator(s) | Relevant outcomes | Reported status
Arnaud, 2012^74^ Germany | RCT | Adolescents ages 16 to 18 years with a positive screen on the CRAFFT for risky substance use | WISEteens Web-based screening and brief intervention | No intervention | Reductions in frequency and quantity of use of drugs, consumption per occasion | Ongoing, estimated completion 2013
Blow, 2012^75^ United States | RCT | Adolescents ages 12 to 18 years | 1. Brief motivational intervention by therapist; 2. Computerized brief motivational intervention | Drug prevention booklet | Marijuana use, other substance use, initiation of drug use | Estimated completion November 2013
Bukstein, 2011^76^ United States | RCT | Adolescents ages 11 to 14 years with a disruptive behavior diagnosis and using ≥1 substances regularly | Adolescent skills, parent management, parent-adolescent negotiation, home-based treatment | Treatment as usual (for behavioral problems and substance use) | Substance use | Completed May 2009, no publications
Chaplin, 2013^77^ United States | RCT | Parents of 12- to 14-year-olds reporting high parenting stress | Parenting-focused, mindfulness-based stress reduction | Parent advice only | Substance use | Ongoing
Collins, 2010^78^ United States | RCT | Rural Mexican American female adolescents ages 13 to 19 years | Community-based cognitive behavioral intervention based on an AIDS risk reduction model, including individual and group sessions with support groups | Enhanced counseling | Substance use | Ongoing
Epton, 2013^79^ United Kingdom | RCT | Undergraduate student entering a university | Online health behavior intervention, including self-affirmation, theory-based message, and implementation intentions | Control | Recreational drug use | Ongoing
Hides, 2011^80^ Australia | RCT | Adolescents and young adults ages 16 to 25 years with a Kessler 10 score of ≥18 and weekly cannabis use | Two sessions of brief motivational interviewing | One session assessment feedback/intervention | Reduction in cannabis use | Ongoing
Knight, 2011^81^ United States | RCT | Adolescents ages 12 to 18 years screened for substance use | Internet-facilitated screening, brief intervention, and referral to treatment | Treatment as usual | Substance use | Estimated completion, October 2016
Knight, 2011^73^ United States | RCT | Adolescents and young adults ages 12 to 21 years | 1. Internet/intranet-based motivational enhancement therapy; 2. Internet/intranet-based motivational enhancement therapy + technological extenders | Treatment as usual | Substance use, initiation and cessation of substance use | Completed September 2011, no publications
Knight, 2011^82^ United States | RCT | Adolescents and young adults ages 12 to 21 years who used alcohol, marijuana, or other drugs in the last 3 months | Brief motivational enhancement therapy | Enhanced standard care | Substance use, driving or riding while under the influence of substances, substance-related risk behaviors | Completed May 2010, no publications
Laporte, 2012 United States | RCT | French adolescents and young adults ages 15 to 25 years who are repeat or regular users of cannabis | Brief intervention for cannabis use | Control (details NR) | Marijuana use | Estimated completion, March 2014
Levy, 2012^83^ United States | RCT | Adolescents ages 14 to 18 years with a chronic medical condition (e.g., diabetes, asthma, ulcerative colitis, rheumatologic disorder) | Brief motivational intervention aimed at encouraging the participant to decrease substance use | Treatment as usual (brief health education brochure) | Days abstinent from substance use | Estimated completion, December 2014
Lewis, 2012^84^ Australia | RCT | Adolescents and young adults ages 16 to 25 years diagnosed with anxiety or depression and substance misuse | BEST Plus, SHADEY or SHADEY and BEST Plus cognitive therapy, and family education | Waitlist control and those who refused to participate | Adolescent Substance Abuse Subtle Screening Inventory Score | Ongoing
Metzler, 2013^85^ United States | RCT | Families of 3- to 8-year-olds with elevated behavior problems | Internet-based Triple P Positive Parenting Program | Usual community services/waitlist control | Substance abuse | Ongoing
Mericle, 2012^86^ United States | RCT | Adolescents ages 12 to 18 years | 1. Computer-assisted screening and brief advice; 2. Computer-assisted screening and brief advice + motivational enhancement therapy | Treatment as usual | Substance use | Estimated completion, February 2016
Shaw, 2012^87^ United States | RCT | Families of children ages 2 to 4 years | Family-centered early intervention | NR | Reductions in substance use risk from ages 2 to 10 years | Ongoing
Skeer, 2013^88^ United States | RCT | Parents and guardians of preadolescents ages 9 to 12 years | Brief, sex-specific substance use and misuse prevention intervention | Control | Intentions of use of substances, attitudes and expectancies regarding substance use | Ongoing
Spirito, 2012^89^ United States | RCT | Preadolescent children with a history of emotional/behavioral problems and their families | Individually-tailored family program utilizing principles of motivational interviewing | Standard care | Marijuana use | Completed March 2011, no publications
Van Hook, 2013^71,72^ United States | RCT | Patients coming to primary care office | VYou: computerized motivational enhancement therapy tool with 8 interactive exercises | NR | Substance use | Trial not yet conducted, awaiting funding
Walker, 2010^90^ United States | RCT | Adolescents ages 14 to 19 years who use marijuana | Motivational enhancement treatment with optional skills training | Educational feedback | Marijuana use | Estimated completion, September 2014