# Excluded Studies

Exclusion code key

E1. Geography: Not a country with a very high Human Development Index ranking
E2a. Setting: Excluded on the basis of setting alone (e.g., substance abuse treatment centers, school classrooms, worksites, inpatient/residential, other institutions [e.g., juvenile detention facilities])
E2b. Setting: Setting potentially applicable to primary care but not directly or indirectly linked to health care or widely available in community to refer to (e.g., research clinic, community centers, homes, virtual)
E3. Comparative effectiveness (control group received active intervention)
E4. No relevant outcomes
E5a. Population: Adults (age >18 years) or average age of study sample >18 years (unless age <18 years subgroup reported)
E5b. Population: Treatment-seeking children or adolescents or mandated treatment
E5c. Population: Psychiatric inpatients, individuals in juvenile detention centers, court-mandated, juvenile offenders
E6a. Condition: >50% of children or adolescents in trial have drug abuse/dependence or drug use disorder
E6b. Condition: Nonpsychoactive drugs
E7a. Intervention: Not a primary care–relevant behavioral counseling intervention
E7b. Intervention: Drug misuse is not a primary target of the intervention
E8. Study design: Not a randomized, controlled trial or clinical controlled trial
E9. Followup: <6 months (24 weeks) followup postbaseline (does not apply to harms)
E10. Study relevance
E11. Poor-quality rating

1 Aalborg AE, Miller BA, Husson G, et al. Implementation of adolescent family-based substance use prevention programs in health care settings: comparisons across conditions and programs. Health Educ J. Jan. 1. 2012;71(1):53-61. KQ1E4, KQ2E4, KQ3E4. [pmid: 22984294].
2 Baer JS, Peterson PL, Wells EA, et al. Brief intervention for drug use with homeless adolescents: a preliminary report. Proceedings of the 67th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2005 Jun 19. Orlando, FL. 2005. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
3 Baer JS, Garrett SB, Beadnell B, et al. Brief motivational intervention with homeless adolescents: evaluating effects on substance use and service utilization. Psychol Addict Behav. Dec. 2007;21(4):582-6. KQ1E9, KQ2E9, KQ3E9. [pmid: 18072842].
4 Bailey KA, Baker AL, Webster RA, et al. Pilot randomized controlled trial of a brief alcohol intervention group for adolescents. Drug Alcohol Rev. Jun. 2004;23(2):157-66. KQ1E10, KQ2E10, KQ3E10. [pmid: 15370021].
5 Barlow A, Mullany B, Neault N, et al. Effect of a paraprofessional home-visiting intervention on American Indian teen mothers' and infants' behavioral risks: a randomized controlled trial. Am J Psychiatry. Jan. 1. 2013;170(1):83-93. KQ1E4, KQ2E4, KQ3E4. [pmid: 23409290].
6 Battjes RJ, Gordon MS, O'Grady KE, et al. Evaluation of a group-based substance abuse treatment program for adolescents. J Subst Abuse Treat. 2004;27:123-34. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 15450645].
7 Behrendt S, Wittchen HU, Hofler M, et al. Transitions from first substance use to substance use disorders in adolescence: is early onset associated with a rapid escalation?. Drug Alcohol Depend. Jan. 1. 2009;99(1-3):68-78. KQ1E10, KQ2E10, KQ3E10. [pmid: 18768267].
8 Bernat DH, August GJ, Hektner JM, et al. The Early Risers preventive intervention: testing for six-year outcomes and mediational processes. J Abnorm Child Psychol. Aug. 2007;35(4):605-17. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 17333359].
9 Bernstein E, Edwards E, Dorfman D, et al. Screening and brief intervention to reduce marijuana use among youth and young adults in a pediatric emergency department. Acad Emerg Med. Nov. 2009;16(11):1174-85. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 20053238].
10 Bohnert KM, Walton MA, Barry K, et al. Three-month efficacy of a brief intervention for reducing marijuana use and consequences among adolescents presenting to indigent primary care clinics. Proceedings of the 73rd Annual Scientific Meeting of the College on Problems of Drug Dependence. 2011 Jun 18. Hollywood, FL. 2011:16. PMID: None. KQ1E9, KQ2E9, KQ3E9.
11 Bonds DD, Wolchik SA, Winslow E, et al. Developmental cascade effects of the New Beginnings Program on adolescent adaptation outcomes. Dev Psychopathol. 2010;22:771-84. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 20883581].
12 Bonsack C, Gibellini MS, Favrod J, et al. Motivational intervention to reduce cannabis use in young people with psychosis: a randomized controlled trial. Psychother Psychosom. 2011;80(5):287-97. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 21646823].
13 Botvin GJ, Schinke SP, Epstein JA, et al. Effectiveness of culturally focused and generic skills training approaches to alcohol and drug abuse prevention among minority youths. Psychol Addict Behav. 1994;8(2):116-27. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
14 Brody GH, Murry VM, Gerrard M, et al. The strong African American families program: prevention of youths' high-risk behavior and a test of a model of change. J Fam Psychol. Mar. 2006;20(1):1-11. KQ1E3, KQ2E3, KQ3E3. [pmid: 16569084].
15 Brody GH, Yu T, Chen YF, et al. The Adults in the Making program: long-term protective stabilizing effects on alcohol use and substance use problems for rural African American emerging adults. J Consult Clin Psychol. Feb. 2012;80(1):17-28. KQ1E4, KQ2E4, KQ3E4. [pmid: 22182263].
16 Brody GH, Chen YF, Kogan SM, et al. Family-centered program deters substance use, conduct problems, and depressive symptoms in black adolescents. Pediatrics. Jan. 2012;129(1):108-15. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 22157131].
17 Brody GH, Chen Yf, Beach SRH, et al. Participation in a family-centered prevention program decreases genetic risk for adolescents' risky behaviors. Pediatrics. 2009;124(3):911-7. PMID: None. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 19706565].
18 Burleson JA, Kaminer Y, Dennis ML. Absence of iatrogenic or contagion effects in adolescent group therapy: findings from the Cannabis Youth Treatment (CYT) study. Am J Addict. 2006;15:Suppl-15. KQ1E10, KQ2E10, KQ3E10. [pmid: 17182415].
19 Burrow-Sanchez JJ, Wrona M. Comparing culturally accommodated versus standard group CBT for Latino adolescents with substance use disorders: a pilot study. Cultur Divers Ethnic Minor Psychol. Oct. 2012;18(4):373-83. KQ1E5c, KQ2E5c, KQ3E5c. [pmid: 22866693].
20 Catalano RF, Gainey RR, Fleming CB, et al. An experimental intervention with families of substance abusers: one-year follow-up of the focus on families project. Addiction. Feb. 1999;94(2):241-54. KQ1E7a, KQ2E7a, KQ3E7a. [pmid: 10396792].
21 Comulada WS, Weiss RE, Cumberland W, et al. Reductions in drug use among young people living with HIV. Am J Drug Alcohol Abuse. 2007;33(3):493-501. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 17613977].
22 Connell AM, Dishion TJ, Deater-Deckard K. Variable- and person-centered approaches to the analysis of early adolescent substance use: linking peer, family, and intervention effects with developmental trajectories. Merrill-Palmer Quarterly. 2006;52(3):421-48. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
23 Conrod PJ, Castellanos-Ryan N, Strang J. Brief, personality-targeted coping skills interventions and survival as a non-drug user over a 2-year period during adolescence. Arch Gen Psychiatry. Jan. 2010;67(1):85-93. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 20048226].
24 Corby EA, Russell JC. Substance abuse risk reduction: verbal mediational training for children by parental and nonparental models. Subst Abuse. 1997;18(4):145-64. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
25 Cordova D, Huang S, Pantin H, et al. Do the effects of a family intervention on alcohol and drug use vary by nativity status?. Psychol Addict Behav. Sep. 2012;26(3):655-60. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 22141423].
26 Correia CJ, Benson TA, Carey KB. Decreased substance use following increases in alternative behaviors: a preliminary investigation. Addict Behav. 2005;30:19-27. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 15561446].
27 D'Amico EJ, Fromme K. Brief prevention for adolescent risk-taking behavior. Addiction. May. 2002;97(5):563-74. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 12033657].
28 D'Amico EJ, Miles JN, Stern SA, et al. Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. Jul. 2008;35(1):53-61. KQ1E9, KQ2E9, KQ3E9. [pmid: 18037603].
29 Danielson CK, McCart MR, Walsh K, et al. Reducing substance use risk and mental health problems among sexually assaulted adolescents: a pilot randomized controlled trial. J Fam Psychol. Aug. 2012;26(4):628-35. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 22686269].
30 Edwards J, Elkins K, Hinton M, et al. Randomized controlled trial of a cannabis-focused intervention for young people with first-episode psychosis. Acta Psychiatr Scand. Aug. 2006;114(2):109-17. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 16836598].
31 Erickson SJ, Gerstle M, Feldstein SW. Brief interventions and motivational interviewing with children, adolescents, and their parents in pediatric health care settings: a review. Arch Pediatr Adolesc Med. Dec. 2005;159(12):1173-80. KQ1E8, KQ2E8, KQ3E8. [pmid: 16330743].
32 Fang L, Schinke SP, Cole KC. Preventing substance use among early Asian-American adolescent girls: initial evaluation of a web-based, mother-daughter program. J Adolesc Health. Nov. 2010;47(5):529-32. KQ3E4. [pmid: 20970090].
33 Fang L, Schinke SP. Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychol Addict Behav. 2012. Dec. 31. KQ3E4. [pmid: 23276322].
34 Fischer B, Dawe M, McGuire F, et al. Feasibility and impact of brief interventions for frequent cannabis users in Canada. J Subst Abuse Treat. Jan. 2013;44(1):132-8. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 22520278].
35 Fors SW, Jarvis S. Evaluation of a peer-led drug abuse risk reduction project for runaway/homeless youths. J Drug Educ. 1995;25(4):321-33. KQ1E4, KQ2E4, KQ3E4. [pmid: 8907403].
36 Garfein RS, Golub ET, Greenberg AE, et al. A peer-education intervention to reduce injection risk behaviors for HIV and hepatitis C virus infection in young injection drug users. AIDS. Sep. 12. 2007;21(14):1923-32. KQ1E4, KQ2E4, KQ3E4. [pmid: 17721100].
37 Gonzales NA, Dumka LE, Millsap RE, et al. Randomized trial of a broad preventive intervention for Mexican American adolescents. J Consult Clin Psychol. Feb. 2012;80(1):1-16. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 22103956].
38 Goti J, Diaz R, Serrano L, et al. Brief intervention in substance-use among adolescent psychiatric patients: a randomized controlled trial. Eur Child Adolesc Psychiatry. Jun. 2010;19(6):503-11. KQ1E9, KQ2E9, KQ3E9. [pmid: 19779855].
39 Gray E, McCambridge J, Strang J. The effectiveness of motivational interviewing delivered by youth workers in reducing drinking, cigarette and cannabis smoking among young people: quasi-experimental pilot study. Alcohol Alcohol. Nov. 2005;40(6):535-9. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 16131498].
40 Griffin KW, Samuolis J, Williams C. Efficacy of a self-administered home-based parent intervention on parenting behaviors for preventing adolescent substance use. J Child Family Stud. 2011;20(3):319-25. PMID: None. KQ1E4, KQ2E4, KQ3E4.
41 Gross J, McCaul ME. An evaluation of a psychoeducational and substance abuse risk reduction intervention for children of substance-abusers. J Community Psychol. 1992:75-87. PMID: None. KQ1E8, KQ2E8, KQ3E8.
42 Haggerty KP, Skinner ML, MacKenzie EP, et al. A randomized trial of Parents Who Care: effects on key outcomes at 24-month follow-up. Prev Sci. Dec. 2007;8(4):249-60. KQ1E3, KQ2E3, KQ3E3. [pmid: 17987388].
43 Haggerty KP, Skinner M, Fleming CB, et al. Long-term effects of the Focus on Families project on substance use disorders among children of parents in methadone treatment. Addiction. Dec. 2008;103(12):2008-16. KQ1E7a, KQ2E7a, KQ3E7a. [pmid: 18855808].
44 Harris SK, Csemy L, Sherritt L, et al. Computer-facilitated substance use screening and brief advice for teens in primary care: an international trial. Pediatrics. Jun. 2012;129(6):1072-82. KQ1E4, KQ3E4. [pmid: 22566420].
45 Henderson CE, Rowe CL, Dakof GA, et al. Parenting practices as mediators of treatment effects in an early-intervention trial of multidimensional family therapy. Am J Drug Alcohol Abuse. 2009;35(4):220-6. KQ1E3, KQ2E3, KQ3E3. [pmid: 20180674].
46 Hides L, Carroll S, Scott R, et al. Quik Fix: a randomized controlled trial of an enhanced brief motivational interviewing intervention for alcohol/cannabis and psychological distress in young people. Psychother Psychosom. 2013;82(2):122-4. KQ1E3, KQ2E3, KQ3E3. [pmid: 23295899].
47 Hollen PJ, Tyc VL, Donnangelo SF, et al. A use decision aid for medically at-risk adolescents: results of a randomized controlled trial for cancer-surviving adolescents. Cancer Nurs. 2013. Jan. 25. KQ1E4, KQ2E4, KQ3E4. [pmid: 23357887].
48 Horigian VE, Robbins MS, Dominguez R, et al. Principles for defining adverse events in behavioral intervention research: lessons from a family-focused adolescent drug abuse trial. Clin Trials. Feb. 2010;7(1):58-68. KQ1E4, KQ2E4, KQ3E4. [pmid: 20156957].
49 Humeniuk R, Ali R, Babor T, et al. A randomized controlled trial of a brief intervention for illicit drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in clients recruited from primary health-care settings in four countries. Addiction. May. 2012;107(5):957-66. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 22126102].
50 Kaminer Y, Burleson JA, Blitz C, et al. Psychotherapies for adolescent substance abusers: a pilot study. J Nerv Ment Dis. Nov. 1998;186(11):684-90. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 9824170].
51 Kaminer Y, Burleson JA. Psychotherapies for adolescent substance abusers: 15-month follow-up of a pilot study. Am J Addict. 1999;8(2):114-9. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 10365191].
52 Kaminer Y, Burleson JA, Goldberger R. Cognitive-behavioral coping skills and psychoeducation therapies for adolescent substance abuse. J Nerv Ment Dis. Nov. 2002;190(11):737-45. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 12436013].
53 Kamon J, Budney A, Stanger C. A contingency management intervention for adolescent marijuana abuse and conduct problems. J Amer Acad Child Adolesc Psychiatry. Jun. 2005;44(6):513-21. KQ1E8, KQ2E8, KQ3E8. [pmid: 15908833].
54 Kemp R, Harris A, Vurel E, et al. Stop Using Stuff: trial of a drug and alcohol intervention for young people with comorbid mental illness and drug and alcohol problems. Australas Psychiatry. Dec. 2007;15(6):490-3. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 17852064].
55 Kim HK, Leve LD. Substance use and delinquency among middle school girls in foster care: a three-year follow-up of a randomized controlled trial. J Consult Clin Psychol. Dec. 2011;79(6):740-50. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 22004305].
56 Knight JR, Sherritt L, Van HS, et al. Motivational interviewing for adolescent substance use: a pilot study. J Adolesc Health. Aug. 2005;37(2):167-9. KQ1E8, KQ2E8, KQ3E8. [pmid: 16026730].
57 Koniak-Griffin D, Anderson NL, Verzemnieks I, et al. A public health nursing early intervention program for adolescent mothers: outcomes from pregnancy through 6 weeks postpartum. Nurs Res. May. 2000;49(3):130-8. KQ1E10, KQ2E10, KQ3E10. [pmid: 10882317].
58 Kumpfer KL, Whiteside HO, Greene JA, et al. Effectiveness outcomes of four age versions of the Strengthening Families Program in statewide field sites. Group Dyn. 2010;14(3):211-29. KQ1E2a, KQ2E2a, KQ3E2a.
59 Latimer WW, Winters KC, D'Zurilla T, et al. Integrated family and cognitive-behavioral therapy for adolescent substance abusers: a stage I efficacy study. Drug Alcohol Depend. Sep. 10. 2003;71(3):303-17. KQ1E3, KQ2E3, KQ3E3. [pmid: 12957348].
60 Lecallier D, Hadj SF, Landry M, et al. Screening, referring and counseling of adolescents for substance abuse. A randomized controlled study on 2120 students. Reperer, orienter, conseiller les adolescents consommateurs de substances psycho-actives (ROC-ADO). etude prospective randomisee controlee aupres de 2120 adolescents. Presse Med. 2012;41:e411-e419. KQ1E12, KQ2E12, KQ3E12. [pmid: 22445839].
61 Lee CM, Neighbors C, Kilmer JR, et al. A brief, web-based personalized feedback selective intervention for college student marijuana use: a randomized clinical trial. Psychol Addict Behav. Jun. 2010;24(2):265-73. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 20565152].
62 Liddle HA, Dakof GA, Turner RM, et al. Treating adolescent drug abuse: a randomized trial comparing multidimensional family therapy and cognitive behavior therapy. Addiction. Oct. 2008;103(10):1660-70. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 18705691].
63 Liddle HA, Dakof GA, Parker K, et al. Multidimiensional family therapy for adolescent drug abuse: Results of a randomized clinical trial. Am J Drug Alcohol Abuse. 2001;27(4):651-88. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 11727882].
64 Lochman JE, Wells KC. The Coping Power program at the middle-school transition: universal and indicated prevention effects. Psychol Addict Behaviors. Dec. 2002;16(4:Suppl):Suppl-54. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 12502276].
65 Lord SE, D'Amante D, Clements K, et al. Efficacy of an online substance abuse prevention program for early adolescents. Proceedings of the 70th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2008 Jun 14. San Juan, Puerto Rico. 2008:116. PMID: None. KQ1E4, KQ2E4, KQ3E4.
66 Mackesy-Amiti ME, Ouellet LJ, Golub ET, et al. Predictors and correlates of reduced frequency or cessation of injection drug use during a randomized HIV prevention intervention trial. Addiction. Mar. 2011;106(3):601-8. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 21182555].
67 Marsden J, Stillwell G, Barlow H, et al. An evaluation of a brief motivational intervention among young ecstasy and cocaine users: no effect on substance and alcohol use outcomes. Addiction. Jul. 2006;101(7):1014-26. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 16771893].
68 Marsden J, Stillwell G, Barlow H, et al. An evaluation of a brief intervention model for use with young non-injecting stimulant users. Drugs. 2005;12(Suppl1):90-3. PMID: None. KQ1E2b, KQ2E2b, KQ3E2b.
69 Martin G, Copeland J. The adolescent cannabis check-up: randomized trial of a brief intervention for young cannabis users. J Subst Abuse Treat. Jun. 2008;34(4):407-14. KQ1E3, KQ2E3, KQ3E3. [pmid: 17869051].
70 Martinez CR Jr., Eddy JM. Effects of culturally adapted parent management training on Latino youth behavioral health outcomes. J Consult Clin Psychol. Oct. 2005;73(5):841-51. KQ1E4, KQ2E4, KQ3E4. [pmid: 16287384].
71 Mason M, Pate P, Drapkin M, et al. Motivational interviewing integrated with social network counseling for female adolescents: a randomized pilot study in urban primary care. J Subst Abuse Treat. Sep. 2011;41(2):148-55. KQ1E9, KQ2E9, KQ3E9. [pmid: 21489741].
72 Mason WA, Kosterman R, Hawkins JD, et al. Influence of a family-focused substance use preventive intervention on growth in adolescent depressive symptoms. J Res Adolesc. 2007;17(3):541-64. PMID: None. KQ1E2b, KQ2E2b, KQ3E2b.
73 Mason WA, Haggerty KP, Fleming AP, et al. Family intervention to prevent depression and substance use among adolescents of depressed parents. J Child Fam Stud. 2012;21(6):891-905. PMID: None. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 23798891].
74 McCambridge J, Strang J. The efficacy of single-session motivational interviewing in reducing drug consumption and perceptions of drug-related risk and harm among young people: results from a multi-site cluster randomized trial. Addiction. Jan. 2004;99(1):39-52. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 14678061].
75 McCambridge J, Strang J. Deterioration over time in effect of Motivational Interviewing in reducing drug consumption and related risk among young people. Addiction. Apr. 2005;100(4):470-8. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 15784061].
76 McCambridge J, Slym RL, Strang J. Randomized controlled trial of motivational interviewing compared with drug information and advice for early intervention among young cannabis users. Addiction. Nov. 2008;103(11):1809-18. KQ1E3, KQ2E3, KQ3E3. [pmid: 18778385].
77 McCambridge J, Day M, Thomas BA, et al. Fidelity to Motivational Interviewing and subsequent cannabis cessation among adolescents. Addict Behav. Jul. 2011;36(7):749-54. KQ1E9, KQ2E9, KQ3E9. [pmid: 21440994].
78 McCambridge J, Hunt C, Jenkins RJ, et al. Cluster randomised trial of the effectiveness of motivational interviewing for universal prevention. Drug Alcohol Depend. Apr. 1. 2011;114(2-3):177-84. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 21075562].
79 McGillicuddy NB, Rychtarik RG, Duquette JA, et al. Development of a skill training program for parents of substance-abusing adolescents. J Subst Abuse Treat. Jan. 2001;20(1):59-68. KQ1E9, KQ2E9, KQ3E9. [pmid: 11239729].
80 Milburn NG, Iribarren FJ, Rice E, et al. A family intervention to reduce sexual risk behavior, substance use, and delinquency among newly homeless youth. J Adolesc Health. Apr. 2012;50(4):358-64. KQ1E9, KQ2E9, KQ3E9. [pmid: 22443839].
81 Miller WR, Toscova RT, Miller JH, et al. A theory-based motivational approach for reducing alcohol/drug problems in college. Health Educ Behav. Dec. 2000;27(6):744-59. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 11104373].
82 Molina BS, Flory K, Hinshaw SP, et al. Delinquent behavior and emerging substance use in the MTA at 36 months: prevalence, course, and treatment effects. J Am Acad Child Adolesc Psychiatry. Aug. 2007;46(8):1028-40. KQ1E8, KQ2E8, KQ3E8. [pmid: 17667481].
83 Morris J, Parker H, Aldridge J. The Integrated Programme: An evaluation of a multi-component drugs prevention programme in northern England (1996-1999). Drugs. 2002;9(2):153-68. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
84 Mullany B, Barlow A, Neault N, et al. The Family Spirit Trial for American Indian teen mothers and their children: CBPR rationale, design, methods and baseline characteristics. Prev Sci. Oct. 2012;13(5):504-18. PMID: None. KQ1E4, KQ2E4, KQ3E4. [pmid: 22932743].
85 Murphy DA, Chen X, Naar-King S, et al. Alcohol and marijuana use outcomes in the Healthy Choices motivational interviewing intervention for HIV-positive youth. Aids Patient Care STDS. Feb. 2012;26(2):95-100. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 22191456].
86 Murry VM, Berkel C, Chen YF, et al. Intervention induced changes on parenting practices, youth self-pride and sexual norms to reduce HIV-related behaviors among rural African American youths. J Youth Adolesc. Sep. 2011;40(9):1147-63. KQ1E4, KQ2E4, KQ3E4. [pmid: 21373904].
87 Naar-King S, Wright K, Parsons JT, et al. Healthy choices: motivational enhancement therapy for health risk behaviors in HIV-positive youth. AIDS Educ Prev. Feb. 2006;18(1):1-11. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 16539572].
88 Naar-King S, Lam P, Wang B, et al. Brief report: maintenance of effects of motivational enhancement therapy to improve risk behaviors and HIV-related Health in a randomized controlled trial of youth living with HIV. J Pediatr Psychol. May. 2008;33(4):441-5. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 17905800].
89 Naar-King S, Parsons JT, Murphy DA, et al. Improving health outcomes for youth living with the human immunodeficiency virus: a multisite randomized trial of a motivational intervention targeting multiple risk behaviors. Arch Pediatr Adolesc Med. Dec. 2009;163(12):1092-8. KQ1E3, KQ2E3, KQ3E3. [pmid: 19996045].
90 Newton NC, Andrews G, Teesson M, et al. Delivering prevention for alcohol and cannabis using the Internet: a cluster randomised controlled trial. Prev Med. Jun. 2009;48(6):579-84. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 19389420].
91 Nyamathi A, Branson C, Kennedy B, et al. Impact of nursing intervention on decreasing substances among homeless youth. Am J Addict. Nov. 2012;21(6):558-65. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 23082836].
92 Oliansky DM, Wildenhaus KJ, Manlove K, et al. Effectiveness of brief interventions in reducing substance use among at-risk primary care patients in three community-based clinics. Subst Abuse. 1997;18(3):95-103. PMID: None. KQ1E9, KQ2E9, KQ3E9.
93 Ozer EM, Adams SH, Orrell-Valente JK, et al. Does delivering preventive services in primary care reduce adolescent risky behavior?. J Adolesc Health. Nov. 2011;49(5):476-82. KQ1E8, KQ2E8, KQ3E8. [pmid: 22018561].
94 Palinkas LA, Atkins CJ, Miller C, et al. Social skills training for drug prevention in high-risk female adolescents. Prev Med. Nov. 1996;25(6):692-701. KQ1E7a, KQ2E7a, KQ3E7a. [pmid: 8936571].
95 Pantin H, Coatsworth JD, Feaster DJ, et al. Familias Unidas: the efficacy of an intervention to promote parental investment in Hispanic immigrant families. Prev Sci. Sep. 2003;4(3):189-201. KQ1E4, KQ2E4, KQ3E4. [pmid: 12940469].
96 Pantin H, Prado G, Lopez B, et al. A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosom Med. Nov. 2009;71(9):987-95. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 19834053].
97 Peterson PL, Baer JS, Wells EA, et al. Short-term effects of a brief motivational intervention to reduce alcohol and drug risk among homeless adolescents. Psychol Addict Behav. Sep. 2006;20(3):254-64. KQ1E9, KQ2E9, KQ3E9. [pmid: 16938063].
98 Pierce JP, James LE, Messer K, et al. Telephone counseling to implement best parenting practices to prevent adolescent problem behaviors. Contemp Clin Trials. 2008;29(3):324-34. KQ1E4, KQ2E4, KQ3E4. [pmid: 17964223].
99 Prado G, Pantin H, Briones E, et al. A randomized controlled trial of a parent-centered intervention in preventing substance use and HIV risk behaviors in Hispanic adolescents. J Consult Clin Psychol. Dec. 2007;75(6):914-26. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 18085908].
100 Ramchand R, Griffin BA, Suttorp M, et al. Using a cross-study design to assess the efficacy of motivational enhancement therapy-cognitive behavioral therapy 5 (MET/CBT5) in treating adolescents with cannabis-related disorders. J Stud Alcohol Drugs. May. 2011;72(3):380-9. KQ1E3, KQ2E3, KQ3E3. [pmid: 21513674].
101 Rhee H, Hollen PJ, Belyea MJ, et al. Decision-making program for rural adolescents with asthma: a pilot study. J Pediatr Nurs. Dec. 2008;23(6):439-50. KQ1E4, KQ3E4. [pmid: 19026912].
102 Riesch SK, Brown RL, Anderson LS, et al. Strengthening families program (10-14): effects on the family environment. West J Nurs Res. Apr. 2012;34(3):340-76. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 21403057].
103 Robbins MS, Szapocznik J, Horigian VE, et al. Brief strategic family therapy for adolescent drug abusers: a multi-site effectiveness study. Contemp Clin Trials. 2009;30:269-78. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 19470315].
104 Rotheram-Borus MJ, Song J, Gwadz M, et al. Reductions in HIV risk among runaway youth. Prev Sci. Sep. 2003;4(3):173-87. KQ1E10, KQ2E10, KQ3E10. [pmid: 12940468].
105 Rotheram-Borus MJ, Swendeman D, Comulada WS, et al. Prevention for substance-using HIV-positive young people: telephone and in-person delivery. J Acquir Immune Defic Syndr. Oct. 1. 2004;37:Suppl-77. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 15385902].
106 Sarvela PD, Ford TD. Indicators of substance use among pregnant adolescents in the Mississippi Delta. J Sch Health. May. 1992;62(5):175-9. KQ1E4, KQ2E4, KQ3E4. [pmid: 1522698].
107 Sarvela PD, Ford TD. An evaluation of a substance abuse education program for Mississippi delta pregnant adolescents. J Sch Health. Mar. 1993;63(3):147-52. KQ1E11, KQ2E11, KQ3E11. [pmid: 8487513].
108 Schinke S, Schwinn T. Gender-specific computer-based intervention for preventing drug abuse among girls. Am J Drug Alcohol Abuse. 2005;31(4):609-16. KQ1E9, KQ2E9, KQ3E9. [pmid: 16320437].
109 Schinke S, Di NJ, Schwinn T, et al. Drug abuse risk and protective factors among black urban adolescent girls: a group-randomized trial of computer-delivered mother-daughter intervention. Psychol Addict Behav. Dec. 2006;20(4):496-500. KQ1E4, KQ2E4, KQ3E4. [pmid: 17176186].
110 Schinke SP, Schwinn TM, Di NJ, et al. Reducing the risks of alcohol use among urban youth: three-year effects of a computer-based intervention with and without parent involvement. J Stud Alcohol. Jul. 2004;65(4):443-9. KQ1E10, KQ2E10, KQ3E10. [pmid: 15376818].
111 Schinke SP, Fang L, Cole KC. Preventing substance use among adolescent girls: 1-year outcomes of a computerized, mother-daughter program. Addict Behav. Dec. 2009;34(12):1060-4. KQ3E4. [pmid: 19632053].
112 Schinke SP, Cole KC, Fang L. Gender-specific intervention to reduce underage drinking among early adolescent girls: a test of a computer-mediated, mother-daughter program. J Stud Alcohol Drugs. Jan. 2009;70(1):70-7. KQ1E4, KQ2E4, KQ3E4. [pmid: 19118394].
113 Schinke SP, Fang L, Cole KC. Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Prev Med. Nov. 2009;49(5):429-35. KQ3E4. [pmid: 19682490].
114 Schwinn TM, Schinke SP, Di NJ. Preventing drug abuse among adolescent girls: outcome data from an internet-based intervention. Prev Sci. Mar. 2010;11(1):24-32. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 19728091].
115 Siegel JT, Alvaro EM, Crano WD, et al. Influencing inhalant intentions by changing socio-personal expectations. Prev Sci. Sep. 2008;9(3):153-65. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 18543103].
116 Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with internet-based screening and brief intervention: A randomized controlled trial. Drug Alcohol Depend. Nov. 2012;126(1-2):42-50. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 22613182].
117 Slesnick N, Kang MJ. The impact of an integrated treatment on HIV risk behavior among homeless youth: a randomized controlled trial. J Behav Med. Feb. 2008;31(1):45-59. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 17940861].
118 Smith DC, Hall JA, Williams JK, et al. Comparative efficacy of family and group treatment for adolescent substance abuse. Am J Addict. 2006;15:Suppl-6. KQ1E3, KQ2E3, KQ3E3. [pmid: 17182429].
119 Smith DK, Chamberlain P, Eddy JM. Preliminary support for multidimensional treatment foster care in reducing substance use in delinquent boys. J Child Adolesc Subst Abuse. 2010;19(4):343-58. KQ1E5c, KQ2E5c, KQ3E5c. [pmid: 20953309].
120 Srisurapanont M, Sombatmai S, Boripuntakul T. Brief intervention for students with methamphetamine use disorders: a randomized controlled trial. Am J Addict. Mar. 2007;16(2):111-6. KQ1E1, KQ2E1, KQ3E1. [pmid: 17453612].
121 Stanger C, Budney AJ, Kamon JL, et al. A randomized trial of contingency management for adolescent marijuana abuse and dependence. Drug Alcohol Depend. Dec. 1. 2009;105(3):240-7. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 19717250].
122 Stern SA, Meredith LS, Gholson J, et al. Project CHAT: a brief motivational substance abuse intervention for teens in primary care. J Subst Abuse Treat. 2007;32(2):153-65. KQ1E4, KQ2E4, KQ3E4. [pmid: 17306724].
123 Stormshak EA, Connell AM, Veronneau MH, et al. An ecological approach to promoting early adolescent mental health and social adaptation: family-centered intervention in public middle schools. Child Dev. Jan. 2011;82(1):209-25. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 21291438].
124 Tait RJ, Hulse GK, Robertson SI. Effectiveness of a brief-intervention and continuity of care in enhancing attendance for treatment by adolescent substance users. Drug Alcohol Depend. Jun. 11. 2004;74(3):289-96. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 15194207].
125 Tait RJ, Hulse GK, Robertson SI, et al. Emergency department-based intervention with adolescent substance users: 12-month outcomes. Drug Alcohol Depend. Sep. 1. 2005;79(3):359-63. KQ1E5b, KQ2E5b, KQ3E5b. [pmid: 16102378].
126 Vitaro F, Dobkin PL. Prevention of substance use/abuse in early adolescents with behavior problems. J Alcohol Drug Educ. 1996;41(2):11-38. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
127 Waldron HB, Slesnick N, Brody JL, et al. Treatment outcomes for adolescent substance abuse at 4- and 7-month assessments. J Consult Clin Psychol. Oct. 2001;69(5):802-13. KQ1E5c, KQ2E5c, KQ3E5c. [pmid: 11680557].
128 Walker DD, Stephens R, Roffman R, et al. Randomized controlled trial of motivational enhancement therapy with nontreatment-seeking adolescent cannabis users: a further test of the teen marijuana check-up. Psychol Addict Behav. Sep. 2011;25(3):474-84. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 21688877].
129 Walton MA, Bohnert K, Resko S, et al. Computer and therapist based brief interventions among cannabis-using adolescents presenting to primary care: One year outcomes. Drug Alcohol Depend. 2013. May. 24. KQ3E4. [pmid: 23711998].
130 Wechsberg WM, Novak SP, Zule WA, et al. Sustainability of intervention effects of an evidence-based HIV prevention intervention for African American women who smoke crack cocaine. Drug Alcohol Depend. Jun. 1. 2010;109(1-3):205-12. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 20219294].
131 Weiss FL, Nicholson HJ. Friendly PEERsuasion against substance use: The Girls Incorporated model and evaluation. Drugs Soc. 1998;12(1-2):7-22. PMID: None. KQ1E4, KQ2E4, KQ3E4.
132 Werch CC, Moore MJ, DiClemente CC, et al. A multihealth behavior intervention integrating physical activity and substance use prevention for adolescents. Prev Sci. Sep. 2005;6(3):213-26. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 16133900].
133 Werch CE, Moore MM, DiClemente CC, et al. Single vs. multiple drug prevention: is more always better?: a pilot study. Subst Use Misuse. 2005;40(8):1085-101. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 16040370].
134 Werch CE, Moore MJ, Bian H, et al. Efficacy of a brief image-based multiple-behavior intervention for college students. Ann Behav Med. Oct. 2008;36(2):149-57. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 18800217].
135 Werch CE, Bian H, Moore MJ, et al. Brief multiple behavior health interventions for older adolescents. Am J Health Promot. Nov. 2008;23(2):92-6. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 19004157].
136 Whicher EV, Utku F, Schirmer G, et al. Pilot project to evaluate the effectiveness and acceptability of single-session brief counseling for the prevention of substance misuse in pregnant adolescents. Addict Disord Their Treat. 2012;11(1):43-9. PMID: None. KQ1E8, KQ2E8, KQ3E8.
137 Wiggins M, Bonell C, Sawtell M, et al. Health outcomes of youth development programme in England: prospective matched comparison study. BMJ. 2009;339:b2534. KQ1E7a, KQ2E7a, KQ3E7a. [pmid: 19584408].
138 Williams C, Griffin KW, Macaulay AP, et al. Efficacy of a drug prevention CD-ROM intervention for adolescents. Subst Use Misuse. 2005;40(6):869-78. KQ1E9, KQ2E9, KQ3E9. [pmid: 15974146].
139 Winters K. Brief intervention for drug-abusing adolescents. Proceedings of the 70th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2008 Jun 14. San Juan, Puerto Rico. 2008:204. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a.
140 Winters KC, Leitten W. Brief intervention for drug-abusing adolescents in a school setting. Psychol Addict Behav. Jun. 2007;21(2):249-54. KQ1E2a, KQ2E2a, KQ3E2a. [pmid: 17563146].
141 Wolchik SA, Sandler IN, Millsap RE, et al. Six-year follow-up of preventive interventions for children of divorce: a randomized controlled trial. JAMA. Oct. 16. 2002;288(15):1874-81. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 12377086].
142 Wolchik SA, Millsap RE. Group based interventions for mothers and mothers plus children reduced mental health problems in adolescent children of divorced parents. Evid Based Nurs. 2003;6(3):74. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 12882187].
143 Zahradnik A, Otto C, Crackau B, et al. Randomized controlled trial of a brief intervention for problematic prescription drug use in non-treatment-seeking patients. Addiction. Jan. 2009;104(1):109-17. KQ1E5a, KQ2E5a, KQ3E5a. [pmid: 19133895].
144 Zonnevylle-Bender MJ, Matthys W, van de Wiel NM, et al. Preventive effects of treatment of disruptive behavior disorder in middle childhood on substance use and delinquent behavior. J Amer Acad Child Adolesc Psychiatry. Jan. 2007;46(1):33-9. KQ1E7a, KQ2E7a, KQ3E7a. [pmid: 17195727].