# Detailed Methods

## Systematic Review Search Strategies

### Database of Abstracts of Reviews of Effects (DARE) search strategy

1. (addict* OR abuse* OR abusing OR misus* OR nonmedical OR “non medical”):ti,ab,kw IN DARE FROM 2007 TO 2012
2. (drug OR drugs OR substance* OR opioid* OR opiate* OR prescription* OR psychotherapeutic*):ti,ab,kw IN DARE FROM 2007 TO 2012
3. #1 AND #2
4. (drug use* OR substance use* ):ti,ab,kw IN DARE FROM 2007 TO 2012
5. #3 OR #4
6. (child OR children OR teen OR teens OR teenage* OR adolescen* OR youth OR youths OR “young people”):ti,ab,kw IN DARE FROM 2007 TO 2012
7. #5 AND #6

### MEDLINE (Ovid) search strategy

Database(s): Ovid MEDLINE(R) without Revisions 1996 to November Week 3 2012, Ovid MEDLINE(R) Daily Update November 14, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations November 21, 2012

# Searches
1. substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or inhalant abuse/ or marijuana abuse/ or opioid-related disorders/ or heroin dependence/ or morphine dependence/ or phencyclidine abuse/ or substance abuse, intravenous/
2. Prescription Drug$.ti,ab,mh.
3. ((drug or drugs or substance* or opioid* or opiate* or prescription* or psychotherapeutic*) adj3 (addict* or abuse* or abusing or misus* or nonmedical or non medical)).ti,ab.
4. (drug use$ or substance use$).ti,ab.
5. 1 or 2 or 3 or 4
6. Mass Screening/
7. screen$.ti,ab.
8. 6 or 7
9. 5 and 8
10. substance abuse detection/
11. 9 or 10
12. adolescent/ or child/
13. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people).ti,ab.
14. 12 or 13
15. 11 and 14
16. limit 15 to systematic reviews
17. limit 16 to (english language and yr=“2007 -Current”)
18. Behavior Therapy/
19. Cognitive Therapy/
20. Directive Counseling/ or Counseling/
21. Patient Education as Topic/
22. Risk Reduction Behavior/
23. counsel$.ti,ab.
24. advice.ti,ab.
25. advise$.ti,ab.
26. behavio?r$ chang$.ti,ab.
27. behavio?r$ intervention$.ti,ab.
28. behavio?r$ modification$.ti,ab.
29. motivational interview$.ti,ab.
30. substance-related disorders/dt, pc, rh, th or amphetamine-related disorders/dt, pc, rh, th or cocaine-related disorders/dt, pc, rh, th or inhalant abuse/dt, pc, rh, th or marijuana abuse/dt, pc, rh, th or opioid-related disorders/dt, pc, rh, th or heroin dependence/dt, pc, rh, th or morphine dependence/dt, pc, rh, th or phencyclidine abuse/dt, pc, rh, th or substance abuse, intravenous/dt, pc, rh, th
31. (intervention$ or prevention or preventive or psychosocial).ti.
32. or/18-31
33. 5 and 14 and 32
34. limit 33 to systematic reviews
35. limit 34 to (english language and yr=“2007 -Current”)
36. 17 or 35
37. remove duplicates from 36

### PubMed search strategy (searched only for “publisher” unindexed references)

#1 (drug[tiab] OR drugs[tiab] OR substance*[tiab] OR opioid*[tiab] OR opiate*[tiab] OR prescription*[tiab] OR psychotherapeutic*[tiab]) AND (ict*[tiab] OR abuse*[tiab] OR abusing[tiab] OR misus*[tiab] OR nonmedical[tiab] OR “non medical”[tiab])
#2 drug use*[tiab] OR substance use* [tiab]
#3 #1 OR #2
#4 screen* [tiab]
#5 counsel*[tiab]
#6 advice[tiab]
#7 advise*[tiab]
#8 behavi*[tiab] AND change*[tiab]
#9 motivational*[tiab] AND interview*[tiab]
#10 behavi*[tiab] AND intervention*[tiab]
#11 behavi*[tiab] AND modification*[tiab]
#12 #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11
#13 #3 AND #12
#14 child[tiab] OR children[tiab] OR teen[tiab] OR teens[tiab] OR teenage* [tiab] OR adolescen* [tiab] OR youth[tiab] OR youths[tiab] OR “young people”[tiab]
#15 #13 AND #14
#16 #15 AND systematic[sb]
#17 #16 AND publisher[sb]

### PsycINFO search strategy

#1 Drug Abuse OR Drug Abuse Prevention OR Drug Addiction OR Drug Dependency OR Drug Usage OR Intravenous Drug Usage OR Polydrug Abuse:Index Terms
#2 (School Age (6-12 yrs) OR Adolescence (13-17 yrs)): Age Group
#3 ( Systematic Review): Methodology
#4 #1 AND #2 AND #3 AND [2007 TO 2012]:PublicationYear

## Key Question Search Strategies

Ovid MEDLINE(R) without Revisions 1996 to January Week 1 2013, Ovid MEDLINE(R) 1988 to 1995, Ovid MEDLINE(R) Daily Update January 15, 2013, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations January 15, 2013

# Searches
1. substance-related disorders/
2. amphetamine-related disorders/
3. cocaine-related disorders/
4. inhalant abuse/
5. marijuana abuse/
6. opioid-related disorders/
7. phencyclidine abuse/
8. substance abuse, intravenous/
9. ((drug or drugs or substance$ or opioid$ or opiate$ or prescription$ or psychotherapeutic$) adj3 (abuse$ or abusing or misus$ or nonmedical or non medical or extramedical or extra medical)).ti,ab.
10. (drug use$ or substance use$).ti,ab.
11. drug abstinence.ti,ab.
12. street drugs/
13. hallucinogens/
14. marijuana.ti,ab.
15. cocaine.ti,ab.
16. methamphetamine.ti,ab.
17. (mdma or ecstasy).ti,ab.
18. lsd.ti,ab.
19. ((ritalin or adderall or methylphenidate or oxycodone or hydrocodone or pain relief or pain reliever$ or pain medication$) adj3 (abuse$ or abusing or misus$ or nonmedical or non medical or extramedical or extra medical)).ti,ab.
20. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21. adolescent/ or child/
22. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
23. 21 or 22
24. Behavior Therapy/
25. Cognitive Therapy/
26. Counseling/
27. Directive Counseling/
28. Patient Education as Topic/
29. Risk Reduction Behavior/
30. Feedback, psychological/
31. Health education/
32. Health promotion/
33. Motivation/
34. Internet/
35. Motivational interviewing/
36. Persuasive communication/
37. Preventive health services/
38. Self-help groups/
39. Text messaging/
40. Therapy, computer-assisted/
41. counsel$.ti,ab.
42. advice.ti,ab.
43. advise$.ti,ab.
44. behavio?r$ chang$.ti,ab.
45. behavio?r$ intervention$.ti,ab.
46. behavio?r$ modification$.ti,ab.
47. motivational interview$.ti,ab.
48. (cognitive behavio$ or behavio$ therapy or cbt).ti,ab.
49. brief intervention$.ti,ab.
50. computer based.ti,ab.
51. self help.ti,ab.
52. email$.ti,ab.
53. internet.ti,ab.
54. text messag$.ti,ab.
55. (web or website).ti,ab.
56. (intervention$ or prevention or preventive or psychosocial).ti.
57. 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
58. substance-related disorders/pc
59. amphetamine-related disorders/pc
60. cocaine-related disorders/pc
61. inhalant abuse/pc
62. marijuana abuse/pc
63. opioid-related disorders/pc
64. phencyclidine abuse/pc
65. substance abuse, intravenous/pc
66. 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65
67. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
68. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
69. Meta-Analysis as Topic/
70. random$.ti,ab.
71. clinical trial$.ti,ab.
72. controlled trial$.ti,ab.
73. 67 or 68 or 69 or 70 or 71 or 72
74. 20 and 23 and 57 and 73
75. 23 and 66 and 73
76. 74 or 75
77. limit 76 to (english language and yr=“1992 -Current”)
78. remove duplicates from 77

### PubMed (publisher subset only) 1/16/2013

Search | Query
#26 | Search #24 AND publisher[sb] Filters: Publication date from 1992/01/01 to 2013/12/31; English Sort by: PublicationDate
#25 | Search #24 AND publisher[sb]
#24 | Search #22 AND #23
#23 | Search random*[tiab] OR clinical trial*[tiab] OR controlled trial*[tiab]
#22 | Search #10 AND #21
#21 | Search #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20
#20 | Search intervention*[ti] OR prevention[ti] OR preventive[ti] OR psychosocial[ti]
#19 | Search “patient education”[tiab] OR “health education”[tiab] OR “health promotion”[tiab]
#18 | Search email*[tiab] OR internet[tiab] OR text messag*[tiab] OR web[tiab] OR website[tiab]
#17 | Search cbt[tiab] OR brief intervention*[tiab] OR computer based[tiab] OR self help[tiab]
#16 | Search behavio*[tiab] AND therapy[tiab]
#15 | Search motivational interview*[tiab] OR cognitive behavio*[tiab]
#14 | Search behavio*[tiab] AND modification*[tiab]
#13 | Search behavio*[tiab] AND intervention*[tiab]
#12 | Search behavio*[tiab] AND chang*[tiab]
#11 | Search counsel*[tiab] OR advice[tiab] OR advise*[tiab]
#10 | Search #8 AND #9
#9 | Search child*[tiab] OR teen[tiab] OR teens[tiab] OR teenage*[tiab] OR adolescen*[tiab] OR youth[tiab] OR youths[tiab] OR “young people”[tiab] OR pediatric*[tiab] OR paediatric*[tiab]
#8 | Search #3 OR #4 OR #5 OR #7
#7 | Search #2 AND #6
#6 | Search ritalin[tiab] OR adderall[tiab] OR methylphenidate[tiab] OR oxycodone[tiab] OR hydrocodone[tiab] OR “pain relief”[tiab] OR pain reliever*[tiab] OR pain medication*[tiab]
#5 | Search marijuana[tiab] OR cocaine[tiab] OR methamphetamine[tiab] OR mdma[tiab] OR ecstasy[tiab] OR lsd[tiab]
#4 | Search drug use*[tiab] OR substance use*[tiab]
#3 | Search #1 AND #2
#2 | Search abuse*[tiab] OR abusing[tiab] OR misus*[tiab] OR nonmedical[tiab] OR “non medical”[tiab] OR extramedical[tiab] OR “extra medical”[tiab]
#1 | Search drug[tiab] OR drugs[tiab] OR substance*[tiab] OR opioid*[tiab] OR opiate*[tiab] OR prescription*[tiab] OR psychotherapeutic*[tiab]

### Ovid PsycINFO 1987 to January Week 2 2013

# Searches
1. Drug Abuse/
2. Drug Usage/
3. Inhalant Abuse/
4. Glue Sniffing/
5. Polydrug Abuse/
6. Drug Abstinence/
7. Intravenous Drug Usage/
8. Marijuana Usage/
9. Cocaine/
10. Opiates/
11. Hallucinogenic Drugs/
12. Phencyclidine/
13. Methamphetamine/
14. Methylenedioxymethamphetamine/
15. Lysergic Acid Diethylamide/
16. ((drug or drugs or substance$ or opioid$ or opiate$ or prescription$ or psychotherapeutic$) adj3 (abuse$ or abusing or misus$ or nonmedical or non medical or extramedical or extra medical)).ti,ab.
17. (drug use$ or substance use$).ti,ab.
18. ((ritalin or adderall or methylphenidate or oxycodone or hydrocodone or pain relief or pain reliever$ or pain medication$) adj3 (abuse$ or abusing or misus$ or nonmedical or non medical or extramedical or extra medical)).ti,ab.
19. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18
20. Health Promotion/
21. Motivation/
22. behavio?r$ chang$.ti,ab.
23. behavio?r$ intervention$.ti,ab.
24. behavio?r$ modification$.ti,ab.
25. behavior therapy/
26. cognitive behavior therapy/
27. cognitive therapy/
28. Cognitive Techniques/
29. (cognitive behavio$ or behavio$ therapy or cbt).ti,ab.
30. brief intervention$.ti,ab.
31. Behavior Modification/
32. Behavior Change/
33. Persuasive Communication/
34. Motivational Interviewing/
35. motivational interview$.ti,ab.
36. Health Knowledge/
37. Health Behavior/
38. Health Education/
39. Client Education/
40. Feedback/
41. Online Therapy/
42. Computer Assisted Therapy/
43. Computer Mediated Communication/
44. Internet/
45. computer based.ti,ab.
46. text messag$.ti,ab.
47. email$.ti,ab.
48. internet.ti,ab.
49. (web or website).ti,ab.
50. Self Help Techniques/
51. self help.ti,ab.
52. counseling/
53. Group Counseling/
54. counseling.ti,ab.
55. counselling.ti,ab.
56. advice.ti,ab.
57. advise$.ti,ab.
58. (intervention$ or prevention or preventive or psychosocial).ti.
59. 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58
60. 19 and 59
61. Drug Abuse Prevention/
62. 60 or 61
63. (adolescence 13 17 yrs or childhood birth 12 yrs).ag.
64. (child$ or adolescen$ or teen$ or youth$ or young people or pediatric$ or paediatric$).ti,ab.
65. 63 or 64
66. 62 and 65
67. treatment outcome clinical trial.md.
68. Experiment Controls/
69. controlled trial$.ti,ab.
70. clinical trial$.ti,ab.
71. random$.ti,ab.
72. meta analy$.ti,ab.
73. metaanaly$.ti,ab.
74. 67 or 68 or 69 or 70 or 71 or 72 or 73
75. 66 and 74
76. limit 75 to (english language and yr=“1992 -Current”)

### Cochrane Central Register of Controlled Trials, Issue 12 of 12, Dec. 2012

#1 drug:ti,ab,kw or drugs:ti,ab,kw or substance*:ti,ab,kw or opioid*:ti,ab,kw or opiate*:ti,ab,kw or prescription*:ti,ab,kw or psychotherapeutic*:ti,ab,kw from 1992 to 2013, in Trials
#2 abuse*:ti,ab,kw or abusing:ti,ab,kw or misus*:ti,ab,kw or nonmedical:ti,ab,kw or “non medical”:ti,ab,kw or extramedical:ti,ab,kw or “extra medical”:ti,ab,kw from 1992 to 2013, in Trials
#3 #1 and #2 from 1992 to 2013, in Trials
#4 drug next use*:ti,ab,kw or substance next use*:ti,ab,kw from 1992 to 2013, in Trials
#5 marijuana:ti,ab,kw or cocaine:ti,ab,kw or methamphetamine:ti,ab,kw or mdma:ti,ab,kw or ecstasy:ti,ab,kw or lsd:ti,ab,kw from 1992 to 2013, in Trials
#6 ritalin:ti,ab,kw or adderall:ti,ab,kw or methylphenidate:ti,ab,kw or oxycodone:ti,ab,kw or hydrocodone:ti,ab,kw or “pain relief”:ti,ab,kw or pain next reliever*:ti,ab,kw or pain next medication*:ti,ab,kw from 1992 to 2013, in Trials
#7 #2 and #6 from 1992 to 2013, in Trials
#8 #3 or #4 or #5 or #7 from 1992 to 2013, in Trials
#9 child*:ti,ab,kw or teen:ti,ab,kw or teens:ti,ab,kw or teenage*:ti,ab,kw or adolescen*:ti,ab,kw or youth:ti,ab,kw or youths:ti,ab,kw or “young people”:ti,ab,kw or pediatric*:ti,ab,kw or paediatric*:ti,ab,kw from 1992 to 2013, in Trials
#10 #8 and #9 from 1992 to 2013, in Trials
#11 counsel*:ti,ab,kw or advice:ti,ab,kw or advise*:ti,ab,kw from 1992 to 2013, in Trials
#12 behavio*:ti,ab,kw and chang*:ti,ab,kw from 1992 to 2013, in Trials
#13 behavio*:ti,ab,kw and intervention*:ti,ab,kw from 1992 to 2013, in Trials
#14 behavio*:ti,ab,kw and modification*:ti,ab,kw from 1992 to 2013, in Trials
#15 motivational next interview*:ti,ab,kw or cognitive next behavio*:ti,ab,kw from 1992 to 2013, in Trials
#16 behavio*:ti,ab,kw and therapy:ti,ab,kw from 1992 to 2013, in Trials
#17 cbt:ti,ab,kw or brief next intervention*:ti,ab,kw or computer next based:ti,ab,kw or “self help”:ti,ab,kw from 1992 to 2013, in Trials
#18 email*:ti,ab,kw or internet:ti,ab,kw or text next messag*:ti,ab,kw or web:ti,ab,kw or website:ti,ab,kw from 1992 to 2013, in Trials
#19 “patient education”:ti,ab,kw or “health education”:ti,ab,kw or “health promotion”:ti,ab,kw from 1992 to 2013, in Trials
#20 intervention*:ti or prevention:ti or preventive:ti or psychosocial:ti from 1992 to 2013, in Trials
#21 #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 from 1992 to 2013, in Trials
#22 #10 and #21 from 1992 to 2013, in Trials

Appendix A Figure 1 Literature Flow Diagram

Appendix A Figure 1 displays the literature search results and article flow for the review. A total of 4,279 articles were identified through database searching, and 71 articles were identified through other sources. 2,219 articles were screened after duplicates were removed. 143 full-text articles were assessed for eligibility. Five articles (4 studies) were included for KQ 1. Seven articles (6 studies) were included for KQ 2. No articles were included for KQ 3.

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | Preventing and/or reducing drug use is a primary aim with or without addressing other substances or behaviors (e.g., addressing drug use and alcohol and tobacco use, addressing drug use and risky sexual behaviors) | Targeting another behavior is only aim (e.g., alcohol misuse, tobacco use) (i.e., change in drug use is not a stated aim but is reported outcome)
Condition | Children or adolescents who are at the following stages of use: 1) never use, 2) experimentation, 3) regular use, or 4) problem use. Use of the following drugs:; ■ Cannabinoids (marijuana, hashish^*^, synthetic marijuana); ■ Prescription drugs for nonmedical purposes^*^ (opioid pain relievers, CNS depressants, stimulants); ■ Stimulants (cocaine, amphetamine^*^, methamphetamine^*^); ■ Opioids (heroin, opium^*^); ■ Club drugs^*^ (MDMA [ecstasy], flunitrazepam, GHB); ■ Dissociative drugs^*^ (ketamine, PCP and analogs, Salvia divinorum, DXM); ■ Hallucinogens^*^ (LSD [acid], mescaline, Psilocybin); ■ Inhalants^*^ (also known as volatile substances); ■ Other emerging drugs^*^ (Salvia, bath salts); ■ Use of over-the-counter drugs for psychoactive purposes (e.g., cough and cold medicines,; ■ sleep aids); ■ Combination of the above drugs | ■ Diagnosis of drug abuse or dependence (DSM-IV-TR) or drug use disorder (DSM V) (studies of children and adolescents narratively described; ■ as “substance abusing” will be included); ■ Medical use of drugs as prescribed; ■ Nonpsychoactive drugs (e.g., anabolic steroids, laxatives, aspirin)
Population | ■ Children and adolescents (age ≤18 years) (includes studies in which >50% of participants are ≤18 years or subgroup of participants age ≤18 years are analyzed and reported separately from adults), including trials limited to targeted groups with cognitive, mental health, or other health issues and trials limited to pregnant adolescents | ■ Adults (age >18), unless adolescent subgroup results reported separately from adult results; ■ Treatment-seeking children or adolescents; ■ Children and adolescents who are referred to treatment by juvenile justice system, social or health agency, parents, or otherwise directly referred for substance abuse treatment in specialty settings; ■ Trials in which ≥50% of the sample have severe mental health issues, such as schizophrenia, bipolar disorder, major depression, or acute psychosis; ■ Trials in which ≥50% of the sample are diagnosed as having drug abuse or dependence (DSM-IV-TR) or a drug use disorder (DSM V); ■ Trials limited to other groups not generalizable to primary care: psychiatric inpatients, individuals in juvenile detention centers, court-mandated, juvenile offenders
Interventions | Primary care–relevant behavioral counseling interventions designed primarily to prevent or reduce the nonmedical use of drugs with or without referral. Including, but not limited to: advice, brief intervention^†^, motivational interviewing, action plans, written materials, and personalized feedback. Conducted in primary care (i.e., office-based) or judged to be feasible or applicable to primary care:; ■ Whom targeted: Individual-level identification; ■ Who delivered: Usually involves primary care staff (primary care clinicians [e.g., family medicine, internal medicine, pediatrics], nurses, nurse practitioners, physician assistants, or related clinical staff [e.g., social workers, health educators, other counselors]) in some direct or indirect way or is seen as connected to the health care system by participant; ■ How delivered: To individuals or in small groups (≤15). Generally involves no more than 8 group sessions total, and intervention time period is no longer than 12 months; ■ Where delivered: Located anywhere, as long as linked to health care (e.g., clinic, research setting, community, home, or interactive technologies [e.g., Web, text]) or primary care referable, such that the intervention is conducted as part of a health care setting or is widely available in the community (i.e., open enrollment) | ■ Detoxification, medically managed withdrawal, or opioid substitution therapy (methadone maintenance programs); ■ Maintaining abstinence after substance use treatment for abuse or dependence (i.e., secondary abstinence); ■ Broad public health, media, or policy interventions; ■ Trials within closed (pre-existing) social networks (e.g., worksites, churches, schools); ■ Inpatient/residential treatment (short- or long-term); ■ Contingency management/vouchers; ■ Vocational rehabilitation/Customized Employment Supports (CES); ■ Outward Bound/life skills training; ■ Payer-level interventions aimed at influencing patient utilization
Comparators | ■ No intervention; ■ Usual care; ■ Waitlist; ■ Attention control (e.g., similar in format and intensity, but intervention on a different content area); ■ Minimal intervention (no more than 1 single brief contact [i.e., <5 minutes] per year or brief written materials such as pamphlets) | Active intervention (i.e., more than a single brief contact per year or brief written materials); comparative effectiveness
Outcomes | KQ 1: Health, Social, Educational, and Other Outcomes Health Outcomes:; ■ All-cause mortality; ■ Drug-related mortality (intentional and unintentional); ■ Drug-related morbidity (including, but not limited to: mental health disorders; STI/HIV transmission; hepatitis B or C transmission; unintended pregnancy/pregnancy complications; respiratory infections; cardiovascular complications; stroke; seizures); ■ Drug-related injury or accidents; ■ Other risky behaviors (e.g., alcohol, tobacco, other drug use; risky sexual behaviors); ■ Nonfatal overdose; ■ Quality of life; ■ Other related health outcome; Social, Educational, or Other Outcomes:; ■ Health care utilization; ■ Global functioning; ■ Educational attainment/school performance; ■ Social/legal outcomes (e.g., incarcerations, out-of-home juvenile placements, criminal activity, violence, drugged driving); ■ Family functioning; ■ Other related social or educational outcome; KQ 2: Behavioral Outcomes (Based on self-report or toxicology screen; will favor outcomes with biochemical verification); ■ No use; ■ Frequency of use; ■ Quantity of use; KQ 3: Adverse Events; ■ Serious treatment-related harms at any time point after the intervention began (e.g., death, including suicide, seizure, cardiovascular event, or other medical issue requiring urgent medical treatment); ■ Paradoxical increase in drug use; ■ Demoralization due to failed quit attempt | ■ Attitudes, knowledge, beliefs related to drug use; ■ Intentions to change behavior; ■ Intervention participation/compliance
Outcome assessment timing | ≥6-month followup postbaseline assessment (26 weeks) (Note: Studies with shorter followup will not be excluded at the title/abstract review phase so that we can evaluate how many total studies would be excluded for this reason only) | <6-month followup postbaseline assessment
Setting | ■ Primary care settings; ■ Emergency departments; ■ Other settings included if study is linked to primary care or other health care, including: research clinics/offices, community centers, homes, and virtual (e.g., online support groups) | ■ Substance abuse treatment centers; ■ School classrooms; ■ Worksites; ■ Inpatient/residential; ■ Other institutions (e.g., juvenile detention facilities)
Study Design | KQs 1–3:; ■ RCTs; ■ Cluster-randomized controlled trials; ■ Nonrandomized controlled trials (CCTs) | KQs 1–3:; ■ Prospective or retrospective cohort studies; ■ Case-control studies; ■ Time series studies; ■ Before-after studies; ■ Cross-sectional studies; ■ Editorials, commentaries, case study, case series
Study geography | Developed countries, rated “Very High” according to the 2011 Human Development Index (http://hdr.undp.org/en/statistics): Andorra, Argentina, Australia, Austria, Bahrain, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, China (SAR), Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea (Republic of, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States | Countries with a Human Development Index below “Very High”
Publication language | English | Any language other than English
Publication date | 1992 to present | Studies published before 1992
Quality rating | Fair or good quality | Poor quality

* Not included in 2008 review.

† Brief Intervention: typically delivered to those individuals at low to moderate risk. Goal is to provide education or advice, increase motivation to avoid substance use, or to teach behavior change skills that will reduce substance use as well as the chances of negative consequences. Usually involves 1 to 2 sessions that each last 5 minutes to 1 hour.

Abbreviations: CNS = central nervous system; DSM = Diagnostic and Statistical Manual of Mental Disorders; DXM = dextromethorphan; GHB = gamma-hydroxybutyrate; KQ = Key Question, LSD = lysergic acid diethylamine; MDMA = methylenedioxy-methamphetamine; PCP = phencyclidine.

Appendix A Table 2 Quality Criteria and Ratings Used for Article Assessment29

Criteria | Good Rating | Fair Rating | Poor Rating
Initial assembly of comparable groups (adequate randomization, including first concealment and whether potential confounders were distributed equally among groups) | Met all criteria: Comparable groups were assembled initially and maintained throughout the study (overall followup at least 90% and difference in followup between groups no greater than 10 percentage points); reliable and valid measurement instruments were used and applied equally to the groups; interventions were spelled out clearly; all important outcomes were considered; and appropriate attention to confounders in analysis; participants were analyzed in the groups to which they were randomized. Conservative data substitution methods were used, such as baseline observation carried forward or multiple imputation, where data substitution is used. | Studies were graded “fair” if any or allof the following problems occurred, without the fatal flaws noted in the “poor” category: Generally comparable groups were assembled initially but some question remained whether some (although not major) differences occurred with followup; measurement instruments were acceptable (although not the best) and generally applied equally; some but not all important outcomes were considered; and some but not all potential confounders were accounted for. Participants were analyzed in the groups to which they were randomized. | Studies were graded “poor” if any of the following fatal flaws existed: Groups assembled initially were not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments were used or not applied at all equally among groups (including not masking outcome assessment); key confounders were given little or no attention; or participants were analyzed according to intervention received, rather than an intention-to-treat approach.
Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
Important differential loss to followup or overall high loss to followup
Equal, reliable, and valid measurements (includes masking of outcome assessment)
Clear definition of interventions
All important outcomes considered
Analysis (analyzed according to randomization status [intention-to-treat] rather than intervention received)