# References

1 Humphrey LL, Teutsch S, Johnson M, U. S. Preventive Services Task Force. Lung cancer screening with sputum cytologic examination, chest radiography, and computed tomography: an update for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(9):740-53. [pmid: 15126259].
2 U. S. Preventive Services Task Force. Lung cancer screening: recommendation statement. Ann Intern Med. 2004;140(9):738-9. [pmid: 15126258].
3 Ebeling K, Nischan P. Screening for lung cancer: results from a case-control study. Int J Cancer. 1987;40(2):141-4. [pmid: 3610384].
4 Howlader N, Noone AM, Krapcho M, Neyman N, Aminou R, Waldron W, et al., editors. SEER Cancer Statistics Review, 1975–2009 (Vintage 2009 Populations). Bethesda, MD. National Cancer Institute. 2011. Accessed at http://seer.cancer.gov/csr/1975_2009_pops09 on 8 August 2013.
5 Travis WD, Brambilla E, Noguchi M, Nicholson AG, Geisinger KR, Yatabe Y, et al. International Association for the Study of Lung Cancer/American Thoracic Society/European Respiratory Society international multidisciplinary classification of lung adenocarcinoma. J Thorac Oncol. 2011;6(2):244-85. [pmid: 21252716].
6 Clark JR, Rumcheva P, Veness MJ. Analysis and comparison of the 7th edition American Joint Committee on Cancer (AJCC) nodal staging system for metastatic cutaneous squamous cell carcinoma of the head and neck. Ann Surg Oncol. 2012;19(13):4252-8. [pmid: 22805870].
7 Detterbeck FC, Boffa DJ, Tanoue LT. The new lung cancer staging system. Chest. 2009;136(1):260-71. [pmid: 19584208].
8 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2007 Incidence and Mortality Web-Based Report. Atlanta. Centers for Disease Control and Prevention. 2010.
9 American Cancer Society. Cancer Facts & Figures 2010. Atlanta. American Cancer Society. 2010.
10 Naff JL, Cote ML, Wenzlaff AS, Schwartz AG. Racial differences in cancer risk among relatives of patients with early onset lung cancer. Chest. 2007;131(5):1289-94. [pmid: 17400658].
11 Jemal A, Bray F, Center M, Ferlay J, Ward E, Forman D. Global cancer statistics. CA Cancer J Clin. 2011;61:69-90. [pmid: 21296855].
12 Vollset S, Tverdal A, Gjessing H. Smoking and deaths between 40 and 70 years of age in women and men. Ann Intern Med. 2006;144:381-9. [pmid: 16549850].
13 National Cancer Institute. Cancer Trends Progress Report—2011/2012 Update. Bethesda, MD. National Cancer Institute. 2012. Accessed at http://progressreport.cancer.gov/index.asp on 8 August 2013.
14 Strauss GM. Screening for lung cancer: an evidence-based synthesis. Surg Oncol Clin N Am. 1999;8(4):747-74. [pmid: 10452939].
15 Osann K. Lung cancer in women: the importance of smoking, family history of cancer, and medical history of respiratory disease. Cancer Res. 1991;51(18):4893-7. [pmid: 1654203].
16 Sun SS, Schiller JH, Gazdar AF. Lung cancer in never smokers—a different disease. Nat Rev Cancer. 2007;7:778-90. [pmid: 17882278].
17 Tockman M, Anothonisen N, Wright E, Donithan M. Airways obstruction and the risk for lung cancer. Ann Intern Med. 1987;106(4):512-8. [pmid: 3826952].
18 Hole D, Watt G, Davey-Smith G, Hart C, Gillis C, Hawthorne VM. Impaired lung function and mortality risk in men and women: findings from the Renfrew and Paisley prospective population study. BMJ. 1996;313(7059):711-5. [pmid: 8819439].
19 National Cancer Institute. What Do the 2006–2007 Tobacco Use Supplement Data Say About Tobacco Use?. Bethesda, MD. National Cancer Institute. 2012. Accessed at http://riskfactor.cancer.gov/studies/tus-cps/results/data0607/ on 8 August 2013.
20 Centers for Disease Control and Prevention. Vital signs: current cigarette smoking among adults aged ≥18 years—United States, 2005–2010. MMWR Morb Mortal Wkly Rep. 2011;60(35):1207-12. [pmid: 21900875].
21 Mendez D, Warner KE. Setting a challenging yet realistic smoking prevalence target for Healthy People 2020: learning from the California experience. Am J Public Health. 2008;98(3):556-9. [pmid: 17901429].
22 National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines in Oncology: Lung Cancer Screening. Fort Washington, PA. National Comprehensive Cancer Network. 2012.
23 Burns DM. Primary prevention, smoking, and smoking cessation: implications for future trends in lung cancer prevention. Cancer. 2000;89(11 Suppl):2506-9. [pmid: 11147637].
24 Halpern MT, Gillespie BW, Warner KE. Patterns of absolute risk of lung cancer mortality in former smokers. Natl Cancer Inst. 1993;85(6):457-64.
25 Tong L, Spitz MR, Fueger JJ, Amos CA. Lung carcinoma in former smokers. Cancer. 1996;78(5):1004-10. [pmid: 8780538].
26 Skillrud D, Offord K, Miller R. Higher risk of lung cancer in chronic obstructive pulmonary disease: a prospective, matched, controlled study. Ann Intern Med. 1986;105(4):503-7. [pmid: 3752756].
27 Fontham E, Correa P, Reynolds P, Wu-Williams A, Buffler P, Greenberg R. Environmental tobacco smoke and lung cancer in nonsmoking women. JAMA. 1994;271(22):1752-9. [pmid: 8196118].
28 Trichopoulos D, Mollo F, Tomatis L, Agapitos E, Delsedime L, Zavitsanos X. Active and passive smoking and pathological indicators of lung cancer risk in an autopsy study. JAMA. 1992;268(13):1697-701. [pmid: 1527879].
29 Davila D, Williams D. The etiology of lung cancer. Mayo Clin. Proc. 1993;68(2):170-82. [pmid: 8423698].
30 Nesbitt JC, Lee J, Komaki R, Roth JA. Cancer of the lung. Holland JF, Bast RC Jr, Morton DL, Frei E III, Kufe DW, Weichselbaum RR, editors. Cancer Medicine. Baltimore. William & Wilkins. 1997.
31 International Early Lung Cancer Action Program Investigators, Henschke CI, Yip R, Miettinen OS. Women's susceptibility to tobacco carcinogens and survival after diagnosis of lung cancer. JAMA. 2006;296(2):180-4. [pmid: 16835423].
32 Mimura T, Ito A, Sakuma T, et al. Novel marker D2-40, combined with calretinin, CEA, and TTF-1: an optimal set of immunodiagnostic markers for pleural mesothelioma. Cancer. 2007;109(5):933-8. [pmid: 17279584].
33 Slatore CG, Au DH, Gould MK. An official American Thoracic Society systematic review: insurance status and disparities in lung cancer practices and outcomes. Am J Respir Crit Care Med. 2010;182(9):1195-205. [pmid: 21041563].
34 Alberg AJ, Ford JG, Samet JM. Epidemiology of lung cancer: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):29S-55S. [pmid: 17873159].
35 Jett J. Current treatment of unresectable lung cancer. Mayo Clinic Proc. 1993;68(6):603-11.
36 Osann KE, Anton-Culver H, Kurosaki T, Taylor T. Sex differences in lung-cancer risk associated with cigarette smoking. Int J Cancer. 1993;54(1):44-8. [pmid: 8386708].
37 Klabunde CN, Marcus PM, Han PK, et al. Lung cancer screening practices of primary care physicians: results from a national survey. Ann Fam Med. 2012;10(2):102-10. [pmid: 22412001].
38 Klabunde CN, Marcus PM, Silvestri GA, et al. U.S. primary care physicians' lung cancer screening beliefs and recommendations. Am J Prev Med. 2010;39(5):411-20. [pmid: 20965378].
39 Slatore CG, Gould MK, Au DH, Deffebach ME, White E. Lung cancer stage at diagnosis: individual associations in the prospective Vitamins and lifestyle (VITAL) cohort. BMC Cancer. 2011;11:228. [pmid: 21649915].
40 Bach PB, Mirkin JN, Oliver TK, et al. Benefits and harms of CT screening for lung cancer: a systematic review. JAMA. 2012;307(22):2418-29. [pmid: 22610500].
41 American Lung Association. Providing Guidance on Lung Cancer Screening to Patients and Physicians. Washington, DC. American Lung Association. 2012. Accessed at http://www.lung.org/finding-cures/research-news/new-screening-guidelines/lung-cancer-screening.pdf on 8 August 2013.
42 Jaklitsch MT, Jacobson FL, Austin JH, et al. The American Association for Thoracic Surgery guidelines for lung cancer screening using low-dose computed tomography scans for lung cancer survivors and other high-risk groups. J Thor Cardiovas Surg. 2012;144(1):33-8.
43 Wender R, Fontham ET, Barrera E, et al. American Cancer Society lung cancer screening guidelines. CA Cancer J Clin. 2013;63(2):107-17. [pmid: 23315954].
44 Lung Cancer Alliance. Rights and Expectations for Excellence in Lung Cancer Screening and Continuum of Care. Washington, DC. Lung Cancer Alliance. 2013. Accessed at http://www.lungcanceralliance.org/get-information/am-i-at-risk/national-framework-for-lung-screening-excellence.html on 8 August 2013.
45 Ambrose LF, Healton CG, Idige CR. Letter Regarding U.S. Preventive Services Task Force Review of Lung Cancer Screening. Washington, DC. Lung Cancer Alliance. 2012.
46 Ambrose LF, Lopez TJ. Letter Regarding Essential Health Benefits Bulletin. Washington, DC. Lung Cancer Alliance. 2012.
47 National Lung Cancer Partnership. Lung Cancer Screening Trial, Options. [Press release]. Madison, WI. National Lung Cancer Partnership. 2010.
48 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
49 DerSimonian R, Laird NM. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
50 Higgins J, Thompson S, Higgins J. Quatifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
51 Infante M, Cavuto S, Lutman FR, et al. A randomized study of lung cancer screening with spiral computed tomography: three-year results from the DANTE trial. Am J Respir Crit Care Med. 2009;180(5):445-53. [pmid: 19520905].
52 Saghir Z, Dirksen A, Ashraf H, et al. CT screening for lung cancer brings forward early disease. The randomised Danish Lung Cancer Screening Trial: status after five annual screening rounds with low-dose CT. Thorax. 2012;67(4):296-301. [pmid: 22286927].
53 Pastorino U, Rossi M, Rosato V, et al. Annual or biennial CT screening versus observation in heavy smokers: 5-year results of the MILD trial. Eur J Cancer Prev. 2012;21(3):308-15. [pmid: 22465911].
54 National Lung Screening Trial Research Team, Aberle DR, Adams AM, et al. Reduced lung-cancer mortality with low-dose computed tomographic screening. N Engl J Med. 2011;365(5):395-409. [pmid: 21714641].
55 Gohagan J, Marcus P, Fagerstrom R, et al. Baseline findings of a randomized feasibility trial of lung cancer screening with spiral CT scan vs chest radiograph: the Lung Screening Study of the National Cancer Institute. Chest. 2004;126(1):114-21. [pmid: 15249451].
56 van Klaveren RJ, Oudkerk M, Prokop M, et al. Management of lung nodules detected by volume CT scanning. N Engl J Med. 2009;361(23):2221-9. [pmid: 19955524].
57 Lopes Pegna A, Picozzi G, Mascalchi M, et al. Design, recruitment and baseline results of the ITALUNG trial for lung cancer screening with low-dose CT. Lung Cancer. 2009;64(1):34-40. [pmid: 18723240].
58 Marcus PM, Bergstralh EJ, Zweig MH, Harris A, Offord KP, Fontana RS. Extended lung cancer incidence follow-up in the Mayo Lung Project and overdiagnosis. J Natl Cancer Inst. 2006;98(11):748-56. [pmid: 16757699].
59 Oken MM, Hocking WG, Kvale PA, et al. Screening by chest radiograph and lung cancer mortality: the Prostate, Lung, Colorectal, and Ovarian (PLCO) randomized trial. JAMA. 2011;306(17):1865-73. [pmid: 22031728].
60 National Lung Screening Trial Research Team, Aberle DR, Adams AM, et al. Baseline characteristics of participants in the randomized national lung screening trial. J Natl Cancer Inst. 2010;102(23):1771-9. [pmid: 21119104].
61 Infante M, Lutman FR, Cavuto S, et al. Lung cancer screening with spiral CT: baseline results of the randomized DANTE trial. Lung Cancer. 2008;59(3):355-63. [pmid: 17936405].
62 Ashraf H, Tonnesen P, Pedersen JH, Dirksen A, Dossing M. Smoking habits are unaffected by CT screening at 1 year follow up in the Danish Lung Cancer Screening Trial (DLCST). Thorax. 2009;64(5):388-92. [pmid: 19052048].
63 Gietema HA, Wang Y, Xu D, et al. Pulmonary nodules detected at lung cancer screening: interobserver variability of semiautomated volume measurements. Radiol. 2006;241(1):251-7.
64 Xu DM, Gietema H, de Koning H, et al. Nodule management protocol of the NELSON randomised lung cancer screening trial. Lung Cancer. 2006;54(2):177-84. [pmid: 16989922].
65 Xu DM, van Klaveren RJ, de Bock GH, et al. Limited value of shape, margin and CT density in the discrimination between benign and malignant screen detected solid pulmonary nodules of the NELSON trial. Eur J Radiol. 2008;68(2):347-52. [pmid: 17920800].
66 Xu DM, van der Zaag-Loonen HJ, Oudkerk M, et al. Smooth or attached solid indeterminate nodules detected at baseline CT screening in the NELSON study: cancer risk during 1 year of follow-up. Radiol. 2009;250(1):264-72.
67 Xu DM, van Klaveren RJ, de Bock GH, et al. Role of baseline nodule density and changes in density and nodule features in the discrimination between benign and malignant solid indeterminate pulmonary nodules. Eur J Radiol. 2009;70(3):492-8. [pmid: 18417311].
68 van den Bergh KA, Essink-Bot ML, Bunge EM, et al. Impact of computed tomography screening for lung cancer on participants in a randomized controlled trial (NELSON trial). Cancer. 2008;113(2):396-404. [pmid: 18484588].
69 van den Bergh KA, Essink-Bot ML, Borsboom GJ, Scholten E, van Klaveren RJ, de Koning HJ. Long-term effects of lung cancer computed tomography screening on health-related quality of life: the NELSON trial. Eur Respir J. 2011;38:154-61. [pmid: 21148229].
70 van der Aalst CM, van den Bergh KA, Willemsen MC, de Koning HJ, van Klaveren RJ. Lung cancer screening and smoking abstinence: 2 year follow-up data from the Dutch-Belgian randomised controlled lung cancer screening trial. Thorax. 2010;65(7):600-5. [pmid: 20627916].
71 Van't Westeinde SC, van Klaveren RJ. Screening and early detection of lung cancer. Cancer J. 2011;17(1):3-10. [pmid: 21263260].
72 Taylor KL, Cox LS, Zincke N, Mehta L, McGuire C, Gelmann E. Lung cancer screening as a teachable moment for smoking cessation. Lung Cancer. 2007;56(1):125-34. [pmid: 17196298].
73 Croswell JM, Baker SG, Marcus PM, Clapp JD, Kramer BS. Cumulative incidence of false-positive test results in lung cancer screening: a randomized trial. Ann Intern Med. 2010;152(8):505-12. [pmid: 20404381].
74 Gohagan JK, Marcus PM, Fagerstrom RM, et al. Final results of the Lung Screening Study, a randomized feasibility study of spiral CT versus chest x-ray screening for lung cancer. Lung Cancer. 2005;47(1):9-15. [pmid: 15603850].
75 Pinsky PF, Marcus PM, Kramer BS, et al. Diagnostic procedures after a positive spiral computed tomography lung carcinoma screen. Cancer. 2005;103(1):157-63. [pmid: 15529306].
76 Pedersen JH, Ashraf H, Dirksen A, et al. The Danish randomized lung cancer CT screening trial—overall design and results of the prevalence round. J Thorac Oncol. 2009;4(5):608-14. [pmid: 19357536].
77 van den Bergh KA, Essink-Bot ML, Borsboom GJ, et al. Short-term health-related quality of life consequences in a lung cancer CT screening trial (NELSON). Br J Cancer. 2010;102(1):27-34. [pmid: 19935789].
78 van den Bergh KA, Essink-Bot ML, van Klaveren RJ, de Koning HJ. Informed participation in a randomised controlled trial of computed tomography screening for lung cancer. Eur Respir J. 2009;34(3):711-20. [pmid: 19282345].
79 van Iersel CA, de Koning HJ, Draisma G, et al. Risk-based selection from the general population in a screening trial: selection criteria, recruitment and power for the Dutch-Belgian randomised lung cancer multi-slice CT screening trial (NELSON). Int J Cancer. 2006;120(4):868-74. [pmid: 17131307].
80 van der Aalst CM, van Klaveren RJ, van den Bergh KA, Willemsen MC, de Koning HJ. The impact of a lung cancer computed tomography screening result on smoking abstinence. Eur Respir J. 2011;37:1466-37. [pmid: 21148233].
81 Mascalchi M, Belli G, Zappa M, et al. Risk-benefit analysis of X-ray exposure associated with lung cancer screening in the ITALUNG-CT trial. AJR Am J Roentgenol. 2006;187(2):421-9. [pmid: 16861547].
82 Mascalchi M, Mazzoni LN, Falchini M, et al. Dose exposure in the ITALUNG trial of lung cancer screening with low-dose CT. Br J Radiol. 2012;85(1016):1134-9. [pmid: 21976631].
83 Croswell JM, Kramer BS, Kreimer AR, et al. Cumulative incidence of false-positive results in repeated, multimodal cancer screening. Ann Fam Med. 2009;7(3):212-22. [pmid: 19433838].
84 Hocking WG, Hu P, Oken MM, et al. Lung cancer screening in the randomized Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. J Natl Cancer Inst. 2010;102(10):722-31. [pmid: 20442215].
85 Woloshin S, Schwartz LM, Black WC, Kramer BS. Cancer screening campaigns—getting past uninformative persuasion. N Engl J Med. 2012;367(18):1677-9. [pmid: 23113476].
86 Menezes RJ, Roberts HC, Paul NS, et al. Lung cancer screening using low-dose computed tomography in at-risk individuals: the Toronto experience. Lung Cancer. 2010;67(2):177-83. [pmid: 19427055].
87 Swensen SJ, Jett JR, Hartman TE, et al. CT screening for lung cancer: five-year prospective experience. Radiol. 2005;235(1):259-65.
88 Henschke CI, Yankelevitz DF, Smith JP, et al. CT screening for lung cancer: assessing a regimen's diagnostic performance. Clin Imaging. 2004;28(5):317-21. [pmid: 15471661].
89 Toyoda Y, Nakayama T, Kusunoki Y, Iso H, Suzuki T. Sensitivity and specificity of lung cancer screening using chest low-dose computed tomography. Br J Cancer. 2008;98(10):1602-7. [pmid: 18475292].
90 Tsushima K, Sone S, Hanaoka T, Kubo K. Radiological diagnosis of small pulmonary nodules detected on low-dose screening computed tomography. Respirology. 2008;13(6):817-24. [pmid: 18811880].
91 Veronesi G, Bellomi M, Mulshine JL, et al. Lung cancer screening with low-dose computed tomography: a non-invasive diagnostic protocol for baseline lung nodules. Lung Cancer. 2008;61(3):340-9. [pmid: 18308420].
92 Mettler F, Huda W, Yoshizumi T, Mahesh M. Effective doses in radiology and diagnostic nuclear medicine: a catalog. Radiology. 2008;248(1):254. [pmid: 18566177].
93 Brenner D, Doll R, Goodhead D, et al. Cancer risks attributable to low doses of ionizing radiation: assessing what we really know. Proc Natl Acad Sci U S A. 2003;100(24):1363-6.
94 Wagnetz U, Menezes RJ, Boerner S, et al. CT screening for lung cancer: implication of lung biopsy recommendations. AJR Am J Roentgenol. 2012;198(2):351-8. [pmid: 22268177].
95 Liu X, Liang M, Wang Y, et al. The outcome differences of CT screening for lung cancer pre and post following an algorithm in Zhuhai, China. Lung Cancer. 2011;73(2):230-6. [pmid: 21168238].
96 Veronesi G, Bellomi M, Scanagatta P, et al. Difficulties encountered managing nodules detected during a computed tomography lung cancer screening program. J Thorac Cardiovasc Surg. 2008;136(3):611-7. [pmid: 18805261].
97 Wilson DO, Weissfeld JL, Fuhrman CR, et al. The Pittsburgh Lung Screening Study (PLuSS): outcomes within 3 years of a first computed tomography scan. Am J Respir Crit Care Med. 2008;178(9):956-61. [pmid: 18635890].
98 Becker N, Motsch E, Gross ML, et al. Randomized study on early detection of lung cancer with MSCT in Germany: study design and results of the first screening round. J. Cancer Res Clin Oncol. 2012;138:1474-86.
99 Veronesi G, Maisonneuve P, Bellomi M, et al. Estimating overdiagnosis in low-dose computed tomography screening for lung cancer. Ann Intern Med. 2012;157:776-84. [pmid: 23208167].
100 Byrne MM, Weissfeld J, Roberts MS. Anxiety, fear of cancer, and perceived risk of cancer following lung cancer screening. Med Decis Making. 2008;28(6):917-25. [pmid: 18725404].
101 Sinicrope PS, Rabe KG, Brockman TA, et al. Perceptions of lung cancer risk and beliefs in screening accuracy of spiral computed tomography among high-risk lung cancer family members. Acad Radiol. 2010;17(8):1012-25. [pmid: 20599157].
102 Ashraf H, Tonnesen P, Holst Pedersen J, Dirksen A, Thorsen H, Dossing M. Effect of CT screening on smoking habits at 1-year follow-up in the Danish Lung Cancer Screening Trial (DLCST). Thorax. 2009;64(5):388-92. [pmid: 19052048].
103 MacRedmond R, McVey G, Lee M, et al. Screening for lung cancer using low dose CT scanning: results of 2 year follow up. Thorax. 2006;61(1):54-6. [pmid: 16396954].
104 Anderson CM, Yip R, Henschke CI, Yankelevitz DF, Ostroff JS, Burns DM. Smoking cessation and relapse during a lung cancer screening program. Cancer Epidemiol Biomarkers Prev. 2009;18(12):3476-83. [pmid: 19959698].
105 Cox LS, Clark MM, Jett JR, et al. Change in smoking status after spiral chest computed tomography scan screening. Cancer. 2003;98(11):2495-501. [pmid: 14635086].
106 Townsend CO, Clark MM, Jett JR, et al. Relation between smoking cessation and receiving results from three annual spiral chest computed tomography scans for lung carcinoma screening. Cancer. 2005;103(10):2154-62. [pmid: 15825210].
107 Styn MA, Land SR, Perkins KA, Wilson DO, Romkes M, Weissfeld JL. Smoking behavior 1 year after computed tomography screening for lung cancer: effect of physician referral for abnormal CT findings. Cancer Epidemiol Biomarkers Prev. 2009;18(12):3484-9. [pmid: 19959699].
108 Chang MY, Mentzer SJ, Colson YL, et al. Factors predicting poor survival after resection of stage IA non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007;134(4):850-6. [pmid: 17903494].
109 Christian C, Erica S, Morandi U. The prognostic impact of tumor size in resected stage I non-small cell lung cancer: evidence for a two thresholds tumor diameters classification. Lung Cancer. 2006;54(2):185-91. [pmid: 16996167].
110 Goodgame B, Viswanathan A, Miller CR, et al. A clinical model to estimate recurrence risk in resected stage I non-small cell lung cancer. Am J Clin Oncol. 2008;31(1):22-8. [pmid: 18376223].
111 Goya T, Asamura H, Yoshimura H, et al. Prognosis of 6644 resected non-small cell lung cancers in Japan: a Japanese lung cancer registry study. Lung Cancer. 2005;50(2):227-34. [pmid: 16061304].
112 Kates M, Swanson S, Wisnivesky JP. Survival following lobectomy and limited resection for the treatment of stage I non-small cell lung cancer ≤1 cm in size: a review of SEER data. Chest. 2011;139(3):491-6. [pmid: 20576736].
113 Maeda R, Yoshida J, Ishii G, et al. Long-term survival and risk factors for recurrence in stage I non-small cell lung cancer patients with tumors up to 3 cm in maximum dimension. Chest. 2010;138(2):357-62. [pmid: 20435660].
114 Maeda H, Matsumura A, Kawabata T, et al. Adenosquamous carcinoma of the lung: surgical results as compared with squamous cell and adenocarcinoma cases. Eur J Cardiothorac Surg. 2012;41(2):357-61. [pmid: 21737295].
115 McKenna J, Robert J, Houck W, Fuller CB. Video-assisted thoracic surgery lobectomy: experience with 1,100 cases. Ann Thorac Surg. 2006;81(2):421-6. [pmid: 16427825].
116 Okada M, Nishio W, Sakamoto T, et al. Evolution of surgical outcomes for nonsmall cell lung cancer: time trends in 1465 consecutive patients undergoing complete resection. Ann Thorac Surg. 2004;77(6):1926-30. [pmid: 15172237].
117 Okada M, Koike T, Higashiyama M, Yamato Y, Kodama K, Tsubota N. Radical sublobar resection for small-sized non-small cell lung cancer: a multicenter study. J Thorac Cardiovasc Surg. 2006;132(4):769-75. [pmid: 17000286].
118 Sawabata N, Miyaoka E, Asamura H, et al. Japanese lung cancer registry study of 11,663 surgical cases in 2004: demographic and prognosis changes over decade. J Thorac Oncol. 2011;6(7):1229-35. [pmid: 21610521].
119 Shirvani S, Jiang J, Chang J, et al. Comparative effectiveness of 5 treatment strategies for early-stage non-small cell lung cancer in the elderly. Int J Rad Onc. 2012;84(5):1061-70.
120 Strand TE, Rostad H, Moller B, Norstein J. Survival after resection for primary lung cancer: a population based study of 3211 resected patients. Thorax. 2006;61(8):710-5. [pmid: 16601091].
121 Humphrey L, Helfand M, Chan BK, Woolf SH. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(5 Pt 1):347-60. [pmid: 12204020].
122 Wiener RS, Gould MK, Woloshin S, Schwartz LM, Clark JA. What do you mean, a spot?: a qualitative analysis of patients' reactions to discussions with their doctors about pulmonary nodules. Chest. 2013;143(3):672-7. [pmid: 22814873].
123 Scott WJ, Howington J, Feigenberg S, Movsas B, Pisters K. Treatment of non-small cell lung cancer stage I and stage II: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):234S-42S. [pmid: 17873171].
124 Smythe WR, American College of Chest Physicians. Treatment of stage I non-small cell lung carcinoma. Chest. 2003;123(1 Suppl):181S-7S. [pmid: 12527578].
125 Manser RL, Irving LB, Stone C, Byrnes G, Abramson M, Campbell D. Screening for lung cancer. Cochrane Database Syst Rev. 2013;6:CD001991. [pmid: 23794187].
126 Schultz EM, Silvestri GA, Gould MK. Variation in experts' beliefs about lung cancer growth, progression, and prognosis. J Thorac Onc. 2008;3(4):422-6.
127 Goodney P, Lucas F, Stuke T, Birkmeyer J. Surgeon specialty and operative mortality with lung resection. Ann Surg. 2005;241(1):179-84. [pmid: 15622006].
128 Farjah F, Flum D, Varghese T, Symons R, Wood D. Surgeon specialty and long-term survival after pulmonary resection for lung cancer. Ann Thorac Surg. 2009;87:995-1006. [pmid: 19324119].
129 Tieu B, Schipper P. Specialty matters in the treatment of lung cancer. Semin Thoracic Surg. 2012;24:99-105.
130 Lau K, Rathinam S, Waller D, Peake M. The effects of increased provision of thoracic surgical specialists on the variation in lung cancer resection rate in England. J Thorac Onc. 2013;8(1):68-71.
131 Bach PB, Cramer LD, Schrag D, Downey RJ, Gelfand SD, Begg CB. The influence of hospital volume on survival after resection for lung cancer. N Engl J Med. 2001;345(3):181-8. [pmid: 11463014].
132 Bach P, Gould M. When the average applies to no one: personalized decision making about potential benefits of lung cancer screening. Ann Intern Med. 2012;157(8):571-3. [pmid: 22893040].
133 Black WC. Overdiagnosis: an underrecognized cause of confusion and harm in cancer screening. J Natl Cancer Inst. 2000;92(16):1280-2. [pmid: 10944539].
134 Chan CK, Wells CK, McFarlane MJ, Feinstein AR. More lung cancer but better survival. Implications of secular trends in “necropsy surprise” rates. Chest. 1989;96(2):291-6. [pmid: 2787730].
135 Flehinger B, Kimmel M, Melamed M. The effect of surgical treatment on survival from early lung cancer: implications for screening. Chest Surg Clin N Am. 1992;101(4):1013.
136 Sobue T, Suzuki T, Matsuda M, Kuroishi T, Ikeda S, Naruke T. Survival for clinical stage I lung cancer not surgically treated: comparison between screen-detected and symptom-detected cases. Cancer. 1992;69(3):685-92. [pmid: 1730119].
137 Grogan EL, Stukenborg GJ, Nagji AS, et al. Radiotracer-guided thoracoscopic resection is a cost-effective technique for the evaluation of subcentimeter pulmonary nodules. Ann Thorac Surg. 2008;86(3):934-40. [pmid: 18721586].
138 Cardillo G, Regal M, Sera F, et al. Videothoracoscopic management of the solitary pulmonary nodule: a single-institution study on 429 cases. Ann Thorac Surg. 2003;75(5):1607-11. [pmid: 12735587].
139 Midthun DE. Screening for lung cancer. Clin Chest Med. 2011;32(4):659-68. [pmid: 22054878].
140 McWilliams A, Mayo J, MacDonald S, et al. Lung cancer screening: a different paradigm. Am J Respir Crit Care Med. 2003;168(10):1167-73. [pmid: 12882756].
141 O'Connor GT, Hatabu H. Lung cancer screening, radiation, risks, benefits, and uncertainty. JAMA. 2012;307:2434-5. [pmid: 22692175].
142 Hall EJ, Brenner DJ. Cancer risks from diagnostic radiology. Br J Radiol. 2008;81(965):362-78. [pmid: 18440940].
143 Cody DD, Kim HJ, Cagnon CH, et al. Normalized CT dose index of the CT scanners used in the National Lung Screening Trial. AJR Am J Roentgenol. 2010;194(6):1539-46. [pmid: 20489094].
144 Boice JD Jr, Monson RR. Breast cancer in women after repeated fluoroscopic examinations of the chest. J Natl Cancer Inst. 1977;59(3):823-32. [pmid: 894747].
145 Lester RG. Risk versus benefit in mammography. Radiol. 1977;124(1):1-6.
146 Brenner DJ. Radiation risks potentially associated with low-dose CT screening of adult smokers for lung cancer. Radiol. 2004;231(2):440-5.
147 Raji OY, Duffy SW, Agbaje OF, et al. Predictive accuracy of the Liverpool Lung Project risk model for stratifying patients for computed tomography screening for lung cancer: a case-control and cohort validation study. Ann Intern Med. 2012;157(4):242-50. [pmid: 22910935].
148 Amann A, Corradi M, Mazzone P, Mutti A. Lung cancer biomarkers in exhaled breath. Expert Rev Mol Diagn. 2011;11(2):207-17. [pmid: 21405971].
149 Barash O, Peled N, Hirsch FR, Haick H. Sniffing the unique “odor print” of non-small-cell lung cancer with gold nanoparticles. Small. 2009;5(22):2618-24. [pmid: 19705367].
150 Anglim PP, Galler JS, Koss MN, et al. Identification of a panel of sensitive and specific DNA methylation markers for squamous cell lung cancer. Mol Cancer. 2008;7:62. [pmid: 18616821].
151 Greenberg AK, Rimal B, Felner K, et al. S-adenosylmethionine as a biomarker for the early detection of lung cancer. Chest. 2007;132(4):1247-52. [pmid: 17934114].
152 Bianchi F, Nicassio F, Veronesi G, Di Fiore PP. Circulating microRNAs: next-generation biomarkers for early lung cancer detection. Ecancermedicalscience. 2012;6:246. [pmid: 22518197].
153 Boeri M, Verri C, Conte D, et al. MicroRNA signatures in tissues and plasma predict development and prognosis of computed tomography detected lung cancer. Proc Natl Acad Sci U S A. 2011;108(9):3713-8. [pmid: 21300873].
154 Hennessey PT, Sanford T, Choudhary A, et al. Serum microrna biomarkers for detection of non-small cell lung cancer. PLoS One. 2012;7(2):e32307. [pmid: 22389695].
155 Zheng D, Haddadin S, Wang Y, et al. Plasma microRNAs as novel biomarkers for early detection of lung cancer. Int J Clin Exp Pathol. 2011;4(6):575-86. [pmid: 21904633].
156 Wang Q, Wang S, Wang H, Li P, Ma Z. MicroRNAs: novel biomarkers for lung cancer diagnosis, prediction and treatment. Exp Biol Med. 2012;237(3):227-35.
157 Rotunno M, Hu N, Su H, et al. A gene expression signature from peripheral whole blood for stage I lung adenocarcinoma. Cancer Prev Res (Phila). 2011;4(10):1599-608. [pmid: 21742797].
158 Hoagland LF 4th, Campa MJ, Gottlin EB, et al. Haptoglobin and posttranslational glycan-modified derivatives as serum biomarkers for the diagnosis of nonsmall cell lung cancer. Cancer. 2007;110(10):2260-8. [pmid: 17918261].
159 Patz EF Jr, Campa MJ, Gottlin EB, et al. Panel of serum biomarkers for the diagnosis of lung cancer. J Clin Oncol. 2007;25(35):5578-83. [pmid: 18065730].
160 Monari E, Casali C, Cuoghi A, et al. Enriched sera protein profiling for detection of non-small cell lung cancer biomarkers. Proteome Sci. 2011;9(1):55. [pmid: 21929752].
161 Kazarian M, Laird-Offringa IA. Small-cell lung cancer-associated autoantibodies: potential applications to cancer diagnosis, early detection, and therapy. Mol Cancer. 2011;10:33. [pmid: 21450098].
162 McCulloch M, Turner K, Broffman M. Lung cancer detection by canine scent: will there be a lab in the lab?. Eur Respir J. 2012;39(3):511-2. [pmid: 22379142].
163 Pepe MS, Feng Z, Janes H, Bossuyt PM, Potter JD. Pivotal evaluation of the accuracy of a biomarker used for classification or prediction: standards for study design. J Natl Cancer Inst. 2008;100(20):1432-8. [pmid: 18840817].
164 MacMahon H, Austin JH, Gamsu G, et al. Guidelines for management of small pulmonary nodules detected on CT scans: a statement from the Fleischner Society. Radiol. 2005;237:395-400.
165 Nelson H, Tyne K, Naik A, et al. Screening for Breast Cancer: Systematic Evidence Review Update for the U.S. Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
166 Schoen RE, Pinsky PF, Weissfeld JL, et al. Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N Engl J Med. 2012;366(25):2345-57. [pmid: 22612596].
167 Henschke CI, Investigators for the International Early Lung Cancer Action Program. Survival of patients with clinical stage I lung cancer diagnosed by computed tomography screening for lung cancer. Clin Cancer Res. 2006;13(17):4949-50. [pmid: 17785541].
168 Shemesh J, Henschke CI, Farooqi A, et al. Frequency of coronary artery calcification on low-dose computed tomography screening for lung cancer. Clin Imaging. 2006;30(3):181-5. [pmid: 16632153].