# DISCUSSION

## Summary of Review Findings

The personal and public health importance of lung cancer in the United States and worldwide is enormous, and even a small benefit from screening could save many lives. The current evidence review found that in one large (n=53,454) good-quality trial (the NLST) of lung cancer screening with three annual LDCT scans in high-risk individuals ages 55 to 74 years, both lung cancer and all-cause mortality were reduced in the LDCT group compared with those receiving annual CXR screening by 20 and 7 percent, respectively.54 The absolute lung cancer mortality reduction was 4 per 1,000 people screened. One fair-quality Italian trial conducted among men older than age 60 years suggested reduced lung cancer mortality but did not show statistical significance.51 Two European trials (one of fair-quality [n=4,104] and one of poor-quality [n=4,099]) in populations of lower risk and younger age showed no benefit of LDCT in reducing lung cancer mortality.52,53

We found no evidence to support the use of CXR for lung cancer screening, although data from the PLCO Screening Trial evaluating CXR screening among smokers suggested there might be benefit among high-risk individuals and possibly among women of high and average risk.59 If there is any benefit of CXR screening, then the benefits of lung cancer screening with LDCT demonstrated by the NLST may be even greater if applied to an unscreened population. We found no new data on sputum cytology for the current evidence review, although sputum samples were collected in some of the studies. Table 9 summarizes the evidence reviewed in the current review.

Table 9 Summary of Evidence

Number of studies | Design | Limitations | Consistency | Applicability | Overall quality | Findings
Key Question 1. How effective is screening for lung cancer in reducing mortality and morbidity?
6 studies (7 publications) | RCTs | 3 RCTs evaluating LDCT had short followup and were underpowered | Low | High | Fair | - 1 good-quality trial (n=53,454) of high-risk participants with good generalizability showed that LDCT compared with CXR conducted over 3 screens reduced lung cancer mortality by 20% and all-cause mortality by 6.7%.; - 3 smaller (n=2472, 4099, and 4104) European trials of fair- and poor-quality included high-risk participants and showed no benefit associated with LDCT screening compared with no LDCT screening.; - Meta-analysis of 3 fair- or good-quality trials showed RR of lung cancer mortality of 0.81 (95% CI, 0.72–0.91) and of all-cause mortality of 1.02 (95% CI, 0.78–1.33).; - 2 trials of CXR screening compared with no screening (1 in the general population and 1 in high-risk individuals) showed no benefit associated with CXR screening.; - 1 study reported findings on screening in women and did not show a significant reduction in lung cancer mortality associated with CXR screening.; - No trials reported data on lung cancer screening in different racial or ethnic populations.
Key Question 2. What are the test characteristics (sensitivity, specificity, predictive value) of screening tests for lung cancer?
15 studies (24 publications) | RCTs Cohort | Variable methods of determining sensitivity and specificity | High | High | Fair | - Sensitivity of LDCT was reported in 1 trial and 5 cohort studies and ranged from 80%–100%.; - Specificity of LDCT was reported in 2 RCTs and 5 cohort studies and ranged from 28%–100%.; - The calculated positive predictive value for an abnormal (positive or indeterminate) LDCT scan predicting lung cancer ranged from 2.2%–42%.; - The sensitivity of CXR for lung cancer was reported in the prior review as 25% when compared with LDCT; specificity was not evaluated.; - No studies reported test parameters for sputum cytology.
Key Question 3. What are the harms associated with lung cancer screening and are there ways to modify harms (e.g., unnecessary biopsy, radiation exposure, overdiagnosis, and psychosocial harms)?
13 studies (32 publications) | RCTs Cohort | Harms variably reported among the studies | Fair | High | Fair | Radiation:; - 2 RCTs and 2 cohort studies reported radiation associated with 1 LDCT scan ranged from 0.6 mSv–1.5 mSv.; - 1 study reported cumulative radiation exposure associated with its screening program estimated at 6 mSv–7 mSv.; False-positive examinations and followup evaluations:; - Positive examinations at baseline screen ranged from 9.2%–51% (of participants) with calculated positive predictive values for abnormal scans ranging from 2.2%–36%; most were resolved with further imaging.; - Positive examinations were lower in subsequent screens with positive predictive values for abnormal scans predicting lung cancer of 4%–42%; most were resolved with further imaging.; - Positive predictive values for abnormal LDCT scans with recommendations for biopsy ranged from 50%–92%.; False reassurance:; - Sensitivity of LDCT ranged from 80%–100%, implying a false-negative rate of 0%–20%. The harms of false reassurance were not evaluated in any study.; Overdiagnosis:; - Overdiagnosis was not formally reported in any study. It was suggested in 1 trial of LDCT compared with no LDCT that showed an excess of 119 lung cancers among approximately 26,000 participants after 6.5 years of followup. 3 RCTS with limited followup reported more early-stage lung cancer in LDCT screened groups than among controls but not a smaller number of advanced lung cancer.; - 1 older trial of CXR screening of approximately 9000 high-risk participants reported that an excess of lung cancers diagnosed in the screened group persisted after 20 years of followup.; - 1 trial of CXR screening compared with no screening in the general population (n=155,000) showed 18 excess lung cancers in the screened group after 6 years of followup and 76 excess lung cancers after 13 years of followup (RR, 1.05 [95% CI, 0.98–1.12]); data from the same trial evaluating overdiagnosis among a high-risk population showed a cumulative incidence of lung cancer of 606/100,000 py in the CXR group and 608/100,000 py in the usual care group after 6 years of followup (RR, 1.00 [95% CI, 0.88–1.13]).; Psychosocial consequences:; - 5 studies showed that LDCT screening did not significantly impact overall health-related quality of life. Most studies reported no long-term difference in anxiety among participants, although 3 studies suggested increased short-term anxiety among those with positive or indeterminate results. Distress was decreased among individuals with negative results (compared with baseline) in 1 trial.; Smoking behavior:; - 3 RCTs identified no differences in smoking cessation rates, smoking relapse rates, or smoking intensity between LDCT and no LDCT screening groups.; - In RCTs, smoking behavior among subjects with abnormal scans and those with negative scans showed mixed results, with 1 study showing a tendency toward smoking abstinence among those with abnormal scans. Mixed results were also seen in cohort studies.; - 1 cohort study suggested that physician referral for patients with abnormal screening LDCT may result in higher smoking cessation rates.; Incidental findings:; - There was no standardized approach to reporting incidental findings. Among LDCT studies, nonpulmonary lung findings were common; infections and other cancers were also diagnosed. Coronary artery calcification was identified in approximately 50% of participants in 1 cohort study evaluating CT scans retrospectively.
Key Question 4. How effective is surgical resection for the treatment of early (stage IA) non-small cell lung cancer?
12 studies | Cohorts | No RCTs evaluated surgical resection of stage IA or IB NSCLC. All reported survival among patients with clinically-detected lung cancer and not selected for comorbidity | Fair | Moderate | Fair | - No RCTs have compared treating stage IA or IB lung cancer with surgical resection compared with no treatment.; - 5 studies from 4 cohorts in Japan showed 5-year survival rates for resected pathologic stage IA NSCLC ranging from 71%–90%. Five-year survival among cohorts evaluating pathologic stage IB resected lung cancer ranged from 70%–74%.; - 2 large U.S. cohorts showed 5-year survival rates of 58%–66% for stage IA and 55% for stage IB lung cancer resected between 1990 and 2000.
Key Question 5. What are the harms associated with surgical resection of early (stage IA) non-small cell lung cancer?
6 studies | Cohorts | Studies reflect harms of surgical resection in patients identified in clinical practice with comorbidities; not necessarily a population eligible for screening | Fair | Low | Fair | - No RCTs of LDCT screening evaluated the harms associated with resection of screen-detected NSCLC.; - 2 cohort studies reported harms associated with resection of stage IA NSCLC. 1 Japanese study reported 1 postoperative death among 510 individuals undergoing resection between 1992 and 2001. 1 Italian study reported 9 postoperative deaths among 548 patients with resections of stage I NSCLC between 1991 and 1994.; - 6 studies reported harms among large cohorts of individuals undergoing resection but did not specify results specifically for stage IA NSCLC.

Abbreviations: CI = confidence interval; CT = computed tomography; CXR = chest x-ray; LDCT = low-dose computed tomography; NSCLC = non-small cell lung cancer; py = person-years; RCT = randomized, controlled trial; RR = relative risk

Sensitivity of LDCT is relatively high but the specificity varied, with positive predictive values for abnormal LDCT findings ranging from 2.2 to 42 percent, depending on the basis of calculation (by screening round or by including only positive or indeterminate scans). These findings are comparable with other screening modalities, such as breast cancer screening with mammography.121 The low specificity of screening with LDCT suggests the benefit of screening comes at some cost in terms of positive tests requiring subsequent clinical evaluations. The range of positive or indeterminate findings at baseline screening was high (9% to 51%), and most patients required some type of further evaluation, including clinical examinations, CXR, repeat CT, PET scans, and sometimes biopsy or surgical procedures. However, while lung biopsy is a fairly invasive procedure, the majority of biopsies performed were for cancer, not benign disease, with positive predictive values for invasive procedures or biopsy ranging from 50 to 92 percent. This contrasts with the high number of false-positive examinations requiring further evaluation with imaging or clinical/imaging followup, which were predominantly done for benign disease. Screening with LDCT did not seem to reduce overall quality of life, but was associated with short-term increased worry and distress compared with baseline for those with indeterminate results and decreased distress for those with negative screening results.68,69,77,100,122 Smoking cessation rates were not affected by screening in seven included studies, although there was a suggestion of reduced smoking among individuals with abnormal screening LDCT scans compared with those with negative LDCT scans. Finally, LDCT detected many incidental findings that were reported in variable ways in the included studies. The most commonly reported findings were emphysema and coronary artery calcifications.

While we found no trials evaluating the effect of surgical resection of early-stage lung cancer on mortality, this treatment is universally recommended and the benefit of this approach can be inferred given the positive results shown in the NLST of screening and early treatment of screen-detected disease.22 In fact, the NLST results may be the most compelling data to date that surgical resection of NSCLC improves survival, given the absence of RCTs on this topic. These findings were similar to the results of previous reviews. In a recent review conducted on behalf of the ACCP, the authors found no evidence from RCTs on the effectiveness of surgical resection for early-stage disease.123 In an earlier review for the ACCP, authors conducted a search from the founding date of multiple electronic databases through 2001 that also found no relevant trials.124 Finally, a Cochrane review of treatment for early-stage NSCLC also found no data from RCTs on the effectiveness of surgical resection of NSCLC.125 Despite this lack of evidence, surgical resection of stage I lung cancer has a 1A recommendation by the ACCP123 and is recommended by the NCCN.22 The strength of these recommendations is based on expected NSCLC growth rates,126 detailed information from observational studies that show clear differences in early- versus late-stage mortality,4,7,126 and clinical experience. For patients with early-stage NSCLC who can tolerate its adverse effects, surgical resection is universally felt to be beneficial. It is important to note that prior research evaluating the outcomes of lung cancer treatment and resection show that the best patient outcomes occur when surgery is performed by experienced surgeons in high-volume centers.127-131 The NCCN recommends that patients with clinical stage I and II NSCLC be evaluated by a thoracic surgical oncologist whose practice prominently focuses on lung cancer, even if patients are being considered for nonsurgical therapies such as percutaneous ablation or stereotactic body radiation therapy.123

We evaluated what might account for different findings in the four trials, with the NLST showing a benefit of screening54 and the three European studies (MILD, DANTE, and DLCST) not showing benefit.51-53,61 The European studies were small, with sample sizes ranging from 2,472 to 5,861 (compared with 53,454 in NLST), and were inadequately powered to detect benefit outcomes such as lung cancer mortality. The European trials also had shorter followup durations ranging from 3 to 5 years (compared with 6.5 years in NLST), which would impact the power of the studies to show a benefit.

A subtle but important issue in all three European studies is the difference in duration of followup in the LDCT groups compared with the nonLDCT groups. In the MILD trial, this results in a significant difference in risk of lung cancer, lung cancer mortality, and all-cause mortality when true followup time is accounted for in the rate denominators then when a median duration of followup is used for calculating incidence/mortality rates. In the MILD trial, the average followup was 53 months for both groups. However, actual followup duration was 56 months in the LDCT group compared with 45 months in the control group. Thus, it is not surprising there were more lung cancer and other deaths in an older population with nearly an extra year of followup. Similarly, when we adjusted for the true denominator of followup in both the LDCT and control groups in the DANTE trial, rather than a neutral effect on lung cancer mortality, the findings suggested a benefit of screening, although it was not statistically significant. Finally, the DLCST authors note that followup of the control group was less complete than for intervention patients (the difference was not reported), which could bias the study against showing a benefit of LDCT screening as well.

Another consideration when comparing the results of studies either showing or suggesting reduced lung cancer mortality (NLST and DANTE) with those showing no benefit or harm is that the populations screened in the NLST and DANTE trial were older and had more smoking exposure, and thus were at significantly higher risk of lung cancer compared with the DLCST and MILD populations. To better understand this, we compared lung cancer incidence and mortality rates among the control groups in each of the main trials. Notably, lung cancer incidence rates in the NLST and DANTE trial are higher than in the DLCST and MILD studies (Table 3). Similarly, the rate of lung cancer mortality is nearly 5-fold higher in the DANTE trial and 3-fold higher in the NLST when compared with either the MILD study or DLCST. All-cause mortality among the control groups in the NLST and DANTE trial was nearly equal and approximately 4-fold higher than the all-cause mortality shown in the DLCST and MILD study. These data indicate that different risk groups were enrolled in these four trials and suggest, but do not prove, that LDCT screening might be more beneficial in higher-risk populations similar to the NLST participants. This has been suggested and modeled in a recent paper where high-risk participants in the NLST were contrasted with the minimally eligible participants.132 Among high-risk participants, the NNS to save one life from lung cancer over 6 years (3 years of annual screening) was 82 compared with 3,180 for the minimally eligible NLST participant.

Finally, for many of the reasons noted in the Results section, there is reason to have great concern about the randomization of the MILD trial, which impacts the evaluation of its validity. There are important differences in the control and LDCT groups that correlate with each other and suggest systematic differences in the groups randomized to LDCT compared with the control group. This is further suggested by the great differential in followup and the authors' comments suggesting that the control group may have been added at a later time.

Data from other work has described the effect of “sticky diagnosis” bias, which may result in patients with a history of malignancy erroneously being labeled as dying of that malignancy when cause of death is uncertain. This bias may differentially impact screened groups since they typically have more diagnoses of cancer given during a screening trial because of lead time and some degree of overdiagnosis. This is especially true for patients diagnosed with adenocarcinoma, and was demonstrated in the Mayo Lung Project CXR screening trial.133 Thus, patients diagnosed with lung cancer in the intervention group may be more likely to be coded as dying from lung cancer than individuals in the control group, especially if cause of death is not reviewed blind to intervention or control status or prior diagnoses and in the setting of shorter durations of followup. In addition, all three European studies that showed no benefit or suggested harm from screening involved some degree of intervention in the usual care group (such as clinical evaluation or PFT). Finally, the surgical/medical care of lung cancer likely differs between Europe and the United States.

Differences in study results may also be related to differences in the LDCT method used. For example, in the DANTE trial, 5-mm single-slice spiral CT was used, which might impact the radiographic resolution of the images. In addition, all participants in the DANTE trial had CXR as well as sputum cytology as part of the baseline evaluation, which would effectively reduce the power to detect a difference associated with LDCT, since nine patients in the control group and 16 patients in the LDCT group were diagnosed with lung cancer at baseline with CXR and sputum cytology. This difference in cancers diagnosed in the two groups at baseline also raises the issue of possible inadequate randomization or sample size, since the baseline risk of cancer diagnosed by either sputum cytology or CXR is nearly two-fold higher in the LDCT group.61 A feature that differs among the European trials is that these studies tend to have higher positive predictive values associated with abnormal studies. High positive predictive values limit followup and worry among patients, but may also reflect a loss in sensitivity (or propensity for further evaluation) that results in different patient outcomes.

An important and controversial issue in lung cancer screening is the question of overdiagnosis and consequent overtreatment. The relatively high prevalence of unrecognized lung cancer in several studies suggests there is a significant preclinical pool of lung cancer in high-risk populations. Whether all of these tumors would eventually present clinically is uncertain. In addition, there currently is no way to tell which lung cancer has lethal potential and which does not, although LDCT VDT may prove helpful in the future. Thus, all patients diagnosed with lung cancer are typically treated, resulting in harm to patients with nonlethal lung cancer or those with tumors that might naturally regress.

Overdiagnosis is supported by data from the Mayo Lung Project study of CXR screening which, after 20 years of followup, still showed more (585 vs. 500) lung cancer diagnosed in individuals randomized to intense CXR screening compared with the control group.58 Data from this study also showed increased rates of early tumors in the intensely screened group compared with the control group, without a change in numbers of advanced tumors or subsequent mortality rates, suggesting diagnosis of a pool of indolent tumors.58 An intriguing finding in the Mayo Lung Project is that in the 16 years after screening ended, there were 39 more lung cancers diagnosed in the intervention group (379 vs. 340), which is difficult to explain. In contrast, the PLCO Screening Trial of CXR screening did not identify significantly more lung cancer in the screened group than in the control group, either in the general population or in the high-risk smoking population over 6 years of followup (808 vs. 790), although there were 76 more lung cancers in the CXR group after 13 years of followup, approximately 9 years after screening ended (1,696 vs. 1,620).59 While the NLST identified more lung cancer in the LDCT group (1,040 vs. 941), this finding is within the context of results that showed a 20 percent reduction in lung cancer mortality and a 6.7 percent reduction in all-cause mortality, suggesting that even with overdiagnosis, there is benefit to screening that outweighs this potential harm.54 Other data that supports overdiagnosis comes from the DLCST, which identified more early-stage lung cancers in the LDCT group than in the control group, but no difference in advanced-stage lung cancer between the groups. However, this may relate to shorter duration of followup and less up to date information about lung cancer in the control population.52 Data from the MILD trial that might support overdiagnosis come from a comparison of the LDCT biennial and annual screened groups.53 In contrast to many LDCT studies, which have tended to show a preponderance of adenocarcinomas diagnosed in participants undergoing LDCT, the MILD trial showed a 10-fold increase in squamous cell cancers among those who were annually screened, which may suggest there is some degree of overdiagnosis of squamous cell cancer as well. However, given concerns about this study's randomization, these findings must be interpreted cautiously.

Arguments against an important role for overdiagnosis in lung cancer come from autopsy and clinical studies. One study of 15,812 necropsies conducted between the years 1953 and 1982 identified unsuspected “surprise” lung cancer in 68 patients (0.4%) who had died of a multitude of causes, suggesting a relatively low rate of clinically unrecognized lung cancer.134 However, autopsy may underestimate rates of lung cancer when compared with LDCT, since the lungs are not always thinly sectioned. Moreover, whether autopsy data are generalizable to living populations is questionable, particularly given selection biases for autopsy. Other data arguing against overdiagnosis come from studies of patients involved in screening programs who were diagnosed with stage I NSCLC and not treated for variable reasons.135,136 In one study of 45 screen-detected but untreated stage I NSCLC patients, only two patients survived 5 years.135

A recent study evaluating the comparative effectiveness of five treatment strategies for stage 1A and 1B NSCLC indicates that among individuals age 66 years and older who were untreated, 30-day mortality was 8.6 percent. Among those untreated, 6-month mortality was 32.8 percent and 2-year mortality was 73.4 percent overall; lung cancer specific mortality at 4 years of followup was 95.4 percent.119 These data do not support a large pool of indolent lung cancer among patients with clinically-detected lung cancer, which likely differs from screen-detected populations.

Overdiagnosis in lung cancer almost certainly exists but its magnitude is unknown. The optimal followup time to calculate overdiagnosis from LDCT is not known but theoretically is the lead-time of the slowest-growing cancers, though it may be shorter in practice because of competing mortality. Currently, the best way to measure the magnitude of overdiagnosis caused by LDCT will be with continued followup of lung cancer incidence in the NLST (if the participants choose not to continue screening).

One of the most difficult challenges of LDCT screening is the high false-positive rate that results in downstream evaluations, which are associated with cost, anxiety, and risk. Reducing false-positive rates without reducing sensitivity and effectiveness will be one of the major challenges associated with CT screening and will require careful study of current protocols and guidelines. Data from the NELSON trial suggest that positive results requiring followup can be decreased significantly by following indeterminate nodules for VDT.56 However, what is not yet known from the NELSON trial is whether this protocol will show the same mortality reduction as in the NLST. Clarifying parameters for indeterminate and positive LDCT screens involves a tradeoff between sensitivity and specificity that will require the best judgment of pulmonologists and radiologists and careful study of protocols that yield the highest sensitivity and specificity, since this will greatly impact the cost, risks, and effectiveness of LDCT screening. Technologic approaches to the problem of false-positive tests may also be on the horizon. Notably, in a recent surgical series, resection of benign nodules occurred in 50 to 86 percent of cases,137,138 highlighting the need for better discrimination of lung cancer nodules from benign nodules preoperatively in all domains. VDT, as well as risk prediction models, may independently, or in combination with biomarkers, improve lung cancer prediction and reduce followup imaging and procedures for people with positive scans, in both screening and clinical settings.

False-positive rates also seem to vary by geographic region, with higher rates in the Midwest that are thought to be related to increased rates of granulomatous diseases. One author also notes that rates of identification of noncalcified nodules is correlated with CT collimation.139 A Canadian study showed that the number of participants with one or more nodules increased from 36 to 60 percent when scan thickness was decreased from 7 to 1.25 mm.140

Although the false-positive rate was high in the studies included in this review, false-positive results from lung cancer screening may have a different effect on patients than false-positive results associated with other types of cancer screening tests. Patients who smoke potentially have some control over their subsequent risk and may be able to more effectively modify their high-risk behavior. Data from our review of smoking cessation associated with positive or indeterminate lung cancer screening results showed mixed results, with some studies suggesting or showing a trend that patients with abnormal results reduced smoking or more frequently remained abstinent.62,70,106,107

Radiation exposure is a direct harm of lung cancer screening. It is widely accepted that medical imaging radiation exposure is associated with a real and measurable future risk of cancer.141 Radiation-associated cancer risk increases with younger age at the time of exposure and cumulative dose, and there may be interaction with other lung cancer risks, such as smoking.142 The effective dose from one LDCT scan averaged 1.6 mSv in the NLST and varied by a factor of two over the varying number of detectors and manufacturers used.143 In addition, as doses are adjusted for body weight, the effective dose can further increase by a factor of two.66 LDCT on a modern 16+ MDCT can have a dose as low as 0.8 mSv. In comparison, a standard diagnostic CXR is 0.02 mSv. Given the high frequency of positive LDCT examinations in the trials to date, it is important to note there is also radiation exposure associated with followup imaging of abnormal LDCT screens. These procedures include diagnostic chest CT with an effective radiation dose of 8 mSv and PET/CT with radiation doses ranging from 7 to 14 mSv.

Estimates of cancer risk associated with medical radiation are based on extrapolations and models derived from observations in atomic bomb survivors and occupational exposures.144,145 In one modeling study146 using a LDCT dose of 5.2 mGy (approximately 5.2 mSv) for annual screening from ages 50 to 75 years, the model suggested that the lifetime risk of lung cancer in women would increase by 5 percent and in men by 1.5 percent. Chest radiation would also likely increase the risk of breast cancer among women given prior estimates for the radiation associated with mammography, as well as from childhood radiation exposures.146 However, data on radiation and breast cancer development suggest most of the harm occurs in women sustaining radiation at ages younger than 30 years, significantly younger than the current age group in which lung cancer screening is being evaluated and considered. Notably, with decreasing LDCT radiation dose and frequency, the risks of subsequent lung cancer are proportionally reduced. This highlights the importance of radiation dose, screening interval and duration, and age at onset of screening in lung cancer screening programs and investigation.

## Limitations

This review has several limitations. Some of these are discussed above and relate to limitations of the studies reviewed for this report. It could be argued that the NLST results were obtained in volunteers at mostly large academic centers and that the results are not generalizable to most people who might choose to be screened. However, the large size of this trial and its conduct at several centers in the United States, as well as involvement of community physicians and health care providers, improve the odds that these results are generalizable to a community population. The NLST participants were younger, better educated, and less likely to be current smokers than the general population in the United States that would be eligible for LDCT screening by the NLST criteria. However, this difference is likely more important to consider if LDCT screening is implemented rather than as a limit to the validity of the NLST results. It is much less likely that the European studies would be generalizable to the United States given their very small size and different clinical practices.

The previous evidence review identified a paucity of screening studies among women and found some evidence to suggest that lung cancer screening might perform differently among women. Unfortunately, in spite of the fact that lung cancer is the leading cause of cancer-related death among women, the current evidence review found very little new information in women. There was a suggestion in the PLCO Screening Trial of possible benefit of CXR screening, but the findings were not statistically significant.59 Hopefully, some of the trials currently underway will report data separately for women. This is especially important in the NLST, given the high number of participants and the statistical chance of identifying benefit if it exists. There are biological reasons to think that screening among women may be associated with different effectiveness, including the propensity of women to develop adenocarcinomas, which are often more peripheral and may be amenable to limited resection. Similarly, the current evidence review identified no studies of screening that evaluated benefits or harms in different racial and ethnic groups.

The rates of biopsy-associated complications were rarely described in the studies reviewed. In addition, while we attempted to evaluate the benefit and harm associated with the treatment of early-stage lung cancer, we found no RCTs that had evaluated surgical resection versus observation. The harms and benefits of surgical resection of lung cancer reported in this review are derived from large series of treatment in unselected symptomatic patients with stage I NSCLC who were treated surgically. Almost certainly, the harms would be higher in such a group and the benefits likely differ as well, making generalizing these results to a screening population problematic.

We excluded nonEnglish language articles, which could result in language bias, though we identified no nonEnglish language studies that would have met inclusion criteria. We did not search for studies published only as abstracts and could not formally assess for publication bias with graphical or statistical methods because of small numbers of studies for each key question and differences in study design, populations, and outcomes assessed. We found few or no randomized trials for a number of key questions. We therefore included nonrandomized trials, as well as observational studies (for harms), which are more susceptible to bias and confounding than well-conducted randomized trials.

## Emerging Issues and Future Research

Over the next several years, the large NELSON trial will be publishing information on the benefits and harms of LDCT screening. In addition, longer followup of the smaller trials that will contribute to the NELSON trial should be available. Finally, more analyses of the NLST will be forthcoming and help define whether there are subgroups that might disproportionately benefit or be harmed with LDCT screening. In addition, new studies of risk modeling which could be applied to currently screened groups may facilitate identification of patients at higher risk who might benefit differentially from screening with LDCT.40,147

At this time in the United States, smoking occurs disproportionately in more disadvantaged groups as measured by socioeconomic status and/or educational level.60 In addition, there is some evidence that individuals of disadvantaged socioeconomic and insurance status have increased lung cancer incidence as well.19,33,34 While it is not clear how much these associations are mediated by smoking behaviors, these findings will have important resource allocation and financial implications if lung cancer screening is widely adopted. It is important to continue to evaluate the psychosocial consequences in patients who undergo screening. As noted, patients in trials self-select to undergo screening and may differ in their psychological responses to screening and abnormal or normal results. If screening is implemented, it will be imperative that these issues be studied carefully, especially the impact on smoking behavior. Furthermore, the method and quality of communication between clinicians and patients with nonnegative results in screening trials is likely different than occurs in routine practice.122 All of these factors could influence the occurrence and magnitude of anxiety and distress that patients in the general population might experience. More research among patients in clinical settings is required to better address these concerns.

There is considerable interest in the use of biomarkers to increase the benefits and minimize the harms of lung cancer screening. The goal of this research is to focus LDCT efforts among individuals at highest risk of disease, provide more accurate discrimination between benign and malignant pulmonary nodules, and to find early indicators of aggressive disease. Many studies have examined the role of biomarkers in these settings. It is beyond the scope of our review to describe all of the potential biomarkers and analytic techniques currently being evaluated, but some that have been studied include exhaled breath biomarkers, such as volatile organic compounds;148,149 DNA methylation analyses using serum, sputum, or exhaled breath condensate;150,151 circulating serum microRNA;152-157 and protein and proteomic analyses (such as haptoglobin and posttranslational glycan modifications of haptoglobin,158 panel of proteins,159 and proteomic analyses160); autoantibodies for small cell lung cancer;161 and the use of dogs to detect scent changes.162 Of note, the NLST collected multiple biologic specimens during enrollment, though no studies have yet reported results.54

No studies were found that evaluated the efficacy of using these biomarkers as a screening test. One paper describes a series of steps necessary for biomarker development163 that will likely guide the clinical relevance of biomarker development. Currently, many biomarker studies have been cross-sectional and most studied in patients with known lung cancer, so it is not known if these biomarkers are present in detectable quantities prior to the development of symptomatic disease. In the near future, it is unlikely that biomarkers will be directly proven to be efficacious at defining at-risk cohorts to target for screening. They may ultimately prove informative in models to assess the baseline risk of developing lung cancer and the potential benefits of LDCT for specific groups.

Biomarkers will likely be found that help distinguish between benign and malignant nodules, the source of the majority of false-positive LDCT findings. However, experts currently recommend serial followup of nodules with repeat CT scans, even for patients with a relatively low risk of lung cancer.164 The negative predictive value of these biomarkers will likely need to be very high in order to substantially reduce the number of patients who receive followup imaging or the number of scans these patients receive.

## Conclusions

The current evidence review found LDCT screening for lung cancer reduced lung cancer mortality by 20 percent and all-cause mortality by nearly 7 percent in one very large, good-quality study conducted in the United States. The NNS to prevent one lung cancer death in this trial was reported as 320 and the NNS to prevent one death overall was calculated to be 219. This compares with a number needed to invite to screen to prevent one breast cancer death of 1,905 in mammography trials following women ages 40 to 49 years for 11 to 20 years, 1,339 for women ages 50 to 59 years, and 377 for women ages 60 to 69 years.165 It also compares with a NNS with flexible sigmoidoscopy of 871 to save one life from colon cancer.166 A small Italian study conducted among a population similar to the NLST population suggested benefit but was not statistically significant. A reduction in lung cancer and all-cause mortality was not shown in two small European trials. However, LDCT identified a high number of patients with positive findings that are not due to lung cancer and require further evaluation, which typically involves more radiation exposure and may cause anxiety among those screened in the short-term, as well as significant costs. New data on CXR screening did not show benefit for CXR in reducing lung cancer deaths, although there was a nonstatistical suggestion of benefit among women. The rates of surgical procedures to evaluate positive findings were variable among the studies reviewed, but generally, most patients undergoing biopsy or surgical procedures were diagnosed with lung cancer. Finally, some patients will likely be diagnosed with and treated for lung cancer that would not have impacted their life (overdiagnosis), which is a net harm to the screened patient. The magnitude of this harm is currently not known. We did not find evidence that LDCT screening reduced smoking rates among those screened, but this will be important to vigilantly monitor and study if LDCT screening is broadly implemented, since smoking cessation is by far the most important intervention for reducing lung cancer risk, as well as improving overall health. More work in public health to reduce smoking rates will be the most important approach to reducing morbidity and mortality from lung cancer. However, in the meantime, given the high number of current and former smokers in the population at risk for lung cancer, work on identifying and treating early-stage lung cancer with screening will hopefully clarify the balance of benefits and harms associated with screening.