# RESULTS

We reviewed 8,149 references from electronic searches, reference list review, and manual searches of recently published studies. After applying inclusion and exclusion criteria, 1,734 full-text papers were reviewed. Of the full-text papers, 63 provided data to answer one or more of the key questions and were included in this evidence review. Appendix A5 shows the results of our literature search and selection process and Appendix A6 shows the list of excluded full-text papers.

## Description of Randomized, Controlled Trials

We identified seven RCTs that reported results of screening with LDCT51-57 and two of screening with CXR (Table 2 and Appendix B1).58,59

Table 2 Summary of Included Randomized, Controlled Trials

Study, recruitment years | Population | Baseline smoking status (intervention vs. control) | Screening strategy | | Total followup | Followup after screening ended
Study, recruitment years | Population | Baseline smoking status (intervention vs. control) | Number of screening rounds | Screening times (years) | Total followup | Followup after screening ended
LDCT vs. CXR
NLST54, 72 August 2002–April 2004 | N=26,722 vs. 26,732 Ages 55–74 years 59% male | Current: 48% (n=12,862) vs. 48% (12,900) Former: 52% (n=13,860) vs. 52% (n=13,832) Mean pack-years: 56 | 3 | 0, 1, 2 | Median: 6.5 years Longest: 7.4 years | NR but presumably 4.5 years
LSS55, 73-75 September 2000–January 2001 | N=1660 vs. 1658 Ages 55–74 years 59% male | Current: 58% (n=961) vs. 57% (n=947) Former: 42% (n=699) vs. 43% (n=711) Median pack-years: 54 | 2 | 0, 1 | NR but approximately 12–24 months | None
LDCT vs. no LDCT
DANTE51, 61 2001–2006 | N=1276 vs. 1196 Ages 60–74 years 100% male | Current: 56% (n=714) vs. 57% (n=681) Former: NR Mean pack-years: 47.3 vs. 47.2 | 5 | 0, 1, 2, 3, 4 | Median: 33.7 months Controls: 31.5 months LDCT: 35.7 months | Unknown (final results pending)
DLCST52, 62, 76 October 2004–March 2006 | N=2052 vs. 2052 Ages 50–70 years 55% male | Current: 75% (n=1545) vs. 77% (n=1579) Former: 25% (n=507) vs. 23% (n=473) Mean pack-years: 36.4 vs. 35.9 | 5 | 0, 1, 2, 3, 4 | Median person-years: 4.8 | NR
MILD53 September 2005–January 2011 | N=2376 (1190 annual, 1186 biennial) vs. 1723 Ages ≥49 years 66% male | Current: 68% (annual) vs. 68% (biennial) vs. 90% (control) Former: 31% (annual) vs. 32% (biennial) vs. 10% (control) Median pack-years: 39 vs. 39 vs. 38 | Median number of CT scans (annual vs. biennial): 5 vs. 3 | Every 12 months (annual) vs. every 24 months (biennial) | Median: 4.4 years (maximum 6 years in both groups) Controls: 56 months LDCT: 45 months | Recruitment ended January 2011; followup until November 2011
NELSON56, 63-67, 69-71, 77-80 1st phase: 2003–NR 2nd phase: October 2005–NR | N=7915 vs. 7907 Ages 50–75 years 84% male | Current: NR Former: NR Mean pack-years: NR, but had to have 15 cigarettes/day for >25 years, or >10 cigarettes/day for >30 years smoking history, and if former smoker, quit ≤10 years ago for inclusion | 3 | 0, 1, 3 | 2 years | 2 years
ITALUNG57, 81, 82 2004–NR | N=1406 vs. 1593 Ages 55–69 years 65% male | Current: 65% (n=2078) Former: NR Median pack -years: 39 | 4 | 0, 1, 2, 3 | Baseline only | NA
CXR vs. usual care
PLCO59, 83, 84 1993–2001 | N=77,445 vs. 77,456 Ages 55–74 50% male | Current: 10% Former: 42% Never: Approximately 45% Mean pack-years: NR | 4 | 0, 1, 2, 3 | Median (mean): 11.9 (11.2) years (range: 10–13 years) | NR

Abbreviations: CT = computed tomography; CXR = chest x-ray; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays Trial; DLCST = Danish Lung Cancer Screening Trial; LDCT = low-dose computed tomography; LSS = Lung Screening Study; MILD = Multi-centric Italian Lung Detection; NA = not applicable; NELSON = Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST = National Lung Screening Trial; NR = not reported; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial

### Randomized Trials of Low-Dose Computed Tomography Compared With Chest X-Ray

#### National Lung Screening Trial

The NLST was a good-quality trial of lung cancer screening comparing LDCT with single-view posterior-anterior (PA) CXR.54 The NLST enrolled participants from August 2002 through April 2004 at 33 sites in the United States. Asymptomatic men and women ages 55 to 74 years who had at least 30 pack-years of smoking history and were current or former (>15 years since quitting) smokers were eligible. Of the 53,454 subjects enrolled, 26,722 were randomized to LDCT and 26,732 to CXR. Subjects were followed for a median of 6.5 years from randomization (maximum 7.4 years) for the outcomes of lung cancer incidence and all-cause mortality and 5.5 years for lung cancer mortality. Screening was conducted from 2002 to 2006 and participants followed in the trial from 2002 to 2009, when the trial was stopped early; participants are still being followed, however.

Subjects received a baseline evaluation (LDCT or CXR) with annual evaluations at 1 and 2 years. Screening radiology procedures were performed in accordance with a standard protocol. Results and recommendations of interpreting radiologists were reported to the participant and their health care provider within 4 weeks of a positive study; followup of abnormal scans was determined by the subject's individual health care provider. A positive (“suspicious for lung cancer”) LDCT scan was one that showed any noncalcified nodule or mass 4 mm or greater in any diameter. A positive CXR image was one showing any noncalcified nodule or mass. Abnormalities such as adenopathy or pleural effusions were also classified as positive findings. Radiology findings suggesting other clinically significant processes were noted but not categorized in the publications to date. Abnormalities that were suspicious for lung cancer were classified as minor if they remained stable after the third round of screening.

The LDCT and CXR groups were both comprised of 59 percent men and 73 percent were ages 55 to 64 years, with a mean age of 61.4 years.60 At baseline, 48 percent in both groups were current smokers and 52 percent were former smokers, with a mean smoking history of 56 pack-years.60

Overall, adherence to the screening protocol was high: 95 percent in the LDCT group and 93 percent in the CXR group. Contamination was also relatively small; among a subgroup of 500 subjects, 4.3 percent of the participants in the CXR group self-reported that they received a screening CT outside of the study.

#### Lung Screening Study

The Lung Screening Study (LSS) was a trial of lung cancer screening comparing LDCT with PA CXR designed as a feasibility study in preparation for the NLST.55 The trial was conducted at six sites in the United States from September 2000 through November 2001 and followup continued into 2002. Men and women ages 55 to 74 years who were current (≥30 pack-years) or former (quit <10 years ago) smokers were enrolled. Of the 3,318 subjects enrolled, 1,660 were randomized to LDCT and 1,658 to CXR. Subjects received a baseline (LDCT or CXR) and one annual evaluation, which were evaluated by 32 different radiologists; abnormalities were evaluated by community providers.

The definition of a positive screen changed between the baseline and annual screens. At baseline, noncalcified nodules 4 mm or greater, as well as several other specific findings (even with nodules <4 mm), were described as positive. At the 1 year examination, any noncalcified nodule 4 mm or greater was considered a positive screen, and other abnormalities could be considered suspicious for lung cancer at the discretion of the radiologist. Thus, the incidence screen involved more radiologist discretion than the baseline screen. Although more participants were randomized, only 1,586 (96% of 1,660) received a baseline LDCT and 1,550 (93% of 1,658) received a baseline CXR.

The overall population was 59 percent male and 68 percent were ages 55 to 64 years, though no mean or median age was reported. At baseline, 58 and 57 percent in the LDCT and CXR groups, respectively, were current smokers and 42 and 43 percent, respectively, were former smokers, with a median smoking history of 54 pack-years.

### Randomized Trials of Low-Dose Computed Tomography Compared With No Low-Dose Computed Tomography

#### Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays Trial

The Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays (DANTE) Trial51,61 was a fair-quality trial of lung cancer screening comparing the addition of LDCT with a usual care protocol that involved baseline CXR (type not specified) and sputum cytology for all participants. The trial was conducted in Italy from March 2001 through February 2006. Male current or former smokers (≥20 pack-years) ages 60 to 74 years were eligible. Men were excluded if they did not meet eligibility criteria or if they had severe comorbidity or a life expectancy less than 5 years. Participants could have had cancer if treated more than 10 years previously or prior “early ” squamous cell cancer of the oral cavity or larynx if treated more than 5 years prior to enrollment.

Of the 2,472 subjects enrolled, 1,276 were randomized to LDCT and 1,196 to usual care. LDCT results were considered positive if they showed noncalcified pulmonary nodules or nonnodular lesions suggestive of malignancy. Generally, abnormalities were followed with interval LDCT or high resolution CT over several months; patients with lesions greater than 6 mm often underwent a trial of antibiotics with followup CT. Other LDCT abnormalities, such as noncalcified nodules 10 mm or greater in diameter or smaller nodules with spiculated margins, or nonnodular lesions that were suggestive of malignancy were also reported.61 Abnormalities found on screening LDCT were evaluated within the study by a diagnostic algorithm based on the abnormality's size, growth, descriptive characteristics, and response to a trial of antibiotics.

All subjects received a baseline clinical interview and examination, CXR, and 3-day sputum cytology; those in the LDCT group also received LDCT. All subjects were followed annually for approximately 4 years with clinical interviews and physical examinations focused on detecting lung cancer; participants randomized to LDCT also underwent annual LDCT.

This trial included only men; the LDCT group had a mean age of 64 years and the usual care group of 65 years. At baseline, 56 and 57 percent in the LDCT and usual care groups, respectively, were current smokers, with a mean smoking history of 47 pack-years in both groups. The LDCT group had significantly more subjects with respiratory comorbidities at baseline compared with the CXR group (35% vs. 31%; p=0.04).

The final results of this trial have not yet been reported, but preliminary findings with median followup of 34 months were reported in 2009.^51^ As of January 2008, 3,612 LDCT scans had been performed,51 95 percent of participants had completed baseline questionnaires, and 68 percent had provided baseline sputum samples.61 At 3 years, equivalent numbers of patients in each group had received an extra CT scan (6.0% and 6.1%) and an extra CXR (19%).

#### Danish Lung Cancer Screening Trial

The Danish Lung Cancer Screening Trial (DLCST)62 was a fair-quality trial comparing LDCT with usual care (no lung cancer screening). The DLCST enrolled participants between June 2000 and June 2001 and was conducted from October 2004 through March 2006 in a single center in Denmark. The study was planned to last 5 years, with a baseline LDCT followed by four annual LDCT scans. It was also designed to study predictors of smoking cessation and the effect of LDCT participation on smoking behaviors. The study population involved healthy men and women ages 50 to 70 years who were current or former smokers (≥20 pack-years smoking history). Former smokers must have quit after age 50 years and less than 10 years prior to enrollment in the study. Eligibility required the ability to walk up 36 steps without stopping; exclusions included prior treatment for breast or lung cancer, any cancer within the last 4 years, and any illness that would be expected to shorten life expectancy to less than 10 years. All study participants underwent baseline pulmonary function testing (PFT) and, to confirm smoking status, carbon monoxide level in exhaled air. In addition, all participants had an annual visit with PFTs and health questionnaires.

Nodules 5 mm or greater in diameter were considered positive or indeterminate unless they had benign characteristics. Nodules 5 to 15 mm in size were considered indeterminate and rescanned after 3 months; individuals with nonbenign appearing nodules greater than 15 mm were referred to chest physicians in two lung cancer diagnostic centers for evaluation. Nodules were considered benign if they appeared benign or were less than 5 mm. Nodules greater than 14 mm and any growing nodules were referred for diagnostic evaluation, as well as “suspicious” nodules. Growth was defined as an increase in volume of at least 25 percent. Volume doubling time (VDT) was used to measure growth rate and supplemented decisionmaking. Rapid VDT increased the suspicion that a nodule might be cancer. Participants needing further evaluation were referred to chest physicians in two specialized centers. Lung cancers in the usual care group were diagnosed and treated by the subject's personal clinician, independent of the study, but this mostly involved the same lung cancer diagnostic centers used in the LDCT group.

Of the 4,104 subjects enrolled, 2,052 were randomized to LDCT and 2,052 to usual care. There were no significant baseline differences between the study groups in mean age (58 years), sex (56% male in LDCT and 55% male in usual care), mean smoking history (36 pack-years), or PFT results (mean forced expiratory volume in 1 second [FEV1], 2.9 in both groups; mean FEV1 % predicted, 93% in LDCT group and 94% in usual care group). Current smokers comprised 75 percent of the LDCT group and former smokers 25 percent. The usual care group included 77 percent current smokers and 23 percent former smokers. The authors noted that followup among the usual care group was not as complete as it was for the LDCT group.

Smoking cessation education for the DLCST involved less than 5 minutes of smoking cessation counseling by a certified smoking cessation nurse at annual visits. PFT results (abnormal and normal) were used to motivate participants to stop smoking. From the publication, it is unclear whether this counseling occurred at the initial visit or only at the annual followup visits.

#### Multi-Centric Italian Lung Detection

The Multi-centric Italian Lung Detection (MILD) study was a poor-quality trial of lung cancer screening comparing LDCT, either annually or biennially, with usual care (no lung cancer screening).53 The trial was conducted from September 2005 through January 2011 in a single center in Italy. Eligible subjects were men and women ages 49 years or older who were either current or former (quit ≥10 years ago) smokers with at least 20 pack-years of smoking and no history of cancer within the previous 5 years. Of the 4,099 subjects enrolled, 1,190 were randomized to annual LDCT, 1,186 to biennial LDCT, and 1,723 to usual care, with a median followup of 4.4 years. All subjects in this trial underwent PFT, blood testing, and a program of smoking cessation.

Evaluation of positive or suspicious LDCT scans was coordinated through the study center.53 Solid lesions with volume of 6 mm^3^ or less (diameter of ≤4.8 mm) were considered nonsuspicious. Solid nodules of approximately 5 to 8 mm received further evaluation, typically repeat LDCT at 3 months. Nodules greater than 250 mm^3^ were referred for additional evaluation, including positron emission tomography (PET) scanning or biopsy. Computer-aided detection that showed volumetric growth of 25 percent or more was considered suggestive of malignancy.

Participants in all three groups were similar at baseline in age (median of 57, 58, and 57 years for annual, biennial, and usual care, respectively), percent male (68%, 69%, and 63%, respectively), and smoking history (median of 39, 39, and 38 pack-years, respectively). There were more current smokers in the usual care group compared with the annual and biennial group (90% vs. 68 vs. 68%, respectively) and less former smokers (10% vs. 31% vs. 32%, respectively). Fewer participants in the usual care group had a FEV1 percent predicted that was less than 90 percent compared with both the annual and biennial groups (19% vs. 28% vs. 28%, respectively).

This study was rated poor-quality due to significant differences in the LDCT and usual care groups at baseline, raising concerns about the adequacy of randomization. In addition, there was substantially less followup among the usual care group (44.9 vs. 56 months). Finally, the study was underpowered and did not reach its planned size of 10,000 participants.

#### Nederlands-Leuvens Longkanker Screenings Onderzoek

The Nederlands-Leuvens Longkanker Screenings Onderzoek (NELSON) study is a trial of lung cancer screening comparing LDCT with no screening.56 The NELSON trial is currently ongoing; it began in 2003 and is being conducted in The Netherlands and Belgium. Male and female former and current smokers ages 50 to 75 years with adequate health status, no chest LDCT in the prior year, and no prior diagnosis of melanoma, renal, or breast cancer were eligible. Unlike other studies, lung cancer survivors (≥5 years) were eligible. To date, 15,588 subjects have been enrolled with one-to-one ratio randomization; screening results for 7,557 participants randomized to the LDCT group have been reported.

The LDCT group received LDCT at years 0, 1, and 3; the control group received no screening. In this trial, LDCT scans utilized volumetric measurements of detected nodules with calculation of VDT for evaluation. A positive test result was defined as a solid nodule with a volume greater than 500 mm^3^, a solid, pleural-based nodule with a diameter greater than 10 mm, or a partially solid nodule with solid component measuring greater than 500 mm^3^. Positive scans were also defined by VDT; a VDT less than 400 days was considered positive.

The NELSON investigators also assessed characterization and automated detection and measurement of lung nodules detected at screening,63-67 effect of screening on quality of life,68,69 smoking cessation during lung cancer screening,70 and the role of PET scans in evaluation of screen-detected nodules.71

Smoking cessation education for the NELSON trial included a standard smoking cessation brochure or a questionnaire requesting tailored smoking cessation information from the Dutch expert center on tobacco control. The standard brochure contained brief information about the advantages of quitting, the barriers to quitting, tips about how to quit smoking and how to prevent smoking relapse, and the possibilities for smoking cessation support. The questionnaire asked about smoking history, previous attempts to quit, attitudes toward smoking cessation, and self-efficacy in smoking abstinence.

Most baseline characteristics, including those for the no screening group, have not been reported to date. The LDCT group was described as 84 percent male with a mean age of 59 years.

#### ITALUNG

The ITALUNG study was a trial of lung cancer screening comparing LDCT with usual care (no lung cancer screening).57 The trial began in 2004 in Italy and baseline results were reported in 2009 for the LDCT group only. Enrolled subjects were men and women ages 55 to 69 years who were either current or former (>10 years since quitting) smokers with at least 20 pack-years of smoking history. Of the 3,206 subjects enrolled, 1,613 were randomized to LDCT and 1,593 to usual care.

Subjects in the LDCT group underwent a baseline scan plus three annual scans. The control group received usual care. All subjects were invited for free access to a smoking cessation program. LDCT was considered positive when it showed at least one noncalcified nodule 5 mm or greater or a nonsolid nodule 10 mm or greater in size. Nodules 8 mm or greater underwent PET scanning. Management of positive screening tests was carried out using followup LDCT, fluorodeoxyglucose PET, fine needle aspiration cytology, or fiber optic bronchoscopy. Subjects with positive screening tests were phoned and invited to meet with a pulmonologist for further assessment.

The overall population was 65 percent male, with a mean age of 64 years, and 65 percent were current smokers, with a median smoking history of 39 pack-years.

### Randomized Trials of Chest X-Ray Compared With Usual Care

#### Mayo Lung Project

The Mayo Lung Project was a fair-quality trial comparing CXR and pooled 3-day sputum cytology examination every 4 months for 6 years (intensive screening) with a control group advised to have annual CXR and sputum cytology examinations (usual care).1 The trial was conducted from November 1971 through July 1976. There were 10,933 male smokers ages 45 years or older enrolled and after eliminating all cases of prevalent lung cancer (91 participants, or 0.8% prevalence), 4,618 subjects were randomized to intensive screening and 4,593 to usual care.58

#### Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial

The Prostate, Lung, Colorectal, and Ovarian Cancer (PLCO) Screening Trial was a good-quality trial comparing annual CXR with usual care (no screening). Participants were enrolled from 1993 through 2001 and the trial was conducted from 1993 to 2011, with screening carried out from 1993 through 2004. Men and women from the general population ages 55 to 74 years were enrolled. Of the 154,901 subjects enrolled, 77,445 were randomized to PA CXR and 77,456 to usual care, with a median followup of 12 years.59 The population was approximately 85 percent white, 49 percent male, and 45 percent never smokers. The evaluation of abnormal tests was conducted by participants' personal health care providers, not within the study.

## Key Question 1 How Effective Is Screening for Lung Cancer in Reducing Mortality and Morbidity?

### Summary

One good-quality trial (n=53,454) of high-risk lung cancer participants with good generalizability found that LDCT compared with CXR conducted over three screens reduced lung cancer mortality by 20 percent and all-cause mortality by 6.7 percent. Two smaller (n=2,472 and n=5,861) fair-quality European trials of high-risk lung cancer participants showed no benefit associated with LDCT screening compared with no LDCT screening. However, these were small trials with limited power that could have missed a true benefit. One small (n=4,099) poor-quality trial also suggested no benefit from screening with LDCT, and perhaps harm. When the three fair- or good-quality trials were combined in a meta-analysis, the combined RR of lung cancer mortality was 0.81 (95% CI, 0.72 to 0.91). When the poor-quality MILD trial was included, the RR of lung cancer mortality was 0.98 (95% CI, 0.68 to 1.40).

Two trials of screening with CXR compared with either less intense or no screening, one in the general population and one in high-risk individuals, showed no benefit associated with CXR screening. Only one study evaluated or reported findings on lung cancer screening in women and did not show a significant reduction in lung cancer mortality associated with CXR screening. No trials have reported data on lung cancer screening in different racial or ethnic populations. See Table 3 for a summary of lung cancer outcomes in these trials; for complete details on the RCTs included in this review, see Appendix B1, and for the details on their quality ratings, see Appendix B2.

Table 3 Incidence Rates of Lung Cancer Outcomes

Study | N | Incidence | | | Lung cancer mortality | | | All-cause mortality | | | Duration of followup^*^
Study | N | IN | CO | RR (95% CI) | IN | CO | RR (95% CI) | IN | CO | RR (95% CI) | Duration of followup^*^
LDCT vs. CXR
NLST54, 72 | 53,454 | 645 | 572 | 1.13 (1.03–1.23) | 247 | 309 | 0.80 (0.73–0.93)^†^ | 1302 | 1395 | 0.93 (0.86–0.99)^†^ | 6.5
NLST women | 41% | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
LDCT vs. no LDCT
DANTE51, 61 | 2472 | 1600 | 1015 | 1.46 (0.96–2.22)^†^ | 558 | 597 | 0.83 (0.45–1.54)^†^ | 1283 | 1344 | 0.85 (0.56–1.27)^†^ | 2.9 (IN) vs. 2.6 (CO)
DANTE women | 0% | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
DLCST52 | 4104 | 706 | 245 | 2.88 (1.85–4.49)^†^ | 154 | 112 | 1.37 (0.63–2.97)^†^ | 624 | 429 | 1.46 (0.99–2.15)^†^ | 4.8
DLCST women | 45% | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
MILD53 | 4099 | 457^‡^ 620║ | 311 | 1.47 (0.82–2.64)^†,‡^ 1.99 (1.16–3.43)^†^,║ | 109^‡^ 216║ | 109 | 1.00 (0.34–2.98)^†,‡^ 1.99 (0.80–4.96)^†^,║ | 363^‡^ 558║ | 310 | 1.17 (0.63–2.17)^†,‡^ 1.80 (1.03–3.13)^†^,║ | 3.8 (IN) vs. 4.7 (CO)
MILD women | 34% | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
CXR vs. usual care
PLCO59 | 154,901 | 200 | 192 | 1.05 (0.98–1.12) | 140 | 142 | 0.99 (0.87–1.22) | 1052 | 1071 | 0.98 (0.95–1.01) | 11.9
PLCO^¶^ | 30,321 | 606 | 608 | 1.00 (0.88–1.13) | 361 | 383 | 0.94 (0.81–1.10) | NR | NR | NR | 6
PLCO women | 50.5% | NR | NR | NR | NR | NR | 0.92 (0.81–1.06) | NR | NR | NR | 11.9

* Data presented as medians in years.

† Data were calculated.

‡ Biennial exam group.

║ Annual exam group.

¶ NLST-eligible patients only.

Abbreviations: CI = confidence interval; CO = control group; CXR = chest x-ray; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST = Danish Lung Cancer Screening Trial; IN = intervention group; LDCT = low-dose computed tomography; MILD = Multi-centric Italian Lung Detection; NA = not applicable; NLST = National Lung Screening Trial; NR = not reported; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; RR = relative risk

### Evidence

#### Low-Dose Computed Tomography

To evaluate the effectiveness of screening for lung cancer with LDCT, we limited our review to RCTs of screening published since the previous evidence review that reported results in both the LDCT and control groups (Table 2 and Appendix B1). We identified seven RCTs that reported results of screening with LDCT; however, only four51-54 have reported results in both the intervention and control groups (Appendix B2).

Comparing low-dose computed tomography with chest x-ray. Only the NLST54 has reported results for both the intervention and control groups comparing periodic LDCT with CXR. The NLST (n=53,454) reported its findings after the trial was stopped early on review by the data safety monitoring board.54 After a median followup of 6.5 years for lung cancer incidence and all-cause mortality, the cumulative incidence of lung cancer in the LDCT group was 645 per 100,000 person-years (py) and 572 per 100,000 py in the CXR group; the RR was 1.13 (95% CI, 1.03 to 1.23) for incident lung cancer. Over 5.4 years of followup, lung cancer mortality in the LDCT group was 247 per 100,000 py and 309 per 100,000 py in the CXR group, with a reduction of lung cancer mortality of 20.0 percent (95% CI, 6.8 to 26.7; p=0.004) in the LDCT group. The RR of all-cause mortality was reduced by 6.7 percent (95% CI, 1.2 to 13.6). The authors calculated a number needed to screen (NNS) with LDCT to prevent one lung cancer death as 320 (among those undergoing ≥1 screens). Intention-to-screen analysis determined a NNS of 310 (95% CI, 190 to 840) to prevent one lung cancer death. The NNS to prevent one death from any cause was 219 (95% CI, 112 to 5,000).54 This corresponds with an absolute risk reduction of lung cancer death of 4.6 (95% CI, 0.2 to 9.0) per 1,000 participants.85

Comparing low-dose computed tomography with no low-dose computed tomography. Three randomized trials in four publications comparing periodic LDCT screening with no LDCT screening (“usual care”) have reported lung cancer outcomes in both groups.51-53,61

Though the final results of the DANTE trial (n=2,472) have not been published, preliminary findings were reported in 2009, with a median followup of 34 months. However, as noted above, followup was longer in the LDCT group by 657 person-months (35.7 months in the LDCT group compared with 31.5 months in the control group).51 The baseline prevalence of lung cancer was 2.2 percent (28 cases) in participants randomized to LDCT and 0.7 percent (8 cases) in the control group. After approximately 3 years of followup, the cumulative incidence of lung cancer was 4.7 percent (60 cases) for LDCT and 2.9 percent (34 cases) for the control group. The corresponding incidence rate was 1,600 per 100,000 py in the LDCT group and 1,015 per 100,000 py in the usual care (nonLDCT) group. The 3-year cumulative lung cancer mortality rates were 1.6 percent (n=20) in the LDCT group and 1.7 percent (n=20) in the control group, a nonstatistically significant difference. The corresponding lung cancer mortality rates were 558 per 100,000 py in the LDCT group and 597 per 100,000 py in the control group (RR, 0.83 [95% CI, 0.45 to 1.54]). All-cause mortality was also equivalent in both groups at 3 years, with a RR of 0.85 (95% CI, 0.56 to 1.27). All rates are calculated given the person-months of followup appropriate for each study group (rather than the mean). The study had only 80 percent power to show a 35 percent reduction in lung cancer mortality.

In the DLCST (n=4,104), the cumulative incidence of lung cancer in the LDCT group was 0.7 percent (incidence, 706 per 100,000 py) and 0.5 percent (incidence, 245 per 100,000 py) in the usual care group after a median followup of 4.8 years (RR, 2.88 [95% CI, 1.85 to 4.49]).52 Lung cancer mortality was 0.7 percent (mortality rate, 154 per 100,000 py) in the LDCT group and 0.5 percent (mortality rate, 112 per 100,000 py) in the usual care group, with a RR of 1.37 (95% CI, 0.63 to 2.97). Overall, there were 61 deaths (3%) in the LDCT group (624 per 100,000 py) and 42 deaths (2.1%) in the usual care group (429 per 100,000 py), with a RR of 1.46 (95% CI, 0.99 to 2.15).52 This study had 80 percent power to show a 20 percent lung cancer mortality reduction after 5 years at the 0.05 p-value level.

In the MILD trial (n=4,099), 25 lung cancers were diagnosed (20 LDCT-detected) in the biennial LDCT group, 34 (29 LDCT-detected) in the annual LDCT group, and 20 in the control group.53 The incidence rates of lung cancer per 100,000 py were reported as 457 in the LDCT biennial group, 620 in the LDCT annual group, and 311 in the control group (RR, 1.47 [95% CI, 0.82 to 2.64] for biennial vs. control and RR, 1.99 [95% CI, 1.16 to 3.43] for annual vs. control). Lung cancer mortality was not significantly different between the control and screened groups combined after adjustment for age and smoking (hazard ratio [HR], 1.64 [95% CI, 0.67 to 4.01]). When comparing the lung cancer mortality rate among the biennially screened group with the control group, the RR was 1.00 (95% CI, 0.34 to 2.98); among the annual screen group compared with the control group, the lung cancer mortality HR was 1.99 (95% CI, 0.80 to 4.96); however, this is not adjusted for age and smoking. All-cause mortality was not statistically different comparing screened groups combined with the control group (RR, 1.40 [95% CI, 0.82 to 2.38]). However, when comparing the annually screened group with the control group, the all-cause mortality RR was 1.80 (95% CI, 1.03 to 3.13). The RR of all-cause mortality among the biennially screened compared with the control group was 1.17 (95% CI, 0.63 to 2.17). Of note, 10 squamous cell cancers were identified in the annual LDCT group and one in the biennial LDCT group, with similar numbers of adenocarcinomas in each of the LDCT groups; tumor histology was not reported for the control group.53 As with the DANTE trial, all rates are calculated based on the followup reported for each study group. Again, as noted above, there are significant concerns about the adequacy of randomization in this study, as well as differences in followup between groups, with substantially more followup in the LDCT groups compared with the usual care group.

Results of pooled analysis. When the three fair- or good-quality studies were combined in a random effects meta-analysis, the RR of lung cancer incidence was 1.63 (95% CI, 0.95 to 2.80) (Figure 2); when the poor-quality MILD trial was included, the RR was 1.70 (95% CI, 1.07 to 2.68). For lung cancer mortality, the RR was 0.81 (95% CI, 0.72 to 0.91) (Figure 3); when the poor-quality MILD trial was included, the RR was 0.98 (95% CI, 0.68 to 1.40). For all-cause mortality, the RR was 1.02 (95% CI, 0.78 to 1.33) (Figure 4); when the poor-quality MILD study was included, the RR was 1.13 (95% CI, 0.84 to 1.53).

Figure 2 Meta-Analysis of Lung Cancer Incidence

* Per 100,000 person-years

Abbreviations: CI = confidence interval; Co = control; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST = Danish Lung Cancer Screening Trial; F/u = followup; In = intervention; NLST = National Lung Screening Trial; RR = relative risk; vs. = versus; yrs = years

Figure 2 is a forest plot diagram of a meta-analysis of lung cancer incidence reporting the results of the NLST, DANTE, and DLCST alone and pooled together The NLST in 2011 included 59 percent male participants, the DANTE in 2009 included 100 percent males, and the DLCST included 56 percent males. The NLST had 6.5 years of followup, the DANTE had 2.8 years of followup, and the DLCST had 4.8 years of followup. The rates of lung cancer incidence were per 100,000 person-years to allow comparison across trials. The NLST reported 645 per 100,000 person-years, while the DANTE reported 1582 per 100,000 person-years, and the DLCST reported 706 per 100,000 person-years of lung cancer in the intervention groups. This was compared with 572 per 100,000 person-years in the NLST, 1083 per 100,000 person-years in the DANTE, and 245 per 100,000 person-years in the DLCST control groups. The mean age in the NLST was 61.4 years, in the DANTE 64 years in the intervention group versus 65 years in the control group, and the DLCST was 58 years. The mean pack-year smoking history in the NLST was 56, in the DANTE 47.3 in the intervention group versus 47.2 in the control group, and in the DLCST 36.4 in the intervention group versus 35.9 in the control group. The screening times, in terms of years, were year 0, year 1, and year 2 in the NLST, year 0, year 1, year 2, year 3, and year 4 in both the DANTE and DLCST. The relative risk of lung cancer incidence in the NLST was 1.13 with a 95 percent confidence interval of 1.03 to 1.23, the DANTE was 1.46 with a 95 percent confidence interval of 0.96 to 2.22, and the DLCST was 2.88 with a 95 percent confidence interval of 1.85 to 4.49. The studies were combined for an overall relative risk of 1.63 with a 95 percent confidence interval of 0.95 to 2.80, with an I-squared of 88.6 percent and p of 0.000.

Figure 3 Meta-Analysis of Lung Cancer Mortality

* Per 100,000 person-years

Abbreviations: CI = confidence interval; Co = control; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST = Danish Lung Cancer Screening Trial; F/u = followup; In = intervention; NLST = National Lung Screening Trial; RR = relative risk; vs. = versus; yrs = years

Figure 3 is a forest plot diagram of a meta-analysis of lung cancer mortality reporting the results of the NLST, DANTE, and DLCST alone and pooled together The NLST in 2011 included 59 percent male participants, the DANTE in 2009 included 100 percent males, and the DLCST included 56 percent males. The NLST had 6.5 years of followup, the DANTE had 2.8 years of followup, and the DLCST had 4.8 years of followup. The rates of lung cancer mortality were per 100,000 person-years to allow comparison across trials. The NLST reported 247 per 100,000 person-years, while the DANTE reported 527 per 100,000 person-years, and the DLCST reported 154 per 100,000 person-years of deaths from lung cancer in the intervention groups. This was compared with 309 per 100,000 person-years in the NLST, 637 per 100,000 person-years in the DANTE, and 112 per 100,000 person-years in the DLCST control groups. The mean age in the NLST was 61.4 years, in the DANTE 64 years in the intervention group versus 65 years in the control group, and the DLCST was 58 years. The mean pack-year smoking history in the NLST was 56, in the DANTE 47.3 in the intervention group versus 47.2 in the control group, and in the DLCST 36.4 in the intervention group versus 35.9 in the control group. The screening times, in terms of years, were year 0, year 1, and year 2 in the NLST, year 0, year 1, year 2, year 3, and year 4 in both the DANTE and DLCST. The relative risk of lung cancer mortality in the NLST was 0.80 with a 95 percent confidence interval of 0.73 to 0.93, the DANTE was 0.83 with a 95 percent confidence interval of 0.45 to 1.54, and the DLCST was 1.37 with a 95 percent confidence interval of 0.63 to 2.97 The studies were combined for an overall relative risk of 0.81 with a 95 percent confidence interval of 0.72 to 0.91 with an I-squared of 0.0 percent and p of 0.406.

Figure 4 Meta-Analysis of All-Cause Mortality

* Per 100,000 person-years

Abbreviations: CI = confidence interval; Co = control; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST = Danish Lung Cancer Screening Trial; F/u = followup; In = intervention; NLST = National Lung Screening Trial; RR = relative risk; vs. = versus; yrs = years

Figure 4 is a forest plot diagram of a meta-analysis of all-cause mortality reporting the results of the NLST, DANTE, and DLCST alone and pooled together The NLST in 2011 included 59 percent male participants, the DANTE in 2009 included 100 percent males, and the DLCST included 56 percent males. The NLST had 6.5 years of followup, the DANTE had 2.8 years of followup, and the DLCST had 4.8 years of followup. The rates of all-cause mortality were per 100,000 person-years to allow comparison across trials. The NLST reported 1142 per 100,000 person-years, while the DANTE reported 1212 per 100,000 person-years, and the DLCST reported 625 per 100,000 person-years of deaths from all causes in the intervention groups. This was compared with 1216 per 100,000 person-years in the NLST, 1433 per 100,000 person-years in the DANTE, and 429 per 100,000 person-years in the DLCST control groups. The mean age in the NLST was 61.4 years, in the DANTE 64 years in the intervention group versus 65 years in the control group, and the DLCST was 58 years. The mean pack-year smoking history in the NLST was 56, in the DANTE 47.3 in the intervention group versus 47.2 in the control group, and in the DLCST 36.4 in the intervention group versus 35.9 in the control group. The screening times, in terms of years, were year 0, year 1, and year 2 in the NLST, year 0, year 1, year 2, year 3, and year 4 in both the DANTE and DLCST. The relative risk of all-cause mortality in the NLST was 0.93 with a 95 percent confidence interval of 0.86 to 0.99, the DANTE was 0.85 with a 95 percent confidence interval of 0.56 to 1.27, and the DLCST was 1.46 with a 95 percent confidence interval of 0.99 to 2.15. The studies were combined for an overall relative risk of 1.02 with a 95 percent confidence interval of 0.78 to 1.33, with an I-squared of 61.0 percent and p of 0.077.

#### Chest X-Ray

To evaluate the effectiveness of screening for lung cancer with CXR, we limited our review to RCTs of screening that reported results in both the CXR and control groups published since the previous evidence review. We identified an update of the Mayo Lung Project of lung cancer screening with quarterly CXR screening conducted in the 1970s,58 and the first major publication of lung cancer results from the PLCO Screening Trial, which evaluated the effectiveness of screening with annual CXR in reducing lung cancer mortality (Table 2 and Appendix B1).59

After 20 years of followup in the Mayo Lung Project, lung cancer mortality rates were 440 per 100,000 py (95% CI, 390 to 490) and 390 per 100,000 py (95% CI, 350 to 440) in the intensive screening group and control group, respectively. In 2006, the results of this trial were updated and continued to show no benefit for intensive versus periodic screening with CXR in reducing lung cancer mortality.58

After 6 years of followup in the PLCO Screening Trial, the RR for lung cancer mortality among the entire CXR screened group compared with the usual care group was 0.91 (95% CI, 0.80 to 1.03). After 13 years of followup, the cumulative incidence of lung cancer in the CXR group was 200 per 100,000 py and 192 per 100,000 py in the usual care group. Over the same time period, there were 1,213 lung cancer deaths (140 per 100,000 py) in the CXR group and 1,230 (142 per 100,000 py) in the usual care group, with a RR of 0.99 (95% CI, 0.87 to 1.22). All-cause mortality rates were 1,052 per 100,000 py in the CXR group and 1,071 per 100,000 py in the usual care group, with a RR of 0.98 (95% CI, 0.95 to 1.01) after 13 years of followup.59

In addition to the analysis of CXR screening outcomes in the general population, the PLCO Screening Trial also assessed the effectiveness of CXR screening among individuals at high risk of lung cancer by evaluating the outcomes of individuals who would be eligible for the NLST (all current and former smokers ages 55 to 74 years with ≥30 pack-year smoking history). Among the 30,321 individuals meeting these criteria, the cumulative incidence of lung cancer through 6 years of followup was 606 per 100,000 py in the intervention group and 608 per 100,000 py in the control group (RR, 1.00 [95% CI, 0.88 to 1.13]). Over the same period of followup, the lung cancer mortality rates were 361 per 100,000 py in the CXR group and 383 per 100,000 py in the usual care group, with a RR of 0.94 (95% CI, 0.81 to 1.10). This study also evaluated lung cancer mortality associated with screening among women and found a RR of 0.92 (95% CI, 0.81 to 1.06) after 13 years of followup.59

#### Sputum Cytology

The searches did not identify any new studies that evaluated screening for lung cancer with sputum cytology. Sputum cytology was included as part of the study protocol in the DANTE trial, but results on effectiveness have not been reported.51,61

#### Benefits by Subgroup

All of the RCTs of screening with LDCT were conducted in participants at high risk of lung cancer based on participants' history of prior or current smoking. None evaluated low- or average-risk participants. The only CXR trial evaluating annual CXR screening compared with usual care among the general population was the PLCO Screening Trial, which showed no benefit of screening, with a RR of lung cancer death of 0.94 (95% CI, 0.81 to 1.10) after 6 years of followup and 0.99 (95% CI, 0.87 to 1.22) after 13 years of followup.59 None of the trials of LDCT reported findings by sex or race. Only the PLCO Screening Trial reported findings by sex, as noted above, and found the RR for lung cancer mortality among women from the general population (smokers and nonsmokers) screened annually with CXR was 0.92 (95% CI, 0.81 to 1.06). Data on women smokers enrolled in this trial have not yet been reported.

## Key Question 2 What Are the Test Characteristics of Screening Tests for Lung Cancer?

### Summary

Sensitivity of LDCT was reported in one trial and five cohort studies and ranged from 80 to 100 percent but was most often greater than 90 percent; however, the method for determining sensitivity varied among studies. Specificity was reported in two RCTs and five cohort studies and ranged from 28 to 100 percent; again the method for determining specificity varied among the studies. The calculated positive predictive value for an abnormal (positive or indeterminate) LDCT scan predicting lung cancer ranged from 2.2 to 42 percent. The calculated positive predictive value of a recommendation for biopsy or surgery based on LDCT for predicting lung cancer ranged from 50 to 92 percent. The sensitivity of CXR for lung cancer was reported in the prior review as 25 percent compared with LDCT, while specificity was not evaluated. No studies reported test parameters for sputum cytology.

### Evidence

In the previous evidence review,1 test characteristics of CXR and LDCT were summarized but not systematically reviewed; test characteristics of sputum cytology testing were not reviewed, although the effectiveness of screening with cytology was. For the current evidence review, data were included from the RCTs described above, as well as eight cohort studies meeting criteria for this review (Appendix B3). In addition, when data were not directly reported but were provided, we calculated the positive predictive value of LDCT both for “abnormal” or “suspicious” findings requiring further evaluation and for biopsy (or surgery if biopsy not reported) that resulted from the evaluation of an abnormal or suspicious LDCT.

#### Low-Dose Computed Tomography

All of the RCTs that reported data contributed to the discussion of test characteristics of LDCT. In addition, we identified eight cohort studies of LDCT that provided data on test characteristics. The findings from the cohort studies are summarized in Appendix B3. Because of variable ways of reporting results and/or test parameters, we did not calculate test parameters. It is important to note that there is no defined “gold standard” for evaluating either the sensitivity or specificity of LDCT.

Reported sensitivity of LDCT in prevalence and incidence screens ranged from 80 to 100 percent, with most studies reporting sensitivity greater than 90 percent.56,86-91 This number reflects variation in the definition of a false-negative. Most studies report a false-negative scan as LDCT that was negative within 1 year or less of the participant developing lung cancer. However, one study defined false-negative scans as those in which a participant developed greater than stage I lung cancer within 1 year of a negative screening scan.57 In addition, some studies reviewed prior LDCT scans when a nodule was identified on an incidence scan. If the abnormality was seen on a prior LDCT scan, the sensitivity was reported as if the prior scan had identified the nodule.

Specificity was reported in two RCTs52,56 and five cohort studies.86,87,89-91 In these studies, specificity ranged from 28^87^ to 100 percent.91 Variability in reporting of specificity can be attributed to heterogeneity in definitions between studies. Some trials report three categories of findings: positive, indeterminate, and negative. Also, some studies reported false-positive examinations as those categorized as “positive” on the screening LDCT scan; indeterminate examinations that were clarified by either treatment of an abnormality or another CT scan within the first few months of the indeterminate LDCT scan were not always considered or reported as false-positive examinations.56 We considered this type of specificity program or protocol specificity. Further complicating this issue, some studies only reported the number of positive scans or the number of nodules, rather than the number of participants with a positive scan, which is the most important measure in considering potential harms. This issue also complicates the understanding of positive predictive values discussed below.

#### Chest X-Ray

The previous evidence review assessed the test characteristics of CXR by comparing the findings among patients subjected to both LDCT and CXR and evaluating these parameters using LDCT as the gold standard, which may be problematic because of LDCT's low specificity. In that review, the sensitivity of CXR for detecting lung cancer compared with LDCT was 25 percent.1 No new studies directly reporting CXR test characteristics were identified by the current evidence review.

#### Sputum Cytology

As noted above, the previous evidence review did not evaluate the test characteristics of sputum cytology as a screening test for lung cancer, and thus did not provide data on this measure for the current evidence review. The current evidence review did not identify any papers that reported sputum cytology test characteristics published in the medical literature since the previous evidence review. One RCT and two cohort studies included in the current evidence review collected sputum samples from participants,58,61,89 but no studies formally reported on the test characteristics of sputum cytology testing. It is likely that the absence of recent data on this topic reflects the fact that sputum cytology has not been studied as a screening method since trials conducted in the mid1970s failed to show benefit from screening with sputum cytology.1 Accordingly, sputum cytology testing is now rarely used for lung cancer screening.

#### Test Characteristics by Subgroups

No studies provided data on test characteristics by subgroups other than by risk profile. Since the predictive value of tests will vary with prevalence, all screening tests will have higher predictive value in individuals at higher baseline risk of lung cancer.

## Key Question 3 What Are the Harms Associated With Lung Cancer Screening and Are There Ways to Modify Harms?

### Summary

#### Radiation Exposure

Two RCTs and two cohort studies reported radiation associated with one LDCT scan ranging from 0.61 to 1.5 mSv; however, only one study reported cumulative radiation exposure associated with the screening program, which was estimated at 6 to 7 mSv.

#### False-Positive Examinations and Followup Evaluations

Positive examinations ranged from 9.2 to 51 percent (of participants) in baseline screens, with calculated positive predictive values for abnormal studies ranging from 2.2 to 36 percent; most abnormal scans were resolved with further imaging. Positive examinations were lower in subsequent screens, with positive predictive values for abnormal studies predicting lung cancer of 4 to 42 percent and most abnormal scans were resolved with further imaging. Positive predictive values for abnormal LDCT scans with recommendations for biopsy ranged from 50 to 92 percent.

#### False Reassurance

The sensitivity of LDCT for detecting lung cancer ranged from 80 to 100 percent, implying a false-negative rate of 0 to 20 percent. The harm of false reassurance was not evaluated in any study.

#### Overdiagnosis

Overdiagnosis was not formally reported in any study. However, of the four RCTs of LDCT reporting results in both the LDCT and no LDCT groups, overdiagnosis was suggested in one trial showing an excess of 119 lung cancers among 26,722 participants after 6.5 years of followup. Four RCTS reported more early-stage lung cancer in LDCT-screened groups than among the control group but not a smaller number of advanced lung cancers. However, there was insufficient followup in these studies to fully evaluate overdiagnosis. Data from one older trial of lung cancer screening with CXR involving approximately 9,000 high-risk participants showed that after 20 years of followup an excess of lung cancers diagnosed in the screened group persisted. The PLCO Screening Trial of CXR screening in the general population (n=155,000) found 18 excess lung cancers in the CXR group (compared with no CXR) after 6 years of followup (2 years after screening ended) and 76 lung cancers after 13 years of followup (RR, 1.05 [95% CI, 0.98 to 1.12]); data from the same trial evaluating overdiagnosis only among a high-risk population showed a cumulative incidence of lung cancer of 606 per 100,000 py in the CXR group and 608 per 100,000 py in the usual care group after 6 years of followup (RR, 1.00 [95% CI, 0.88 to 1.13]).

#### Psychosocial Consequences

Five studies evaluated psychosocial consequences among individuals undergoing LDCT screening. Overall, LDCT screening did not appear to significantly impact overall health-related quality of life and no long-term difference in anxiety was reported, although in the short-term, three studies suggested increased anxiety among those with positive or indeterminate results compared with baseline. Distress was decreased among individuals in one trial with negative results compared with baseline.

#### Smoking Behavior

RCTs identified no differences in smoking cessation rates, smoking relapse rates, or smoking intensity when comparing individuals randomized to LDCT with no LDCT. In RCTs, smoking behavior among subjects with abnormal scans compared with those with negative scans showed mixed results; one study showed a tendency toward smoking abstinence among those with abnormal scans and one showed no difference. Similar mixed results were seen in cohort studies that compared smoking behaviors among those with abnormal and negative scans. One cohort study suggested that physician referral for patients with abnormal screening LDCT scans (compared with nonreferral for those with negative studies) may result in higher smoking cessation rates.

#### Incidental Findings

Most of the studies included in this review reported incidental findings. However, there was no standardized approach to reporting these findings. Among the studies of LDCT, nonpulmonary findings were common; infections and other cancers were also diagnosed. Coronary artery calcification was identified in approximately 50 percent of participants in one cohort study evaluating LDCT.

### Evidence

#### Radiation Exposure

One of the direct harms associated with LDCT is radiation exposure. Data on LDCT parameters and radiation exposure in trials of LDCT screening are shown in Table 4. Two RCTs and two cohort studies reported the radiation associated with one LDCT scan as ranging from 0.65 to 1.5 mSv. Of the seven RCTs of LDCT screening included in the current evidence review, only the ITALUNG trial accounted for cumulative radiation exposure, using estimates of exposure for specific scanners and techniques employed.81 In 1,406 subjects randomized to LDCT screening, the four screening LDCT scans accounted for 77 percent of all radiation exposure, and evaluation of abnormal findings with additional CT scans, PET/CT, and CT-guided biopsy accounted for 23 percent. The cumulative exposure from screening over 4 years averaged 6 to 7 mSv. In individual patients screened on a single detector scanner, exposure over 4 years was as high as 21.5 mSv, and with four negative studies on multidetector (MD) CT scanners, as low as 1.9 mSv.82 MDCT is associated with lower radiation doses than single-detector CT technology. The cumulative effective doses per 1,000 subjects were 3.3 mSv using an MDCT scanner and 5.8 or 7.1 mSv using a single-detector scanner.81 No studies reported radiation exposure among individuals enrolled in CXR trials. The reported LDCT exposures compare with background radiation exposures in the United States that average 2.4 mSv per year, with significantly higher exposures at higher elevations.92 Also, to provide context, other imaging radiation exposure rates are approximately 1.7 mSv for head CT, 5 mSv for lumbosacral spine x-ray, and 0.7 mSv for mammography. Notably, a roundtrip flight from New York City to London would be associated with radiation exposure of approximately 0.1 mSv.92,93

Table 4 Computed Tomography Parameters

Study | kV | mAs | Slice width (mm) | Overlap | Multi/single detector | Estimated dose/study (mSv)
Randomized, controlled trials
NLST54, 72 | 120–140 | 40–80 | 1–2.5 | Yes | MDCT | 1.5
LSS55, 73-75 | 120–140 | 60–120 | NR | NR | NR | NR
DANTE51, 61 | 140 | 40 | 5 | NR | Both | NR
MILD53 | 120 | 30 | 1–5 | No | Both | 0.7
NELSON56, 63-67, 69-71, 77-80 | 80–90 | 40–80 | 1 | Yes | MDCT | NR
DLCST76 | 120 | 40 | 3 and 1 | Yes | 16 row MDCT | NR
Cohort studies
Canada ELCAP86, 94 September 2003–May 2007 | 120 | 40–60 | 1–1.25 | Yes | Variable row 4–64 | NR
China ELCAP95 2 cohorts: 1993–2002 and 2003–2009 | 120 | 80 | 5 | NR | Both | NR
COSMOS91, 96 October 2004–October 2005 | 140 | 30 | 2.5 | NR | 8–16 row MDCT | 0.8 men 1.0 women
Toyoda et al, 2008^89^ August 1998–May 2002 | NR | NR | NR | NR | NR | NR
Mayo Lung Project87 1999 | 120 | 40 | 5 | NR | 4 row MDCT | 0.65
PLuSS97 March 2002–November 2006 | 140 | 40–60 | 2.5 | NR | NR | NR
Tsushima et al, 2008^90^ 2000–2001 | 120 | 25 | 5 | NR | MDCT | NR
LUSI98 | NR | NR | 1 | Yes | MDCT | 1.62–2

Abbreviations: COSMOS = Continuing Observation of Smoking Subjects; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST = Danish Lung Cancer Screening Trial; ELCAP = Early Lung Cancer Action Program; LSS = Lung Screening Study; LUSI = The German Lung Cancer Screening Intervention Trial; MDCT = Multidetector computed tomography; MILD = Multi-centric Italian Lung Detection; NELSON = Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST = National Lung Screening Trial; NR = not reported; PLuSS = Pittsburgh Lung Screening Study

#### False-Positive Examinations and Followup Evaluations

The RCTs of LDCT reported the number of noncalcified nodules identified on screening and associated followup evaluations in varying detail. However, the definition of a positive LDCT scan, the categorization of nodules, the methods used to follow nodules, and the method of reporting nodules (by individual or by screen) varied among the studies, making comparisons difficult. In addition, some studies reported all lung cancer and some (NSCLC) only the primary object of screening. Notably also, the evaluations occurring in patients randomized to usual care were rarely reported in the trials that only presented early information on the intervention groups or baseline data.

Since the predictive value of tests will vary with the prevalence of the disease in the population, we have summarized baseline and annual or overall prevalence rates (cumulative incidence) in Table 5 for both intervention and control groups. In trials of LDCT that reported the prevalence of lung cancer detected at baseline in high-risk populations, the prevalence ranged from 0.6 to 2.2 percent,52,54,56,61,62,74,82 suggesting different baseline risk for lung cancer or different LDCT program characteristics. Among the cohort studies, reported baseline prevalence ranged from 1.1 to 4.5 percent58,88,91,96 in high-risk populations. The studies included in the current evidence review vary by number of incidence screens, as well as length of followup, and some only report cumulative incidence or overall rates, making it difficult to compare cumulative incidence rates. These numbers are shown in Tables 5 and 6. Two cohort studies conducted in Japanese populations89,90 evaluated LDCT screening in the general population and reported lower lung cancer prevalence rates of 0.9 to 1.0 percent overall,89,90 but did not separately report data on prevalence and incidence screens.

Table 5 Results of Screening Rounds in Randomized, Controlled Trials^*^

Author, year | Round screening | Number screened | | Study positives, n (%) | | Imaging followup
Author, year | Round screening | Number screened | | Study positives, n (%) | | CXR, n (%) | | CT, n (%) | | PET, n (%)
Author, year | Round screening | IN | CO | IN | CO | IN | CO | IN | CO | IN | CO
NLST54 Reported by procedure, except where noted | Baseline Round 1 Round 2 Cumulative | 26,722 | 26,732 | 7191 (27)^†^ 6901 (26)^†^ 4054 (15)^†^ 18,146 (68)^†^ 10,421 (39) | 2387 (8.9)^†^ 1482 (5.5)^†^ 1174 (4.4)^†^ 5043 (19)^†^ 4277 (16) | 1284 (4.8)^†^ 613 (2.3)^†^ 650 (2.4)^†^ 2547 (9.5)^†^ | 867 (3.2)^†^ 381 (1.4)^†^ 365 (1.4)^†^ 1613 (6.0)^†^ | 5153 (19)^†^ 2046 (7.7)^†^ 1608 (6.0)^†^ 8807 (33)^†^ | 1546 (5.8)^†^ 745 (2.8)^†^ 712 (2.7)^†^ 3003 (11)^†^ | 728 (2.7)^†^ 350 (1.3)^†^ 393 (1.5)^†^ 1471 (5.5)^†^ | 179 (0.7)^†^ 105 (0.4)^†^ 113 (0.4)^†^ 397 (1.5)^†^
LSS55 | Baseline | 1660 | 1658 | 325 (20) | 152 (9.2) | 92 (5.5) | 68 (4.1) | 232 (14) | 76 (4.6) | NR | NR
LSS74 | Annual | 1629 | 1648 | 295 (18) | 145 (8.8) | 64 (3.9) | 45 (2.7) | 140 (8.6) | 55 (3.3) | NR | NR
DLCST52 | Baseline | 2052 (2047 had 1st LDCT) | 2052 | 189 (9.2) Baseline recall rate (7.6) | NR | NR | NR | 155 (7.6) | NR | NR | NR
DLCST52 | 1 | 1976 | 1953 | 117 (5.9) | NR | NR | NR | 20 (1.0) | NR | NR | NR
DLCST52 | 2 | 1944 | 1877 | 52 (2.7) | NR | NR | NR | 24 (1.2) | NR | NR | NR
DLCST52 | 3 | 1982 | 1838 | 82 (4.1) | NR | NR | NR | 18 (0.1) | NR | NR | NR
DLCST52 | 4 | 1851 | 1820 | 72 (3.9) | NR | NR | NR | 24 (1.3) | NR | NR | NR
DLCST52 | All annual | 96% | 93% | 198/2054 (9.6) | NR | NR | NR | 24 | NR | NR | NR
NELSON56 | Baseline | 7557 | NR | 1451 (19) indeterminate and 119 (1.6) positive; 196 (2.6) referred for further evaluation | NR | 55 (0.7) | NR | 1438 (19) | NR | 0 | 0
NELSON56 | 1 | 7289 | NR | 480 (6.6) indeterminate and 90 (1.2) positive; 118 (1.6) referred for further evaluation | NR | 35 (0.5) | NR | 275 (3.8) | NR | NR | NR
MILD53 | Overall | Biennial 1186 | 1723 | Biennial 158 (13) | NR | NR | NR | NR | NR | Biennial 34 (2.9) | NR
MILD53 | Overall | Annual 1190 | 1723 | Annual 177 (15) | NR | NR | NR | NR | NR | Annual 49 (4.1) | NR
ITALUNG57 | Baseline | 1406 | 1593 | 426 (30) | NR | NR | NR | 366 (26) | NR | 59 (4.2) | NR
DANTE51 | Overall | 1276 | 1196 | 351 (28) (226 further evaluation) | 153 (12.8) | NR | 38 (3.2) | 199 (16) | 22 (1.8) | 57 (4.5) | 4 (0.3)

Author, year | Biopsy^‡^, n (%) | | Surgery^‡^, n (%) | | Bronchoscopy, n (%) | | Screen-detected lung cancer, n (%) | | Total lung cancer, n (%)
Author, year | IN | CO | IN | CO | IN | CO | IN | CO | IN | CO
NLST54 | 155^‡^ (0.6)^†^ 74 (0.3)^†^ 93 (0.3)^†^ 322 (1.2)^†^ | 83 (0.3)^†^ 37 (0.1)^†^ 52 (0.2)^†^ 172 (0.6)^†^ | 297 (1.1)^†^ 197 (0.7)^†^ 219 (0.8)^†^ 713 (2.7)^†^ | 121 (0.5)^†^ 51 (0.2)^†^ 67 (0.3)^†^ 239 (0.9)^†^ | 306 (1.1)^†^ 178 (0.7)^†^ 187 (0.7)^†^ 671 (2.5)^†^ | 107 (0.4)^†^ 56 (0.2)^†^ 62 (0.2)^†^ 225 (0.8)^†^ | 270 (1.0)^†^ 168 (0.6)^†^ 211 (0.8)^†^ 649 (2.4)^†^ | 136 (0.5)^†^ 65 (0.2)^†^ 78 (0.3)^†^ 279 (1.0)^†^ | 1060 (4.0)^†^ 367 after screening or among those missing LDCT; 44 interval | 941 (3.5)^†^ 527 among those missing a screen or after screening ended;137 interval
LSS75 | 63 | NR | 46 (2.8) | 12 (0.7) | 29 (1.7) | 8 (0.5) | 30 (1.8) | 7 (0.4)
LSS75 | 63 | NR | 18 (1.1) | 19 (1.2) | 14 (0.9) | 8 (0.5) | 8 (0.5) | 9 (0.5) | 40 (2.5) | 20 (1.2)
DLCST52 | NR | NR | NR | NR | NR | NR | 17 (0.8) | 1 (0.05)
DLCST52 | 2 (0.1) | NR | 18 (0.9) | NR | 13 (0.7) | NR | 11 (0.6) | 4 (0.2)
DLCST52 | NR | NR | NR | NR | NR | NR | 13 (0.7) | 6 (0.3)
DLCST52 | NR | NR | NR | NR | NR | NR | 12 (0.6) | 7 (0.4)
DLCST52 | NR | NR | NR | NR | NR | NR | 16 (0.9) | 6 (0.3)
DLCST52 | NR | NR | NR | NR | NR | NR | 69 | 24 | 69 (3.8) | 24 (1.2)
NELSON56 | 13 (0.2) | NR | 92 (1.2) invasive procedures | NR | 149 (2.0) | NR | 70 (0.9) | NR | 74 (1.0) | NR
NELSON56 | 3 (0.04) | NR | 61 (0.4) invasive procedures | NR | 98 (1.3) | NR | 54 (0.7) | NR | Uncertain | NR
MILD53 | NR | NR | NR | NR | NR | NR | 20 (1.7) | 20 (1.2) | 25 (2.1) | 20 (1.2)
| NR | | NR | | NR | | 29 (2.4) | | 34 (2.9) | NR
ITALUNG57 | 16 (1.1) FNA | NR | 16 (1.1) for treatment | NR | NR | NR | 20 (1.4) | NR | 20 (1.4) | NR
DANTE51 | NR | NR | 96 (7.5) invasive procedures, 46 (3.6) thoracotomy, 20 (1.6) VATS | 36 (3.0) any invasive procedure, 20 (1.7) thoracotomy, 6 (0.5) VATS | NR | NR | 47 (3.7) | 11 (0.9) | 60 (4.7) | 34 (2.8)

* Per individual, unless otherwise noted.

† Per test.

‡ Per study definition.

Abbreviations: CO = control group; CT = computed tomography; CXR = chest x-ray; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays Trial; DLCST = Danish Lung Cancer Screening Trial; FNA = fine needle aspiration; IN = intervention group; LDCT = low-dose computed tomography; LSS = The Lung Screening Study; MILD = Multi-centric Italian Lung Detection; NELSON = Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST = National Lung Screening Trial; NR = not reported; PET = positron emission tomography; VATS = video-assisted thoracic surgery

Table 6 Results of Screening Rounds in Cohort Studies

Study | Round of screening | Number screened | Study positives, n (%) | Repeat CT or PET, n (%) | Biopsy^*^, n (%) | Surgery^*^, n (%) | Lung cancer, n (%)
Cornell ELCAP88 | Baseline Repeat | 2968 4538 | 368/2968 (12) 254/4538 (5.6) | NR NR | NR NR | NR NR | 79/2968; 77 screen-detected (2.7) 29/4538; 28 screen-detected (0.6)
China ELCAP95 | Baseline | 3582 | 351/3582 (10) | 313/3582 (8.7) | NR | 37/3582 (1.0) | 34/3582 (0.95); interval cancers NR
Canada ELCAP86 | Baseline Repeat | 3352 2286 | 600/3352 (18) 259/2286 (11) | NR NR | 57/3352 (1.7) 25/2286 (1.1) 78 done | NR | 44/3352 (1.3) 21/2286 (0.9); 18 screen-detected
COSMOS91, 96 | Baseline Round 1 | 5201 4821 | 560/5201 (11) 500/4821 (10) | 561/5201 (11) NR | NR 101/5201 overall (1.9) | 62/5201 (1.2) 46/4821 (0.9) | 55/5201 (1.0) 37/4821 (0.8); 36 screen-detected
Mayo Lung Project87 | Baseline Repeat (4) | 1520 | 780/1520 (51) 1118/1520 (73) | NR NR | NR NR | NR NR | 31/1520 (2.0) 35/1520 (2.2); 34 screen-detected
Japan Toyoda et al, 2008^89^ | Overall | 4689 | NR | NR | NR | NR | 45/4689 (0.96) - all screen detected
PLuSS97 | Baseline | 3642 | 1477/3642 (40) | 821/3642 (22) | NR | 90/3642; 54 for cancer (2.5) | 80/3642 (2.2); interval cancers NR
Japan Tsushima et al, 2008^90^ | Overall | 2486 | 214/2486 (8.6) | 170/2486 HRCT (6.8) | NR | 7/2486 (0.3) | 8/2486 (0.3); all screen-detected
LUSI98 | Baseline | 2029 | 540/2029 (27) | NR | 31/2029 (1.5) | 19/2029 (0.9) | 23/2029 (1.1); 22 screen-detected

* Per study definition.

Abbreviations: COSMOS = Continuing Observation of Smoking Subjects; CT = computed tomography; ELCAP = Early Lung Cancer Action Program; HRCT = high-resolution computed tomography; LUSI = The German Lung Cancer Screening Intervention Trial; NR = not reported; PET = positron emission tomography; PLuSS = Pittsburgh Lung Screening Study

One of the most common and important harms to consider in screening for lung cancer is the evaluation of patients with positive scans, which often involves more imaging and sometimes more invasive procedures such as bronchoscopy, fine needle biopsy, and/or surgery. Importantly, surgery is used both for diagnosis and treatment of early-stage lung cancer, making it difficult to separate the two. We attempted to evaluate these harms when they were reported in the studies; however, reporting varied substantially. To address this issue, we examined rates of positive scans and the subsequent evaluation of abnormal scans in both the RCTs52,54-56 and the cohort studies;86,88,96,98 this information is summarized in Tables 5 and 6. The prevalence of findings defined as “positive” varied between studies. On average, the number of positive examinations was higher on baseline screens and ranged from 9.2 to 39 percent in the RCTs52,54-56 and 9.8 to 51 percent in the cohort studies,86,88,91,96 with most in the 10 to 20 percent range. The positive predictive value for an abnormal baseline finding showing cancer ranged from 2.2 to 36 percent in the RCTs.55-57,73 Among the cohort studies, the positive predictive value of abnormal baseline scans requiring further evaluations ranged from 4 to 21 percent, meaning that 79 to 96 percent of positive baseline scans did not result in a diagnosis of cancer.86-88,91 Since most positive scans were resolved by comparison with prior scans or further imaging, we also calculated the positive predictive value for a patient being referred for biopsy in the RCTs as a measure of harm. These positive predictive values ranged from 50 to 81 percent, suggesting that most patients who undergo an invasive procedure, such as biopsy, are diagnosed with lung cancer; in the cohort studies, the positive predictive value for patients referred to biopsy or surgery ranged from 66 to 92 percent.

The NLST was the only RCT that reported complications from diagnostic procedures used to evaluate a positive LDCT scan.54 In this study, complications from diagnostic procedures were low; the rate of at least one complication was 1.4 percent in the LDCT group and 1.6 percent in the CXR group. Major complications were infrequent in both groups of this study. Among individuals diagnosed with lung cancer, there were 75 major complications in the LDCT group (11.5% of positive screen results determined to be cancer) and 24 in the CXR group (8.6% of positive screen results determined to be cancer) that were associated with invasive diagnostic procedures. However, among individuals with positive studies who were not found to have lung cancer and underwent invasive procedures, there were 12 major complications among LDCT participants (0.1% of positive screen results determined to not be cancer) and four among CXR participants (0.1% of positive screen results determined to not be cancer). Notably, 16 participants in the LDCT group died within 60 days after an invasive procedure (10 of whom had lung cancer), as did 10 (all with lung cancer) in the CXR group. It is not known if the procedure itself was the cause of death and deaths were not reported separately by procedure.

#### False-Negative Examinations and False Reassurance

The sensitivity of LDCT for detecting lung cancer at baseline was reported in one RCT as 96 percent.56 Though sensitivity of incidence screens was rarely reported, the NELSON trial reported it as 96 percent.56 Sensitivity was reported in five cohort studies56,86,87,89,90 and ranged from 80 to 100 percent. These data imply false-negative examination rates in the range of 4 to 20 percent. We found no studies that evaluated the potential harm associated with false-negative examinations, although this is an important harm to consider given the potential for false reassurance of patients and/or providers, which may delay evaluation of suspicious symptoms in the future.

#### Overdiagnosis and Overtreatment

One of the most concerning aspects of screening for lung cancer is the issue of possible overdiagnosis and treatment of lung cancer that will not impact a patient's life either due to mild disease that does not progress, cancer that resolves spontaneously, or death from other causes (competing mortality). If screening is effective and does not cause overdiagnosis after an adequate period of followup, both groups of a RCT will have the same number of cancers, but more early-stage and less late-stage (in absolute terms) disease should be found in the screened group. Alternately, finding more cancers in the screened group compared with the control group, especially more early-stage disease with the same number of later-stage disease, would be evidence for overdiagnosis.

While the optimum followup duration for measuring overdiagnosis is not known, the NLST found 119 more lung cancers (1,060 vs. 941) in the LDCT group compared with the CXR group after a median of 6.5 years of followup, suggesting overdiagnosis.54 In addition, we found evidence in the LDCT trials of more early-stage lung cancers in the LSS, DANTE, MILD, and DLCST trials.51-53,55 However, with the exception of the NLST, these studies did not report fewer stage III to IV lung cancers in the LDCT group compared either with CXR or usual care.

Recent data from the Italian Continuing Observation of Smoking Subjects cohort study involving 5,203 asymptomatic participants aged 50 years and older describing VDT as a measure of potential overdiagnosis indicates variable VDT among lung cancers diagnosed in a screening program.99 There were 175 patients diagnosed with lung cancer either with baseline LDCT (n=55) or subsequent LDCT (n=120). Of the 120 incident lung cancers, the authors demonstrated that VDT varies continuously from very slow-growing (VDT ≥600 days) to fast-growing (VDT of 52 days), with 75 percent of the incident lung cancer categorized as fast-growing. The authors suggest that this pool of slow-growing tumors are potentially those that are “overdiagnosed,” but note that the growth rate of what appear to be slow-growing (indolent) cancers can increase markedly from one scan to the next, complicating decisions about appropriate followup and treatment of slower-growing lesions. In addition, the lung cancer risk profile of patients with lung cancer in this study correlated with VDT, suggesting that slow-growing cancer is more common in lower-risk people.

Data from the 1970s Mayo Lung Project of quarterly CXR screening compared with less frequent CXR screening over 4 years have shown a persistent excess of lung cancers diagnosed in the CXR group (585 vs. 500) after 20 years of followup (16 years after screening ended) without a reduction in mortality or tumors identified at late stages.58 Interestingly, in the 16 years after the Mayo Lung Project trial ended, more lung cancer was diagnosed in the CXR group (379 cases) compared with the control group (340 cases), in the absence of a screening program. Data from the PLCO Screening Trial conducted in the general population identified 76 extra lung cancers after 13 years of followup, with a cumulative incidence RR of 1.05 (95% CI, 0.98 to 1.12), suggesting less overdiagnosis. However, data from the PLCO Screening Trial at 6 years of followup (2 years after screening stopped) showed an excess of 18 lung cancers in the CXR group compared with the usual care group.59 More relevant to screening high-risk individuals, in PLCO participants at high risk of lung cancer due to tobacco exposure, the cumulative incidence of lung cancer after 6 years of followup was the same in both groups: 606 per 100,000 py in the CXR group and 608 per 100,000 py in the usual care group after 6 years of followup (RR, 1.00 [95% CI, 0.88 to 1.13]).

#### Psychosocial Consequences

Three RCTs (in five publications) of either fair- or good-quality evaluated psychosocial consequences among individuals undergoing lung cancer screening with LDCT.68,69,77,100,101 Overall, LDCT screening did not appear to significantly impact general health-related quality of life, regardless of whether the screen findings were negative or indeterminate. Similarly, most studies did not find a long-term difference in anxiety, regardless of the screen result. In the short-term after a LDCT, approximately half of the patients reported discomfort about waiting for the results and dread of the results.68 Measured 2 months after baseline LDCT in the NELSON trial, distress levels increased from baseline after an indeterminate result.77 Compared with baseline, distress decreased for subjects with negative LDCT results.69,77 For subjects in the Pittsburgh Lung Screening Study (PLuSS),100 compared with baseline, state anxiety increased at 1 to 2 weeks and 6 months after an indeterminate result but returned to baseline 12 months after the LDCT scan. Similarly, for 60 subjects in the Mayo Clinic Project with a family risk of lung cancer who had a nonnegative result, worry increased from baseline in the short-term but returned to baseline 6 months after the LDCT scan.101 In a report based on the NELSON trial,69 the only study to compare screened subjects with usual care subjects, health-related quality of life and anxiety were similar 2 years after enrolling in the study for both screened and usual care subjects. This study did report a short-term increase from baseline in distress for subjects who received an indeterminate result after LDCT that returned to baseline 2 years after the baseline scan.

#### Smoking Behavior

Seven studies, including three RCTs (in four publications)70,72,80,102 and four cohort studies (in five publications),103-107 reported smoking behavior changes in lung cancer screening studies and were included (Table 7).

Table 7 Smoking Rates

Study | N | Quit rates (for baseline smokers) | Relapse rate | Measure for abstinence
Randomized, controlled trials
NELSON70 Random sample of baseline smokers | 1284 | 24 months: CT group: 13% (84/641)^*^ Control group: 15% (96/643)^*^ p=0.35 | NR | 7 day PPA plus <5 cigarettes since 2 weeks after quit date
NELSON80 Random sample of baseline smokers in CT group | 990 | 24 months: Negative CT group: 8.9% (46/519)^*^ Indeterminate CT group: 11% (48/419)^*^ p=0.19 | NR | 7 day PPA plus <5 cigarettes since 2 weeks after quit date
DLCST62 | 4104 | 12 months: CT group: 11% (174/1545)^*^ Control group: 10% (165/1579)^*^ p=0.47 | Former smokers: CT: 9.3% (47/507)^*,†^ Control: 9.3% (44/473)^*,†^ | >4 weeks PPA
Cohorts from randomized, controlled trials
NLST72 LSS | NLST: 169 LSS: 144 | 1 month: NLST: 6.3% (5/79)^*,†^ LSS: 4.8% (4/83)^*,†^ | Former smokers: NLST: 4.4% (4/90)^*,†^ LSS: 3.3% (2/61)^*,†^
Cohorts
ELCAP104 | 2078 | Up to 72 months: 14% (103/730)^*,‡^ | Recent quitters (during study) with followup: 34% (52/155) Recent quitters (<12 months prior to study): 42% (51/121) Former smokers: 4.4% (54/1227) | 30 day PPA
Mayo Lung Project105 12-month followup | 1475 | 12 months: 14% (129/901) | Former smokers: 10% (numerator/denominator NR) | PPA
Mayo Lung Project106 36-month followup | 1520 | 12 months: 14% (129/926)^*,†^ 24 months: 22% (202/926)^*,†^ 36 months: 23% (211/926)^*,†^ Repeat 7 day PPA × 36 months: 9.3% (86/926)^*,†^ | Recent quitters (during study) 12 months: NA 24 months: 26% (33/129)^*,†^ 36 months: 31% (62/202)^*,†^ Recent quitters (<12 months prior to study) 12 months: 32% (48/151)^*,†^ 24 months: 26% (40/151)^*,†^ 36 months: 27% (41/151)^*,†^ Former smokers: 12 months: 2.3% (10/439)^*,†^ 24 months: 2.7% (12/439)^*,†^ 36 months: 3.0% (13/439)^*,†^ | 7 day PPA
PLuSS107 | 2094 | 12 months: 16% (325/2094) | Recent quitters (during study): 12 months: 12% (244/2094) | >30 day PPA
PALCAD103 | 449 | 24 months: 19% (59/307) | 24 months: 1.6% | PPA

* Intention-to-treat analysis.

† Calculated.

‡ Point abstinent with subsequent followup.

Abbreviations: CT = computed tomography; DLCST = Danish Lung Cancer Screening Trial; ELCAP = Early Lung Cancer Action Program; LSS = Lung Screening Study; NELSON = Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST = National Lung Screening Trial; NR = not reported; PALCAD = ProActive Lung Cancer Detection; PLuSS = Pittsburgh Lung Screening Study; PPA = point prevalence abstinence

Screening versus no screening. Two RCTs compared the effect of LDCT lung cancer screening with no screening on rates of smoking cessation.62,70 The DLCST found smoking abstinence (defined as >4 weeks of abstinence) rates of 10 and 11 percent in the no screening and LDCT groups, respectively, after 1 year of followup.62 The NELSON trial reported prolonged smoking abstinence (defined as 7-day point prevalence abstinence and <5 cigarettes since 2 weeks after their quit date) rates of 15 and 13 percent in the no screening and LDCT groups, respectively, after 2 years of followup (p=0.35).70 The study also reported a non–intention-to-treat analysis among only those who responded to the followup smoking behavior survey. In this analysis, the prolonged abstinence rates were 19 percent in the no screening group and 15 percent in the LDCT group (OR, 1.40 [95% CI, 1.01 to 1.92]; p=0.04), which the authors interpreted as an unfavorable influence of screening on smoking behavior. However, response rates differed significantly among the groups, with a 78 percent response from the no screening group and 91 percent response from the LDCT participants. Because of the significantly different response rates among LDCT and control groups, we believe the most valid measure of smoking cessation comes from evaluating the full sample rather than just the responders.

Relapse rates were only reported in the DLCST,62 which found baseline former smokers had a relapse rate of 9.3 percent in both the no screening and the LDCT groups after 1 year, assuming nonattendees did not restart smoking. If nonattendees resumed smoking, the relapse rates may have been as high as 21 and 17 percent in the no screening and LDCT groups, respectively. Smoking intensity changes were only reported in the NELSON trial and did not differ between the no screening and LDCT groups.70 In the no screening group and LDCT groups, respectively, 32 compared with 29 percent maintained baseline smoking intensity, 14 compared with 18 percent increased smoking intensity, and 54 compared with 53 percent decreased smoking intensity.70

Comparing positive, indeterminate, and negative results. Two RCTs and two cohort studies in three publications62,80,104,106 compared the effect of receiving a positive, negative, or indeterminate LDCT screening result on smoking cessation and relapse rates. An additional study evaluated the effect of physician referral category on these outcomes.107

The two RCTs reported on different groups and had varying followup durations, making comparisons difficult. The DLCST demonstrated a tendency toward increased smoking abstinence and decreased relapse rates after 1 year in participants with a positive LDCT result.62 For baseline smokers with a positive result, the quit rate was 18 versus 11 percent in the group with negative LDCT results (p=0.04). In baseline former smokers with a positive LDCT result, the relapse rate (smoking during the year before followup) was significantly less (4.7%) than for those with a negative result (11%; p<0.01). A second trial (NELSON)80 reported no statistically significant differences in prolonged smoking abstinence between male baseline smokers who received a negative LDCT screen result and those who received an indeterminate result after 2 years of followup (8.9% vs. 12%, respectively; p=0.19). Prolonged abstinence rates in this study did not differ significantly between participants with a single indeterminate LDCT result and those with multiple indeterminate results, though there was a trend toward higher abstinence rates among participants with multiple indeterminate findings (11% for single indeterminate result and 15% for ≥2 indeterminate results; p=0.26).

Two cohort studies in three publications reported mixed findings for the effect of LDCT screen results on smoking behavior.104,106 The Mayo Clinic Project cohort study reported increased odds of smoking abstinence among current smokers who received followup recommendations based on the prior year's LDCT scan (OR, 1.37 [95% CI, 1.12 to 1.67]; p=0.002). At 3 years of followup, those who received three recommendations for interim followup had the highest percentage of smoking abstinence (42%). For those that received no recommendations (implying a negative screening LDCT), the smoking abstinence rate was 20 percent. The influence of followup recommendations did not reach statistical significance for relapse rates among former smokers or recent quitters. Another cohort study, the Early Lung Cancer Action Program (ELCAP),104 reported that a positive LDCT scan was not a significant predictor for prolonged abstinence in participants without a lung cancer diagnosis within 1 year (HR, 1.34 [95% CI, 0.90 to 1.99]). A positive LDCT finding was also not significantly associated with relapse of baseline smokers who quit.

The PLuSS107 cohort study reported the effect of physician referral category on smoking behavior. LDCT screen results were used to categorize participants by risk (based on the LDCT findings): no referral, other referral, low suspicion (<5% predicted probability for lung cancer), or moderate/high suspicion (>5% predicted probability for lung cancer). The proportion of baseline smokers who were abstinent for more than 30 days at 1 year followup increased with increasing category of risk, from 14 percent in the no referral group to 26 percent in the moderate/high suspicion group (excluding participants who received a lung cancer diagnosis over this period).

#### Incidental Findings

Most of the studies included in the current evidence review reported incidental findings discovered in the course of screening for lung cancer. As there is no standardized research approach to defining what is considered an important incidental finding in lung cancer screening, investigators varied in what findings they reported. For example, researchers from the PLCO Screening Trial reported the frequency of emphysema and chronic obstructive pulmonary disease incidentally detected by screening CXR,59 whereas the majority of other RCTs in the current evidence review did not. Additionally, some studies reported incidental findings by radiographic description, such as lymphadenopathy, but others provided a clinical diagnosis, such as lymphoma. Given the variability in reporting practices between studies and that the reported incidental findings could not always be traced to screening modality (CXR or LDCT), it was not possible to calculate the frequency of incidental findings in a meaningful way.

Among the lung cancer screening RCTs, nonpulmonary nodule lung findings were common and included diagnoses such as bronchiectasis, pulmonary fibrosis, carcinoid tumors, and hamartomas. The NLST reported clinically significant abnormalities other than lung cancer in 7.5 percent of LDCT and 2.1 percent of CXR participants.54 Notable infections included tuberculosis and fungal diseases. Other cancers discovered in the course of lung cancer screening included esophageal, thyroid, breast, renal, parathyroid, lymphomas, and metastatic cancers, such as colon and renal cell carcinoma. Some studies described cardiovascular findings such as coronary calcifications or aortic aneurysms. The finding of coronary artery calcification was reported in the Toronto ELCAP study and was approximately 50 percent.86,94 None of the studies reported what evaluations occurred in response to incidental findings.

While we have included this information under the key question dealing with harms for the current evidence review, it is plausible that there may also be some benefit to patients of identifying incidental findings. However, we found no data on either the harms or benefits associated with the incidental findings identified in the studies of screening reported in the current evidence review. Clearly, potential harms and benefits will vary by the finding, the clinical situation, and the patient's perspective.

## Key Question 4 How Effective Is the Treatment of Surgical Resection of Early (Stage IA) Non-Small Cell Lung Cancer?

### Summary

No RCTs compared treating stage IA or IB lung cancer with surgical resection with no treatment. Five studies from four cohorts in Japan showed 5-year survival rates for resected pathologic stage IA NSCLC ranging from 71 to 90 percent. Five-year survival among cohorts evaluating pathologic stage IB resected lung cancer ranged from 70 to 74 percent. Data from two large U.S. cohorts on 5-year survival among patients with resected stage IA NSCLC showed 5-year survival rates of 58 to 66 percent for stage IA and 55 percent for stage IB lung cancer resected between 1990 and 2000 (Table 8).

Table 8 Survival Benefit and Adverse Events After Treatment of Stage I Lung Cancer

Author, year Recruitment years | Population | Duration of followup | Stage IA (n) | Stage IB (n) | Surgery | 5-year survival | Harms
Chang et al, 2007^108^ 1988–1997 | N=10,761 stage IA 5320 women, 5441 men Median age: 67 years Other: SEER population | NR | 10,761 | 0 | Lobectomy: 79% Sublobectomy: 21% | Overall: 58% Women: 63% Men: 53% | NR
Christian et al, 2006^109^ 1991–2004 | N=1421 NSCLC resection, 548 complete resection stage IA/IB Mean age: 67 years Location: Italy | Median 49 months | 250 | 298 | Complete resection | Overall: 57% IA: 67% IB: 49% | 9 postoperative deaths
Goodgame et al, 2008^110^ 1990–2000 | N=715 consecutive patients undergoing resection 46% female 45% adenocarcinoma Location: United States Other: pathologic stage IA/IB Median age: 67 years | 4.7 years | 378 | 336 | Wedge: 34% Lobectomy: 21% Pneumonectomy: 40% | Overall: 61% IA: 66% IB: 55% | NR
Goya et al, 2005^111^ 1994 | N=6644 resected NSCLC 70% male Mean age: 64.5 yearsLocation: Japan | At least 5 years | 2423 | 1542 | NR | IA: 80% IB: 60% All stages: Men: 49% Women: 62% | NR
Kates et al, 2011^112^ 1988–2005 | N=2090 resected tumors ≤1 cm Lobectomy vs. sublobectomy Location: United States Other: SEER | 37 months | 2090 | 0 | 1402 lobectomy 688 “limited” resection | 64% alive after 37 months Not clear | NR
Maeda et al, 2010^113^ 1994–2003 | N=713 consecutive, 569 stage I 80% adenocarcinoma 46% female Location: Japan | NR | 249 | 320 | Wedge: 14% Lobectomy: 86% | 85% | NR
Maeda et al, 2012^114^ 1997–2003 | N=4668 all stages resected Location: Japan | Retrospective cohort with followup until March 2010 | 1487 | 1214 | NR by stage | IA: 42% ASC 89% AC 63% SC IB: 19% ASC 65% AC 47% SC | NR
McKenna et al, 2006^115^ 1992–2004 | N=1100 patients of all stages undergoing VATS Location: NR | NR but data out to 10 years | 561 | 248 | VATS lobectomy | NR | Entire cohort: Benign dissection: 53/1100 (4.8%) Lung cancer: 1015/1100 (92%) No intraoperative deaths 9 postoperative deaths (0.8%) 168 had complications: 56 air leak, 32 atrial fibillation, 13 readmission, 13 pneumonia
Okada et al, 2004^116^ 1985–1995 1996–2002 | N=1465 consecutive patients, of which 859 stage I Location: Japan Other: NSCLC | 103 months early era 41 months later era | 523 | 326 | NR by stage | IA: 71% early era 90% later era IB: 63% early era 75% later era | Entire cohort: 6.3% operative deaths Postoperative complications: Early era: 28% Late era: 12% In-hospital deaths: Early era: 2% Late era: 0.5%
Okada et al, 2006^117^ 1992–2001 | N=510, ≤2 cm undergoing sublobar, lobar, or wedge resection Location: Japan Other: Peripheral NSCLC | 72 months | 510 | 0 | Wedge: 30 Segmentectomy: 230 Lobectomy: 260 | 90% 89% | 1 operative death (29 days postoperative MI)
Sawabata et al, 2011^118^ 2004 1999 1994 | N=11,663 (2004), 13,344 (1999), 7393 (1994), 7530 stage I Location: Japan Other: NSCLC undergoing resection in 2004 | 2–78 months | Pathologic: 2004: 5611 1999: 5007 1994: 2142 Overall: 12,760 | Pathologic: 2004: 2398 1999: 2803 1994: 1488 Overall: 6689 | NR | 2004 IA: 87% IB: 74% 1999 IA: 83% IB: 66% 1994 IA: 79% IB: 66% | Entire cohort: Postoperative complications: 2004: 4.5% 1999: 11% 1994: NR Operative deaths: 2004: 0.4% 1999: 0.9% 1994: 1.4% Hospital death: 2004: 0.4% 1999: 1.1% 1994: 1.7% Cause of death original cancer: 2004: 21% 1999: 25% 1994: 57%
Shirvani et al, 2012^119^ 2001–2007 | N=7808 (3582 men; 4226 women) Location: United States Other: SEER | Retrospective cohort with followup through May 2010 | 6047 | 1761 | Lobectomy: 6531 Sublobar resection: 1277 | NR | NR
Strand et al, 2006^120^ 1993–1999 | N=3211 resected 2061 men, 1150 women (resection rate in country 16%, of which 1375=stage I) Location: Norway | NR | 559 | 816 | NR by stage | IA: 64% IB: 42% | Entire cohort 30-day mortality: 4.8%

Abbreviations: AC = adenocarcinoma; ASC = adenosquamous carcinoma; MI = myocardial infarction; NR = not reported; NSCLC = non-small cell lung cancer; SC = squamous cell carcinoma; SEER = Surveillance Epidemiology and End Results; VATS = video-assisted thoracic surgery

### Evidence

No RCTs that assessed the effectiveness of surgical resection for stage IA NSCLC compared with no treatment were identified. Data from the United States on 5-year survival rates among patients with resected stage I NSCLC come from four studies.108,110,112,119 Data from the Surveillance Epidemiology and End Results (SEER) Program on 2,090 NSCLC cases less than 1 cm, resected between 1988 and 2005, and comparing lobectomy with sublobectomy showed 67 percent of patients overall were alive at 37 months.112 A large study (n=10,761) utilizing SEER data of stage IA patients with a median age of 67 years, resected between 1988 and 1997, and a mean followup of 8.3 years, reported overall 5-year survival of 58 percent (63% for women and 53% for men).108 Another study (n=715) of consecutive patients with pathologic stage I NSCLC, a median age of 67 years, and resected between 1990 and 2000 reported 5-year survival rates of 66 percent for stage IA and 55 percent for stage IB NSCLC.110 Finally, the most relevant evidence may come from a study of various treatment strategies evaluated in a cohort of 10,923 Medicare patients age 66 years or older diagnosed with stage IA to IB NSCLC between the years of 2001 and 2007. In this study, 2-year overall mortality was 18 percent among patients treated with lobectomy (n=6,531), 25 percent with sublobar resections, 41 percent with stereotactic ablative radiation, 57 percent with conventional radiation, and 73 percent with observation without treatment. In a multivariable adjusted analysis, observation was associated with a higher risk for lung cancer–specific mortality compared with anatomic surgical resection (HR, 3.01 [95% CI, 2.51 to 3.60]) more than 6 months after treatment.119

Five studies of four cohorts from Japan with survival data on patients with resected stage IA NSCLC were included.111,113,116-118 Generally, these studies included from 510 to 12,760 subjects and reported 5-year survival rates for resected stage IA lung cancer ranging from 71 to 90 percent, with the more recent studies consistently showing approximate survival in the 85 to 90 percent range.111,113,116-118 Because screening often detects stage IB NSCLC, we also report survival rates for resected pathologic stage IB NSCLC. Five-year survival among the cohorts evaluating pathologic stage IB patients ranged from 70 to 74 percent in the more recent studies evaluating survival among these patients.113,118

Several comparative studies evaluated secular trends in survival that support significant improvement in 5-year survival rates over time.116 One large study (n=12,760) of pathologic stage IA patients resected during 2004, 1999, and 1994 reported 5-year survival rates of 89, 83, and 79 percent, respectively. While these numbers likely reflect improved staging technology and surgical technique, they may also show secular changes in patient populations, since widespread lung cancer screening with LDCT was implemented in Japan in the early 2000s.111

Two studies from Europe were also identified. In these studies, 5-year survival for stage IA NSCLC ranged from 64 to 67 percent and survival for stage IB from 42 to 49 percent.109,120 However, these studies reported data collected on patients resected in the 1990s, which is unlikely generalizable to current practice.

While the rates described above from the United States are likely the most generalizable to the United States, it is important to note that these survival rates reflect survival among unselected and presumably symptomatic patients, since, for the most part, there has been little lung cancer screening in the United States during the time periods reviewed. Because of this, the survival rates identified in Japan may represent the “best” estimates for long-term survival from NSCLC under ideal circumstances or are more comparable to a screening population, since screening has been widespread there for many years.

## Key Question 5 What Are the Harms Associated With Surgical Resection of Early (Stage IA) Non-Small Cell Lung Cancer?

### Summary

None of the RCTs of LDCT screening evaluated the harms associated with resection of screen-detected stage 1A NSCLC. Two cohort studies evaluated the harms associated with resection of stage IA NSCLC. One Japanese study reported one postoperative death among 510 individuals undergoing resection between 1992 and 2001. One Italian study conducted between 1991 and 1994 (n=548) with complete resections of stage I NSCLC reported nine postoperative deaths among those resected. Six studies reported harms among large cohorts of individuals undergoing resection but did not specify results specifically for stage IA NSCLC.

### Evidence

The NLST reported 60-day mortality after surgery associated with lung cancer resection of 1 percent; however, this included all resections, not just stage IA or IB resections.54 To more fully address the harm associated with the treatment of early-stage lung cancer, we included several cohort studies of resection.108-120 However, of the 13 large studies (n≥500) we reviewed, only two reported on operative complications among patients undergoing surgery for stage IA NSCLC. One study (n=510) reporting outcomes among patients with NSCLC 2 cm or less in diameter undergoing resection in Japan between 1992 and 2001 identified one postoperative death among this cohort.117 Another trial from Italy (n=548) conducted between 1991 and 1994 and involving the complete resection of patients with stage IA or IB lung cancer reported nine postoperative deaths among those resected.109

Six studies reported harms associated with resection in all patients with resected lung cancer, not limited to those with stage IA lung cancer.109,115-118,120 Among these cohorts, one study reporting on patients resected between 1993 and 1999 in Norway, where resection rates are very low (16%), reported a 30-day postoperative mortality rate of 4.8 percent in the entire cohort.120 Another study (n=1,465) of consecutive patients of all stages resected in Japan during the years 1985 to 1995 and 1996 to 2002 reported postoperative complication rates of 28 percent in the 1985 to 1995 cohort and 12 percent in the 1996 to 2002 cohort. In-hospital deaths among those resected between 1985 and 1995 were 2 percent and among those resected from 1996 to 2002 were 0.5 percent.116 More applicable data comes from a large cohort (n=11,663) resected in 2004 in Japan. Among those resected, 4.5 percent had postoperative complications and 0.4 percent operative deaths and 0.4 percent hospital deaths occurred.118 Notably, these complications were summarized for the entire cohort, including all stages and all degrees of comorbidity and symptomatology. Finally, a study of patients in the United States (n=1,100) undergoing video-assisted thorascopic surgery procedures between 1992 and 2004 reported no intraoperative deaths, nine postoperative deaths (0.8%), and 168 complications, including 56 air leaks, 32 cases of atrial fibrillation, 13 pneumonias, and 13 readmissions.115 Similar to the large Japanese cohort described above, these data reflect complications and adverse events associated with resection of all stages of lung cancer and symptomatic disease among patients with unknown comorbidities. Thus, the applicability of these complication rates to screening populations is uncertain.