# METHODS

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,48 the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed (Figure 1). The target population for lung cancer screening was asymptomatic men and women at average risk or current and former smokers at high risk.

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts the pathway that asymptomatic adults at average or high risk for lung cancer may experience during screening for lung cancer. The figure shows that adults who undergo screening for lung cancer may have early detection of lung cancer or harms related to screening. The figure shows the next steps in the pathway for those who have early detection of lung cancer, is receiving treatment for lung cancer and harms related to treatment. The pathway shows outcomes of interest after screening and treatment to be decreased mortality and morbidity.

### Key Questions

1. How effective is screening for lung cancer in reducing mortality and morbidity?
  a. How effective is screening in persons at average risk?
  b. How effective is screening in persons at higher risk for lung cancer (e.g., current or former smokers)?
  c. Does effectiveness differ by subgroups (e.g., sex, age, race, presence of comorbid conditions, other lung cancer risk factors)?
2. What are the test characteristics (sensitivity, specificity, predictive value) of screening tests for lung cancer?
  a. How do these test characteristics vary by lung cancer risk?
  b. How are test characteristics different by subgroups (e.g., sex, age, race)?
3. What are the harms associated with lung cancer screening and are there ways to modify harms (e.g., unnecessary biopsy, radiation exposure, overdiagnosis, and psychosocial harms)?
4. How effective is surgical resection for the treatment of early (stage IA) NSCLC?
5. What are the harms associated with surgical resection of early (stage IA) NSCLC?

Key question 1 focuses on direct evidence that screening for lung cancer improves important health outcomes compared with no screening. The remainder of the analytic framework (key questions 2 through 5) evaluates the chain of indirect evidence needed to link screening for lung cancer with improvement in important health outcomes. Links in the chain of indirect evidence include the performance, yield, and acceptability of the screening test for lung cancer; the effectiveness of interventions for reducing morbidity and mortality; and any harms associated with screening and subsequent interventions.

## Search Strategies

In conjunction with a research librarian, investigators searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through the fourth Quarter 2012), MEDLINE (2000 through December 2012), reference lists of papers, and Scopus for relevant English-language studies and systematic reviews. Search strategies are described in Appendix A1.

## Study Selection

At least two reviewers independently evaluated each study to determine eligibility for inclusion. Investigators selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). Papers were selected for full-text review if they were about lung cancer screening, were relevant to a key question, and met the predefined inclusion criteria. We restricted inclusion to English-language articles and excluded studies only published as abstracts. Studies of nonhuman subjects were also excluded, and studies had to include original data.

For key questions 1, 2, and 3, we included large (n ≥1,000) screening trials and/or studies of adult (age ≥18 years) men and women without signs of lung cancer. The screening interventions were LDCT, CXR, sputum cytology, or a combination of these screening interventions. For key questions 4 and 5, we focused on surgical resection of early (stage I) NSCLC. Outcomes were mortality, morbidity, impact on smoking cessation, quality of life, incidental findings, and harms from screening (such as false-positives, radiation, and overdiagnosis) and treatment. For key questions 4 and 5, we limited our review of treatments to studies involving 500 or more people and those published in the last 12 years, as our interest was in treatment outcomes that are relevant to current practice. Given differences in stage classification, diagnostic procedures used to define stage, and surgical techniques, we determined studies published before those dates would be unlikely to be generalizable to current clinical practice.

## Data Abstraction and Quality Rating

For each included study, an investigator abstracted details about the patient population, study design, screening procedure, imaging assessment, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Investigators used criteria developed by the USPSTF48 to rate the quality of each RCT as good, fair, or poor (Appendix A3) if they reported results for both comparison groups. Two investigators independently rated the quality of studies and resolved discrepancies by consensus. Several studies reported their findings in more than one paper. When this occurred, the data reported in this review are from the most recent publication unless unique data were presented in an older publication.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (“good,” “fair,” “poor”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence.48

Meta-analyses were conducted to summarize data and obtain more precise estimates on outcomes for trials that were homogeneous enough to provide a meaningful combined estimate. In order to determine whether meta-analysis could be meaningfully performed, we considered the quality of the studies and the heterogeneity among studies in design, patient population, interventions, and outcomes. When meta-analysis could not be performed, the data were summarized qualitatively.

Only dichotomous outcomes (cancer incidence and mortality and all-cause mortality) were included in meta-analysis and relative risk (RR) was used as the effect measure. All combined effects were estimated using random-effects models.49 The Q statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess heterogeneity in effects between studies.50 Because of the small number of studies, it was not feasible to conduct subgroup analysis and meta-regression to explore heterogeneity. We conducted sensitivity analyses to check the impact of quality on the results. All analyses were performed using Stata/IC 12.0 (StataCorp, College Station, TX).

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners (Appendix A4). Revisions have been made in response to reviewers' and USPSTF members' comments.