# Evidence Tables and Quality Tables

Appendix B1 Evidence Table of Included Randomized, Controlled Trials

Appendix B2 Quality Rating Table of Included Studies

Appendix B3 Evidence Table of Included Cohort Studies