# Detailed Methods

## Appendix A1 Search Strategies

### Screening key questions 1, 2, and 3

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1947 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Lung Neoplasms/ (146585)
2. exp Mass Screening/ (85357)
3. screen$.mp. (381192)
4. ((early or earlier or earliest) adj5 (detect$ or diagnos$ or discover$ or find or finding)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] (123562)
5. exp early diagnosis/ (9549)
6. 2 or 3 or 4 or 5 (492801)
7. 1 and 6 (7310)
8. limit 7 to (english language and humans and yr=“2000 -Current”) (3399)

Database: EBM Reviews - Database of Abstracts of Reviews of Effects <4th Quarter 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. ((Lung or lungs or bronchi$ or alveol$ or respiratory tract$ or pulmonar$) adj5 (Neoplas$ or cancer$ or malig$ or tumor$ or tumour$ or carcino$ or adenocarcino$ or metastas$)).mp. [mp=title, full text, keywords] (276)
2. screen$.mp. (2503)
3. ((early or earlier or earliest) adj5 (detect$ or diagnos$ or discover$ or find or finding)).mp. [mp=title, full text, keywords] (132)
4. 2 or 3 (2562)
5. 1 and 4 (52)

Database: EBM Reviews - NHS Economic Evaluation Database <4th Quarter 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. ((Lung or lungs or bronchi$ or alveol$ or respiratory tract$ or pulmonar$) adj5 (Neoplas$ or cancer$ or malig$ or tumor$ or tumour$ or carcino$ or adenocarcino$ or metastas$)).mp. [mp=title, text, subject heading word] (416)
2. screen$.mp. (2484)
3. ((early or earlier or earliest) adj5 (detect$ or diagnos$ or discover$ or find or finding)).mp. [mp=title, text, subject heading word] (259)
4. 2 or 3 (2575)
5. 1 and 4 (50)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <4th Quarter 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. ((Lung or lungs or bronchi$ or alveol$ or respiratory tract$ or pulmonar$) adj5 (Neoplas$ or cancer$ or malig$ or tumor$ or tumour$ or carcino$ or adenocarcino$ or metastas$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (6652)
2. screen$.mp. (11379)
3. ((early or earlier or earliest) adj5 (detect$ or diagnos$ or discover$ or find or finding)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (2242)
4. 2 or 3 (13141)
5. 1 and 4 (252)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. ((Lung or lungs or bronchi$ or alveol$ or respiratory tract$ or pulmonar$) adj5 (Neoplas$ or cancer$ or malig$ or tumor$ or tumour$ or carcino$ or adenocarcino$ or metastas$)).mp. [mp=title, abstract, full text, keywords, caption text] (227)
2. screen$.mp. (3227)
3. ((early or earlier or earliest) adj5 (detect$ or diagnos$ or discover$ or find or finding)).mp. [mp=title, abstract, full text, keywords, caption text] (527)
4. 2 or 3 (3431)
5. 1 and 4 (142)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$)).mp. [mp=title, abstract, full text, keywords, caption text] (242)
2. ((x ray$ or radiogra$ or sputum$ or cytolog$) adj5 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. [mp=title, abstract, full text, keywords, caption text] (302)
3. 1 and 2 (17)
4. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$) adj7 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. (55)
5. ((chest$ or thorax$ or thoracic$) adj5 (x-ray$ or radiogra$)).mp. [mp=title, abstract, full text, keywords, caption text] (233)
6. 4 and 5 (9)
7. sputum.mp. [mp=title, abstract, full text, keywords, caption text] (221)
8. 4 and 7 (5)
9. 3 or 6 or 8 (23)
10. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$)).mp. [mp=title, abstract, full text, keywords, caption text] (242)
11. ((x ray$ or xray$ or radiogra$ or sputum$) adj5 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. [mp=title, abstract, full text, keywords, caption text] (260)
12. 10 and 11 (11)
13. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$) adj7 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. (55)
14. ((chest$ or thorax$ or thoracic$) adj5 (x-ray$ or xray$ or radiogra$)).mp. [mp=title, abstract, full text, keywords, caption text] (236)
15. 13 and 14 (9)
16. sputum.mp. [mp=title, abstract, full text, keywords, caption text] (221)
17. 13 and 16 (5)
18. 12 or 15 or 17 (18)

Database: EBM Reviews - Health Technology Assessment <4th Quarter 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$)).mp. [mp=title, text, subject heading word] (186)
2. ((x ray$ or radiogra$ or sputum$ or cytolog$) adj5 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. [mp=title, text, subject heading word] (52)
3. 1 and 2 (3)
4. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$) adj7 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. (42)
5. ((chest$ or thorax$ or thoracic$) adj5 (x-ray$ or radiogra$)).mp. [mp=title, text, subject heading word] (19)
6. 4 and 5 (8)
7. sputum.mp. [mp=title, text, subject heading word] (8)
8. 4 and 7 (2)
9. 3 or 6 or 8 (8)
10. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$)).mp. [mp=title, text, subject heading word] (186)
11. ((x ray$ or xray$ or radiogra$ or sputum$) adj5 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. [mp=title, text, subject heading word] (26)
12. 10 and 11 (3)
13. ((lung$ or pulmonar$ or bronch$ or alveol$) adj5 (cancer$ or carcino$ or adenocarcino$ or malig$ or tumor$ or tumour$ or neopla$) adj7 (test$ or diagno$ or screen$ or find$ or found$ or discover$ or uncover$)).mp. (42)
14. ((chest$ or thorax$ or thoracic$) adj5 (x-ray$ or xray$ or radiogra$)).mp. [mp=title, text, subject heading word] (19)
15. 13 and 14 (8)
16. sputum.mp. [mp=title, text, subject heading word] (8)
17. 13 and 16 (2)
18. 12 or 15 or 17 (8)

### Intervention key questions 4 and 5

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1946 to 2012>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Lung Neoplasms/su [Surgery] (21220)
2. (stag$ adj (one or “1” or I or two or “2” or II or 1a or Ia or 1b or Ib or 1c or Ic or 2a or IIa or 2b or IIb)).mp. (54937)
3. ((early or earlier or earliest) adj5 (discover$ or found or find or finding or uncover$ or diagnos$ or detect$ or stage$ or staging)).mp. (239290)
4. 2 or 3 (286513)
5. 1 and 4 (3023)
6. exp lung neoplasms/ (157194)
7. exp Surgical Procedures, Operative/ (2186270)
8. 4 and 6 and 7 (2707)
9. 5 or 8 (3945)
10. exp “Outcome and Process Assessment (Health Care)”/ (602752)
11. 9 and 10 (748)
12. exp Mortality/ (249169)
13. mo.fs. (367310)
14. 12 or 13 (507080)
15. 9 and 14 (1650)
16. exp survival analysis/ (150994)
17. 9 and 16 (823)
18. exp Postoperative Complications/ (382994)
19. exp Intraoperative Complications/ (33158)
20. 18 or 19 (405151)
21. 9 and 20 (291)
22. ae.fs. (1238248)
23. ((advers$ or undesir$ or unwant$) adj5 (effect$ or outcome$ or result$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier] (131512)
24. exp “Wounds and Injuries”/et [Etiology] (109143)
25. 22 or 23 or 24 (1394472)
26. 9 and 25 (490)
27. exp “Quality of Life”/ (99185)
28. exp Quality-Adjusted Life Years/ (5646)
29. 27 or 28 (103891)
30. 9 and 29 (49)
31. exp “Costs and Cost Analysis”/ (164677)
32. 9 and 31 (34)
33. 11 or 15 or 17 or 21 or 26 or 30 or 32 (2450)
34. limit 33 to yr=“2000 -Current” (1725)

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | [underlined: Key questions 1–3:] Asymptomatic adults (ages ≥18 years) from large screening trials and/or studies who are generalizeable to the United States [underlined: Key questions 4–5:] Adults (ages ≥18 years) with early (stage IA) non-small cell lung cancer who are generalizeable to the United States | [underlined: Key questions 1–3:] Children Symptoms of lung cancer Prior lung cancer diagnosis [underlined: Key questions 4–5:] Children Not primary lung cancer Greater than stage IA lung cancer
Interventions | [underlined: Key questions 1–3:] Chest x-ray, computed tomography, and/or sputum cytology [underlined: Key questions 4–5:] Surgical resection | [underlined: Key questions 1–3:] No screening [underlined: Key questions 4–5:] Chemotherapy, radiation therapy, and natural therapies
Outcomes | Reduction in morbidity and/or all-cause mortality Reduction in lung cancer mortality/morbidity 5-year and 10-year survival rates Impact on smoking cessation Detection of other abnormalities Quality of life Direct harms from screening and/or treatment interventions | Cost-effectiveness
Study types and designs | Randomized, controlled trials; systematic reviews/meta-analyses; cohorts; case-control studies; and case series Published in or after 2001 | Opinions, editorials, case reports, no comparison group [underlined: Key questions 1–3:] Sample size less than 1000 [underlined: Key questions 4–5:] Sample size less than 500
Duration | [underlined: Key questions 1–3:] Any length of duration [underlined: Key questions 4–5:] At least 5 years of followup | [underlined: Key questions 1–3:] None [underlined: Key Questions 4–5:] Less than 5 years of followup

## Appendix A3 U.S. Preventive Services Task Force Quality Rating Criteria for Randomized, Controlled Trials

### Randomized, Controlled Trials (RCTs)

Criteria
- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of ratings based on above criteria

Good: | Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Sources: Harris et al, 2001^48^

## Appendix A4 List of Reviewers

### Expert Reviewers

- Peter B. Bach, MD, MAPP, Full Member, Director, Center for Health Policy and Outcomes, Memorial Sloan-Kettering Cancer Center
- Harold Sox, MD, Associate Director for Faculty, The Dartmouth Institute, Dartmouth Medical School
- David J. Ballard, MD, MSPH, PhD, FACP, Senior Vice President and Chief Quality Officer, Baylor Health Care System, Executive Director and BHCS Endowed Chair, Institute for Health Care Research and Improvement

### Federal Reviewers

- Joseph Chin, MD, Office of Clinical Standards and Quality, Centers for Medicare and Medicaid Services
- Barnett Kramer, MD, MPH, Associate Director for Disease Prevention, Director Office of Medical Applications of Research, Office of Disease Prevention, Office of the Director, National Institutes of Health
- Linda Kinsinger, MD, MPH, VHA, National Center for Health Promotion and Disease Prevention
- Paul Pinsky, PhD, National Institutes of Health

## Appendix A5 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, hand searching, and suggestions by experts.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

Abbreviations: COSMOS = Continuing Observation of Smoking Subjects; DANTE = Detection and Screening of Early Lung Cancer by Novel Imaging Technology and Molecular Essays; DLCST = Danish Lung Cancer Screening Trial; I-ELCAP = International Early Lung Cancer Action Program; LSS = Lung Screening Study; MILD = Multicentric Italian Lung Detection; NELSON = Nederlands-Leuvens Longkanker Screenings Onderzoek; NLST = National Lung Screening Trial ; PALCAD = ProActive Lung Cancer Detection; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; PLUSS = Pittsburgh Lung Screening Study; SCTS = Spiral Chest Computed Tomography Study

Appendix A5 is a flow chart that summarizes the search and selection of articles. There were 8,149 citations identified by searching MEDLINE, Cochrane Central Register of Controlled Trials, and other sources, such as reference lists and suggestions from peer reviewers. After screening, 6,415 abstracts were excluded. The full text of 1,734 citations were examined for inclusion for one or more of the five Key Questions and a total of 63 articles were included. 50 articles were included for Key Questions 1 through 3 and 13 were included for Key Questions 4 and 5.

## Appendix A6 List of Excluded Full-Text Papers

Key to exclusion codes

2 | Background
3 | Wrong population
4 | Wrong intervention
5 | Wrong publication
6 | Non-English, otherwise relevant
7 | Wrong outcome
8 | Conducted/Published prior to 2000
9 | Followup too short
10 | Sample size too small

## Listing of excluded papers

Screening for lung cancer. Med Lett Drugs Ther. 2001;43(1109):61-62. Exclusion code: 5. [pmid: 11468601].
Smoking cessation counseling needed with spiral CT screening for lung cancer. Oncology (Williston). 2002;16(6):816. 839. Exclusion code: 5. [pmid: 12088301].
National Lung Screening Trial (NLST). 2002. http://clinicaltrials.gov/ct/gui/show/NCT00047385;jsessionid=20DAB829F5C5A123FB490104A003A4BA?order=1. May 23, 2011. Exclusion code: 2.
Lung cancer can be diagnosed early. Health News. 2005;11(12):14. Exclusion code: 5. [pmid: 16419178].
Screening for cancer: colon, lung and skin cancers. Harv. Mens Health Watch. 2005;10(3):1-5. Exclusion code: 5. [pmid: 16296122].
Electronic nose shows promise for detecting early-stage lung cancer. Disease Management Advisor. 2005;11(6):71-72. 61. Exclusion code: 5. [pmid: 16060297].
Eleventh international conference on screening for lung cancer. Clin. Imaging. 2005;29(4):298-299. Exclusion code: 5. [pmid: 15967325].
Medicare Lung Cancer Screening Benefit Act of 2006. Shaw C. 109th Congress. 2006. Exclusion code: 5.
Potential new options for lung cancer screening. Disease Management Advisor. 2007;13(6):68-70. 61. Exclusion code: 2. [pmid: 17595920].
Can lung cancer screening save lives?. Johns Hopkins Med. Lett. Health After 50. 2007;19(2):7. Exclusion code: 5. [pmid: 17443995].
Lung cancer screening in women. Women seem to have a special vulnerability to lung cancer, whether they smoke or not. Is it time to be tested?. Harvard Women's Health Watch. 2007;14(7):1-2. Exclusion code: 5. [pmid: 17393589].
Screening for lung cancer. Vopr. Onkol. 2009;55(1):7-14. Exclusion code: 6. [pmid: 19435192].
Clinical implications. Cancer Treat. Res. 2010;154:201-214. Exclusion code: 5.
Study shows CT scans can reduce lung cancer deaths in smokers. Mayo Clin Womens Healthsource. 2011;15(5):3. Exclusion code: 5. [pmid: 21467956].
Why aren't you being screened for lung cancer? Research suggests CT scans may help pinpoint problems early enough to make a difference. Johns Hopkins. Med. Lett. Health After 50. 2011;23(2):4-5. Exclusion code: 5. [pmid: 21523950].
Abe H, Ishida T, Shiraishi J, et al. Effect of temporal subtraction images on radiologists' detection of lung cancer on CT: results of the observer performance study with use of film computed tomography images. Acad. Radiol. 2004;11(12):1337-1343. Exclusion code: 7. [pmid: 15596371].
Abe Y, Hanai K, Nakano M, et al. A computer-aided diagnosis (CAD) system in lung cancer screening with computed tomography. Anticancer Res. 2005;25(1B):483-488. Exclusion code: 2. [pmid: 15816616].
Aberle DR, Brown K. Lung cancer screening with CT. Clin. Chest Med. 2008;29(1):1-14. v. Exclusion code: 5. [pmid: 18267181].
Aberle DR, Gamsu G, Henschke CI, Naidich DP, Swensen SJ. A consensus statement of the Society of Thoracic Radiology: screening for lung cancer with helical computed tomography. J. Thorac. Imaging. 2001;16(1):65-68. Exclusion code: 5. [pmid: 11149694].
ACOG Committee. ACOG committee opinion. Routine cancer screening. Number 247, December 2000. Int. J._Gynaecol. Obstet. 2003;82(2):241-245. Exclusion code: 2. [pmid: 12926412].
Adachi H, Maehara T. Surgical treatment and outcome of multiple primary lung cancers. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(5):347-351. discussion 351-344. Exclusion code: 6. [pmid: 20446600].
Agarwal M, Brahmanday G, Chmielewski GW, Welsh RJ, Ravikrishnan KP. Age, tumor size, type of surgery, and gender predict survival in early stage (stage I and II) non-small cell lung cancer after surgical resection. Lung Cancer. 2010;68(3):398-402. Exclusion code: 9. [pmid: 19762109].
Ahn MI, Gleeson TG, Chan IH, et al. Perifissural nodules seen at CT screening for lung cancer. Radiology. 2010;254(3):949-956. Exclusion code: 2. [pmid: 20177105].
Aisner J. CT screening for lung cancer: are we ready for wide-scale application?. Clin. Cancer Res. 2007;13(17):4951-4953. Exclusion code: 5. [pmid: 17785542].
Ak I, Sivrikoz MC, Entok E, Vardareli E. Discordant findings in patients with non-small-cell lung cancer: absolutely normal bone scans versus disseminated bone metastases on positron-emission tomography/computed tomography. Eur. J. Cardiothorac. Surg. 2010;37(4):792-796. Exclusion code: 4. [pmid: 20015657].
Ak I, Stokkel MP, Pauwels EK. Positron emission tomography with 2-[18F]fluoro-2-deoxy-D-glucose in oncology. Part II. The clinical value in detecting and staging primary tumours. J. Cancer Res. Clin. Oncol. 2000;126(10):560-574. Exclusion code: 5. [pmid: 11043393].
Akata S, Yoshimura M, Nishio R, et al. High-resolution computed tomographic findings of small peripherally located squamous cell carcinoma. Clin. Imaging. 2008;32(4):259-263. Exclusion code: 4. [pmid: 18603179].
Aketa A, Yamada G, Aketa K, et al. Two younger male patients with rapidly progressing pulmonary pleomorphic carcinoma. Nihon Kokyuki Gakkai Zasshi. 2004;42(2):164-169. Exclusion code: 6. [pmid: 15007917].
Akopov AL, Dvorakovskaia IV. Vascular invasion by tumor in the absence of regional lymph node metastases in patients with locally advanced non-small cell lung cancer. Vopr. Onkol. 2004;50(4):417-420. Exclusion code: 6. [pmid: 15605763].
Alam N, Flores RM. Video-assisted thoracic surgery (VATS) lobectomy: the evidence base. J. Soc. Laparoendosc. Surg. 2007;11(3):368-374. Exclusion code: 5. [pmid: 17931521].
Alberg AJ, Ford JG, Samet JM. Epidemiology of lung cancer: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):29S-55S. Exclusion code: 2. [pmid: 17873159].
Alexandersson A, Jonsson S, Isaksson HJ, Gudbjartsson T. Sublobar resection for non-small cell lung cancer in Iceland. Laeknabladid. 2011;97(5):303-308. Exclusion code: 6. [pmid: 21586802].
Alexiou C, Beggs D, Onyeaka P, et al. Pneumonectomy for stage I (T1N0 and T2N0) nonsmall cell lung cancer has potent, adverse impact on survival. Ann. Thorac. Surg. 2003;76(4):1023-1028. Exclusion code: 10. [pmid: 14529978].
Alexiou C, Onyeaka CVP, Beggs D, et al. Do women live longer following lung resection for carcinoma?. Eur. J. Cardiothorac. Surg. 2002;21(2):319-325. Exclusion code: 3. [pmid: 11825743].
Allen JW, Farooq A, O'Brien TF, Osarogiagbon RU. Quality of surgical resection for nonsmall cell lung cancer in a US metropolitan area. Cancer. 2011;117(1):134-142. Exclusion code: 3. [pmid: 20737568].
Allen MS, Darling GE, Pechet TTV, et al. Morbidity and mortality of major pulmonary resections in patients with early-stage lung cancer: initial results of the randomized, prospective ACOSOG Z0030 trial. Ann. Thorac. Surg. 2006;81(3):1013-1019. discussion 1019-1020. Exclusion code: 2. [pmid: 16488712].
Altorki N, Kent M, Pasmantier M. Detection of early-stage lung cancer: computed tomographic scan or chest radiograph?. J. Thorac. Cardiovasc. Surg. 2001;121(6):1053-1057. Exclusion code: 2. [pmid: 11385370].
Amann A, Corradi M, Mazzone P, Mutti A. Lung cancer biomarkers in exhaled breath. Expert Rev Mol Diagn. 2011;11(2):207-217. Exclusion code: 2. [pmid: 21405971].
Amann A, Ligor M, Ligor T, et al. Analysis of exhaled breath for screening of lung cancer patients. Memo - Magazine of European Medical Oncology. 2010;3:106-112. Exclusion code: 4.
Ambrose LF. Lung cancer screening. CMAJ Canadian Medical Association Journal. 2009;180(13):1330. Exclusion code: 5. [pmid: 19546459].
Ambrose LF, Healton CG, Idige CR. Letter regarding US Preventive Services Task Force Review of Lung Cancer Screening. The Honorable Kathleen Sebelius S. US Department of Health and Human Services, editor. Washington, D.C. 2012. Exclusion code: 2.
Ambrose LF, Lopez TJ. Bulletin Essential Health Benefits. The Honorable Kathleen Sebelius S. US Department of Health and Human Services, editor. Washington, D.C. 2012. Exclusion code: 2.
American Cancer Society. Cancer Facts and Figures 2000. Exclusion code: 2.
American Cancer Society. Cancer Facts & Figures 2010. Atlanta. 2010. Exclusion code: 2.
American Cancer Society. Cancer Facts & Figures for African Americans 2011-12. Atlanta. 2011. Exclusion code: 2.
American Cancer Society. Cancer Facts & Figures 2011. Atlanta. 2011. Exclusion code: 2.
American Lung Association. Providing Guidance on Lung Cancer Screening To Patients and Physicians. 2012. http://www.lung.org/finding-cures/research-news/new-screening-guidelines/lung-cancer-screening.pdf. 30 Sept 2012. Exclusion code: 2.
Andersen KB, Dirksen A. Screening for lung cancer. Ugeskr. Laeger. 2000;162(14):2013. Exclusion code: 6. [pmid: 10815513].
Anderson MW, Goodin C, Zhang Y, et al. Effect of dietary green tea extract and aerosolized difluoromethylornithine during lung tumor progression in A/J strain mice. Carcinogenesis. 2008;29(8):1594-1600. Exclusion code: 3. [pmid: 18515278].
Andrade RS, Maddaus MA. Thoracoscopic lobectomy for stage I non-small cell lung cancer. Semin. Thorac. Cardiovasc. Surg. 2010;22(1):14-21. Exclusion code: 3. [pmid: 20813312].
Andreas S, Gamarra F, Herth F, et al. Prevention and early detection. Prävention und früherkennung. 2011;34(SUPPL. 4):2-10. Exclusion code: 6. [pmid: 21677467].
Andriani F, Conte D, Mastrangelo T, et al. Detecting lung cancer in plasma with the use of multiple genetic markers. Int. J. Cancer. 2004;108(1):91-96. Exclusion code: 4. [pmid: 14618621].
Andriole GL, Reding D, Hayes RB, Prorok PC, Gohagan JK, Committee PS. The prostate, lung, colon, and ovarian (PLCO) cancer screening trial: Status and promise. Urologic Oncology. 2004;22(4):358-361. Exclusion code: 5. [pmid: 15283897].
Anglim PP, Alonzo TA, Laird-Offringa IA. DNA methylation-based biomarkers for early detection of non-small cell lung cancer: an update. Molecular Cancer. 2008;7:81. Exclusion code: 5. [pmid: 18947422].
Anglim PP, Galler JS, Koss MN, et al. Identification of a panel of sensitive and specific DNA methylation markers for squamous cell lung cancer. Mol Cancer. 2008;7:62. Exclusion code: 4. [pmid: 18616821].
Aoki T, Tsuchida M, Watanabe T, et al. Surgical strategy for clinical stage I non-small cell lung cancer in octogenarians. Eur. J. Cardiothorac. Surg. 2003;23(4):446-450. Exclusion code: 10. [pmid: 12694757].
Arenberg D, Kazerooni EA. Setting up a lung cancer screening program. Journal of the National Comprehensive Cancer Network. 2012;10(2):277-285. Exclusion code: 5. [pmid: 22308520].
Arimura H, Katsuragawa S, Suzuki K, et al. Computerized scheme for automated detection of lung nodules in low-dose computed tomography images for lung cancer screening. Acad. Radiol. 2004;11(6):617-629. Exclusion code: 7. [pmid: 15172364].
Armato SG 3rd, Roy AS, Macmahon H, et al. Evaluation of automated lung nodule detection on low-dose computed tomography scans from a lung cancer screening program(1). Acad. Radiol. 2005;12(3):337-346. Exclusion code: 7. [pmid: 15766694].
Population screening for lung cancer (Brief record). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858 http://ovidsp.ovid.com/ovidweb.cgi?T=JS&CSC=Y&NEWS=N&PAGE=fulltext&D=cleed&AN=NHSEED-22004008915. Exclusion code: 2.
Armstrong P, Husband JE, Holemans JA. Population screening for lung cancer. Hospital Medicine (London). 2004;65(7):404-411. Exclusion code: 5. [pmid: 15287344].
Arsen'ev AI, Kanaev SV, Barchuk AS, et al. Use of endotracheobronchial surgery in conjunction with radiochemotherapy for advanced non-small lung cancer. Vopr. Onkol. 2007;53(4):461-467. Exclusion code: 6. [pmid: 17969412].
Artinian V, Kvale PA. Update in screening of lung cancer. Respirology. 2005;10(5):558-566. Exclusion code: 2. [pmid: 16268907].
Asamura H. Treatment of choice for stage I non-small cell lung cancer: surgery or radiotherapy?. J Thorac Oncol. 2006;1(8):766-767. Exclusion code: 5. [pmid: 17409957].
Asamura H, Goya T, Koshiishi Y, et al. A Japanese Lung Cancer Registry study: prognosis of 13,010 resected lung cancers. J Thorac Oncol. 2008;3(1):46-52. Exclusion code: 7. [pmid: 18166840].
Asaph JW, Handy JR Jr., Grunkemeier GL, et al. Median sternotomy versus thoracotomy to resect primary lung cancer: analysis of 815 cases. [Erratum appears in Ann Thorac Surg 2000 Dec;70(6):2187]. Ann. Thorac. Surg. 2000;70(2):373-379. Exclusion code: 3. [pmid: 10969647].
Ashizawa K. Problem of diagnosis and follow-up for pulmonary nodules detected on low-dose CT screening. Japanese Journal of Lung Cancer. 2007;47:769-776. Exclusion code: 5.
Ashraf H, de Hoop B, Shaker SB, et al. Lung nodule volumetry: segmentation algorithms within the same software package cannot be used interchangeably. Eur. Radiol. 2010;20(8):1878-1885. Exclusion code: 7. [pmid: 20306082].
Ashraf H, Tonnesen P, Holst Pedersen J, Dirksen A, Thorsen H, Dossing M. Effect of CT screening on smoking habits at 1-year follow-up in the Danish Lung Cancer Screening Trial (DLCST). Thorax. 2009;64(5):388-392. Exclusion code: 2. [pmid: 19052048].
Ashton RW, Jett JR. Screening for non-small cell lung cancer. Semin. Oncol. 2005;32(3):253-258. Exclusion code: 5. [pmid: 15988679].
Aust W, Sandner A, Neumann K, Lowe S, Knipping S, Bloching M. Stomal metastases after translaryngeal tracheotomy (TLT) according to Fantoni: a rare complication. HNO. 2007;55(2):114-117. Exclusion code: 6. [pmid: 16758210].
Austin JH, Stellman SD, Pearson GD. Screening for lung cancer. N. Engl. J. Med. 2001;344(12):935. author reply 936. Exclusion code: 5. [pmid: 11263429].
Austin JHM, Pearson GDN, Thomashow B. CT screening for early stage lung cancer. Chest. 2002;121(5):1725-1726. Exclusion code: 5. [pmid: 12006478].
Austin JHM, Yip R, D'Souza BM, Yankelevitz DF, Henschke CI, International Early Lung Cancer Action Program I. Small-cell carcinoma of the lung detected by CT screening: stage distribution and curability. Lung Cancer. 2012;76(3):339-343. Exclusion code: 2. [pmid: 22189270].
Avery JK. Early error: deadly consequences. Tenn. Med. 2009;102(2):33. Exclusion code: 5. [pmid: 19260553].
Avila RS, Zulueta JJ, Shara NM, et al. A quantitative method for estimating individual lung cancer risk. Acad. Radiol. 2010;17(7):830-840. Exclusion code: 4. [pmid: 20540908].
Cost-effectiveness decision analysis of mass screening for lung cancer (Structured abstract). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 2.
Bach P. Computed tomography screening for lung cancer. [Erratum appears in Clin Cancer Res. 2008 Jun 15;14(12):4025]. Clin. Cancer Res. 2008;14(8):2511. author reply 2511-2512. Exclusion code: 5. [pmid: 18413846].
Bach P, Gould M. When the average applies to no one: personalized decision making about potential benefits of lung cancer screening. Ann. Intern. Med. 2012;157(8):571-573. Exclusion code: 2. [pmid: 22893040].
Bach PB. CT screening for lung cancer. Cleve. Clin. J. Med. 2007;74(11):769-770. author reply 770. Exclusion code: 5. [pmid: 18019997].
Bach PB. Untreated patients in “CT screening for lung cancer: update 2007”. Oncologist. 2008;13(9):1030-1032. author reply 1033. Exclusion code: 2. [pmid: 18820170].
Bach PB. Is our natural-history model of lung cancer wrong?. Lancet Oncol. 2008;9(7):693-697. Exclusion code: 5. [pmid: 18598934].
Bach PB. Response to “CT screening for lung cancer: update 2007”. Oncologist. 2008;13(5):608-609. author reply 610-602. Exclusion code: 2. [pmid: 18581655].
Bach PB. Lung cancer screening. Journal of the National Comprehensive Cancer Network. 2008;6(3):271-275. Exclusion code: 2. [pmid: 18377845].
Bach PB. Inconsistencies in findings from the early lung cancer action project studies of lung cancer screening. J. Natl. Cancer Inst. 2011;103(13):1002-1006. Exclusion code: 5. [pmid: 21685356].
Bach PB. Response: Re: Inconsistencies in Findings from the Early Lung Cancer Action Project Studies of Lung Cancer Screening. J. Natl. Cancer Inst. 2012;104(3):255-256. Exclusion code: 5.
Bach PB, Cramer LD, Schrag D, Downey RJ, Gelfand SD, Begg CB. The influence of hospital volume on survival after resection for lung cancer. N. Engl. J. Med. 2001;345(3):181-188. Exclusion code: 2. [pmid: 11463014].
Bach PB, Jett JR, Pastorino U, Tockman MS, Swensen SJ, Begg CB. Computed tomography screening and lung cancer outcomes. [Erratum appears in JAMA. 2007 Aug 1;298(5):518]. JAMA. 2007;297(9):953-961. Exclusion code: 2. [pmid: 17341709].
Bach PB, Kattan MW, Thornquist MD, et al. Variations in lung cancer risk among smokers. J. Natl. Cancer Inst. 2003;95(6):470-478. Exclusion code: 2. [pmid: 12644540].
Bach PB, Kelley MJ, Tate RC, McCrory DC. Screening for lung cancer: a review of the current literature. Chest. 2003;123(1 Suppl):72S-82S. Exclusion code: 2. [pmid: 12527566].
Bach PB, Mirkin JN, Oliver TK, et al. Benefits and harms of CT screening for lung cancer: A systematic review. JAMA. 2012;307(22):2418-2429. Exclusion code: 2. [pmid: 22610500].
Bach PB, Silvestri GA, Hanger M, Jett JR, American College of Chest P. Screening for lung cancer: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):69S-77S. Exclusion code: 5. [pmid: 17873161].
Baecke E, de Koning HJ, Otto SJ, van Iersel CA, van Klaveren RJ. Limited contamination in the Dutch-Belgian randomized lung cancer screening trial (NELSON). Lung Cancer. 2010;69(1):66-70. Exclusion code: 4. [pmid: 19801174].
Baker RR, Tockman M, Marsh BR, Stitik FP, Ball WC Jr., Eggleston JC. Screening for bronchogenic carcinoma: the surgical experience. J. Thorac. Cardiovasc. Surg. 1979;78(6):876-882. Exclusion code: 5. [pmid: 502570].
Baldwin DR, Duffy SW, Wald NJ, Page R, Hansell DM, Field JK. UK Lung Screen (UKLS) nodule management protocol: modelling of a single screen randomised controlled trial of low-dose CT screening for lung cancer. Thorax. 2011;66(4):308-313. Exclusion code: 2. [pmid: 21317179].
Baldwin DR, White B, Schmidt-Hansen M, Champion AR, Melder AM, Guideline Development G. Diagnosis and treatment of lung cancer: summary of updated NICE guidance. BMJ. 2011;342:d2110. Exclusion code: 2. [pmid: 21525094].
Balevi B. Evidence-based decision making: Should the general dentist adopt the use of the VELscope for routine screening for oral cancer. Prise de décision fondée sur les données probantes: Le dentiste généraliste devrait-il adopter le VELscope pour le dépistage systématique du cancer de la bouche?. 2007;73(7):603-606. Exclusion code: 3. [pmid: 17868507].
Ball CG, Correa-Gallego C, Howard TJ, et al. Radiation Dose from Computed Tomography in Patients with Necrotizing Pancreatitis: How Much Is Too Much?. J. Gastrointest. Surg. 2010;14(10):1529-1535. Exclusion code: 3. [pmid: 20824381].
Banerjee S. Multi-slice/helical computed tomography for lung cancer screening. Issues in Emerging Health Technologies. 2003;(48):1-4. Exclusion code: 2. [pmid: 12812212].
Banks SB, Rose DM, Moore JM, Kline AL. The spectrum of treatment and future diagnosis of early non-small cell lung carcinoma. Curr. Surg. 2003;60(2):199-203. Exclusion code: 7. [pmid: 14972296].
Bao R. Screening for lung cancer with low-dose helical CT: Current date and outlook. Chinese Journal of Clinical Oncology. 2009;36(6):301-307. Exclusion code: 5.
Barash O, Peled N, Hirsch FR, Haick H. Sniffing the unique “odor print” of non-small-cell lung cancer with gold nanoparticles. SMALL. 2009;5(22):2618-2624. Exclusion code: 2. [pmid: 19705367].
Barba M, Felsani A, Rinaldi M, Giunta S, Malorni W, Paggi MG. Reducing the risk of overdiagnosis in lung cancer: a support from molecular biology. J. Cell. Physiol. 2011;226(9):2213-2214. Exclusion code: 4. [pmid: 21660943].
Barchuk AS, Arsen'ev AI, Pozharisskii KM. Clinical and morphologic correlations in bronchoalveolar cancer. Vopr. Onkol. 2003;49(3):316-322. Exclusion code: 6. [pmid: 12926213].
Baryshnikova E, Destro A, Infante MV, et al. Molecular alterations in spontaneous sputum of cancer-free heavy smokers: results from a large screening program. Clin. Cancer Res. 2008;14(6):1913-1919. Exclusion code: 4. [pmid: 18347195].
Bastarrika G, Alonso A, Saiz-Mendiguren R, Arias J, Cosín O. Coronary artery calcium quantification with non-ECG-gated low-radiation dose CT of the chest. Cuantificación de la calcificación coronaria en tomografía computarizada torácica de baja dosis de radiación sin sincronización cardiaca. 2010;52(1):30-36. Exclusion code: 7. [pmid: 20035960].
Bastarrika G, Garcia-Velloso MJ, Lozano MD, et al. Early lung cancer detection using spiral computed tomography and positron emission tomography. Am. J. Respir. Crit. Care Med. 2005;171(12):1378-1383. Exclusion code: 2. [pmid: 15790860].
Bastarrika G, Pueyo JC, Lozano MD, Montuenga L, Zulueta JJ. Screening for lung cancer with low-dose spiral CT: results in 150 asymptomatic subjects. Med. Clin. (Barc). 2003;121(2):41-47. Exclusion code: 6. [pmid: 12828882].
Bastarrika G, Pueyo JC, Mulshine JL. Radiologic screening for lung cancer. Expert Rev Anticancer Ther. 2002;2(4):385-392. Exclusion code: 5. [pmid: 12647981].
Bastarrika G, Wisnivesky JP, Pueyo JC, et al. Low-dose volumetric computed tomography for quantification of emphysema in asymptomatic smokers participating in an early lung cancer detection trial. J. Thorac. Imaging. 2009;24(3):206-211. Exclusion code: 7. [pmid: 19704324].
Battafarano RJ, Piccirillo JF, Meyers BF, Hsu HS, Guthrie TJ, Cooper JD. Impact of comorbidity on survival after surgical resection in patients with stage I non-small cell lung cancer. J. Thorac. Cardiovasc. Surg. 2002;123(2):280-287. Exclusion code: 4. [pmid: 11828287].
Bauer AK, Rondini EA. Review Paper: The role of inflammation in mouse pulmonary neoplasia. Vet. Pathol. 2009;46(3):369-390. Exclusion code: 5. [pmid: 19176494].
Bauer T. Lung cancer screening. Hematology - Oncology Clinics of North America. 2005;19(2):209-217. v. Exclusion code: 5. [pmid: 15833403].
Baumann M. Does chemotherapy improve the results of postoperative radiotherapy in completely resected stage II and IIIA non-small-cell bronchial cancer?. Strahlenther. Onkol. 2001;177(4):220-221. Exclusion code: 6. [pmid: 11370558].
Beane J, Spira A, Lenburg ME. Clinical impact of high-throughput gene expression studies in lung cancer. J Thorac Oncol. 2009;4(1):109-118. Exclusion code: 5. [pmid: 19096318].
Bechtel JJ, Kelley W, Coons T, klein G, Slagel D, Petty TL. Lung cancer detection in asymptomatic patients with airflow obstruction. Chest. 2004;125(no. 5 Suppl):163s. Exclusion code: 2. [pmid: 15136488].
Bechtel JJ, Kelley WA, Coons TA, Klein MG, Slagel DD, Petty TL. Lung cancer detection in patients with airflow obstruction identified in a primary care outpatient practice. Chest. 2005;127(4):1140-1145. Exclusion code: 2. [pmid: 15821187].
Bechtel JJ, Kelley WA, Coons TA, et al. Five-year outcome of lung cancer detection in patients with and without airflow obstruction in a primary care outpatient practice. J Thorac Oncol. 2009;4(11):1347-1351. Exclusion code: 2. [pmid: 19861904].
Strategies in lung cancer detection: achieving early identification in patients at high risk (Brief record). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 5.
Becker C. Support for scans. Studies present strong case for CT screening. Mod. Healthc. 2003;33(49):16. Exclusion code: 5. [pmid: 14712597].
Behera D, Balamugesh T. Lung cancer in India. Indian J. Chest Dis. Allied Sci. 2004;46(4):269-281. Exclusion code: 5. [pmid: 15515828].
Cost-effectiveness of whole-body CT screening (Structured abstract). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 4.
Belda-Iniesta C, de Castro Carpeno J, Carrasco JA, et al. New screening method for lung cancer by detecting volatile organic compounds in breath. Clin Transl Oncol. 2007;9(6):364-368. Exclusion code: 5. [pmid: 17594950].
Belialova NS, Belialov FI. Screening of cancer of the most frequent localizations. Klin. Med. (Mosk). 2005;83(10):4-9. Exclusion code: 6. [pmid: 16320836].
Belinsky SA. Gene-promoter hypermethylation as a biomarker in lung cancer. Nature Reviews. Cancer. 2004;4(9):707-717. Exclusion code: 2. [pmid: 15343277].
Bellomi M, Rampinelli C, De Fiori E, Preda L, Veronesi G. Lung cancer screening update. Cancer Imaging. 2009;9 Spec No A:S122-125. Exclusion code: 5. [pmid: 19965303].
Bellomi M, Veronesi G, Rampinelli C, Ferretti S, De Fiori E, Maisonneuve P. Evolution of lung nodules < or =5 mm detected with low-dose CT in asymptomatic smokers. Br. J. Radiol. 2007;80(957):708-712. Exclusion code: 2. [pmid: 17928499].
Bellomi M, Veronesi G, Trifiro G, et al. Computed tomography-guided preoperative radiotracer localization of nonpalpable lung nodules. Ann. Thorac. Surg. 2010;90(6):1759-1764. Exclusion code: 2. [pmid: 21095303].
Ben-Dor I, Waksman R, Hanna NN, et al. Utility of Radiologic Review for Noncardiac Findings on Multislice Computed Tomography in Patients With Severe Aortic Stenosis Evaluated for Transcatheter Aortic Valve Implantation. Am. J. Cardiol. 2010;105(10):1461-1464. Exclusion code: 5. [pmid: 20451695].
Benko I, Horvath OP, Nagy K, et al. Role of surgery for lung cancer in elderly patients. Magy Seb. 2008;61(1):33-37. Exclusion code: 6. [pmid: 18296283].
Bepler G, Goodridge Carney D, Djulbegovic B, Clark RA, Tockman M. A systematic review and lessons learned from early lung cancer detection trials using low-dose computed tomography of the chest. Cancer Control. 2003;10(4):306-314. Exclusion code: 2. [pmid: 12915809].
Berg CD, Aberle DR. Computed tomography screening for lung cancer. JAMA. 2007;298(5):513-514. author reply 515-516. Exclusion code: 2. [pmid: 17666667].
Berg CD, Aberle DR, National Lung Screening Trial Executive C. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):743-744. author reply 746-747. Exclusion code: 2. [pmid: 17310522].
Berger VW, Semanick L. Refining the assessment of the sensitivity and specificity of diagnostic tests, with applications to prostate cancer screening and non-small cell lung cancer staging. Pan American Journal of Public Health. 2005;18(1):64-70. Exclusion code: 4. [pmid: 16105328].
Berlin NI. Overview of the NCI Cooperative Early Lung Cancer Detection Program. Cancer. 2000;89(11 Suppl):2349-2351. Exclusion code: 2. [pmid: 11147610].
Berlin NI. The prospects for the control of cancer through screening-1976-today-the future. Trans. Am. Clin. Climatol. Assoc. 2004;115:221-232. discussion 232. Exclusion code: 5. [pmid: 17060969].
Berlin NI, Buncher CR, Fontana RS, Frost JK, Melamed MR. The National cancer Institute Cooperative Early Lung Cancer Detection Program. Results of the initial screen (prevalence). Early lung cancer detection: Introduction. Am. Rev. Respir. Dis. 1984;130(4):545-549. Exclusion code: 5. [pmid: 6548343].
Bermejo JL, Hemminki K. Familial risk of cancer shortly after diagnosis of the first familial tumor. J. Natl. Cancer Inst. 2005;97(21):1575-1579. Exclusion code: 3. [pmid: 16264177].
Bernardo WM, Jatene FB, Nobre MRC. What is the survival rate for limited resection of lung cancer in stage I?. Rev. Assoc. Med. Bras. 2005;51(3):123-125. Exclusion code: 6. [pmid: 16007288].
Berrington de Gonzalez A, Kim KP, Berg CD. Low-dose lung computed tomography screening before age 55: estimates of the mortality reduction required to outweigh the radiation-induced cancer risk. J. Med. Screen. 2008;15(3):153-158. Exclusion code: 2. [pmid: 18927099].
Berrington de Gonzalez A, Mahesh M, Kim KP, et al. Projected cancer risks from computed tomographic scans performed in the United States in 2007. Arch. Intern. Med. 2009;169(22):2071-2077. Exclusion code: 2. [pmid: 20008689].
Bessho Y, Yamaguchi M, Fujita H, Azuma M. Usefulness of reduced image display size in softcopy reading: evaluation of lung nodules in chest screening. Acad. Radiol. 2009;16(8):940-946. Exclusion code: 7. [pmid: 19446475].
Betticher DC. Docetaxel in neoadjuvant therapy of early-stage non-small cell carcinoma. Onkologie. Suppl 7. 2003;26:33-36. Exclusion code: 6. [pmid: 14716140].
Bianchi F, Hu J, Pelosi G, et al. Lung cancers detected by screening with spiral computed tomography have a malignant phenotype when analyzed by cDNA microarray. Clin. Cancer Res. 2004;10(18 Pt 1):6023-6028. Exclusion code: 4. [pmid: 15447986].
Bianchi F, Nicassio F, Marzi M, et al. A serum circulating miRNA diagnostic test to identify asymptomatic high-risk individuals with early stage lung cancer. EMBO Mol Med. 2011;3(8):495-503. Exclusion code: 4. [pmid: 21744498].
Bianchi F, Nicassio F, Veronesi G, Di Fiore PP. Circulating microRNAs: Next-generation biomarkers for early lung cancer detection. ecancermedicalscience. 2012;6(1). Exclusion code: 4. [pmid: 22518197].
Bilfinger TV. Surgical aspects in the treatment of lung cancer. Curr. Opin. Pulm. Med. 2004;10(4):261-265. Exclusion code: 5. [pmid: 15220749].
Bilfinger TV, Baram D. Sublobar resection in nonsmall cell lung carcinoma. Curr. Opin. Pulm. Med. 2008;14(4):292-296. Exclusion code: 5. [pmid: 18520261].
Billmeier SE, Ayanian JZ, Zaslavsky AM, Nerenz DR, Jaklitsch MT, Rogers SO. Predictors and outcomes of limited resection for early-stage non-small cell lung cancer. J. Natl. Cancer Inst. 2011;103(21):1621-1629. Exclusion code: 3. [pmid: 21960708].
Birdas TJ. Effects of pneumonectomy on survival of patients with stage I lung cancer. Ann. Thorac. Surg. 2005;79(1):384. author reply 384-385. Exclusion code: 5. [pmid: 15620995].
Birim O, Kappetein AP, van Klaveren RJ, Bogers AJJC. Prognostic factors in non-small cell lung cancer surgery. Eur. J. Surg. Oncol. 2006;32(1):12-23. Exclusion code: 5. [pmid: 16297591].
Birring SS, Peake MD. Symptoms and the early diagnosis of lung cancer. Thorax. 2005;60(4):268-269. Exclusion code: 5. [pmid: 15790977].
Bisenkov LN, Shalaev SA, Orzheshkovskii OV, Platunov SK, Efremov FA. One-stage operations on the lungs and other organs in multifocal and metastatic cancer. Khirurgiia (Sofiia). 2005;(4):33-36. Exclusion code: 6. [pmid: 18693530].
Lung cancer screening using tumour markers? A view in consideration of socioeconomic aspects (Brief record). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 5.
Bjelakovic G, Nikolova D, Gluud LL, Simonetti RG, Gluud C. Antioxidant supplements for prevention of mortality in healthy participants and patients with various diseases [Systematic Review]. Cochrane Database of Systematic Reviews. 2012. Exclusion code: 4.
Black C, Bagust A, Boland A, et al. The clinical effectiveness and cost-effectiveness of computed tomography screening for lung cancer: systematic reviews. Health Technology Assessment (Winchester, England). 2006;10(3):iii-iv. ix. x. 1. 90. Exclusion code: 5. [pmid: 16409881].
Black C, de Verteuil R, Walker S, et al. Population screening for lung cancer using computed tomography, is there evidence of clinical effectiveness? A systematic review of the literature. Thorax. 2007;62(2):131-138. Exclusion code: 5. [pmid: 17287305].
Black WC. Unexpected observations on tumor size and survival in stage 1a non-small cell lung cancer [editorial]. Chest. 2000;117(6):1532-1534. Exclusion code: 5. [pmid: 10858376].
Black WC. Overdiagnosis: An underrecognized cause of confusion and harm in cancer screening. J. Natl. Cancer Inst. 2000;92(16):1280-1282. Exclusion code: 2. [pmid: 10944539].
Black WC. Computed tomography screening for lung cancer: review of screening principles and update on current status. Cancer. 2007;110(11):2370-2384. Exclusion code: 5. [pmid: 17941031].
Black WC, Aberle DR, Berg CD. Large field trial for lung cancer screening: putting the wrong cart before the horse?. Radiology. 2007;243(2):314-316. discussion 317-318. Exclusion code: 2. [pmid: 17456862].
Black WC, Baron JA. CT screening for lung cancer: spiraling into confusion?. JAMA. 2007;297(9):995-997. Exclusion code: 5. [pmid: 17341714].
Black WC, Haggstrom DA, Welch HG. All-cause mortality in randomized trials of cancer screening. J. Natl. Cancer Inst. 2002;94(3):167-173. Exclusion code: 5. [pmid: 11830606].
Blanchon T, Brechot JM, Grenier P, Group FtD. Baseline results of the Depiscan study: A French randomized pilot trial of lung cancer screening comparing low dose CT scan (LDCT) and chest X-ray (CXR). Lung Cancer. 2007;58(1):50-58. Exclusion code: 2. [pmid: 17624475].
Blanchon T, Lukasiewicz-Hajage E, Lemarle E, Milleron B, Brechot JM, Flahault A. DEPISCAN - a pilot study to evaluate low dose spiral CT scanning as a screening method for bronchial carcinoma. Rev. Mal. Respir. 2002;19(6):701-705. Exclusion code: 6. [pmid: 12524489].
Blomquist T, Crawford EL, Mullins D, et al. Pattern of antioxidant and DNA repair gene expression in normal airway epithelium associated with lung cancer diagnosis. Cancer Res. 2009;69(22):8629-8635. Exclusion code: 7. [pmid: 19887610].
Bluoss C. Lung metastases secondary to bronchopulmonary cancer. Pneumologia. 2010;59(2):68-72. Exclusion code: 6. [pmid: 20695360].
Boedeker E, Friedel G, Walles T. Sniffer dogs as part of a bimodal bionic research approach to develop a lung cancer screening. Interact Cardiovasc Thorac Surg. 2012;14(5):511-515. Exclusion code: 4. [pmid: 22345057].
Boeri M, Verri C, Conte D, et al. MicroRNA signatures in tissues and plasma predict development and prognosis of computed tomography detected lung cancer. Proc. Natl. Acad. Sci. U. S. A. 2011;108(9):3713-3718. Exclusion code: 2. [pmid: 21300873].
Boffa D, Allen M, Grab J, Gaissert H, Harpole D, Wright C. Data from the Society of Thoracic Surgeons General Thoracic Surgery database: The surgical management of primary lung tumors. J. Thorac. Cardiovasc. Surg. 2008;135:247-254. Exclusion code: 2. [pmid: 18242243].
Boffetta P, Mannetje At, Zaridze D, et al. Occupational X-ray examinations and lung cancer risk. Int. J. Cancer. 2005;115(2):263-267. Exclusion code: 3. [pmid: 15688400].
Boffetta P, Tarone RE, Blot WJ. Survival in women after diagnosis of lung cancer. JAMA. 2007;297(2):153. author reply 153-154. Exclusion code: 2. [pmid: 17213394].
Boice JD J, Monson RR. Breast cancer in women after repeated fluoroscopic examinations of the chest. J. Natl. Cancer Inst. 1977;59(3):823-832. Exclusion code: 2. [pmid: 894747].
Bolca C, Brontos ML, Conti M, Frechette E. Video-assisted thoracoscopic lobectomy--the treatment of choice for stage I NSCLC. Pneumologia. 2010;59(4):201-203. Exclusion code: 6. [pmid: 21365802].
Bondiau PY, Doyen J, Mammar H, et al. Reirradiation of spine and lung tumor with CyberKnife. Cancer Radiother. 2010;14(6-7):438-441. Exclusion code: 6. [pmid: 20724188].
Bonfill X, Puig MT, Bolíbar I, Quintana MJ. Lung cancer in Spain: The current situation. 2008 SESPAS report. El control del cáncer de pulmón en España: Un análisis de la situación actual. Informe SESPAS 2008. 2008;22(SUPPL. 1):169-178. Exclusion code: 5. [pmid: 18405567].
Bonnet F, Donay JL, Fieux F, Marie O, de Kerviler E, Jacob L. Postoperative nocardiosis caused by Nocardia otitidiscaviarum: pitfalls and delayed diagnosis. Ann. Fr. Anesth. Reanim. 2007;26(7-8):680-684. Exclusion code: 6. [pmid: 17572044].
Bonnette P. Surgery for stage 1[NON-BREAKING SPACE]lung cancer. Cancer Radiother. 2011;15(6-7):518-521. Exclusion code: 6. [pmid: 21802335].
Boughton B. Large screening trial launched by NCI. Lancet Oncol. 2002;3(11):647. Exclusion code: 7. [pmid: 12424054].
Boyd JA, Hubbs JL, Kim DW, Hollis D, Marks LB, Kelsey CR. Timing of local and distant failure in resected lung cancer: implications for reported rates of local failure. J Thorac Oncol. 2010;5(2):211-214. Exclusion code: 3. [pmid: 19901853].
Boyle P. Current situation of screening for cancer. Ann. Oncol. Suppl 4. 2002;13:189-198. Exclusion code: 2. [pmid: 12401689].
Brambilla C, Fievet F, Jeanmart M, et al. Early detection of lung cancer: role of biomarkers. European Respiratory Journal - Supplement. 2003;39:36s-44s. Exclusion code: 5. [pmid: 12572700].
Brant-Zawadzki MN. Screening CT: rationale. Radiographics. 2002;22(6):1532-1536. discussion 1536-1539. Exclusion code: 5. [pmid: 12432125].
Brant-Zawadzki MN. The role of computed tomography in screening for cancer. Eur. Radiol. Suppl 4. 2005;15:D52-54. Exclusion code: 5. [pmid: 16479647].
Brawner EJ, Patrick Nana-Sinkam S, Jett JR. Lung cancer screening in 2008: A review and update. Respiratory Medicine CME. 2008;1(1):2-9. [PMID:. Exclusion code: 5.
Brechot JM, Blanchon T, Lemarie E, et al. Preliminary results of a French randomised feasibility trial of lung cancer screening with multislice-spiral CT scan (MSCT) vs chest x-ray (CXR): Depiscan [Abstract]. European Respiratory Journa. 2005;26. Abstract No. 4434. Exclusion code: 5.
Bremnes RM, Hirsch FR. Lung cancer screening--what now?. Tidsskr. Nor. Laegeforen. 2001;121(13):1600-1604. Exclusion code: 6. [pmid: 11446046].
Bremnes RM, Sirera R, Camps C. Circulating tumour-derived DNA and RNA markers in blood: a tool for early detection, diagnostics, and follow-up?. Lung Cancer. 2005;49(1):1-12. Exclusion code: 4. [pmid: 15949585].
Brennan P, Hainaut P, Boffetta P. Genetics of lung-cancer susceptibility. The Lancet Oncology. 2011;12(4):399-408. Exclusion code: 5. [pmid: 20951091].
Brenner D, Dollc R, Goodheadd D, et al. Cancer risks attributable to low doses of ionizing radiation: Assessing what we really know. Proc Natl Acad Sci USA. 2003;100(24):1363-1366. Exclusion code: 2. [pmid: 14610281].
Brenner DJ. Radiation risks potentially associated with low-dose CT screening of adult smokers for lung cancer. Radiol. 2004;231(2):440-445. Exclusion code: 2. [pmid: 15128988].
Brenner DJ, Hall EJ. Computed tomography - An increasing source of radiation exposure. N. Engl. J. Med. 2007;357(22):2277-2284. Exclusion code: 2. [pmid: 18046031].
Brice J. Low-dose CT. The promise and the paradox of lung cancer screening. Diagn. Imaging. 2000;22(5):44-53. Exclusion code: 5. [pmid: 10947614].
Brodersen J, Thorsen H, Kreiner S. Consequences of screening in lung cancer: development and dimensionality of a questionnaire. Value in Health. 2010;13(5):601-612. Exclusion code: 5. [pmid: 20345552].
Brooks JD. Translational genomics: The challenge of developing cancer biomarkers. Genome Res. 2012;22(2):183-187. Exclusion code: 4. [pmid: 22301132].
Brouchet L, Mazieres J, Bauvin E, et al. Surgical management and outcomes of lung cancer in women - results from the Epithor database. Rev. Mal. Respir. 2007;24(7):877-882. Exclusion code: 6. [pmid: 17925670].
Brower V. Biomarker studies abound for early detection of lung cancer. J. Natl. Cancer Inst. 2009;101(1):11-13. Exclusion code: 2. [pmid: 19116384].
Bu L, Yun L, Fan Y, et al. Completely video-assisted thoracoscopic lobectomy versus open lobectomy for non-small cell lung cancer greater than 5 cm: a retrospective study. Chin. Med. J. (Engl). 2012;125(3):434-439. Exclusion code: 3. [pmid: 22490398].
Buckler AJ, Mulshine JL, Gottlieb R, Zhao B, Mozley PD, Schwartz L. The use of volumetric CT as an imaging biomarker in lung cancer. Acad. Radiol. 2010;17(1):100-106. Exclusion code: 2. [pmid: 19969253].
Budoff MJ, Gopal A. Incidental findings on cardiac computed tomography. Should we look?. Journal of Cardiovascular Computed Tomography. 2007;1(2):97-105. Exclusion code: 5. [pmid: 19083887].
Buls N, de Mey J, Covens P, Stadnik T. Health screening with CT: prospective assessment of radiation dose and associated detriment. Jbr-Btr. 2005;88(1):12-16. Exclusion code: 2. [pmid: 15792162].
Bunge EM, van den Bergh KAM, Essink-Bot ML, van Klaveren RJ, de Koning HJ. High affective risk perception is associated with more lung cancer-specific distress in CT screening for lung cancer. Lung Cancer. 2008;62(3):385-390. Exclusion code: 2. [pmid: 18468717].
Burns DM. Primary prevention, smoking, and smoking cessation: implications for future trends in lung cancer prevention. Cancer. 2000;89(11 Suppl):2506-2509. Exclusion code: 2. [pmid: 11147637].
Buyx AM, Strech D, Schmidt H. Ethical issues raised by direct-to-consumer personal genome analysis and whole body scans: Discussion and contextualisation of a report by the Nuffield Council on Bioethics. Zur Ethik einer Vorsorge durch (direct-to-consumer) individuelle Genanalysen und Ganzkörper-MRTs. Erläuterung und Diskussion der Empfehlungen des Nuffield Council on Bioethics. 2012;106(1):29-39. Exclusion code: 5. [pmid: 22325105].
Byers T, Wolf HJ, Franklin WA, et al. Sputum cytologic atypia predicts incident lung cancer: defining latency and histologic specificity. Cancer Epidemiol. Biomarkers Prev. 2008;17(1):158-162. Exclusion code: 4. [pmid: 18199720].
Byrne MM, Koru-Sengul T, Zhao W, Weissfeld JL, Roberts MS. Healthcare use after screening for lung cancer. Cancer. 2010;116(20):4793-4799. Exclusion code: 2. [pmid: 20597136].
Cagirici U, Cakan A, Samancilar O, Veral A, Ozhan M. Surgical results of large cell neuroendocrine carcinoma of the lung. Tuberk. 2006;54(1):30-33. Exclusion code: 6. [pmid: 16615015].
Cagirici U, Turhan K, Goksel T, Posacioglu H, Veral A, Bilkay O. Results of surgical treatment for lung cancer in advanced age. Tuberk. 2003;51(3):253-257. Exclusion code: 6. [pmid: 15143402].
Cagnon CH, Cody DD, McNitt-Gray MF, Seibert JA, Judy PF, Aberle DR. Description and implementation of a quality control program in an imaging-based clinical trial. Acad. Radiol. 2006;13(11):1431-1441. Exclusion code: 2. [pmid: 17111584].
Cajoto IV, Prim JMG, Barcala FJG, et al. Reason for a medical visit in the diagnosis of lung cancer. A review of 481 cases. Motivo de consulta en el diagnóstico de cáncer de pulmón. Revisión de 481 casos. 2009;209(2):67-72. Exclusion code: 5. [pmid: 19798842].
Calabro E, Randi G, La Vecchia C, et al. Lung function predicts lung cancer risk in smokers: a tool for targeting screening programmes. Eur. Respir. J. 2010;35(1):146-151. Exclusion code: 2. [pmid: 19679603].
Callol L, Roig F, Cuevas A, et al. Low-dose CT: a useful and accessible tool for the early diagnosis of lung cancer in selected populations. Lung Cancer. 2007;56(2):217-221. Exclusion code: 10. [pmid: 17316889].
Calvo Medina V, Padilla Alarcon J, Paris Romeu F, Blasco Armengod E, Pastor Guillem J, Garcia Zarza A. Postoperative survival in stage II non-small-cell bronchogenic carcinoma. Arch. Bronconeumol. 2001;37(1):19-26. Exclusion code: 6. [pmid: 11181226].
Canadian Task Force on Preventive Health Care. Hormone Replacement Therapy for the Primary Prevention of Chronic Diseases. 2004. http://www.canadiantaskforce.ca/recommendations/2003_01_eng.html. Exclusion code: 2.
Cardillo G, Regal M, Sera F, et al. Videothoracoscopic management of the solitary pulmonary nodule: A single-institution study on 429 cases. Ann. Thorac. Surg. 2003;75(5):1607-1611. Exclusion code: 2. [pmid: 12735587].
Cardinale L, Cortese G, Borasio P, et al. Low dose CT in early lung cancer diagnosis: Prevalence data. Radiol. Med. (Torino). 2005;110(5-6):532-543. Exclusion code: 4. [pmid: 16437039].
Cardinale L, Giaj Levra M, Novello S, et al. Low-dose spiral computer tomography screening for lung cancer. Minerva Pneumologica. 2007;46(3):235-242. [PMID:. Exclusion code: 5.
Carel RS. Periodical multiphasic screening and lung cancer prevention. Methods Inf. Med. 1998;37(2):182-187. Exclusion code: 4. [pmid: 9656662].
Caro JJ, Klittich WS, Strauss G. Could chest X-ray screening for lung cancer be cost-effective?. Cancer. 2000;89(11 Suppl):2502-2505. Exclusion code: 7. [pmid: 11147636].
Carozzi FM, Bisanzi S, Falini P, et al. Molecular profile in body fluids in subjects enrolled in a randomised trial for lung cancer screening: Perspectives of integrated strategies for early diagnosis. Lung Cancer. 2010;68(2):216-221. Exclusion code: 2. [pmid: 19646775].
Carpagnano GE, Foschino-Barbaro MP, Mule G, et al. 3p microsatellite alterations in exhaled breath condensate from patients with non-small cell lung cancer. Am. J. Respir. Crit. Care Med. 2005;172(6):738-744. Exclusion code: 3. [pmid: 15947287].
Carr SR, Schuchert MJ, Pennathur A, et al. Impact of tumor size on outcomes after anatomic lung resection for stage 1A non-small cell lung cancer based on the current staging system. J. Thorac. Cardiovasc. Surg. 2012;143(2):390-397. Exclusion code: 7. [pmid: 22169444].
Carre PC, Zalcman G. Adjuvant chemotherapy for stage IB non small cell lung cancer: the standard of care?. Rev. Mal. Respir. 2006;23(4 Pt 1):295-297. Exclusion code: 6. [pmid: 17127903].
Carter D, Vazquez M, Flieder DB, et al. Comparison of pathologic findings of baseline and annual repeat cancers diagnosed on CT screening. Lung Cancer. 2007;56(2):193-199. Exclusion code: 4. [pmid: 17239983].
Cassidy A, Duffy SW, Myles JP, Liloglou T, Field JK. Lung cancer risk prediction: a tool for early detection. Int. J. Cancer. 2007;120(1):1-6. Exclusion code: 5. [pmid: 17058200].
Cassidy A, Myles JP, van Tongeren M, et al. The LLP risk model: an individual risk prediction model for lung cancer. Br. J. Cancer. 2008;98(2):270-276. Exclusion code: 5. [pmid: 18087271].
Castagnaro A, Marangio E, Verduri A, et al. Microsatellite analysis of induced sputum DNA in patients with lung cancer in heavy smokers and in healthy subjects. Exp. Lung Res. 2007;33(6):289-301. Exclusion code: 3. [pmid: 17694439].
Castelao JE, Bart RD 3rd, DiPerna CA, Sievers EM, Bremner RM. Lung cancer and cyclooxygenase-2. Ann. Thorac. Surg. 2003;76(4):1327-1335. Exclusion code: 4. [pmid: 14530048].
Castells X, Sala M, Salas D, Ascunce N, Zubizarreta R, Casamitjana M. Reflections on practices for early cancer diagnosis in Spain. Reflexiones sobre las prácticas de diagnóstico precoz del cáncer en España. 2009;23(3):244-249. Exclusion code: 5. [pmid: 19286278].
Castleberry AW, Smith D, Anderson C, Rotter AJ, Grannis FW Jr. Cost of a 5-year lung cancer survivor: symptomatic tumour identification vs proactive computed tomography screening. Br. J. Cancer. 2009;101(6):882-896. Exclusion code: 7. [pmid: 19690541].
Cost of a 5-year lung cancer survivor: symptomatic tumour identification vs proactive computed tomography screening (Brief record). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 5.
Catalano O, Tamburrini O, Siani A. Ethic, deontologic, social, and economic reflections on screening with helical CT. Part II: specific aspects. Radiol. Med. (Torino). 2004;108(4):310-319. Exclusion code: 5. [pmid: 15525885].
Catarino PA, Goldstraw P. The future in diagnosis and staging of lung cancer: surgical techniques. Respiration. 2006;73(6):717-732. Exclusion code: 5. [pmid: 17119351].
Cattaneo SM, Park BJ, Wilton AS, et al. Use of video-assisted thoracic surgery for lobectomy in the elderly results in fewer complications. Ann. Thorac. Surg. 2008;85(1):231-235. discussion 235-236. Exclusion code: 10. [pmid: 18154816].
Centers for Disease Control and Prevention. Cigarette smoking among adults and trends in smoking cessation - United States, 2008. MMWR. 2009;58(44):1227-1232. Exclusion code: 2. [pmid: 19910909].
Centers for Disease Control and Prevention. Vital signs: current cigarette smoking among adults aged ≥18 years--United States, 2005-2010. MMWR. 2011;60(35):1207-1212. Exclusion code: 2. [pmid: 21900875].
Centre for Reviews and Dissemination. Lung cancer screening: an update for the U.S. Preventive Services Task Force (Provisional abstract). Database of Abstracts of Reviews of Effects. 2011. Exclusion code: 2.
Centre for Reviews and Dissemination. Systematic review of baseline low-dose CT lung cancer screening (Structured abstract). Database of Abstracts of Reviews of Effects. 2011. Exclusion code: 2.
Centre for Reviews and Dissemination. A systematic review and lessons learned from early lung cancer detection trials using low-dose computed tomography of the chest (Structured abstract). Database of Abstracts of Reviews of Effects. 2011. Exclusion code: 2.
Centre for Reviews and Dissemination. Screening for lung cancer with low-dose computed tomography: a systematic review and meta-analysis of the baseline findings of randomized controlled trials (Provisional abstract). Database of Abstracts of Reviews of Effects. 2011. Exclusion code: 2.
Centre for Reviews and Dissemination. Prevalence of incidental findings in computed tomographic screening of the chest: a systematic review (Structured abstract). Database of Abstracts of Reviews of Effects. 2011. Exclusion code: 2.
Cerfolio RJ, Bryant AS. Survival and outcomes of pulmonary resection for non-small cell lung cancer in the elderly: a nested case-control study. Ann. Thorac. Surg. 2006;82(2):424-429. discussion 429-430. Exclusion code: 3. [pmid: 16863740].
Cerfolio RJ, Bryant AS. Survival of patients with true pathologic stage I non-small cell lung cancer. Ann. Thorac. Surg. 2009;88(3):917-922. discussion 922-913. Exclusion code: 10. [pmid: 19699920].
Cerfolio RJ, Bryant AS, Scott E, et al. Women with pathologic stage I, II, and III non-small cell lung cancer have better survival than men. Chest. 2006;130(6):1796-1802. Exclusion code: 3. [pmid: 17166999].
Chabner BA. Smoke, then fire: lung cancer screening studies under further scrutiny. Oncologist. 2008;13(4):348-349. Exclusion code: 2. [pmid: 18448547].
Chabowski M, Orlowski TM, Rabczenko D. Analysis of prognostic factors and efficacy of surgical treatment for non-small cell lung cancer: department of surgery NTLDRI (1998-1999). Pneumonol. Alergol. Pol. 2008;76(1):1-10. Exclusion code: 6. [pmid: 18283649].
Chambers A, Routledge T, Pilling J, Scarci M. In elderly patients with lung cancer is resection justified in terms of morbidity, mortality and residual quality of life?. Interact Cardiovasc Thorac Surg. 2010;10(6):1015-1021. Exclusion code: 5. [pmid: 20354037].
Chamogeorgakis T, Ieromonachos C, Georgiannakis E, Mallios D. Does lobectomy achieve better survival and recurrence rates than limited pulmonary resection for T1N0M0 non-small cell lung cancer patients?. Interact Cardiovasc Thorac Surg. 2009;8(3):364-372. Exclusion code: 5. [pmid: 18641014].
Champeaux-Orange E, Wachter T, Bouscayrol H, Barillot I. Stereotactic radiotherapy for stage I and II lung cancer: a study of 33 patients. Cancer Radiother. 2011;15(3):192-196. Exclusion code: 6. [pmid: 21330178].
Champion VL, Rawl SM, Menon U. Population-based cancer screening. Oncol. Nurs. Forum. 2002;29(5):853-861. Exclusion code: 5. [pmid: 12058160].
Chan CK, Wells CK, McFarlane MJ, Feinstein AR. More lung cancer but better survival. Implications of secular trends in ‘necropsy suprise’ rates. Chest. 1989;96(2):291-296. Exclusion code: 2. [pmid: 2787730].
Chan HP, Hadjiiski L, Zhou C, Sahiner B. Computer-Aided Diagnosis of Lung Cancer and Pulmonary Embolism in Computed Tomography-A Review. Acad. Radiol. 2008;15(5):535-555. Exclusion code: 4. [pmid: 18423310].
Chan HP, Lewis C, Thomas PS. Exhaled breath analysis: novel approach for early detection of lung cancer. Lung Cancer. 2009;63(2):164-168. Exclusion code: 2. [pmid: 18599152].
Chandy D, Maguire G, Aronow WS. Lung cancer: the importance of early intervention. Compr. Ther. 2009;35(1):18-23. Exclusion code: 5. [pmid: 19351101].
Chang ET, Shema SJ, Wakelee HA, Clarke CA, Gomez SL. Uncovering disparities in survival after non-small-cell lung cancer among Asian/Pacific Islander ethnic populations in California. Cancer Epidemiol. Biomarkers Prev. 2009;18(8):2248-2255. Exclusion code: 7. [pmid: 19622719].
Chang JW, Asamura H, Kawachi R, Watanabe Si. Gender difference in survival of resected non-small cell lung cancer: histology-related phenomenon?. J. Thorac. Cardiovasc. Surg. 2009;137(4):807-812. Exclusion code: 3. [pmid: 19327500].
Chang-Ming A, Bin Z, Zhen-Gang X, Ping-Zhang T. Results of stage I and II tongue squamous cell carcinomas treated with different modalities. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2008;30(4):302-305. Exclusion code: 6. [pmid: 18788638].
Chanin TD, Merrick DT, Franklin WA, Hirsch FR. Recent developments in biomarkers for the early detection of lung cancer: perspectives based on publications 2003 to present. Curr. Opin. Pulm. Med. 2004;10(4):242-247. Exclusion code: 4. [pmid: 15220746].
Chansky K, Sculier JP, Crowley JJ, et al. The International Association for the Study of Lung Cancer Staging Project: prognostic factors and pathologic TNM stage in surgically managed non-small cell lung cancer. J Thorac Oncol. 2009;4(7):792-801. Exclusion code: 3. [pmid: 19458556].
Chapman BE, Yankelevitz DF, Henschke CI, Gur D. Lung cancer screening: simulations of effects of imperfect detection on temporal dynamics. Radiology. 2005;234(2):582-590. Exclusion code: 2. [pmid: 15671008].
Chapman CJ, Murray A, McElveen JE, et al. Autoantibodies in lung cancer: possibilities for early detection and subsequent cure. [Erratum appears in Thorax. 2008 Apr;63(4):385]. Thorax. 2008;63(3):228-233. Exclusion code: 7. [pmid: 17932110].
Chek K, Tribuna J, Nashelsky J. Clinical inquiries. Is yearly chest x-ray screening helpful in reducing mortality for smokers?. J. Fam. Pract. 2005;54(9):815-816. Exclusion code: 5. [pmid: 16144598].
Chen C, Chen P, Zhang CC, Li N, Jin ZL, Li K. Clinical characteristics and prognosis of large cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2010;32(12):932-934. Exclusion code: 6. [pmid: 21223803].
Chen J, Shen-Tu Y. Research progress of lobe-specific lymphadenectomy on early stage lung cancer operation. Zhongguo Fei Ai Za Zhi. 2011;14(1):63-68. Exclusion code: 6. [pmid: 21219835].
Chen PC, Zhou XM, Chen QX, Liu JS, Yan FL, Jiang YH. Sleeve resection for lung cancer: a report of 82 cases. Ai Zheng. 2008;27(5):510-515. Exclusion code: 6. [pmid: 18479601].
Chen X, Gorlov IP, Merriman KW, et al. Association of smoking with tumor size at diagnosis in non-small cell lung cancer. Lung Cancer. 2011;74(3):378-383. Exclusion code: 7. [pmid: 21645942].
Chhajed PN, Shibuya K, Hoshino H, et al. A comparison of video and autofluorescence bronchoscopy in patients at high risk of lung cancer. Eur. Respir. J. 2005;25(6):951-955. Exclusion code: 4. [pmid: 15929947].
Chien CC, Zhang G, Hwu Y, et al. Detecting small lung tumors in mouse models by refractive-index microradiology. Analytical and Bioanalytical Chemistry. 2011;401(3):827-835. Exclusion code: 3. [pmid: 21626185].
Chien CR, Chen THH. Mean sojourn time and effectiveness of mortality reduction for lung cancer screening with computed tomography. Int. J. Cancer. 2008;122(11):2594-2599. Exclusion code: 2. [pmid: 18302157].
Chien CR, Lai MS, Chen THH. Estimation of mean sojourn time for lung cancer by chest X-ray screening with a Bayesian approach. Lung Cancer. 2008;62(2):215-220. Exclusion code: 7. [pmid: 18400331].
Chiles C. Lung cancer screening: achieving a reduction in mortality. Semin. Roentgenol. 2011;46(3):230-240. Exclusion code: 2. [pmid: 21726707].
Chirieac LR, Flieder DB. High-resolution computed tomography screening for lung cancer: unexpected findings and new controversies regarding adenocarcinogenesis. Arch. Pathol. Lab. Med. 2010;134(1):41-48. Exclusion code: 2. [pmid: 20073604].
Screening for lung cancer with CT: a preliminary cost-effectiveness analysis (Structured abstract). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 4.
Chiu CH, Chern MS, Wu MH, et al. Usefulness of low-dose spiral CT of the chest in regular follow-up of postoperative non-small cell lung cancer patients: Preliminary report. J. Thorac. Cardiovasc. Surg. 2003;125(6):1300-1305. Exclusion code: 3. [pmid: 12830048].
Chkhikvadze VD, Sokolova VS, Lisitskii AN, Klimov AB, Gass MV, Rukavichnikov VM. Results of surgical treatment of lung cancer in patients over 70 years old. Khirurgiia (Sofiia). 2003;(5):15-16. Exclusion code: 6. [pmid: 15641543].
Cho S, Lee EB. A follow-up of integrated positron emission tomography/computed tomography after curative resection of non-small-cell lung cancer in asymptomatic patients. J. Thorac. Cardiovasc. Surg. 2010;139(6):1447-1451. Exclusion code: 3. [pmid: 20005529].
Choi JI, Choi HJ, Jung DC, et al. Diagnostic value of early-phase-enhanced computed tomography for the differentiation of pulmonary metastases from hepatocellular carcinoma and primary lung cancer. Acta Radiol. 2009;50(9):1005-1010. Exclusion code: 3. [pmid: 19863410].
Choi YS, Shim YM, Kim K, Kim J. Pattern of recurrence after curative resection of local (stage I and II) non-small cell lung cancer: difference according to the histologic type. J. Korean Med. Sci. 2004;19(5):674-676. Exclusion code: 3. [pmid: 15483342].
Chong S, Lee KS, Chung MJ, et al. Lung cancer screening with low-dose helical CT in Korea: experiences at the Samsung Medical Center. J. Korean Med. Sci. 2005;20(3):402-408. Exclusion code: 3. [pmid: 15953860].
Chorostowska-Wynimko J, Szpechcinski A. The impact of genetic markers on the diagnosis of lung cancer: a current perspective. J Thorac Oncol. 2007;2(11):1044-1051. Exclusion code: 2. [pmid: 17975498].
Christie B. Screening trial of blood test for lung cancer is set to start in Scotland. BMJ. 2012;344:e2312. Exclusion code: 4. [pmid: 22451495].
Chua S, Gnanasegaran G, Cook GJR. Miscellaneous cancers (lung, thyroid, renal cancer, myeloma, and neuroendocrine tumors): role of SPECT and PET in imaging bone metastases. Seminars in Nuclear Medicine. 2009;39(6):416-430. Exclusion code: 5. [pmid: 19801221].
Chung SY, Lee JH, Kim TH, et al. F-18 FDG PET scan findings in patients with Loeffler's syndrome. Clin. Nucl. Med. 2009;34(9):570-575. Exclusion code: 3. [pmid: 19692816].
Church TR, National Lung Screening Trial Executive C. Chest radiography as the comparison for spiral CT in the National Lung Screening Trial. Acad. Radiol. 2003;10(6):713-715. Exclusion code: 2. [pmid: 12809426].
Cicenas S, Kurtinaitis J, Smailyte G. Outcome and treatment strategy in female lung cancer: a single institution experience. Adv Med Sci. 2010;55(2):273-280. Exclusion code: 10. [pmid: 21097446].
Cicenas S, Naujokaitis P, Jackevicius A, Piscikas D, Krasauskas A, Tikuisis R. Bronchoplastic operations for lung cancer. Medicina (Kaunas). Suppl 2. 2002;38:23-25. Exclusion code: 6. [pmid: 12560613].
Cilli A, Ozkaynak C, Onur R, et al. Lung cancer detection with low-dose spiral computed tomography in chronic obstructive pulmonary disease patients. Acta Radiol. 2007;48(4):405-411. Exclusion code: 2. [pmid: 17453521].
Cirincione R, Lintas C, Conte D, et al. Methylation profile in tumor and sputum samples of lung cancer patients detected by spiral computed tomography: a nested case-control study. Int. J. Cancer. 2006;118(5):1248-1253. Exclusion code: 2. [pmid: 16152615].
Clark JR, Rumcheva P, Veness MJ. Analysis and Comparison of the 7th Edition American Joint Committee on Cancer (AJCC) Nodal Staging System for Metastatic Cutaneous Squamous Cell Carcinoma of the Head and Neck. Ann Surg Oncol. 2012. Jul. 18. [Epub ahead of print], [. Exclusion code: 2. [pmid: 22805870].
Clark KW, Gierada DS, Marquez G, et al. Collecting 48,000 CT exams for the lung screening study of the National Lung Screening Trial. J. Digit. Imaging. 2009;22(6):667-680. Exclusion code: 2. [pmid: 18777192].
Clark KW, Gierada DS, Moore SM, et al. Creation of a CT Image Library for the Lung Screening Study of the National Lung Screening Trial. J. Digit. Imaging. 2007;20(1):23-31. Exclusion code: 2. [pmid: 16783598].
Clark MM, Cox LS, Jett JR, et al. Effectiveness of smoking cessation self-help materials in a lung cancer screening population. Lung Cancer. 2004;44(1):13-21. Exclusion code: 4. [pmid: 15013579].
Clark MM, Jett JR. Change in smoking status after low-dose spiral chest CT screening for lung cancer: opportunity for smoking intervention. Thorax. 2009;64(5):371-372. Exclusion code: 5. [pmid: 19401483].
Clarke LP, Croft BY, Staab E, Baker H, Sullivan DC. National Cancer Institute initiative: Lung image database resource for imaging research. Acad. Radiol. 2001;8(5):447-450. Exclusion code: 5. [pmid: 11345275].
Clement-Duchene C, Guillemin F, Paris C, Regent D, Martinet Y. Protocols for lung cancer screening: Limitations, and consequences. Rev. Mal. Respir. 2010;27(4):314-328. Exclusion code: 6. [pmid: 20403542].
Clin B, Morlais F, Guittet L, et al. Performance of chest radiograph and CT scan for lung cancer screening in asbestos-exposed workers. Occup. Environ. Med. 2009;66(8):529-534. Exclusion code: 2. [pmid: 19273475].
Coche E. Screening for lung cancer with low-dose CT. Jbr-Btr. 2008;91(1):1-5. Exclusion code: 5. [pmid: 18447122].
Coche E. What's new in lung cancer screening?. Où en est le dépistage du cancer broncho-pulmonaire ?. 2008;64(4):183-186. Exclusion code: 5. [pmid: 19019286].
Cody DD, Kim HJ, Cagnon CH, et al. Normalized CT dose index of the CT scanners used in the National Lung Screening Trial. AJR. Am. J. Roentgenol. 2010;194(6):1539-1546. Exclusion code: 2. [pmid: 20489094].
Colby TV, Tazelaar HD, Travis WD, Bergstralh EJ, Jett JR. Pathologic review of the Mayo Lung Project cancers [corrected]. Is there a case for misdiagnosis or overdiagnosis of lung carcinoma in the screened group?. [Erratum appears in Cancer. 2003 Mar 1;97(5):1367]. Cancer. 2002;95(11):2361-2365. Exclusion code: 2. [pmid: 12436443].
Collins LG, Wynn DT, Barash JH. The future of cancer screening. Prim. Care. 2009;36(3):623-639. Exclusion code: 5. [pmid: 19616158].
Conrad DH, Goyette J, Thomas PS. Proteomics as a method for early detection of cancer: a review of proteomics, exhaled breath condensate, and lung cancer screening. J. Gen. Intern. Med. Suppl 1. 2008;23:78-84. Exclusion code: 4. [pmid: 18095050].
Conti B, Aquilini F, Pistelli F, et al. Lung function in a group of smokers or ex smokers enrolled in a randomized controlled trial (RCT) with low-dose computed tomography (CT) for lung cancer screening (ITALUNG-CT study) [Abstract]. Paper presented at: European Respiratory Society Annual Congress. Barcelona, Spain. September2010. Exclusion code:5.
Cooke DT, Nguyen DV, Yang Y, Chen SL, Yu C, Calhoun RF. Survival comparison of adenosquamous, squamous cell, and adenocarcinoma of the lung after lobectomy. Ann. Thorac. Surg. 2010;90(3):943-948. Exclusion code: 3. [pmid: 20732522].
Corradi M, Poli D, Goldoni M. Molecular diagnosis of lung cancer. Diagnosi molecolare di tumore del polmone. 2008;30(3 SUPPL.):115-116. Exclusion code: 5. [pmid: 19288801].
Coulibaly B, de Biasi C, Gisserot O, de Jaureguiberry JP, Patte JH. Testicular carcinoma and sarcoid-like necrotizing granulomatosis. Ann. Pathol. 2009;29(3):238-240. Exclusion code: 6. [pmid: 19619833].
Coultas DB, Samet JM. Occupational lung cancer. Clin. Chest Med. 1992;13(2):341-354. Exclusion code: 2. [pmid: 1511558].
Crestanello JA, Allen MS, Jett JR, et al. Thoracic surgical operations in patients enrolled in a computed tomographic screening trial. J. Thorac. Cardiovasc. Surg. 2004;128(2):254-259. Exclusion code: 2. [pmid: 15282462].
Crino L, Weder W, van Meerbeeck J, Felip E, Group EGW. Early stage and locally advanced (non-metastatic) non-small-cell lung cancer: ESMO Clinical Practice Guidelines for diagnosis, treatment and follow-up. Ann. Oncol. Suppl 5. 2010;21:v103-115. Exclusion code: 4. [pmid: 20555058].
Criqui M, McClelland R, McDermott M, et al. The ankle-brachial index and incident cardiovascular events in the MESA (Multi-ethnic Study of Atherosclerosis. JACC. 2010;56(18):1506-1512. Exclusion code: 7. [pmid: 20951328].
Cronin KA, Gail MH, Zou Z, Bach PB, Virtamo J, Albanes D. Validation of a model of lung cancer risk prediction among smokers. J. Natl. Cancer Inst. 2006;98(9):637-640. Exclusion code: 5. [pmid: 16670389].
Cuffe S, Moua T, Summerfield R, Roberts H, Jett J, Shepherd FA. Characteristics and outcomes of small cell lung cancer patients diagnosed during two lung cancer computed tomographic screening programs in heavy smokers. J Thorac Oncol. 2011;6(4):818-822. Exclusion code: 2. [pmid: 21623258].
Cullen J, Schwartz MD, Lawrence WF, Selby JV, Mandelblatt JS. Short-term impact of cancer prevention and screening activities on quality of life. J. Clin. Oncol. 2004;22(5):943-952. Exclusion code: 3. [pmid: 14990651].
Dab W. Fundamentals of «screenology»?. Éléments de «dépistologie». 2007;23(6-7):640-643. Exclusion code: 6. [pmid: 17631840].
Dacic S. Pulmonary preneoplasia. Arch. Pathol. Lab. Med. 2008;132(7):1073-1078. Exclusion code: 5. [pmid: 18605763].
Dai W, Yu C, Sun Ye. Prognosis of non-small cell lung cancer patients with microscopic residual disease at bronchial stump after lung resection. Chung Hua I Hsueh Tsa Chih. 2002;82(15):1022-1024. Exclusion code: 6. [pmid: 12194790].
Dai Y, Long H, Lin P, et al. Impact of the number of resected and involved lymph nodes on the outcome in patients with stage II non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2010;32(6):436-440. Exclusion code: 6. [pmid: 20819485].
Dales LG, Friedman GD, Collen MF. Evaluating periodic multiphasic health checkups: a controlled trial. J Chron Dis. 1979;32(5):385-404. Exclusion code: 5. [pmid: 109452].
Dalrymple-Hay MJ, Drury NE. Screening for lung cancer. J. R. Soc. Med. 2001;94(1):2-5. Exclusion code: 5. [pmid: 11220063].
D'Amico TA. Long-term outcomes of thoracoscopic lobectomy. Thorac Surg Clin. 2008;18(3):259-262. Exclusion code: 5. [pmid: 18831500].
D'Amico TA. Operative techniques in early-stage lung cancer. Journal of the National Comprehensive Cancer Network. 2010;8(7):807-813. Exclusion code: 5. [pmid: 20679539].
Dammas S, Patz EF Jr., Goodman PC. Identification of small lung nodules at autopsy: implications for lung cancer screening and overdiagnosis bias. Lung Cancer. 2001;33(1):11-16. Exclusion code: 5. [pmid: 11429191].
D'Andrea N, Sanguinetti CM. Lung cancer screening with low-dose CT: Its effectiveness in early diagnosis and in mortality reduction. Multidisciplinary Respiratory Medicine. 2009;4(5):334-343. Exclusion code: 5.
Darling GE, Allen MS, Decker PA, et al. Randomized trial of mediastinal lymph node sampling versus complete lymphadenectomy during pulmonary resection in the patient with N0 or N1 (less than hilar) non-small cell carcinoma: results of the American College of Surgery Oncology Group Z0030 Trial. J. Thorac. Cardiovasc. Surg. 2011;141(3):662-670. Exclusion code: 7. [pmid: 21335122].
Das M, Muhlenbruch G, Mahnken AH, et al. Asbestos Surveillance Program Aachen (ASPA): initial results from baseline screening for lung cancer in asbestos-exposed high-risk individuals using low-dose multidetector-row CT. Eur. Radiol. 2007;17(5):1193-1199. Exclusion code: 2. [pmid: 17047960].
Das P, Ng AK, Earle CC, Mauch PM, Kuntz KM. Computed tomography screening for lung cancer in Hodgkin's lymphoma survivors: decision analysis and cost-effectiveness analysis. Ann. Oncol. 2006;17(5):785-793. Exclusion code: 3. [pmid: 16500905].
Date H, Andou A, Shimizu N. The value of limited resection for ‘clinical’ stage I peripheral non-small cell lung cancer in poor-risk patients: Comparison of limited resection and lobectomy by a computer-assisted matched study. Tumori. 1994;80(6):422-426. Exclusion code: 8. [pmid: 7900230].
Davila D, Williams D. The etiology of lung cancer. Mayo Clin. Proc. 1993;68(2):170-182. Exclusion code: 2. [pmid: 8423698].
de Fraipont F, Moro-Sibilot D, Michelland S, Brambilla E, Brambilla C, Favrot MC. Promoter methylation of genes in bronchial lavages: a marker for early diagnosis of primary and relapsing non-small cell lung cancer?. Lung Cancer. 2005;50(2):199-209. Exclusion code: 4. [pmid: 16043258].
De Gonzalez AB. Computed tomography screening: Safe and effective?. J. Med. Screen. 2007;14(4):165-168. Exclusion code: 5. [pmid: 18078559].
de Hoop B, De Boo DW, Gietema HA, et al. Computer-aided detection of lung cancer on chest radiographs: effect on observer performance. Radiology. 2010;257(2):532-540. Exclusion code: 2. [pmid: 20807851].
de Hoop B, Gietema H, van de Vorst S, Murphy K, van Klaveren RJ, Prokop M. Pulmonary ground-glass nodules: increase in mass as an early indicator of growth. Radiology. 2010;255(1):199-206. Exclusion code: 7. [pmid: 20123896].
de Hoop B, Schaefer-Prokop C, Gietema HA, et al. Screening for lung cancer with digital chest radiography: sensitivity and number of secondary work-up CT examinations. Radiology. 2010;255(2):629-637. Exclusion code: 2. [pmid: 20413773].
de Leyn P, Decker G. Surgical treatment of non-small cell lung cancer. Rev. Mal. Respir. 2004;21(5 Pt 1):971-982. Exclusion code: 6. [pmid: 15622344].
De Marinis F, Cipri A, Ricciardi S. Is an effective screening for lung cancer possible in COPD? Contra. Multidisciplinary Respiratory Medicine. 2009;4(5):368-371. Exclusion code: 5.
De Marinis F, De Petris L. The role of adjuvant chemotherapy in the treatment of early stage NSCLC after radical surgery. Suppl Tumori. 2004;3(4):S50-51. Exclusion code: 6. [pmid: 15206212].
de Torres JP, Bastarrika G, Wisnivesky JP, et al. Assessing the relationship between lung cancer risk and emphysema detected on low-dose CT of the chest. Chest. 2007;132(6):1932-1938. Exclusion code: 7. [pmid: 18079226].
Debus J, Eberhardt W, Hoffmann H, Passlick B, Rube C, Thomas M. The boundaries of curation. Onkologie. Suppl 5. 2010;33:12-20. Exclusion code: 6. [pmid: 20523102].
Deghaidy AA, Nofal LM, Abd-Elmoneium SE, Mahdy NH. Meta-analysis of survival models of lung cancer. J. Egypt. Public Health Assoc. 2005;80(1-2):77-126. Exclusion code: 5. [pmid: 16922149].
Dehavenon A. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):745-746. author reply 746-747. Exclusion code: 5. [pmid: 17310515].
Dement J, Welch L, Haile E, Myers D. Mortality among sheet metal workers participating in a medical screening program. Am. J. Ind. Med. 2009;52(8):603-613. Exclusion code: 2. [pmid: 19562730].
Deng C, Zhang X, Li N. Investigation of volatile biomarkers in lung cancer blood using solid-phase microextraction and capillary gas chromatography-mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci. 2004;808(2):269-277. Exclusion code: 4. [pmid: 15261821].
Deppermann KM. Lung cancer screening--where we are in 2004 (take home messages). Lung Cancer. Suppl 2. 2004;45:S39-42. Exclusion code: 5. [pmid: 15552780].
DerSimonian R, Laird NM. Meta-analysis in clinical trials. Control. Clin. Trials. 1986;7(3):177-188. Exclusion code: 2. [pmid: 3802833].
Deslauriers J. Should screening for lung cancer be revisited?. J. Thorac. Cardiovasc. Surg. 2001;121(6):1031-1032. Exclusion code: 5. [pmid: 11385366].
Deslauriers J, Ginsberg RJ, Piantadosi S, Fournier B. Prospective assesment of 30-day operative morbidity for surgical resections in lung cancer. Chest. 1994;106(6 Suppl):329S-330S. Exclusion code: 5. [pmid: 7988256].
Deslauriers J, Gregoire J, Jacques LF, Piraux M, Guojin L, Lacasse Y. Sleeve lobectomy versus pneumonectomy for lung cancer: a comparative analysis of survival and sites or recurrences. Ann. Thorac. Surg. 2004;77(4):1152-1156. discussion 1156. Exclusion code: 10. [pmid: 15063224].
Desmetz C, Mange A, Maudelonde T, Solassol J. Autoantibody signatures: Progress and perspectives for early cancer detection. Journal of Cellular and Molecular Medicine. 2011;15(10):2013-2024. Exclusion code: 5. [pmid: 21651719].
Detterbeck F. The fruits of our efforts: time for a different view of lung cancer and CT screening. Thorax. 2009;64(6):465-466. Exclusion code: 5. [pmid: 19478118].
Detterbeck FC. Lumping, splitting, and sorting. Journal of Thoracic Oncology. 2007;2(7):581-582. Exclusion code: 5. [pmid: 17607109].
Detterbeck FC. Maintaining aim at a moving target. Journal of Thoracic Oncology. 2011;6(3):417-422. Exclusion code: 5. [pmid: 21317740].
Detterbeck FC, Boffa DJ, Tanoue LT. The new lung cancer staging system. Chest. 2009;136(1):260-271. Exclusion code: 2. [pmid: 19584208].
Detterbeck FC, Gibson CJ. Turning gray: the natural history of lung cancer over time. J Thorac Oncol. 2008;3(7):781-792. Exclusion code: 2. [pmid: 18594326].
Dewey M. Coronary CT versus MR angiography: Pro CT - The role of CT angiography. Radiology. 2011;258(2):329-339. Exclusion code: 5. [pmid: 21273517].
Dexter EU, Jahangir N, Kohman LJ. Resection for lung cancer in the elderly patient. Thorac Surg Clin. 2004;14(2):163-171. Exclusion code: 5. [pmid: 15382292].
Diciotti S, Lombardo S, Coppini G, Grassi L, Falchini M, Mascalchi M. The LoG characteristic scale: a consistent measurement of lung nodule size in CT imaging. IEEE Trans. Med. Imaging. 2010;29(2):397-409. Exclusion code: 4. [pmid: 20129846].
Diciotti S, Picozzi G, Falchini M, Mascalchi M, Villari N, Valli G. 3-D segmentation algorithm of small lung nodules in spiral CT images. IEEE Transactions on Information Technology in Biomedicine. 2008;12(1):7-19. Exclusion code: 4. [pmid: 18270032].
Diederich S. Screening for early lung cancer with low-dose spiral computed tomography. Lancet. 2003;362(9384):588-589. Exclusion code: 5. [pmid: 12944053].
Diederich S. CT screening for lung cancer. Cancer Imaging. 2008;8 Spec No A:S24-26. Exclusion code: 5. [pmid: 18852077].
Diederich S, Hansen J, Wormanns D. Resolving small pulmonary nodules: CT features. Eur. Radiol. 2005;15(10):2064-2069. Exclusion code: 2. [pmid: 16003507].
Diederich S, Lenzen H. Radiation exposure associated with imaging of the chest: comparison of different radiographic and computed tomography techniques. Cancer. 2000;89(11 Suppl):2457-2460. Exclusion code: 2. [pmid: 11147626].
Diederich S, Thomas M, Semik M, et al. Screening for early lung cancer with low-dose spiral computed tomography: results of annual follow-up examinations in asymptomatic smokers. Eur. Radiol. 2004;14(4):691-702. Exclusion code: 2. [pmid: 14727146].
Diederich S, Wormanns D. Impact of low-dose CT on lung cancer screening. Lung Cancer. Suppl 2. 2004;45:S13-19. Exclusion code: 5. [pmid: 15552777].
Diederich S, Wormanns D, Heindel W. Low-dose CT: new tool for screening lung cancer?. Eur. Radiol. 2001;11(10):1916-1924. Exclusion code: 5. [pmid: 11702123].
Diederich S, Wormanns D, Heindel W. Radiologic screening for lung cancer: present status and future perspectives. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2001;173(10):873-882. Exclusion code: 6. [pmid: 11588672].
Diederich S, Wormanns D, Heindel W. Bronchial carcinoma screening with low dosage CT. Current status. Radiologe. 2001;41(3):256-260. Exclusion code: 6. [pmid: 11322071].
Diederich S, Wormanns D, Heindel W. Lung cancer screening with low-dose CT. Eur. J. Radiol. 2003;45(1):2-7. Exclusion code: 5. [pmid: 12499059].
Diederich S, Wormanns D, Lenzen H, Semik M, Thomas M, Peters PE. Screening for asymptomatic early bronchogenic carcinoma with low dose CT of the chest. Cancer. 2000;89(11 Suppl):2483-2484. Exclusion code: 2. [pmid: 11147631].
Diederich S, Wormanns D, Lenzen H, et al. Screening for early lung cancer with low-dose computed tomography of the chest: results of baseline examinations in 919 asymptomatic smokers. Eur. Radiol. 2000;10(1):S253. Exclusion code: 8.
Diederich S, Wormanns D, Semik M, et al. Screening for early lung cancer with low-dose spiral CT: prevelance in 817 asymptomatic smokers. Radiology. 2002;222(3):773-781. Exclusion code: 2. [pmid: 11867800].
Dienemann H. Principles of surgical treatment in localized non-small cell lung cancer. Lung Cancer. Suppl 1. 2001;33:S3-8. Exclusion code: 5. [pmid: 11576701].
Dienemann H, Hoffmann H, Herth F. Thoracic surgery in the elderly. Chirurg. 2005;76(2):126-130. Exclusion code: 6. [pmid: 15551005].
Ding Z, Zhang J, Shao J. ERCC1 expression as a predictor of survival after operation in stage I non-small cell lung cancer patients. Zhongguo Fei Ai Za Zhi. 2010;13(5):522-525. Exclusion code: 6. [pmid: 20677653].
Divisi D, Di Tommaso S, De Vico A, Crisci R. Early diagnosis of lung cancer using a SAFE-3000 autofluorescence bronchoscopy. Interact Cardiovasc Thorac Surg. 2010;11(6):740-744. Exclusion code: 3. [pmid: 20852332].
Dixon GD. Computed tomography for screening purposes: a review of the literature--2003. Mo. Med. 2003;100(2):140-144. Exclusion code: 5. [pmid: 12710165].
Dobbins Iii JT, McAdams HP. Chest tomosynthesis: Technical principles and clinical update. Eur. J. Radiol. 2009;72(2):244-251. Exclusion code: 5. [pmid: 19616909].
Dobbins JT. Tomosynthesis imaging: At a translational crossroads. Med. Phys. 2009;36(6):1956-1967. Exclusion code: 5. [pmid: 19610284].
Dobbins JT, McAdams HP, Godfrey DJ, Li CM. Digital tomosynthesis of the chest. J. Thorac. Imaging. 2008;23(2):86-92. Exclusion code: 5. [pmid: 18520565].
Dobson R. Screening trial for lung cancer planned for UK. BMJ. 2000;320(7230):270. Exclusion code: 5. [pmid: 10650017].
Doddoli C, Aragon A, Barlesi F, et al. Does the extent of lymph node dissection influence outcome in patients with stage I non-small-cell lung cancer?. Eur. J. Cardiothorac. Surg. 2005;27(4):680-685. Exclusion code: 3. [pmid: 15784374].
Doddoli C, Thomas P, Reynaud-Gaubert M, Giudicelli R, Papazian L, Fuentes P. Postoperative complications after radiochemotherapy or chemotherapy for bronchial cancers. Rev. Mal. Respir. 2000;17(6):1081-1087. Exclusion code: 6. [pmid: 11217503].
Doll R, Hill AB. Smoking and carcinoma of the lung; preliminary report. Br. Med. J. 1950;2(4682):739-748. Exclusion code: 5. [pmid: 14772469].
Dome B, Timar J, Dobos J, et al. Identification and clinical significance of circulating endothelial progenitor cells in human non-small cell lung cancer. Cancer Res. 2006;66(14):7341-7347. Exclusion code: 4. [pmid: 16849585].
Dominioni L, Imperatori A, Rovera F, Ochetti A, Paolucci M, Dionigi G. Lung cancer screening in cigarette smokers in the province of Varese, Italy. Cancer. 2000;89(11 Suppl):2345-2348. Exclusion code: 5. [pmid: 11147609].
Dominioni L, Rotolo N, Mantovani W, et al. A population-based cohort study of chest x-ray screening in smokers: lung cancer detection findings and follow-up. BMC Cancer. 2012;12:18. Exclusion code: 5. [pmid: 22251777].
Dominioni L, Rotolo N, Poli A, et al. Self-selection effects in smokers attending lung cancer screening: a 9.5-year population-based cohort study in Varese, Italy. J Thorac Oncol. 2010;5(4):428-435. Exclusion code: 2. [pmid: 20142770].
Dominioni L, Strauss GM, Imperatori A, Rovera F, Dionigi G. Screening for lung cancer. Chest Surg. Clin. N. Am. 2000;10(4):729-736. Exclusion code: 5. [pmid: 11091922].
Doria-Rose VP, Marcus PM, Szabo E, Tockman MS, Melamed MR, Prorok PC. Randomized controlled trials of the efficacy of lung cancer screening by sputum cytology revisited: a combined mortality analysis from the Johns Hopkins Lung Project and the Memorial Sloan-Kettering Lung Study. Cancer. 2009;115(21):5007-5017. Exclusion code: 5. [pmid: 19637354].
Doria-Rose VP, White MC, Klabunde CN, et al. Use of lung cancer screening tests in the United States: results from the 2010 National Health Interview Survey. Cancer Epidemiol. Biomarkers Prev. 2012;21(7):1049-1059. Exclusion code: 2. [pmid: 22573798].
Dougeni E, Faulkner K, Panayiotakis G. A review of patient dose and optimisation methods in adult and paediatric CT scanning. Eur. J. Radiol. 2012;81(4):e665-e683. Exclusion code: 5. [pmid: 21684099].
Douglas PS, Cerqueria M, Rubin GD, Chin ASL. Extracardiac Findings: What Is a Cardiologist to Do?. JACC: Cardiovascular Imaging. 2008;1(5):682-687. Exclusion code: 5. [pmid: 19356500].
Dowie J, Wildman M. Choosing the surgical mortality threshold for high risk patients with stage Ia non-small cell lung cancer: insights from decision analysis. Thorax. 2002;57(1):7-10. Exclusion code: 5. [pmid: 11809982].
Duan Y, Bai Lq. Long-term results of surgical plus chemotherapy for stage I lung adenocarcinoma. Chung Hua I Hsueh Tsa Chih. 2009;89(23):1630-1632. Exclusion code: 6. [pmid: 19957512].
Duan Y, Bai LQ, Gong CF, Yan DJ, Dou XJ. Preoperative chemotherapy for long-term results of small cell lung cancer. Chung Hua I Hsueh Tsa Chih. 2009;89(31):2199-2201. Exclusion code: 6. [pmid: 20058599].
Duarte IG, Gal AA, Mansour KA, Lee RB, Miller JI. Pathologic findings in lung volume reduction surgery. Chest. 1998;113(3):660-664. Exclusion code: 4. [pmid: 9515839].
Dubey S, Powell CA. Update in lung cancer 2007. Am. J. Respir. Crit. Care Med. 2008;177(9):941-946. Exclusion code: 5. [pmid: 18434333].
Duncan MW. Place for biochemical markers in early-stage lung cancer detection?. J. Clin. Oncol. 2009;27(17):2749-2750. Exclusion code: 5. [pmid: 19414662].
Duque JK, Lopez-Encuentra A, Porta RR, Bronchogenic Carcinoma Cooperative Group of the Spanish Society of P, Thoracic S. Survival of 2,991 patients with surgical lung cancer: the denominator effect in survival. Chest. 2005;128(4):2274-2281. Exclusion code: 5. [pmid: 16236884].
Ebeling K, Nischan P. Screening for lung cancer - Results from a case-control study. Int. J. Cancer. 1987;40(2):141-144. Exclusion code: 8. [pmid: 3610384].
Eberini I, Gianazza E, Pastorino U, Sirtori CR. Assessment of individual lung cancer risk by the proteomic analysis of exhaled breath condensate. Expert Opinion on Medical Diagnostics. 2008;2(12):1309-1315. Exclusion code: 4. [pmid: 23496779].
Eckardt SM, Ashton RW. Lung cancer screening: Is it time for a change in policy?. South. Med. J. 2008;101(1):5-6. Exclusion code: 5.
Eckert R. Recommendations for follow-up of malignant diseases. Praxis. 2006;95(15):567-573. Exclusion code: 6. [pmid: 16640176].
Edey AJ, Hansell DM. CT lung cancer screening in the UK. Br. J. Radiol. 2009;82(979):529-531. Exclusion code: 5. [pmid: 19541944].
Ehmann R, Boedeker E, Friedrich U, et al. Canine scent detection in the diagnosis of lung cancer: revisiting a puzzling phenomenon. Eur. Respir. J. 2012;39(3):669-676. Exclusion code: 4. [pmid: 21852337].
El-Bayoumi E, Silvestri GA. Bronchoscopy for the diagnosis and staging of lung cancer. Semin. 2008;29(3):261-270. Exclusion code: 5. [pmid: 18506664].
Elliott A. Issues in medical exposures. J. Radiol. Prot. 2009;29(2):A107-A121. Exclusion code: 5. [pmid: 19454810].
Ellis JR, Gleeson FV. Lung cancer screening. Br. J. Radiol. 2001;74(882):478-485. Exclusion code: 2. [pmid: 11459725].
Ellis SM, Husband JE, Armstrong P, Hansell DM. Computed tomography screening for lung cancer: back to basics. Clin. Radiol. 2001;56(9):691-699. Exclusion code: 2. [pmid: 11585391].
El-Sherif A, Gooding WE, Santos R, et al. Outcomes of sublobar resection versus lobectomy for stage I non-small cell lung cancer: a 13-year analysis. Ann. Thorac. Surg. 2006;82(2):408-415. discussion 415-406. Exclusion code: 3. [pmid: 16863738].
Elwood M, Campbell DA, de Campo MP. Helical computed tomography for lung cancer screening. Med. J. Aust. 2003;179(3):125-126. Exclusion code: 5. [pmid: 12885278].
Ely S. Personalized medicine: individualized care of cancer patients. Translational Research. 2009;154(6):303-308. Exclusion code: 5. [pmid: 19931196].
El-Zein RA, Fenech M, Lopez MS, Spitz MR, Etzel CJ. Cytokinesis-blocked micronucleus cytome assay biomarkers identify lung cancer cases amongst smokers. Cancer Epidemiol. Biomarkers Prev. 2008;17(5):1111-1119. Exclusion code: 2. [pmid: 18483333].
Emmons KM. Smoking cessation and tobacco control: an overview. Chest. 1999;116(6 Suppl):490S-492S. Exclusion code: 5. [pmid: 10619516].
Endo C, Sagawa M, Sakurada A, Sato M, Kondo T, Fujimura S. Surgical treatment of stage I non-small cell lung carcinoma. Ann. Thorac. Cardiovasc. Surg. 2003;9(5):283-289. Exclusion code: 5. [pmid: 14672523].
Endo S, Saito N, Otani S, et al. Clinicopathologic features of small-sized peripheral lung cancer; is intentional limited resection appropriate for selected patients?. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2004;57(1):46-50. Exclusion code: 6. [pmid: 14733098].
Endo T, Endo S, Hasegawa T, et al. Clinical outcome after video-assisted thoracic surgery (VATS) for clinical stage I lung cancer with pathologically nodal involvement. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2012;65(1):42-45. Exclusion code: 6. [pmid: 22314156].
Enquobahrie AA, Reeves AP, Yankelevitz DF, Henschke CI. Automated detection of small pulmonary nodules in whole lung CT scans. Acad. Radiol. 2007;14(5):579-593. Exclusion code: 4. [pmid: 17434072].
Erasmus JJ. Fluorodeoxyglucose uptake predicts survival in a CT screening trial. J Thorac Oncol. 2009;4(11):1305-1306. Exclusion code: 5. [pmid: 19861902].
Ernst I, Lucking PS, Eickmeyer F, et al. Stereotactic body radiotherapy (SBRT) -- an overview under special consideration of SBRT and LITT in the therapy of liver metastases. Zentralbl. Gynakol. 2006;128(2):71-75. Exclusion code: 6. [pmid: 16673248].
Escarguel B, D'Amore D, Chapel F, et al. Early diagnosis of lung cancer: impact of autofluorescence bronchoscopy. Rev. Pneumol. Clin. 2009;65(5):287-291. Exclusion code: 6. [pmid: 19878802].
Esserman L, Shieh Y, Thompson I. Rethinking screening for breast cancer and prostate cancer. JAMA - Journal of the American Medical Association. 2009;302(15):1685-1692. Exclusion code: 3. [pmid: 19843904].
Ettinger DS, Akerley W, Bepler G, et al. Non-small cell lung cancer: Clinical practice guidelines in oncology. JNCCN Journal of the National Comprehensive Cancer Network. 2010;8(7):740-741. 771. 801. Exclusion code: 2. [pmid: 20679538].
Ettinger DS, Akerley W, Bepler G, et al. Non-small cell lung cancer. JNCCN Journal of the National Comprehensive Cancer Network. 2008;6(3):228-269. Exclusion code: 5. [pmid: 16813724].
Etzel CJ, Bach PB. Estimating individual risk for lung cancer. Semin. 2011;32(1):3-9. Exclusion code: 5. [pmid: 21500119].
Etzel CJ, Lu M, Merriman K, Liu M, Vaporciyan A, Spitz MR. An epidemiologic study of early onset lung cancer. Lung Cancer. 2006;52(2):129-134. Exclusion code: 4. [pmid: 16564601].
Fadeyi OO, Adamson ST, Myles EL, Okoro CO. Novel fluorinated acridone derivatives. Part 1: Synthesis and evaluation as potential anticancer agents. Bioorg. Med. Chem. Lett. 2008;18(14):4172-4176. Exclusion code: 5. [pmid: 18541426].
Fan J, Wang L, Jiang GN, Gao W. Sublobectomy versus lobectomy for stage I non-small-cell lung cancer, a meta-analysis of published studies. Ann. Surg. Oncol. 2012;19(2):661-668. Exclusion code: 5. [pmid: 21769464].
Fan YG, Hu P, Jiang Y, et al. Association between sputum atypia and lung cancer risk in an occupational cohort in Yunnan, China. Chest. 2009;135(3):778-785. Exclusion code: 2. [pmid: 19265088].
Fang D, Zhang D, Huang G, Zhang R, Wang L. Results of surgical resection of patients with primary lung cancer: a retrospective analysis of 1,905 cases. Ann. Thorac. Surg. 2001;72(4):1155-1159. Exclusion code: 10. [pmid: 11603429].
Farjah F, Flum D, Varghese T, Symons R, Wood D. Surgeon Specialty and Long-Term Survival After Pulmonary Resection for Lung Cancer. Ann. Thorac. Surg. 2009;87:995-1006. Exclusion code: 2. [pmid: 19324119].
Farjah F, Wood DE, Mulligan MS, et al. Safety and efficacy of video-assisted versus conventional lung resection for lung cancer. J. Thorac. Cardiovasc. Surg. 2009;137(6):1415-1421. Exclusion code: 10. [pmid: 19464458].
Farjah F, Wood DE, Yanez ND 3rd, et al. Racial disparities among patients with lung cancer who were recommended operative therapy. Arch. Surg. 2009;144(1):14-18. Exclusion code: 3. [pmid: 19153319].
Farlow EC, Vercillo MS, Coon JS, et al. A multi-analyte serum test for the detection of non-small cell lung cancer. Br. J. Cancer. 2010;103(8):1221-1228. Exclusion code: 2. [pmid: 20859284].
Farmer I, Paulus T, Mollus S, Von Busch H, Buurman J, Verbeek XAAM. Oncology: The care cycle approach. Medicamundi. 2007;51(2-3):6-13. +100+102+104+106. Exclusion code: 5.
Fasola G, Belvedere O, Aita M, et al. Low-dose computed tomography screening for lung cancer and pleural mesothelioma in an asbestos-exposed population: baseline results of a prospective, nonrandomized feasibility trial--an Alpe-adria Thoracic Oncology Multidisciplinary Group Study (ATOM 002). Oncologist. 2007;12(10):1215-1224. Exclusion code: 3. [pmid: 17962615].
Favre L, Rochat T. Screening for lung cancer with low-dose chest computed tomography. Med. Hyg. (Geneve). 2003;61(2458):2197-2200. [PMID:. Exclusion code: 6.
Felix L, Lantuejoul S, Jankowski A, Ferretti G. Localized pure or mixed ground-glass lung opacities. J. Radiol. 2009;90(11 Pt 2):1869-1892. Exclusion code: 6. [pmid: 19953078].
Feragalli B, Bonomo L. Non-small cell lung carcinoma. Early diagnosis: applicability of a screening. Suppl Tumori. 2004;3(2):S5-8. Exclusion code: 6. [pmid: 15067955].
Ferguson MK, Karrison T. Does pneumonectomy for lung cancer adversely influence long-term survival?. J. Thorac. Cardiovasc. Surg. 2000;119(3):440-448. Exclusion code: 3. [pmid: 10694601].
Ferketich AK, Otterson GA, King M, Hall N, Browning KK, Wewers ME. A pilot test of a combined tobacco dependence treatment and lung cancer screening program. Lung Cancer. 2012;76(2):211-215. Exclusion code: 2. [pmid: 22088938].
Fernandes OJCB, Almgren SO, Thaning L, et al. Prognostic factors for the survival of surgically treated patients for non-small cell lung cancer. Acta Oncol. 2003;42(4):338-341. Exclusion code: 10. [pmid: 12899506].
Fernandez FG, Force SD, Pickens A, Kilgo PD, Luu T, Miller DL. Impact of laterality on early and late survival after pneumonectomy. Ann. Thorac. Surg. 2011;92(1):244-249. Exclusion code: 3. [pmid: 21718850].
Fernández Ladrón V, Alonso JL, Munuera L, et al. Analysis of lung cancer cases diagnosed in an Internal Medicine Department: From Accessed January 2001 to September 2006. Anales del Sistema Sanitario de Navarra. 2007;30(3):353-362. Exclusion code: 5. [pmid: 18227892].
Fernández Sacasas JA, Díaz Novás J. Some theoretical considerations on the active inquiry. Revista Cubana de Medicina General Integral. 2009;25(4):107-116. Exclusion code: 6.
Fernando HC, Landreneau RJ, Mandrekar SJ, et al. The impact of adjuvant brachytherapy with sublobar resection on pulmonary function and dyspnea in high-risk patients with operable disease: preliminary results from the American College of Surgeons Oncology Group Z4032 trial. J. Thorac. Cardiovasc. Surg. 2011;142(3):554-562. Exclusion code: 10. [pmid: 21724195].
Ferretti G. What are the tools for post-occupational follow-up, how should they be performed and what are their performance, limits and benefit/risk ratio? Chest X-Ray and CT scan. Revue des Maladies Respiratoires. 2011;28(6):761-772. Exclusion code: 6. [pmid: 21742237].
Ferretti G. Exposure to asbestos: Radiography and chest CT. Journal de Radiologie. 2011;92(5):450-460. Exclusion code: 5. [pmid: 21621114].
Ferretti G, Brichon P, Jankowski A, Coulomb M. Postoperative complications after thoracic surgery. J. Radiol. 2009;90(7-8 Pt 2):1001-1012. Exclusion code: 6. [pmid: 19752837].
Ferretti G, Jankowski A, Calizzano A, Moro-Sibilot D, Vuillez JP. Imaging and PET/CT of lung cancer. J Radiol. 2008;89(3 C2):387-402. Exclusion code: 6. [pmid: 18408640].
Fibla Alfara JJ, Gomez Sebastian G, Farina Rios C, Carvajal Carrasco A, Estrada Salo G, Leon Gonzalez C. Lobectomy versus limited resection to treat non-small cell lung cancer in stage I: a study of 78 cases. Arch. Bronconeumol. 2003;39(5):217-220. Exclusion code: 6. [pmid: 12749804].
Field JK, Duffy SW. Lung cancer screening: the way forward. Br. J. Cancer. 2008;99(4):557-562. Exclusion code: 2. [pmid: 18665179].
Field JK, Raji OY. The potential for using risk models in future lung cancer screening trials. Medicine Reports. 2010;2. Exclusion code: 5. [pmid: 20948847].
Field JK, Smith DL, Duffy S, Cassidy A. The Liverpool Lung Project research protocol. Int. J. Oncol. 2005;27(6):1633-1645. Exclusion code: 4. [pmid: 16273220].
Field JK, Smith RA, Aberle DR, et al. International Association for the Study of Lung Cancer Computed Tomography Screening Workshop 2011 Report. Journal of Thoracic Oncology. 2012;7(1):10-19. Exclusion code: 2. [pmid: 22173661].
Field JK, Smith RA, Duffy SW, et al. The Liverpool Statement 2005: priorities for the European Union/United States spiral computed tomography collaborative group. J Thorac Oncol. 2006;1(5):497-498. Exclusion code: 3. [pmid: 17409906].
Field JK, Youngson JH. The Liverpool Lung Project: a molecular epidemiological study of early lung cancer detection. Eur. Respir. J. 2002;20(2):464-479. Exclusion code: 2. [pmid: 12212983].
Fischer BM, Mortensen J, Hojgaard L. Positron emission tomography in the diagnosis and staging of lung cancer: a systematic, quantitative review. Lancet Oncol. 2001;2(11):659-666. Exclusion code: 7. [pmid: 11902536].
Flahault A, Costagliola D. Is lung cancer screening by the helical scanner justified?. MS Md Sci. 2007;23(3):333-334. Exclusion code: 6. [pmid: 17349299].
Flahault A, Lemarie MD. GranDepiscan: Evaluation of early lung cancer screening in a randomized trial in France. Paper presented at: International Symposium on Predictive Oncology and Intervention Strategies. 2004. Exclusion code:5.
Flehinger B, Kimmel M, Melamed M. The effect of surgical treatment on survival from early lung cancer: implications for screening. Chest Surg. Clin. N. Am. 1992;101(4):1013. Exclusion code: 2. [pmid: 1313349].
Flehinger BJ, Kimmel M, Polyak T, Melamed MR. Screening for lung cancer. The Mayo Lung Project revisted. Cancer. 1993;72(5):1573-1580. Exclusion code: 5. [pmid: 8394199].
Flehinger BJ, Melamed MR, Zaman MB, Heelan RT, Perchick WB, Martini N. Early lung cancer detection: results of the initial (prevalence) radiologic and cytologic screening in the Memorial Sloan-Kettering study. Am. Rev. Respir. Dis. 1984;130(4):555-560. Exclusion code: 5. [pmid: 6091506].
Flieder DB. Screen-detected adenocarcinoma of the lung. Practical points for surgical pathologists. Am. J. Clin. Pathol. 2003;119(Suppl):S39-57. Exclusion code: 2. [pmid: 12951843].
Flieder DB, Vazquez M, Carter D, et al. Pathologic findings of lung tumors diagnosed on baseline CT screening. Am. J. Surg. Pathol. 2006;30(5):606-613. Exclusion code: 7. [pmid: 16699315].
Flores RM. Video-assisted thoracic surgery (VATS) lobectomy: focus on technique. World J. Surg. 2010;34(4):616-620. Exclusion code: 5. [pmid: 20082195].
Flores RM, Park BJ, Dycoco J, et al. Lobectomy by video-assisted thoracic surgery (VATS) versus thoracotomy for lung cancer. J. Thorac. Cardiovasc. Surg. 2009;138(1):11-18. Exclusion code: 7. [pmid: 19577048].
Fong KM, Yang IA, Zimmerman PV, Bowman RV. Cochrane systematic reviews of treatments for lung cancer. Respir. Med. 2005;99(9):1071-1078. Exclusion code: 5. [pmid: 15955688].
Fontana RS. The Mayo Lung Project: a perspective. Cancer. 2000;89(11 Suppl):2352-2355. Exclusion code: 5. [pmid: 11147611].
Fontana RS, Sanderson DR, Taylor WF, et al. Early lung cancer detection: results of the initial (prevalence) radiologic and cytologic screening in the Mayo Clinic study. Am. Rev. Respir. Dis. 1984;130(4):561-565. Exclusion code: 5. [pmid: 6091507].
Fontana RS, Sanderson DR, Woolner LB, Taylor WF, Miller WE, Muhm JR. Lung cancer screening: the Mayo program. J. Occup. Med. 1986;28(8):746-750. Exclusion code: 5. [pmid: 3528436].
Fontana RS, Sanderson DR, Woolner LB, et al. Screening for lung cancer. A critique of the Mayo Lung Project. Cancer. 1991;67(4 SUPPL.):1155-1164. Exclusion code: 5. [pmid: 1991274].
Fontana TR, Sanderson DR, Woolner LB, Miller WE, Bernatz PE, Payne WS. The Mayo Lung Project for early detection and localization of bronchogenic carcinoma: a status report. Chest. 1975;67(5):511-522. Exclusion code: 5. [pmid: 1126186].
Fontham E, Correa P, Reynolds P, Wu-Williams A, Buffler P, Greenberg R. Environmental tobacco smoke and lung cancer in nonsmoking women. JAMA. 1994;271(22):1752-1759. Exclusion code: 2. [pmid: 8196118].
Ford ME, Havstad SL, Flickinger L, Johnson CC. Examining the effects of false positive lung cancer screening results on subsequent lung cancer screening adherence. Cancer Epidemiol. Biomarkers Prev. 2003;12(1):28-33. Exclusion code: 2. [pmid: 12540500].
Foss KM, Sima C, Ugolini D, Neri M, Allen KE, Weiss GJ. miR-1254 and miR-574-5p: serum-based microRNA biomarkers for early-stage non-small cell lung cancer. J Thorac Oncol. 2011;6(3):482-488. Exclusion code: 4. [pmid: 21258252].
Foucault C, Berna P, Le Pimpec Barthes F, Souilamas R, Dujon A, Riquet M. Lung cancer in women: surgical aspects related to gender. Rev. Mal. Respir. 2006;23(3 Pt 1):243-253. Exclusion code: 6. [pmid: 16788525].
Foy M, Chen X, Kimmel M, Gorlova OY. Adjusting a cancer mortality-prediction model for disease status-related eligibility criteria. BMC Medical Research Methodology. 2011;11. Exclusion code: 4. [pmid: 21569346].
Foy M, Spitz MR, Kimmel M, Gorlova OY. A smoking-based carcinogenesis model for lung cancer risk prediction. Int. J. Cancer. 2011;129(8):1907-1913. Exclusion code: 5. [pmid: 21140453].
Foy M, Yip R, Chen X, Kimmel M, Gorlova OY, Henschke CI. Modeling the mortality reduction due to computed tomography screening for lung cancer. [Erratum appears in Cancer. 2011 Jul 15;117(14):3286]. Cancer. 2011;117(12):2703-2708. Exclusion code: 2. [pmid: 21656748].
Fraioli F, Bertoletti L, Napoli A, et al. Computer-aided detection (CAD) in lung cancer screening at chest MDCT: ROC analysis of CAD versus radiologist performance. J. Thorac. Imaging. 2007;22(3):241-246. Exclusion code: 2. [pmid: 17721333].
Fraioli F, Catalano C, Almberger M, et al. Evaluation of effectiveness of a computer system (CAD) in the identification of lung nodules with low-dose MSCT: scanning technique and preliminary results. Radiol. Med. (Torino). 2005;109(1-2):40-48. Exclusion code: 4. [pmid: 15729185].
Freedman M. State-of-the-art screening for lung cancer (part 1): the chest radiograph. Thorac Surg Clin. 2004;14(1):43-52. Exclusion code: 7. [pmid: 15382307].
Freedman M, Chang EH, Zhou Q, Pirollo KF. Nanodelivery of MRI Contrast Agent Enhances Sensitivity of Detection of Lung Cancer Metastases. Acad. Radiol. 2009;16(5):627-637. Exclusion code: 4. [pmid: 19345904].
Friedman GD, Collen MF, Fireman BH. Multiphasic Health Checkup Evaluation: a 16-year follow-up. J Chron Dis. 1986;39(6):453-463. Exclusion code: 5. [pmid: 3711252].
Frohlich J, Rischke C, Rentschler J, Drevs J, Stremmel C, Passlick B. Isolated lymph node metastasis in pericardial fat flap after bronchial stump coverage. Chirurg. 2010;81(10):930-932. Exclusion code: 6. [pmid: 19940968].
Frost JK, Ball WC Jr., Levin ML, et al. Early lung cancer detection: results of the initial (prevalence) radiologic and cytologic screening in the Johns Hopkins study. Am. Rev. Respir. Dis. 1984;130(4):549-554. Exclusion code: 5. [pmid: 6091505].
Fujikawa A, Takiguchi Y, Mizuno S, et al. Lung cancer screening--comparison of computed tomography and X-ray. Lung Cancer. 2008;61(2):195-201. Exclusion code: 2. [pmid: 18242764].
Fujimura S. Limited surgery for bronchogenic carcinoma. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2001;54(8 Suppl):707-714. Exclusion code: 6. [pmid: 11517536].
Fujimura S, Sakurada A, Sagawa M, et al. A therapeutic approach to roentgenographically occult squamous cell carcinoma of the lung. Cancer. 2000;89(11 Suppl):2445-2448. Exclusion code: 7. [pmid: 11147623].
Fukino S, Fukata T, Hayashi E, et al. Cases of death after surgery for pathologic stage I non-small cell lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2002;55(2):110-115. Exclusion code: 6. [pmid: 11842546].
Fukino S, Fukata T, Hayashi E, Okada K, Tamai N, Morio S. Lobectomy of two or more lobes in patients with lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2001;54(3):219-224. Exclusion code: 6. [pmid: 11244755].
Fukui T, Mori S, Hatooka S, Shinoda M, Mitsudomi T. Prognostic evaluation based on a new TNM staging system proposed by the International Association for the Study of Lung Cancer for resected non-small cell lung cancers. J. Thorac. Cardiovasc. Surg. 2008;136(5):1343-1348. Exclusion code: 5. [pmid: 19026826].
Fukuoka M. Progress in diagnosis and treatment of lung cancer. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 2002;91(Suppl):15-22. Exclusion code: 6. [pmid: 11989256].
Furak J, Trojan I, Szoke T, Tiszlavicz L, Morvay Z, Balogh A. The occurrence of bronchioloalveolar lung cancer among our patients. Magy Onkol. 2003;47(4):349-353. Exclusion code: 6. [pmid: 14716429].
Futamura Y, Sawa T, Horiba A, et al. The efficacy and safety of stereotactic radiotherapy for non-resectable non-small cell lung cancer. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2010;37(12):2744-2746. Exclusion code: 6. [pmid: 21224699].
Gabrecht T, Radu A, Grosjean P, et al. Improvement of the specificity of cancer detection by autofluorescence imaging in the tracheo-bronchial tree using backscattered violet light. Photodiagnosis Photodyn Ther. 2008;5(1):2-9. Exclusion code: 4. [pmid: 19356630].
Gagnon F, Courchesne M, Levesque B, et al. Assessment of the effectiveness of radon screening programs in reducing lung cancer mortality. Risk Anal. 2008;28(5):1221-1230. Exclusion code: 4. [pmid: 18761730].
Gajra A, Newman N, Gamble GP, Kohman LJ, Graziano SL. Effect of number of lymph nodes sampled on outcome in patients with stage I non-small-cell lung cancer. J. Clin. Oncol. 2003;21(6):1029-1034. Exclusion code: 10. [pmid: 12637467].
Galus M. Preventive medicine and screening. Cleve. Clin. J. Med. 2001;68(1):82-83. Exclusion code: 5. [pmid: 11204369].
Gamarra F. The role of lung cancer screening. Med. Welt. 2008;59(10):376-379. Exclusion code: 5.
Gandara DR, Kawaguchi T, Crowley J, et al. Japanese-US common-arm analysis of paclitaxel plus carboplatin in advanced non-small-cell lung cancer: A model for assessing population-related pharmacogenomics. J. Clin. Oncol. 2009;27(21):3540-3546. Exclusion code: 2. [pmid: 19470925].
Ganti AK, Huang CH, Klein MA, Keefe S, Kelley MJ. Lung cancer management in 2010. Oncology (Williston). 2011;25(1):64-73. Exclusion code: 5. [pmid: 21361246].
Ganti AK, Mulshine JL. Lung cancer screening. Oncologist. 2006;11(5):481-487. Exclusion code: 5. [pmid: 16720848].
Gao L, Li F, Thrall MJ, et al. On-the-spot lung cancer differential diagnosis by label-free, molecular vibrational imaging and knowledge-based classification. Journal of Biomedical Optics. 2011;16(9). Exclusion code: 5. [pmid: 21950918].
Gao W, Xu J, Shu YQ. MiRNA expression and its clinical implications for the prevention and diagnosis of non-small-cell lung cancer. Expert Rev Respir Med. 2011;5(5):699-709. Exclusion code: 4. [pmid: 21955239].
Gao YS, Xing XZ, Shao K, Feng XL, He J. Analysis of prognostic factors in 1826 patients with completely resected non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2008;30(2):134-137. Exclusion code: 6. [pmid: 18646698].
Gao YS, Zhang DC, He J, Sun KL, Zhang DW, Zhang RG. Diagnosis and surgical treatment for stage I non-small-cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2005;27(1):52-55. Exclusion code: 6. [pmid: 15771801].
Garcia-Yuste M, Matilla JM, Duque JL, Heras F, Cerezal LJ, Ramos G. Surgical treatment of lung cancer: comparative assessment of the staging systems of 1986 and 1997. Results in 500 consecutive patients. Arch. Bronconeumol. 2000;36(5):245-250. Exclusion code: 6. [pmid: 10916664].
Garg K, Keith RL, Byers T, et al. Randomized controlled trial with low-dose spiral CT for lung cancer screening: feasibility study and preliminary results. Radiology. 2002;225(2):506-510. Exclusion code: 5. [pmid: 12409588].
Gasent Blesa JM, Esteban Gonzalez E, Alberola Candel V. Screening and chemoprevention in lung cancer. Clin Transl Oncol. 2008;10(5):274-280. Exclusion code: 2. [pmid: 18490244].
Gavelli G, Giampalma E. Sensitivity and specificity of chest X-ray screening for lung cancer: review article. Cancer. 2000;89(11 Suppl):2453-2456. Exclusion code: 5. [pmid: 11147625].
Gazelle GS, Kessler L, Lee DW, et al. A framework for assessing the value of diagnostic imaging in the era of comparative effectiveness research. Radiology. 2011;261(3):692-698. Exclusion code: 5. [pmid: 22095993].
Geddes DM. The natural history of lung cancer: a review based on rates of tumor growth. Br. J. Dis. Chest. 1979;73(1):1-17. Exclusion code: 2. [pmid: 435370].
Gelmann EP, Reding D, Buys S, et al. Multicenter screening trial for prostate, lung, colorectal and ovarian cancer (PLCO) [abstract]. Proceedings of the American Society of Clinical Oncology. 1997;16. Exclusion code: 5.
Ghosal R, Kloer P, Lewis KE. A review of novel biological tools used in screening for the early detection of lung cancer. Postgrad. Med. J. 2009;85(1005):358-363. Exclusion code: 5. [pmid: 19581246].
Ghosh SK, Roland NJ, Kumar A, et al. Detection of synchronous lung tumors in patients presenting with squamous cell carcinoma of the head and neck. Head Neck. 2009;31(12):1563-1570. Exclusion code: 2. [pmid: 19475554].
Ghrairi H, Kartas S, Ammar J, et al. Prognosis of mucoepidermoid carcinoma of the bronchi. Rev. Pneumol. Clin. 2007;63(1):29-34. Exclusion code: 6. [pmid: 17457281].
Giarelli E. To screen or not to screen: using spiral computerized tomography in the early detection of lung cancer. Clin. J. Oncol. Nurs. 2002;6(4):223-224. Exclusion code: 5. [pmid: 12180375].
Gibson L, Spiegelhalter DJ, Camilleri-Ferrante C, Day NE. Trends in invasive cervical cancer incidence in East Anglia from 1971 to 1993. J. Med. Screen. 1997;4(1):44-48. Exclusion code: 8. [pmid: 9200063].
Gierada DS, Garg K, Nath H, Strollo DC, Fagerstrom RM, Ford MB. CT quality assurance in the lung screening study component of the National Lung Screening Trial: implications for multicenter imaging trials. AJR. Am. J. Roentgenol. 2009;193(2):419-424. Exclusion code: 2. [pmid: 19620438].
Gierada DS, Pilgram TK, Ford M, et al. Lung cancer: interobserver agreement on interpretation of pulmonary findings at low-dose CT screening. Radiology. 2008;246(1):265-272. Exclusion code: 2. [pmid: 18024436].
Gietema HA, Wang Y, Xu D, et al. Pulmonary nodules detected at lung cancer screening: interobserver variability of semiautomated volume measurements. Radiol. 2006;241(1):251-257. Exclusion code: 2. [pmid: 16908677].
Gietema HA, Zanen P, Schilham A, et al. Distribution of emphysema in heavy smokers: impact on pulmonary function. Respir. Med. 2010;104(1):76-82. Exclusion code: 4. [pmid: 19734030].
Gilbert ES, Stovall M, Gospodarowicz M, et al. Lung Cancer after Treatment for Hodgkin's Disease: Focus on Radiation Effects. Radiat. Res. 2003;159:161-173. Exclusion code: 3. [pmid: 12537521].
Gilliland FD, Hunt WC, Archer VE, Saccomanno G. Radon progeny exposure and lung cancer risk among non-smoking uranium miners. Health Phys. 2000;79(4):365-372. Exclusion code: 3. [pmid: 11007458].
Gilljam H. Screening for lung cancer--expensive and inefficient. Lakartidningen. 2001;98(24):2952. Exclusion code: 6. [pmid: 11449902].
Gimferrer JM, Belda J, Catalan M, Serra M, Rubio M, Iglesias M. Video-assisted lobectomy through the auscultatory triangle for the surgical treatment of bronchopulmonary carcinoma. Preliminary experience. Arch. Bronconeumol. 2003;39(2):87-90. Exclusion code: 6. [pmid: 12586049].
Girard N, Mornex F. Stereotactic radiotherapy for non-small cell lung cancer: From concept to clinical reality. 2011 update. Cancer Radiother. 2011;15(6-7):522-526. Exclusion code: 6. [pmid: 21889901].
Gleeson FV. Is screening for lung cancer using low dose spiral CT scanning worthwhile?. Thorax. 2006;61(1):5-7. Exclusion code: 5. [pmid: 16396951].
Gleeson FV. Screening for lung cancer with spiral CT is not justified. Nat Clin Pract Oncol. 2007;4(8):442-443. Exclusion code: 5. [pmid: 17579599].
Godoy MCB, Cooperberg PL, Maizlin ZV, et al. Detection sensitivity of a commercial lung nodule CAD system in a series of pathologically proven lung cancers. J. Thorac. Imaging. 2008;23(1):1-6. Exclusion code: 2. [pmid: 18347512].
Goeckenjan G. Lung cancer - historical development, current status, future prospects. Pneumologie. 2010;64(9):555-559. Exclusion code: 6. [pmid: 20827638].
Gohagan JK, Prorok PC, Hayes RB, Kramer BS, Prostate LC, Ovarian Cancer Screening Trial Project T. The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute: history, organization, and status. Control. Clin. Trials. 2000;21(6 Suppl):251S-272S. Exclusion code: 2. [pmid: 11189683].
Gohagan JK, Prorok PC, Kramer BS, Cornett JE. Prostate cancer screening in the prostate, lung, colorectal and ovarian cancer screening trial of the National Cancer Institute. The Journal of urology. 1994;152(5 Pt 2):1905-1909. Exclusion code: 5. [pmid: 7523735].
Gohagan JK, Prorok PC, Kramer BS, Hayes RB, Cornett JE. The prostate, lung, colorectal, and ovarian cancer screening trial of the National Cancer Institute. Cancer. 1995;75(7 SUPPL.):1869-1873. Exclusion code: 5.
Goldberg KB. NCI Lung Cancer Screening Trial: The Cancer Letter. 2002. Exclusion code: 5.
Goldin JG, Brown MS, Petkovska I. Computer-aided diagnosis in lung nodule assessment. J. Thorac. Imaging. 2008;23(2):97-104. Exclusion code: 4. [pmid: 18520567].
Goldstraw P, Ball D, Jett JR, et al. Non-small-cell lung cancer. The Lancet. 2011;378(9804):1727-1740. Exclusion code: 5. [pmid: 21565398].
Goldwasser DL, Kimmel M. Modeling excess lung cancer risk among screened arm participants in the Mayo Lung Project. Cancer. 2010;116(1):122-131. Exclusion code: 5. [pmid: 19918924].
Gomez M, Silvestri GA. Lung cancer screening. Am. J. Med. Sci. 2008;335(1):46-50. Exclusion code: 2. [pmid: 18195583].
Gomez SL, Chang ET, Shema SJ, et al. Survival following non-small cell lung cancer among Asian/Pacific Islander, Latina, and Non-Hispanic white women who have never smoked. Cancer Epidemiol. Biomarkers Prev. 2011;20(3):545-554. Exclusion code: 3. [pmid: 21239685].
Gomi S, Muramatsu Y, Tsukagoshi S, et al. Low-dose CT screening for lung cancer with automatic exposure control: phantom study. Radiol Phys Technol. 2008;1(2):244-250. Exclusion code: 7. [pmid: 20821155].
Goo JM, Lee JW, Lee HJ, Kim S, Kim JH, Im JG. Automated lung nodule detection at low-dose CT: preliminary experience. Korean Journal of Radiology. 2003;4(4):211-216. Exclusion code: 2. [pmid: 14726637].
Goodgame B, Viswanathan A, Zoole J, et al. Risk of recurrence of resected stage I non-small cell lung cancer in elderly patients as compared with younger patients. J Thorac Oncol. 2009;4(11):1370-1374. Exclusion code: 3. [pmid: 19692932].
Goodman PC. Computed tomography scanning for lung cancer screening: an update. Int. J. Tuberc. Lung Dis. 2010;14(7):789-791. Exclusion code: 5. [pmid: 20550758].
Goodney P, Lucas F, Stuke T, Birkmeyer J. Surgeon Specialty and Operative Mortality With Lung Resection. Ann. Surg. 2005;241(1):179-184. Exclusion code: 2. [pmid: 15622006].
Gopal A, Budoff MJ. Computed tomography screening for lung cancer. JAMA. 2007;298(5):513. author reply 515-516. Exclusion code: 2. [pmid: 17666668].
Gopal M, Abdullah SE, Grady JJ, Goodwin JS. Screening for lung cancer with low-dose computed tomography: a systematic review and meta-analysis of the baseline findings of randomized controlled trials. J Thorac Oncol. 2010;5(8):1233-1239. Exclusion code: 2. [pmid: 20548246].
Gorenstein LA, Sonett JR. The Surgical Management of Stage I and Stage II Lung Cancer. Surg. Oncol. Clin. N. Am. 2011;20(4):701-720. Exclusion code: 5. [pmid: 21986267].
Gori I, F ME, Martinez AP. An automated system for lung nodule detection in low-dose computed tomography. Paper presented at: Computer-Aided Diagnosis2007. San Diego, CA. Exclusion code: 4.
Gorlova OY, Amos C, Henschke C, et al. Genetic susceptibility for lung cancer: interactions with gender and smoking history and impact on early detection policies. Hum. Hered. 2003;56(1-3):139-145. Exclusion code: 4. [pmid: 14614248].
Gossot D, Girard P, Raynaud C, et al. Totally endoscopic major pulmonary resection for stage I bronchial carcinoma: initial results. Rev. Mal. Respir. 2009;26(9):961-970. Exclusion code: 6. [pmid: 19953042].
Gossot D, Girard P, Raynaud C, et al. Fully endoscopic major pulmonary resection for stage I bronchial carcinoma: initial results. Rev. Mal. Respir. 2011;28(9):e123-130. Exclusion code: 10. [pmid: 22123151].
Goulart BHL, Bensink ME, Mummy DG, Ramsey SD. Lung cancer screening with low-dose computed tomography: costs, national expenditures, and cost-effectiveness. Journal of the National Comprehensive Cancer Network. 2012;10(2):267-275. Exclusion code: 7. [pmid: 22308519].
Gould MK. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):743. author reply 746-747. Exclusion code: 5. [pmid: 17301309].
Gould MK. Evaluation of screening-detected lung nodules: minimising the risk of unnecessary biopsy and surgery. Thorax. 2011;66(4):277-279. Exclusion code: 2. [pmid: 21357585].
Gralow J, Ozols RF, Bajorin DF, et al. Clinical cancer advances 2007: major research advances in cancer treatment, prevention, and screening--a report from the American Society of Clinical Oncology. [Erratum appears in J Clin Oncol. 2008 Mar 10;26(8):1394]. J. Clin. Oncol. 2008;26(2):313-325. Exclusion code: 5. [pmid: 18086794].
Granat P. Lung cancer screening. JAMA. 2001;285(2):163. author reply 163-164. Exclusion code: 5. [pmid: 11176796].
Granell E, Hidalgo A, Martínez A, et al. Evaluation of the quick diagnosis and treatment program for lung cancer. Evaluación del programa de diagnóstico y tratamiento rápido del cáncer de pulmón. 2009;51(3):294-299. Exclusion code: 4. [pmid: 19286231].
Grannis FW. Overestimation of lung cancer mortality in a computed tomography-screened population. J. Clin. Oncol. 2005;23(10):2439-2440. author reply 2440-2431. Exclusion code: 5. [pmid: 15800348].
Grannis FW Jr. There are major problems with the American College of Chest Physicians Second Lung Cancer Guidelines. Chest. 2008;133(4):1049. author reply 1050-1041. Exclusion code: 5. [pmid: 18398132].
Gray SW, Landrum MB, Lamont EB, McNeil BJ, Jaklitsch MT, Keating NL. Improved outcomes associated with higher surgery rates for older patients with early stage nonsmall cell lung cancer. Cancer. 2012;118(5):1404-1411. Exclusion code: 3. [pmid: 21800285].
Green PM, Davis MA. Lung cancer in African-Americans. J. Natl. Black Nurses Assoc. 2004;15(2):54-60. Exclusion code: 5. [pmid: 15853287].
Greenberg AK, Rimal B, Felner K, et al. S-adenosylmethionine as a biomarker for the early detection of lung cancer. Chest. 2007;132(4):1247-1252. Exclusion code: 5. [pmid: 17934114].
Greenwald HP, Polissar NL, Borgatta EF, McCorkle R, Goodman G. Social factors, treatment, and survival in early-stage non-small cell lung cancer. Am. J. Public Health. 1998;88(11):1681-1684. Exclusion code: 5. [pmid: 9807536].
Gren L, Broski K, Childs J, et al. Recruitment methods employed in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Clinical Trials. 2009;6(1):52-59. Exclusion code: 2. [pmid: 19254935].
Gridelli C, Rossi A, Maione P. 2010 Consensus on Lung Cancer, new clinical recommendations and current status of biomarker assessment--first-line therapy. Eur. J. Cancer. Suppl 3. 2011;47:S248-257. Exclusion code: 2. [pmid: 21943982].
Grogan EL, Stukenborg GJ, Nagji AS, et al. Radiotracer-Guided Thoracoscopic Resection is a Cost-Effective Technique for the Evaluation of Subcentimeter Pulmonary Nodules. Ann. Thorac. Surg. 2008;86(3):934-940. Exclusion code: 4. [pmid: 18721586].
Groth SS, Rueth NM, Hodges JS, et al. Conditional cancer-specific versus cardiovascular-specific survival after lobectomy for stage I non-small cell lung cancer. Ann. Thorac. Surg. 2010;90(2):375-382. Exclusion code: 7. [pmid: 20667314].
Guessous I, Cornuz J, Paccaud F. Lung cancer screening: current situation and perspective. Swiss Med Wkly. 2007;137(21-22):304-311. Exclusion code: 5. [pmid: 17629808].
Guntheroth WG. The cost benefits of early detection. Science. 2008;321(5889):639. Exclusion code: 5. [pmid: 18669840].
Gupta KB, Tandon S, Tandon M. Screening of early detection of lung cancer. Indian J. Chest Dis. Allied Sci. 2002;44(3):177-181. Exclusion code: 5. [pmid: 12206477].
Gur D. Lung cancer screening: radiology's opportunity here and now. Radiology. 2006;238(2):395-397. Exclusion code: 5. [pmid: 16436806].
Gutz S. Chemotherapy in cancer of the lung. MMW Fortschr Med. 2006;148(22):33-34. Exclusion code: 6. [pmid: 16821578].
Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction—GRADE evidence profiles and summary of findings tables. J. Clin. Epidemiol. 2011;64(4):383-394. Exclusion code: 2. [pmid: 21195583].
Haas JS, Earle CC, Orav JE, Brawarsky P, Neville BA, Williams DR. Racial segregation and disparities in cancer stage for seniors. J. Gen. Intern. Med. 2008;23(5):699-705. Exclusion code: 5. [pmid: 18338215].
Hakama M. Screening for lung cancer. J. Clin. Oncol. 2002;20(18):3931. author reply 3931-3934. Exclusion code: 5. [pmid: 12228216].
Hakama M, Chamberlain J, Day NE, Miller AB, Prorok PC. Evaluation of screening programmes for gynaecological cancer. Br. J. Cancer. 1985;52(4):669-673. Exclusion code: 8. [pmid: 4063143].
Hall EJ, Brenner DJ. Cancer risks from diagnostic radiology. Br. J. Radiol. 2008;81(965):362-378. Exclusion code: 5. [pmid: 18440940].
Hall WB, Truitt SG, Scheunemann LP, et al. The prevalence of clinically relevant incidental findings on chest computed tomographic angiograms ordered to diagnose pulmonary embolism. Arch. Intern. Med. 2009;169(21):1961-1965. Exclusion code: 3. [pmid: 19933956].
Haller MA, Moreau L. Screening, prevention, and tobacco. Rev. Pneumol. Clin. Suppl 3. 2000:4-6. Exclusion code: 6. [pmid: 11280979].
Halmos B, Powell CA. Update in lung cancer and oncological disorders 2010. Am. J. Respir. Crit. Care Med. 2011;184(3):297-302. Exclusion code: 5. [pmid: 21804121].
Halpern MT, Gillespie BW, Warner KE. Patterns of absolute risk of lung cancer mortality in former smokers. J. Natl. Cancer Inst. 1993;85(6):457-464. Exclusion code: 2. [pmid: 8445673].
Hamatake D, Miyahara S, Yoshida Y, et al. Surgical management for lung cancer in less than 1 cm. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2012;65(1):25-28. Exclusion code: 6. [pmid: 22314153].
Hammerschmidt S. Early diagnosis of lung cancer: where do we stand?. MMW Fortschr Med. 30. 2006;148(22):28-21. Exclusion code: 6. [pmid: 16821577].
Hampton T. New screening techniques show potential for early detection of lung cancer. JAMA. 2007;298(17):1997. Exclusion code: 5. [pmid: 17986689].
Han KQ, Huang G, Gao CF, et al. Identification of lung cancer patients by serum protein profiling using surface-enhanced laser desorption/ionization time-of-flight mass spectrometry. Am. J. Clin. Oncol. 2008;31(2):133-139. Exclusion code: 4. [pmid: 18391596].
Hanagiri T, Sugio K, Mizukami M, et al. Postoperative prognosis in patients with non-small cell lung cancer according to the method of initial detection. J Thorac Oncol. 2007;2(10):907-911. Exclusion code: 2. [pmid: 17909352].
Hanaoka T, Sone S, Takayama F, Hayano T, Yamaguchi S, Okada M. Presence of local pleural adhesion in CT screening-detected small nodule in the lung periphery suggests noncancerous, inflammatory nature of the lesion. Clin. Imaging. 2007;31(6):385-389. Exclusion code: 3. [pmid: 17996600].
Hanibuchi M, Yano S, Nishioka Y, et al. Autofluorescence bronchoscopy, a novel modality for the early detection of bronchial premalignant and malignant lesions. J. Med. Invest. 2007;54(3-4):261-266. Exclusion code: 4. [pmid: 17878675].
Hara Y, Matsuura Y, Takiguchi H, et al. Reversal of pulmonary hypertrophic osteoarthropathy in surgically treated lung cancer. Nihon Kokyuki Gakkai Zasshi. 2010;48(12):966-971. Exclusion code: 6. [pmid: 21226306].
Harpole DH Jr., DeCamp MM Jr., Daley J, et al. Prognostic models of thirty-day mortality and morbidity after major pulmonary resection. J. Thorac. Cardiovasc. Surg. 1999;117(5):969-979. Exclusion code: 8. [pmid: 10220692].
Hartman TE, Swensen SJ. Lung cancer screening with low-dose computed tomography. Semin. Roentgenol. 2003;38(1):34-38. Exclusion code: 5. [pmid: 12698589].
Hartman TE, Swensen SJ. CT screening for lung cancer. Semin. Roentgenol. 2005;40(2):193-196. Exclusion code: 5. [pmid: 15898415].
Hasegawa M, Sone S, Takashima S, et al. Growth rate of small lung cancers detected on mass CT screening. Br. J. Radiol. 2000;73(876):1252-1259. Exclusion code: 4. [pmid: 11205667].
Hashimoto M, Miyauchi T, Heianna J, et al. Accurate diagnosis of peripheral small cell lung cancer with computed tomography. Tohoku J. Exp. Med. 2009;217(3):217-221. Exclusion code: 7. [pmid: 19282657].
Haskell CM, Holmes EC. Non-small cell lung cancer. Dis. Mon. 1988;34(2):53-108. Exclusion code: 5. [pmid: 2834155].
Hatayama O, Kobayashi T, Fujimoto K, Kubo K. Utility of single-slice high-resolution CT in upper lung field combined with low-dose spiral CT for lung-cancer screening in the detection of emphysema. Intern. Med. 2007;46(18):1519-1525. Exclusion code: 4. [pmid: 17878637].
Haussinger K, Becker H, Stanzel F, et al. Autofluorescence bronchoscopy with white light bronchoscopy compared with white light bronchoscopy alone for the detection of precancerous lesions: a European randomised controlled multicentre trial. Thorax. 2005;60(6):496-503. Exclusion code: 7. [pmid: 15923251].
Hayashi H, Ashizawa K, Uetani M, et al. Detectability of peripheral lung cancer on chest radiographs: effect of the size, location and extent of ground-glass opacity. Br. J. Radiol. 2009;82(976):272-278. Exclusion code: 4. [pmid: 19029222].
Hayashi Y, Tomiyama I, Ishii H, et al. Prognostic assessment of the new UICC TNM classification for resected lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(11):919-925. Exclusion code: 6. [pmid: 11048442].
Hayes RB, Reding D, Kopp W, et al. Etiologic and early marker studies in the prostate, lung, colorectal and ovarian (PLCO) cancer screening trial. Control. Clin. Trials. 2000;21(6 Suppl):349S-355S. Exclusion code: 2. [pmid: 11189687].
Hazelrigg SR, Boley TM, Weber D, Magee MJ, Naunheim KS. Incidence of lung nodules found in patients undergoing lung volume reduction. Ann. Thorac. Cardiovasc. Surg. 1997;64(2):303-306. Exclusion code: 4. [pmid: 9262565].
He J, Shao W, Cao C, et al. Long-term outcome and cost-effectiveness of complete versus assisted video-assisted thoracic surgery for non-small cell lung cancer. J. Surg. Oncol. 2011;104(2):162-168. Exclusion code: 7. [pmid: 21387321].
He T, Xue Z, Wong KK, et al. A minimally invasive multimodality image-guided (MIMIG) molecular imaging system for peripheral lung cancer intervention and diagnosis. LNCS. 2010;6135:102-112. Exclusion code: 4.
Heelan RT, Flehinger BJ, Melamed MR, Zaman MB, Perchick WB, Caravelli JF. Non-small-cell lung cancer: results of the New York screening program. Radiology. 1984;151(2):289-293. Exclusion code: 5. [pmid: 6324279].
Heigener DF, Reck M, Gatzemeier U. Non-small cell lung cancer - diagnostics and stage-adapted therapy. Med. Klin. 2007;102(12):981-988. quiz 989-990. Exclusion code: 6. [pmid: 18075718].
Henderson S, DeGroff A, Richards TB, et al. A qualitative analysis of lung cancer screening practices by primary care physicians. J. Community Health. 2011;36(6):949-956. Exclusion code: 5. [pmid: 21442338].
Hennessey PT, Sanford T, Choudhary A, et al. Serum microrna biomarkers for detection of non-small cell lung cancer. PLoS ONE. 2012;7(2). Exclusion code: 2. [pmid: 22389695].
Henschke. Computed tomographic screening for lung cancer: individualising the benefit of the screening. Eur. Respir. J. 2007;30(5):843-847. Exclusion code: 2. [pmid: 17652316].
Henschke C. International Early Lung Cancer Action Program: Enrollment and Screening Protocol. 2011. http://www.ielcap.org/professionals/docs/ielcap.pdf. 18 Oct 2011. Exclusion code: 2.
Henschke C, McCauley D, Yankelevitz D, Naidich DP, McGuinness G, Miettinen OS. Early Lung Cancer Action Project: overall design and findings from baseline screening. Lancet. 1999;354(9173):99-105. Exclusion code: 8. [pmid: 10408484].
Henschke C, Smith JP, Miettinen OS. CT screening for lung cancer-author's response. N. Engl. J. Med. 2007;356(7):746-747. Exclusion code: 2.
Henschke C, Wisnivesky JP, Yankelevitz D, Miettinen OS. Screen-diagnosed small stage I cancers of the lung: genuineness and curability. Lung Cancer. 2003;39(3):327-330. Exclusion code: 3. [pmid: 12609571].
Henschke CI. Early lung cancer action project: overall design and findings from baseline screening. Cancer. 2000;89(11 Suppl):2474-2482. Exclusion code: 5. [pmid: 11147630].
Henschke CI. Medicine on lung cancer screening: a different paradigm. [Erratum appears in Am J Respir Crit Care Med. 2008 Sep 1;178(5):542]. Am. J. Respir. Crit. Care Med. 2003;168(10):1143-1144. Exclusion code: 5. [pmid: 14607819].
Henschke CI. Computed tomography screening for lung cancer: principles and results. Clin. Cancer Res. 2005;11(13 Pt 2):4984s-4987s. Exclusion code: 5. [pmid: 16000600].
Henschke CI. Clarifying enrollment procedures in the trial of CT screening for lung cancer. N. Engl. J. Med. 2008;359(8):871-873. Exclusion code: 5. [pmid: 18669421].
Henschke CI. Reply to the letters to the editor from Bach and Silvestri. Clin. Cancer Res. 2008;14(8):2511. Exclusion code: 5.
Henschke CI. Correspondence. J. Natl. Cancer Inst. 2012;104(3):254-255. Exclusion code: 5. [pmid: 22275408].
Henschke CI, Austin JHM, Berlin N, et al. Minority opinion: CT screening for lung cancer. J. Thorac. Imaging. 2005;20(4):324-325. Exclusion code: 2. [pmid: 16282919].
Henschke CI, Investigators for the International Early Lung Cancer Action Program. Survival of patients with clinical stage I lung cancer diagnosed by computed tomography screening for lung cancer. Clin. Cancer Res. 2006;13(17):4949-4950. Exclusion code: 2. [pmid: 17785541].
Henschke CI, Investigators IE. CT screening for lung cancer: update 2005. Surg. Oncol. Clin. N. Am. 2005;14(4):761-776. Exclusion code: 5. [pmid: 16226690].
Henschke CI, Lee IJ, Wu N, et al. CT screening for lung cancer: prevalence and incidence of mediastinal masses. Radiology. 2006;239(2):586-590. Exclusion code: 4. [pmid: 16641357].
Henschke CI, McCauley DI, Yankelevitz DF, et al. Early lung cancer action project: a summary of the findings on baseline screening. Oncologist. 2001;6(2):147-152. Exclusion code: 5. [pmid: 11306726].
Henschke CI, Miettinen OS. Women's susceptibility to tobacco carcinogens. Lung Cancer. 2004;43(1):1-5. Exclusion code: 2. [pmid: 14698531].
Henschke CI, Miettinen OS, Yankelevitz DF, Libby DM, Smith JP. Radiographic screening for cancer: Proposed paradigm for requisite search. Clin. Imaging. 1994;18(1):16-20. Exclusion code: 5. [pmid: 8180854].
Henschke CI, Naidich DP, Yankelevitz DF, et al. Early lung cancer action project: initial findings on repeat screening. Cancer. 2001;92(1):153-159. Exclusion code: 2. [pmid: 11443621].
Henschke CI, Shaham D, Farooqi A, Yankelevitz DF. Computerized tomography screening for lung cancer: new findings and diagnostic work-up. Semin. Thorac. Cardiovasc. Surg. 2003;15(4):397-404. Exclusion code: 5. [pmid: 14710382].
Henschke CI, Shaham D, Yankelevitz DF, Altorki NK. CT screening for lung cancer: past and ongoing studies. Semin. Thorac. Cardiovasc. Surg. 2005;17(2):99-106. Exclusion code: 5. [pmid: 16087075].
Henschke CI, Shaham D, Yankelevitz DF, et al. CT screening for lung cancer: significance of diagnoses in its baseline cycle. Clin. Imaging. 2006;30(1):11-15. Exclusion code: 2. [pmid: 16377478].
Henschke CI, Yankelevitz D, Smith JP, Miettinen OS. Computed tomography screening for lung cancer. [Erratum appears in JAMA.2008 Apr 16;299(15):1775]. JAMA. 2007;298(5):514-515. author reply 515-516. Exclusion code: 5. [pmid: 17666669].
Henschke CI, Yankelevitz DF. CT screening for lung cancer. Radiol. Clin. North Am. 2000;38(3):487-495. viii. Exclusion code: 2. [pmid: 10855256].
Henschke CI, Yankelevitz DF. Screening for lung cancer. J. Thorac. Imaging. 2000;15(1):21-27. Exclusion code: 2. [pmid: 10634658].
Henschke CI, Yankelevitz DF. CT screening for lung cancer: update 2007. Oncologist. 2008;13(1):65-78. Exclusion code: 5. [pmid: 18245013].
Henschke CI, Yankelevitz DF. In reply. Oncologist. 2008;13(5):610-612. Exclusion code: 5.
Henschke CI, Yankelevitz DF. Unreported financial disclosures. JAMA - Journal of the American Medical Association. 2008;299(15):1770. Exclusion code: 5. [pmid: 18362124].
Henschke CI, Yankelevitz DF, Altorki NK. The role of CT screening for lung cancer. Thorac Surg Clin. 2007;17(2):137-142. Exclusion code: 5. [pmid: 17626392].
Henschke CI, Yankelevitz DF, Kostis WJ. CT screening for lung cancer. Semin. Ultrasound. CT MR. 2003;24(1):23-32. Exclusion code: 5. [pmid: 12708641].
Henschke CI, Yankelevitz DF, Libby D, Kimmel M. CT screening for lung cancer: the first ten years. Cancer J. Suppl 1. 2002;8:S47-54. Exclusion code: 5. [pmid: 12075702].
Henschke CI, Yankelevitz DF, Libby D, McCauley D, Pasmantier M, Smith JP. Computed tomography screening for lung cancer. Clin. Chest Med. 2002;23(1):49-57. viii. Exclusion code: 5. [pmid: 11901919].
Henschke CI, Yankelevitz DF, Libby DM, et al. Early lung cancer action project: annual screening using single-slice helical CT. Ann. N. Y. Acad. Sci. 2001;952:124-134. Exclusion code: 5. [pmid: 11795431].
Henschke CI, Yankelevitz DF, McCauley D, Libby D, Pasmantier M, Smith JP. CT screening for lung cancer. Cancer Chemotherapy & Biological Response Modifiers. 2002;20:665-676. Exclusion code: 2. [pmid: 12703229].
Henschke CI, Yankelevitz DF, McCauley DI, Libby DM, Pasmantier MW, Smith JP. Guidelines for the use of spiral computed tomography in screening for lung cancer. European Respiratory Journal - Supplement. 2003;39:45s-51s. Exclusion code: 5. [pmid: 12572701].
Henschke CI, Yankelevitz DF, Miettinen OS, International Early Lung Cancer Action Program I. Computed tomographic screening for lung cancer: the relationship of disease stage to tumor size. Arch. Intern. Med. 2006;166(3):321-325. Exclusion code: 8. [pmid: 16476872].
Henschke CI, Yankelevitz DF, Mirtcheva R, et al. CT screening for lung cancer: frequency and significance of part-solid and nonsolid nodules. AJR. Am. J. Roentgenol. 2002;178(5):1053-1057. Exclusion code: 7. [pmid: 11959700].
Henschke CI, Yankelevitz DF, Naidich DP, et al. CT screening for lung cancer: suspiciousness of nodules according to size on baseline scans. Radiology. 2004;231(1):164-168. Exclusion code: 4. [pmid: 14990809].
Henschke CI, Yankelevitz DF, Smith JP, Miettinen OS. The use of spiral CT in lung cancer screening. DeVita VT, Hellman S, Rosenberg SA, editors. Progress in Oncology 2002. Sudbury. Jones and Barlett. 2002:202-213. Exclusion code: 2.
Henschke CI, Yankelevitz DF, Smith JP, Miettinen OS, Group E. Screening for lung cancer: the early lung cancer action approach. Lung Cancer. 2002;35(2):143-148. Exclusion code: 2. [pmid: 11804686].
Henschke CI, Yankelevitz DF, Yip R, et al. Lung cancers diagnosed at annual CT screening: volume doubling times. Radiology. 2012;263(2):578-583. Exclusion code: 2. [pmid: 22454506].
Henschke CI, Yip R, Yankelevitz DF. CT screening for lung cancer: Update 2008. Japanese Journal of Lung Cancer. 2009;49(4):477-490. Exclusion code: 2.
Henschke CI, Yip R, Yankelevitz DF, Miettinen OS. Computed tomography screening for lung cancer: prospects of surviving competing causes of death. Clin Lung Cancer. 2006;7(5):323-325. Exclusion code: 7. [pmid: 16640803].
Herth F, Becker HD. New aspects in early detection and local staging of early lung cancer. Lung Cancer. Suppl 3. 2001;34:S7-11. Exclusion code: 5. [pmid: 11740987].
Herth FJ, Eberhardt R. Screening for bronchial carcinoma -- contra. Dtsch. Med. Wochenschr. 2005;130(9):467. Exclusion code: 6. [pmid: 15731961].
Herth FJF, Eberhardt R, Anantham D, Gompelmann D, Zakaria MW, Ernst A. Narrow-band imaging bronchoscopy increases the specificity of bronchoscopic early lung cancer detection. J Thorac Oncol. 2009;4(9):1060-1065. Exclusion code: 2. [pmid: 19704335].
Heuberger J, Schneider K, Bodis S. Role of radiotherapy in non-small cell lung cancer. Praxis. 2002;91(33):1307-1314. Exclusion code: 6. [pmid: 12224413].
Heuvers ME, Stricker BH, Aerts JG. Generalizing lung-cancer screening results. N. Engl. J. Med. 2012;366(2):192-193. Exclusion code: 5. [pmid: 22236243].
Heyneman LE, Herndon JE, Goodman PC, Patz EF Jr. Stage distribution in patients with a small (< or = 3 cm) primary nonsmall cell lung carcinoma. Implication for lung carcinoma screening. Cancer. 2001;92(12):3051-3055. Exclusion code: 4. [pmid: 11753983].
Higgins J, Thompson S, Higgins J. Quatifying heterogeneity in a meta-analysis. Stat. Med. 2002;21(11):1539-1558. Exclusion code: 2. [pmid: 12111919].
Hilbe W, Dirnhofer S, Greil R, Woll E. Biomarkers in non-small cell lung cancer prevention. Eur. J. Cancer Prev. 2004;13(5):425-436. Exclusion code: 5. [pmid: 15452456].
Hillerdal G. Indolent lung cancers--time for a paradigm shift: a review. J Thorac Oncol. 2008;3(3):208-211. Exclusion code: 5. [pmid: 18317061].
Hillerdal G, Henschke C, Sone S. Screening for lung cancer--new possibilities with new methods!. Lakartidningen. 2001;98(17):2047-2051. Exclusion code: 6. [pmid: 11374234].
Hillerdal G, Koyi H, Branden E. Smoking cessation or lung cancer screening--an artificial antagonism. Lakartidningen. 2001;98(32-33):3453. Exclusion code: 6. [pmid: 11526671].
Hillman BJ. Author's Reply. JACR Journal of the American College of Radiology. 2007;4(6):430. Exclusion code: 5.
Hillman BJ, Acrin. Economic, legal, and ethical rationales for the ACRIN national lung screening trial of CT screening for lung cancer. Acad. Radiol. 2003;10(3):349-350. Exclusion code: 2. [pmid: 12643562].
Hinshaw LB, Jackson SA, Chen MY. Direct mailing was a successful recruitment strategy for a lung-cancer screening trial. J. Clin. Epidemiol. 2007;60(8):853-857. Exclusion code: 5. [pmid: 17606183].
Hirokawa R, Fujino S, Inoue S, et al. Squamous cell type lung cancer that produced granulocyte colony-stimulating factor. Nihon Kokyuki Gakkai Zasshi. 2000;38(5):398-402. Exclusion code: 6. [pmid: 10921288].
Hirsch FR, Franklin WA, Gazdar AF, Bunn PA Jr. Early detection of lung cancer: clinical perspectives of recent advances in biology and radiology. Clin. Cancer Res. 2001;7(1):5-22. Exclusion code: 5. [pmid: 11205917].
Hirsch FR, Merrick DT, Franklin WA. Role of biomarkers for early detection of lung cancer and chemoprevention. Eur. Respir. J. 2002;19(6):1151-1158. Exclusion code: 2. [pmid: 12108871].
Hirsch FR, Prindiville SA, Miller YE, et al. Fluorescence versus white-light bronchoscopy for detection of preneoplastic lesions: a randomized study. J. Natl. Cancer Inst. 2001;93(18):1385-1391. Exclusion code: 4. [pmid: 11562389].
Hirschowitz EA. Biomarkers for lung cancer screening: interpretation and implications of an early negative advanced validation study. Am. J. Respir. Crit. Care Med. 2009;179(1):1-2. Exclusion code: 5. [pmid: 19098155].
Hjelde H, Sundstrom S, Odegard A, Hatlinghus S, Abusland AB, Haaverstad R. Recurrence and survival after surgical treatment of lung cancer. Tidsskr. Nor. Laegeforen. 2010;130(1):25-28. Exclusion code: 6. [pmid: 20094119].
Hoagland ILFM, Campa MJ, Gottlin EB, Herndon Ii JE, Patz EF Jr. Haptoglobin and posttranslational glycan-modified derivatives as serum biomarkers for the diagnosis of nonsmall cell lung cancer. Cancer. 2007;110(10):2260-2268. Exclusion code: 4. [pmid: 17918261].
Hof H, Herfarth K, Debus J. Stereotactic irradiation of lung tumors. Radiologe. 2004;44(5):484-490. Exclusion code: 6. [pmid: 15107979].
Hoff G, Thiis-Evensen E, Grotmol T, Sauar J, Vatn MH, Moen IE. Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983-1996. Eur. J. Cancer Prev. 2001;10(2):131-137. Exclusion code: 4. [pmid: 11330453].
Hole D, Watt G, Davey-Smith G, Hart C, Gillis C, Hawthorne VM. Impaired lung function and mortality risk in men and women: findings from the Renfrew and Paisley prospective population study. BMJ. 1996;313(7059):711-715. Exclusion code: 7. [pmid: 8819439].
Holemans JA. Comments on Diederich et al.: low dose CT: new tool for screening lung cancer. Eur. Radiol. 2002;12(8):2123. author reply 2124. Exclusion code: 5. [pmid: 12211180].
Hollaus PH, Wurnig PN, Pridun NS. Bronchoplastic procedures for the resection of malignant bronchial neoplasms. Chirurg. 2002;73(11):1115-1122. Exclusion code: 6. [pmid: 12430063].
Hollingsworth AB, Stough RG. Breast MRI Screening for High-Risk Patients. Seminars in Breast Disease. 2008;11(2):67-75. Exclusion code: 3.
Hooi LN, Hamzah KM, Jahizah H. Survival of patients surgically treated for lung cancer. Med. J. Malaysia. 2003;58(4):490-498. Exclusion code: 10. [pmid: 15190623].
Horinouchi H, Kobayashi K. Surgical indications for lung cancer: influence of the M factor. Nippon Geka Gakkai Zasshi. 2001;102(7):517-520. Exclusion code: 6. [pmid: 11505503].
Horinouchi H, Yamamoto M, Goto T, et al. Clinical analysis of surgically resected multiple primary lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2002;55(1):45-50. Exclusion code: 6. [pmid: 11797409].
Hoshi K, Kanbara T, Kawasaki Y, Ikeda Y, Namima T, Ohnuma T. Pulmonary and lymph node metastases of renal cell carcinoma which completely responded to oral administration of UFT--a case report. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2007;34(8):1315-1317. Exclusion code: 6. [pmid: 17687222].
Hosokawa Y, Matsuge S, Murakami Y, et al. Validity and controversies in the new postoperative pathologic TNM classification based on the results of surgical treatment of non-small cell lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(11):910-914. Exclusion code: 6. [pmid: 11048440].
Hourani MH, Nassar L, Haydar M, Hourany-Rizk RG. Imaging in oncology. Journal Medical Libanais. 2009;57(3):156-166. Exclusion code: 5. [pmid: 19938400].
Howlader N, Noone A, Krapcho M, et al. SEER Cancer Statistics Review 1975 - 2008. Bethesda, MD. 2011. Exclusion code: 2.
Howlader N, Noone AM, Krapcho M, et al. SEER Cancer Statistics Review, 1975-2009 (Vintage 2009 Populations). 2011. http://seer.cancer.gov/csr/1975_2009_pops09/. Exclusion code: 2.
Hsu YB, Chu PY, Liu JC, et al. Role of chest computed tomography in head and neck cancer. Arch. Otolaryngol. Head Neck Surg. 2008;134(10):1050-1054. Exclusion code: 4. [pmid: 18936349].
Huang H, Shen L, Ford J, Gao L, Pearlman J. Early lung cancer detection based on registered perfusion MRI. Oncol. Rep. 2006;15 Spec no.:1081-1084. Exclusion code: 7. [pmid: 16525705].
Huang Js, Dong Qg, Bao Gl, Han Bh. Implication of micrometastatic cancer cells in the peripheral blood on prognosis of non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2004;26(5):294-296. Exclusion code: 6. [pmid: 15312367].
Huang Y, Shaham D, Austin JHM, Yankelevitz DF, Henschke CI, Investigators IE. Pulmonary lymphoma identified as a result of low-dose CT screening for lung cancer. Clin. Imaging. 2008;32(4):264-268. Exclusion code: 2. [pmid: 18603180].
Hubbard RB, Baldwin DR. Diagnosing lung cancer earlier in the UK. Thorax. 2010;65(9):756-758. Exclusion code: 5. [pmid: 20805161].
Huber RM, Stratakis DF. Molecular oncology--perspectives in lung cancer. Lung Cancer. Suppl 2. 2004;45:S209-213. Exclusion code: 5. [pmid: 15552801].
Humphrey L, Helfand M, Chan BK, W SH. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann. Intern. Med. 2002;137(5 Part 1):347-360. Exclusion code: 2. [pmid: 12204020].
Humphrey LL, Teutsch S, Johnson M, Force USPST. Lung cancer screening with sputum cytologic examination, chest radiography, and computed tomography: an update for the U.S. Preventive Services Task Force. Ann. Intern. Med. 2004;140(9):740-753. Exclusion code: 2. [pmid: 15126259].
Hung JJ, Jeng WJ, Hsu WH, Huang BS, Wu YC. Time trends of overall survival and survival after recurrence in completely resected stage I non-small cell lung cancer. Journal of Thoracic Oncology. 2012;7(2):397-405. Exclusion code: 7. [pmid: 22173701].
Hung JJ, Wang CY, Huang MH, Huang BS, Hsu WH, Wu YC. Prognostic factors in resected stage I non-small cell lung cancer with a diameter of 3 cm or less: visceral pleural invasion did not influence overall and disease-free survival. J. Thorac. Cardiovasc. Surg. 2007;134(3):638-643. Exclusion code: 3. [pmid: 17723811].
Hunink MGM, Gazelle GS. CT screening: a trade-off of risks, benefits, and costs. J. Clin. Invest. 2003;111(11):1612-1619. Exclusion code: 5. [pmid: 12782661].
Hunt I, Siva M, Southon R, Treasure T. Does lung cancer screening with low-dose computerised tomography (LDCT) improve disease-free survival?. Interact Cardiovasc Thorac Surg. 2006;5:612-615. Exclusion code: 2. [pmid: 17670661].
Huppmann MV, Johnson WB, Javitt MC. Radiation risks from exposure to chest computed tomography. Semin. Ultrasound. CT MR. 2010;31(1):14-28. Exclusion code: 2. [pmid: 20102692].
Hutchinson E. Caution over use of lung-cancer screening as standard practice. Lancet. 2000;356(9231):742. Exclusion code: 5. [pmid: 11085700].
Huuskonen MS, Lehtola H, Kivisaari L. Early diagnosis of asbestos-related diseases by CT scanning. International Congress Series. 1997;1153:913-915. [PMID:. Exclusion code: 7.
Hwang J, Chung MJ, Bae Y, Shin KM, Jeong SY, Lee KS. Computer-aided detection of lung nodules: influence of the image reconstruction kernel for computer-aided detection performance. J. Comput. Assist. Tomogr. 2010;34(1):31-34. Exclusion code: 7. [pmid: 20118719].
Hwang SJ, Cheng LSC, Lozano G, Amos CI, Gu X, Strong LC. Lung cancer risk in germline p53 mutation carriers: association between an inherited cancer predisposition, cigarette smoking, and cancer risk. Hum. Genet. 2003;113(3):238-243. Exclusion code: 2. [pmid: 12802680].
Iaitskii NA, Gerasin VA, Orlov SV, et al. Photodynamic therapy in treatment of lung cancer. Vestnik Khirurgii Imeni i - i - Grekova. 2010;169(5):31-34. Exclusion code: 6. [pmid: 21137256].
Iakovou I, Karavida N, Kotzassarlidou M. The computerized tomography scans and their dosimetric safety. Hellenic J Nucl Med. 2008;11(2):82-85. Exclusion code: 5. [pmid: 18815660].
Ichinose J, Kohno T, Fujimori S. Video-assisted thoracic surgery for metachronous lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(11):969-972. Exclusion code: 6. [pmid: 20954352].
Ichinose J, Kohno T, Fujimori S, Mun M. Locoregional control of thoracoscopic lobectomy with selective lymphadenectomy for lung cancer. Ann. Thorac. Surg. 2010;90(1):235-239. Exclusion code: 4. [pmid: 20609783].
Ichinose Y. Postoperative adjuvant treatment for non-small cell lung cancer. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2002;29(13):2470-2474. Exclusion code: 6. [pmid: 12506468].
Ikeda N, Honda H, Hayashi A, et al. Early detection of bronchial lesions using newly developed videoendoscopy-based autofluorescence bronchoscopy. Lung Cancer. 2006;52(1):21-27. Exclusion code: 2. [pmid: 16497411].
Ilonen IK, Rasanen JV, Knuuttila A, Salo JA, Sihvo EI. Anatomic thoracoscopic lung resection for non-small cell lung cancer in stage I is associated with less morbidity and shorter hospitalization than thoracotomy. Acta Oncol. 2011;50(7):1126-1132. Exclusion code: 10. [pmid: 21314296].
Imdahl A, Jenkner S, Brink I, et al. Validation of FDG positron emission tomography for differentiation of unknown pulmonary lesions. Eur. J. Cardiothorac. Surg. 2001;20(2):324-329. Exclusion code: 4. [pmid: 11463551].
Infante M, Chiesa G, Solomon D, et al. Surgical procedures in the DANTE trial, a randomized study of lung cancer early detection with spiral computed tomography: comparative analysis in the screening and control arm. J Thorac Oncol. 2011;6(2):327-335. Exclusion code: 10. [pmid: 21178639].
Infante MV, Fabio LR, Cavuto S, et al. Dante a randomized study on lung cancer screening with low dose spiral CT (LDCT) end of accrual and preliminary results [Abstract]. Chest. 2006;130(4 Suppl):114s. Exclusion code: 5. [pmid: 12409588].
International Early Lung Cancer Program Investigators. An update of CT screening for lung cancer. Semin. Ultrasound. CT MR. 2005;26(5):348-356. Exclusion code: 5. [pmid: 16274003].
Isgum I, Rutten A, Prokop M, et al. Automated aortic calcium scoring on low-dose chest computed tomography. Med. Phys. 2010;37(2):714-723. Exclusion code: 2. [pmid: 20229881].
Ishikawa H, Satoh H, Yamashita YT, Ohtsuka M, Sekizawa K. CEA and survival in patients with stage IA-B NSCLC. Thorac. Cardiovasc. Surg. 2002;50(4):253. Exclusion code: 5. [pmid: 12165878].
Ishiyama T, Aoyama T, Hirahara H, Iwashima A, Tsukada H, Souma T. Successful resection of endotracheal metastatic lung cancer using percutaneous cardiopulmonary support system: a case report. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2001;54(1):19-23. Exclusion code: 6. [pmid: 11197904].
Itani Y, Sone S, Nakayama T, et al. Coronary artery calcification detected by a mobile helical computed tomography unit and future cardiovascular death: 4-year follow-up of 6120 asymptomatic Japanese. Heart Vessels. 2004;19(4):161-163. Exclusion code: 7. [pmid: 15278387].
Ito Y, Ohno Y, Rachet B, Coleman MP, Tsukuma H, Oshima A. Cancer survival trends in Osaka, Japan: the influence of age and stage at diagnosis. Jpn. J. Clin. Oncol. 2007;37(6):452-458. Exclusion code: 7. [pmid: 17635966].
Itoh S, Ikeda M, Isomura T, et al. Screening helical CT for mass screening of lung cancer: Application of low-dose and single-breath-hold scanning. Radiation Medicine - Medical Imaging and Radiation Oncology. 1998;16(2):75-83. Exclusion code: 10. [pmid: 9650893].
Itoh S, Koyama S, Ikeda M, et al. Further reduction of radiation dose in helical CT for lung cancer screening using small tube current and a newly designed filter. J. Thorac. Imaging. 2001;16(2):81-88. Exclusion code: 2. [pmid: 11292209].
Iwano S, Makino N, Ikeda M, et al. Videotaped helical CT images for lung cancer screening. J. Comput. Assist. Tomogr. 2000;24(2):242-246. Exclusion code: 2. [pmid: 10752885].
Iwazaki M, Inoue K. Multidisciplinary treatment of lung cancer: 2008. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(1):47-49. Exclusion code: 6. [pmid: 18186273].
Iyen-Omofoman B, Hubbard RB, Smith CJP, et al. The distribution of lung cancer across sectors of society in the United Kingdom: a study using national primary care data. BMC Public Health. 2011;11:857. Exclusion code: 7. [pmid: 22074413].
Jackevicius A, Cicenas S, Naujokaitis P, Piscikas D. The experience of surgical treatment of lung cancer during fifty years. Medicina (Kaunas). Suppl 1. 2004;40:124-126. Exclusion code: 6. [pmid: 15079119].
Jackevicius A, Cicenas S, Piscikas DA. The treatment of lung cancer relapse after the lung resection. Medicina (Kaunas). Suppl 1. 2004;40:139-141. Exclusion code: 6. [pmid: 15079123].
Jackson BR. The Dangers of False-Positive and False-Negative Test Results: False-Positive Results as a Function of Pretest Probability. Clin. Lab. Med. 2008;28(2):305-319. Exclusion code: 5. [pmid: 18436073].
Jacobs PC, Gondrie MJA, van der Graaf Y, et al. Coronary artery calcium can predict all-cause mortality and cardiovascular events on low-dose CT screening for lung cancer. AJR American Journal of Roentgenology. 2012;198(3):505-511. Exclusion code: 4. [pmid: 22357989].
Jacobs PCA, Isgum I, Gondrie MJA, et al. Coronary artery calcification scoring in low-dose ungated CT screening for lung cancer: interscan agreement. AJR. Am. J. Roentgenol. 2010;194(5):1244-1249. Exclusion code: 7. [pmid: 20410410].
Jacobs PCA, Mali WPTM, Grobbee DE, van der Graaf Y. Prevalence of incidental findings in computed tomographic screening of the chest: a systematic review. J. Comput. Assist. Tomogr. 2008;32(2):214-221. Exclusion code: 2. [pmid: 18379305].
Jacobson FL. Multidetector-row CT of lung cancer screening. Semin. Roentgenol. 2003;38(2):168-175. Exclusion code: 5. [pmid: 12854440].
Jacot W, Lhermitte L, Dossat N, et al. Serum proteomic profiling of lung cancer in high-risk groups and determination of clinical outcomes. J Thorac Oncol. 2008;3(8):840-850. Exclusion code: 2. [pmid: 18670301].
Jain P, Arroliga AC. Spiral CT for lung cancer screening: is it ready for prime time?. Cleve. Clin. J. Med. 2001;68(1):74-81. Exclusion code: 5. [pmid: 11204368].
Jaklitsch MT, Jacobson FL, Austin JHM, et al. The American Association for Thoracic Surgery guidelines for lung cancer screening using low-dose computed tomography scans for lung cancer survivors and other high-risk groups. J Thor Cardiovas Surg. 2012;144(1):33-38. Exclusion code: 2. [pmid: 22710039].
Jakupciak JP, Maragh S, Markowitz ME, et al. Performance of mitochondrial DNA mutations detecting early stage cancer. BMC Cancer. 2008;8:285. Exclusion code: 7. [pmid: 18834532].
Jankowski A, Martinelli T, Timsit JF, et al. Pulmonary nodule detection on MDCT images: evaluation of diagnostic performance using thin axial images, maximum intensity projections, and computer-assisted detection. Eur. Radiol. 2007;17(12):3148-3156. Exclusion code: 2. [pmid: 17763856].
Jassem J, Skokowski J, Dziadziuszko R, et al. Results of surgical treatment of non-small cell lung cancer: validation of the new postoperative pathologic TNM classification. J. Thorac. Cardiovasc. Surg. 2000;119(6):1141-1146. Exclusion code: 10. [pmid: 10838530].
Jazieh AR, Hussain M, Howington JA, et al. Prognostic factors in patients with surgically resected stages I and II non-small cell lung cancer. Ann. Thorac. Surg. 2000;70(4):1168-1171. Exclusion code: 3. [pmid: 11081863].
Jazieh AR, Kyasa MJ, Sethuraman G, Howington J. Disparities in surgical resection of early-stage non-small cell lung cancer. J. Thorac. Cardiovasc. Surg. 2002;123(6):1173-1176. Exclusion code: 5. [pmid: 12063465].
Jemal A, Thun MJ, Ries LAG, et al. Annual report to the nation on the status of cancer, 1975-2005, featuring trends in lung cancer, tobacco use, and tobacco control. J. Natl. Cancer Inst. 2008;100(23):1672-1694. Exclusion code: 5. [pmid: 19033571].
Jeremic B. Impact of comorbidity on survival after surgical resection in patients with stage I non-small cell lung cancer. J. Thorac. Cardiovasc. Surg. 2003;125(2):444-445. Exclusion code: 5. [pmid: 12579133].
Jett JR. Limitations of screening for lung cancer with low-dose spiral computed tomography. Clin. Cancer Res. 2005;11(13 Pt 2):4988s-4992s. Exclusion code: 2. [pmid: 16000601].
Jett JR, Midthun DE. Screening for lung cancer: current status and future directions: Thomas A. Neff lecture. Chest. 2004;125(5 Suppl):158S-162S. Exclusion code: 5. [pmid: 15136487].
Jett JR, Midthun DE. Commentary: CT screening for lung cancer--caveat emptor. Oncologist. 2008;13(4):439-444. Exclusion code: 2. [pmid: 18448559].
Jett JR, Miller YE. Update in lung cancer 2005. Am. J. Respir. Crit. Care Med. 2006;173(7):695-697. Exclusion code: 5. [pmid: 16556699].
Jiang T, Zheng X, Tao X, Liu H, Liu S. How to choose PET-CT or CT in the diagnosis and staging of lung cancer. Practical experience in China. Nucl. Med. (Stuttg). 2010;49(1):28-34. Exclusion code: 3. [pmid: 19847358].
Jiang Zq, Jiang Gl, Shi Dr, Zhang Rx, Fu Xl, Qian H. Study of prognostic factors in patients with stage I non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2004;26(6):364-368. Exclusion code: 6. [pmid: 15312349].
Jin SM, Choi SH, Yoo CG, et al. Small solid noncalcified pulmonary nodules detected by screening chest computed tomography. Respir. Med. 2007;101(9):1880-1884. Exclusion code: 2. [pmid: 17587561].
Johkoh T, Kozuka T, Tomiyama N, et al. Temporal subtraction for detection of solitary pulmonary nodules on chest radiographs: evaluation of a commercially available computer-aided diagnosis system. Radiology. 2002;223(3):806-811. Exclusion code: 4. [pmid: 12034953].
Johnson DA, Helft PR, Rex DK. CT and radiation-related cancer risktime for a paradigm shift?. Nature Reviews Gastroenterology and Hepatology. 2009;6(12):738-740. Exclusion code: 5. [pmid: 19946306].
Jonsson S, Varella-Garcia M, Miller YE, et al. Chromosomal aneusomy in bronchial high-grade lesions is associated with invasive lung cancer. Am. J. Respir. Crit. Care Med. 2008;177(3):342-347. Exclusion code: 5. [pmid: 17989344].
Jung KJ, Kyung Soo L, Su Young K, Tae Sung K, Yong Seon P, Ji Yeaon L. Low-dose, volumetric helical CT: Image quality, radiation dose, and usefulness for evaluation of bronchiectasis. Invest. Radiol. 2000;35(9):557-563. Exclusion code: 7. [pmid: 10982001].
Kagna O, Solomonov A, Keidar Z, et al. The value of FDG-PET/CT in assessing single pulmonary nodules in patients at high risk of lung cancer. Eur J Nucl Med Mol Imaging. 2009;36(6):997-1004. Exclusion code: 4. [pmid: 19194704].
Kaji M, Kobayashi R, Hino Y, et al. Strategy for marginally resectable lung cancer. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2011;38(8):1256-1260. Exclusion code: 6. [pmid: 21829062].
Kaji M, Sakurai H, Masai K, Suemasu K. Is video-assisted thoracic surgery lobectomy better than minimally invasive open thoracotomy?. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2009;62(4):302-307. Exclusion code: 6. [pmid: 19348215].
Kamangar F, Dores GM, Anderson WF. Patterns of cancer incidence, mortality, and prevalence across five continents: Defining priorities to reduce cancer disparities in different geographic regions of the world. J. Clin. Oncol. 2006;24(14):2137-2150. Exclusion code: 2. [pmid: 16682732].
Kamath AV, Chhajed PN. Role of bronchoscopy in early diagnosis of lung cancer. Indian J. Chest Dis. Allied Sci. 2006;48(4):265-269. Exclusion code: 5. [pmid: 16970293].
Kamerow D. Screening for early detection of lung cancer. BMJ. 2010;341:c6544. Exclusion code: 5. [pmid: 21084372].
Kamiyoshihara M, Ibe T. Surgical approach to primary lung cancer using video-assisted thoracic surgery. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2009;62(4):309-315. Exclusion code: 6. [pmid: 19348216].
Kamposioras K, Casazza G, Mauri D, et al. Screening chest radiography: results from a Greek cross-sectional survey. BMC Public Health. 2006;6:113. Exclusion code: 2. [pmid: 16646992].
Kanashiki M, Sairenchi T, Saito Y, Ishikawa H, Satoh H, Sekizawa K. Body mass index and lung cancer: a case-control study of subjects participating in a mass-screening program. Chest. 2005;128(3):1490-1496. Exclusion code: 3 Japan. [pmid: 16162748].
Kanashiki M, Satoh H, Ishikawa H, Yamashita YT, Ohtsuka M, Sekizawa K. Time from finding abnormality on mass-screening to final diagnosis of lung cancer. Oncol. Rep. 2003;10(3):649-652. Exclusion code: 2. [pmid: 12684638].
Kaneko M, Eguchi K, Ohmatsu H, Kakinuma R, Naruke T, Suemasu K. Peripheral lung cancer: screening and detection with low-dose spiral CT versus X-ray. Radiology. 1996;201(3):798-802. Exclusion code: 5. [pmid: 8939234].
Kaneko M, Kusumoto M, Kobayashi T, et al. Computed tomography screening for lung carcinoma in Japan. Cancer. 2000;89(11 Suppl):2485-2488. Exclusion code: 2. [pmid: 11147632].
Kanemoto K, Satoh H, Ishikawa H, Kagohashi K, Kurishima K, Sekizawa K. Diagnostic procedures for small pulmonary nodules detected by mass-screening. Anticancer Res. 2008;28(5B):3153-3155. Exclusion code: 7. [pmid: 19031974].
Kao CH, Hsieh JF, Tsai SC, Ho YJ, Lee JK. Quickly predicting chemotherapy response to paclitaxel-based therapy in non-small cell lung cancer by early technetium-99m methoxyisobutylisonitrile chest single-photon-emission computed tomography. Clin. Cancer Res. 2000;6(3):820-824. Exclusion code: 7. [pmid: 10741702].
Karadayi S, Kayi Cangir A, Ozturk S, Dizbay Sak S, Akal M, Akay H. The prognostic effect of natural killer cell infiltration to tumoral tissues in stage I non-small cell lung cancer. Tuberk. 2008;56(3):251-256. Exclusion code: 6. [pmid: 18932025].
Karadi RL. Radiation risk of screening with low dose CT. Thorax. 2006;61(6):548. Exclusion code: 5. [pmid: 16738051].
Kashiwabara K, Kohshi Si. Outcome in patients with lung cancer invisible on chest roentgenograms but detected only by helical computed tomography. Respirology. 2006;11(5):592-597. Exclusion code: 2. [pmid: 16916332].
Kashiwabara K, Koshi Si, Itonaga K, Nakahara O, Tanaka M, Toyonaga M. Outcome in patients with lung cancer found on lung cancer mass screening roentgenograms, but who did not subsequently consult a doctor. Lung Cancer. 2003;40(1):67-72. Exclusion code: 2. [pmid: 12660008].
Kashiwabara K, Koshi Si, Ota K, Tanaka M, Toyonaga M. Outcome in patients with lung cancer found retrospectively to have had evidence of disease on past lung cancer mass screening roentgenograms. Lung Cancer. 2002;35(3):237-241. Exclusion code: 2. [pmid: 11844596].
Katanoda K, Yako-Suketomo H. Trends in lung cancer mortality rates in Japan, USA, UK, France and Korea based on the WHO mortality database. Jpn. J. Clin. Oncol. 2012;42(3):239-240. Exclusion code: 2. [pmid: 22375029].
Katsimpoula S, Patrinou-Georgoula M, Makrilia N, et al. Overexpression of hnRNPA2/B1 in bronchoscopic specimens: a potential early detection marker in lung cancer. Anticancer Res. 2009;29(4):1373-1382. Exclusion code: 4. [pmid: 19414390].
Katz RL, Zaidi TM, Fernandez RL, et al. Automated detection of genetic abnormalities combined with cytology in sputum is a sensitive predictor of lung cancer. [Erratum appears in Mod Pathol. 2009 May;22(5):734-6].[Erratum appears in Mod Pathol. 2008 Aug;21(8):1065 Note: Jiang, Xiaoying Gao Feng [corrected to Gao, Xiaoying]; Jiang, Feng [added]. Mod. Pathol. 2008;21(8):950-960. Exclusion code: 7. [pmid: 18500269].
Kawachi R, Tsukada H, Nakazato Y, et al. Early recurrence after surgical resection in patients with pathological stage I non-small cell lung cancer. Thorac. Cardiovasc. Surg. 2009;57(8):472-475. Exclusion code: 7. [pmid: 20013621].
Kawachi R, Watanabe Si, Asamura H. Clinicopathological characteristics of screen-detected lung cancers. [Erratum appears in J Thorac Oncol. 2009 Aug;4(8):1045]. J Thorac Oncol. 2009;4(5):615-619. Exclusion code: 2. [pmid: 19318993].
Kawada K, Yonei T, Ueoka H, et al. Comparison of chemosensitivity tests: clonogenic assay versus MTT assay. Acta Med. Okayama. 2002;56(3):129-134. Exclusion code: 7. [pmid: 12108583].
Kawaguchi T, Matsumura A, Fukai S, et al. Japanese ethnicity compared with caucasian ethnicity and never-smoking status are independent favorable prognostic factors for overall survival in non-small cell lung cancer: A collaborative epidemiologic study of the national hospital organization study group for lung cancer (NHSGLC) in japan and a southern california regional cancer registry databases. Journal of Thoracic Oncology. 2010;5(7):1001-1010. Exclusion code: 2. [pmid: 20526205].
Kawaguchi Y, Noriyuki T, Kuroda Y, et al. Right lung cancer with right aortic arch. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(2):113-117. Exclusion code: 6. [pmid: 18268946].
Kawahara M. Screening for lung cancer. Curr. Opin. Oncol. 2004;16(2):141-145. Exclusion code: 5. [pmid: 15075906].
Kawano R, Tamaki K, Karita S, Yokota T, Ikeda S, Hata E. Surgical treatment for clinical stage II and III small cell lung cancer patients. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2006;59(10):879-883. discussion 883-876. Exclusion code: 6. [pmid: 16986681].
Kawashima O, Ibe T, Kakegawa S, Nakano T, Shimizu K. Surgical treatment and outcome for postoperative recurrent or second primary lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(11):935-939. Exclusion code: 6. [pmid: 20954346].
Kawashima O, Sugano M, Kakegawa S, et al. The clinicopathological features of peripheral small-sized (2 cm or less) squamous cell carcinoma of the lung. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2004;57(1):56-60. Exclusion code: 6. [pmid: 14733100].
Kayser G, Gunzenhauser I, Becker HD, Herth F, Kayser K. Proliferation rate of small cell lung carcinoma. A cytomorphometric parameter with prognostic significance. Pathologe. 2001;22(5):326-332. Exclusion code: 6. [pmid: 11572113].
Kazarian M, Laird-Offringa IA. Small-cell lung cancer-associated autoantibodies: potential applications to cancer diagnosis, early detection, and therapy. Mol Cancer. 2011;10:33. Exclusion code: 3. [pmid: 21450098].
Kazerooni EA. Lung cancer screening. Eur. Radiol. Suppl 4. 2005;15:D48-51. Exclusion code: 5. [pmid: 16479646].
Kazerooni EA, Chow LC, Whyte RI, Martinez FJ, Lynch JP. Preoperative examination of lung transplant candidates: Value of chest CT compared with chest radiography. AJR: American Journal of Roentgenology. 1995;165:1343-1348. Exclusion code: 7. [pmid: 7484560].
Kelsey CR, Marks LB, Hollis D, et al. Local recurrence after surgery for early stage lung cancer: an 11-year experience with 975 patients. Cancer. 2009;115(22):5218-5227. Exclusion code: 3. [pmid: 19672942].
Kemp RA, Reinders DM, Turic B. Detection of lung cancer by automated sputum cytometry. J Thorac Oncol. 2007;2(11):993-1000. Exclusion code: 2. [pmid: 17975489].
Kennedy TC, Hirsch FR. Using molecular markers in sputum for the early detection of lung cancer: a review. Lung Cancer. Suppl 2. 2004;45:S21-27. Exclusion code: 5. [pmid: 15552778].
Kennedy TC, Hirsch FR, Miller YE, et al. A randomized controlled trial of fluorescence bronchoscopy versus white-light bronchoscopy for early detection of lung cancer in high risk patients. Lung Cancer. 2000;29(9 Suppl 1):244-245. Exclusion code: 5.
Kennedy TC, Miller Y, Prindiville S. Screening for lung cancer revisited and the role of sputum cytology and fluorescence bronchoscopy in a high-risk group. Chest. 2000;117(4 Suppl 1):72S-79S. Exclusion code: 5. [pmid: 10777459].
Kent MS, Port JL, Altorki NK. Current state of imaging for lung cancer staging. Thorac Surg Clin. 2004;14(1):1-13. Exclusion code: 5. [pmid: 15382304].
Kenzaki K, Sakiyama S, Tomimoto H, et al. Clinical analysis of elderly patients with primary lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(7):519-523. discussion 524-516. Exclusion code: 6. [pmid: 20662228].
Kepka L, Bujko K. Postoperative radiotherapy for non-small cell lung cancer: evidence based data and clinical practice. Pneumonol. Alergol. Pol. 2007;75(3):256-261. Exclusion code: 6. [pmid: 17966101].
Kesting MR, Robitzky L, Al-Benna S, et al. Bronchoscopy screening in primary oral squamous cell carcinoma: a 10-year experience. Br. J. Oral Maxillofac. Surg. 2009;47(4):279-283. Exclusion code: 3. [pmid: 19243866].
Kim H, Kwon YM, Kim JS, et al. Tumor-specific methylation in bronchial lavage for the early detection of non-small-cell lung cancer. J. Clin. Oncol. 2004;22(12):2363-2370. Exclusion code: 2. [pmid: 15197197].
Kim HR, Kim TH, Chung JH, et al. The detection of peripheral lung cancer by MAGE A1-6 RT-nested PCR in bronchial washing specimens. Lung Cancer. 2009;65(2):166-169. Exclusion code: 2. [pmid: 19168258].
Kim IH, Patel MJ, Hirt SL, Kantor ML. Clinical research and diagnostic efficacy studies in the oral and maxillofacial radiology literature: 1996-2005. Dentomaxillofacial Radiology. 2011;40(5):274-281. Exclusion code: 3. [pmid: 21697152].
Kim K, Kim HK, Park JS, et al. Video-assisted thoracic surgery lobectomy: single institutional experience with 704 cases. Ann. Thorac. Surg. 2010;89(6):S2118-2122. Exclusion code: 10. [pmid: 20493994].
Kim TJ, Han DH, Jin KN, Won Lee K. Lung cancer detected at cardiac CT: prevalence, clinicoradiologic features, and importance of full-field-of-view images. Radiology. 2010;255(2):369-376. Exclusion code: 4. [pmid: 20413751].
Kita H, Koshiishi Y, Masui K, et al. Risk factors of recurrence in resected stage I non-small cell lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2007;60(10):883-887. Exclusion code: 6. [pmid: 17877005].
Kitajima T, Nishii K, Ueoka H, et al. Recent improvement in lung cancer screening: a comparison of the results carried out in two different time periods. Acta Med. Okayama. 2006;60(3):173-179. Exclusion code: 3 Japan. [pmid: 16838046].
Kjellgren O. Mass screening in Sweden for cancer of the uterine cervix: Effect on incidence and mortality. An overview. Gynecol. Obstet. Invest. 1986;22(2):57-63. Exclusion code: 8. [pmid: 3770533].
Klabunde CN, Marcus PM, Han PKJ, et al. Lung cancer screening practices of primary care physicians: Results from a national survey. Ann Fam Med. 2012;10(2):102-110. Exclusion code: 5. [pmid: 22412001].
Klabunde CN, Marcus PM, Silvestri GA, et al. U.S. primary care physicians' lung cancer screening beliefs and recommendations. Am. J. Prev. Med. 2010;39(5):411-420. Exclusion code: 2. [pmid: 20965378].
Klar E, Puschel A, Schiffmann L, Pertschy A. The role of intensive care medicine in early postoperative complications. Is surgical expertise in danger?. Chirurg. 2009;80(9):773-779. Exclusion code: 6. [pmid: 19707724].
Kligerman S, White C. Epidemiology of lung cancer in women: risk factors, survival, and screening. AJR. Am. J. Roentgenol. 2011;196(2):287-295. Exclusion code: 2. [pmid: 21257878].
Kloecker GH, Studts JL, Laber DA, Bousamra M. Lung cancer in the US and in Kentucky. J. Ky. Med. Assoc. 2007;105(4):159-164. Exclusion code: 5. [pmid: 17494278].
Kobayashi K. Guide line for the treatment of stage I and stage II non small cell lung cancer. Nippon Geka Gakkai Zasshi. 2004;105(7):392-403. Exclusion code: 6. [pmid: 15303438].
Kodama K, Oda K, Okami J, et al. The value of long-term postoperative follow-up after curative resection of lung cancer and common problems associated with it. Nippon Geka Gakkai Zasshi. 2007;108(3):107-112. Exclusion code: 6. [pmid: 17533945].
Koebel CM, Vermi W, Swann JB, et al. Adaptive immunity maintains occult cancer in an equilibrium state. Nature. 2007;450(7171):903-907. Exclusion code: 5. [pmid: 18026089].
Kohno T, Kakinuma R, Iwasaki M, et al. Association of CYP19A1 polymorphisms with risks for atypical adenomatous hyperplasia and bronchioloalveolar carcinoma in the lungs. Carcinogenesis. 2010;31(10):1794-1799. Exclusion code: 2. [pmid: 20688833].
Koike T, Tsuchiya R, Goya T, Sohara Y, Miyaoka E. Prognostic factors in 3315 completely resected cases of clinical stage I non-small cell lung cancer in Japan. J Thorac Oncol. 2007;2(5):408-413. Exclusion code: 7. [pmid: 17473656].
Koizumi K. Thoracoscopic surgery and postoperative respiratory complications. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2006;59(8 Suppl):760-767. Exclusion code: 6. [pmid: 16910528].
Kojima A, Takeshita K, Fukuchi Y, Dambara T. Usefulness of low-dose single-slice CT (SSCT) for mass screening to detect various thoracic diseases including lung cancer. Nihon Kokyuki Gakkai Zasshi. 2004;42(10):887-892. Exclusion code: 6. [pmid: 15566002].
Kolodziejczyk M, Kepka L, Tyc-Szczepaniak D, Wierzchowski M. Outcome of three-dimensional conformal radiotherapy for early stage non-small cell lung cancer patients who met or not inclusion criteria for stereotactic-body radiation therapy. Pneumonol. Alergol. Pol. 2011;79(5):326-336. Exclusion code: 6. [pmid: 21861256].
Kondo R, Yoshida K, Kawakami S, et al. Efficacy of CT screening for lung cancer in never-smokers: Analysis of Japanese cases detected using a low-dose CT screen. Lung Cancer. 2011;74(3):426-432. Exclusion code: 2. [pmid: 21663997].
Kondo R, Yoshida K, Kawakami S, et al. Different efficacy of CT screening for lung cancer according to histological type: analysis of Japanese-smoker cases detected using a low-dose CT screen. Lung Cancer. 2011;74(3):433-440. Exclusion code: 10. [pmid: 21663995].
Konno S, Morishita Y, Fukasawa M, et al. Anthracotic index and DNA methylation status of sputum contents can be used for identifying the population at risk of lung carcinoma. Cancer. 2004;102(6):348-354. Exclusion code: 3. [pmid: 15481085].
Kono Y, Endo S, Otani S, et al. Non-tuberculous mycobacterial infection along the staple-suture line after segmentectomy for small peripheral lung cancer; report of a case. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2005;58(2):165-168. Exclusion code: 6. [pmid: 15724484].
Korenkov M, Gonner U, Dunschede F, Junginger T. Rectal melanoma: the value of modern treatment. Zentralbl. Chir. 2008;133(6):564-567. Exclusion code: 6. [pmid: 19090435].
Kovacs A, Dobrossy L, Budai A, Cornides A, Boncz I. The state of the organized screening in Hungary in 2006. Orv. Hetil. 2007;148(10):435-440. Exclusion code: 6. [pmid: 17350908].
Kovacs G. Risk group chest X-ray for the early detection of lung cancer. Orv. Hetil. 2008;149(21):975-982. Exclusion code: 6. [pmid: 18487112].
Kovacs G, Dulka E, Mark Z, et al. Our experience using autofluorescence bronchoscopy. Orv. Hetil. 2004;145(28):1473-1478. Exclusion code: 6. [pmid: 15366714].
Kovacs G, Gaudi I, Kovi R. An interdisciplinary malignancy, the lung cancer in Hungary in 2006: epidemiology, prevention and access to therapy. Magy Onkol. 2006;50(3):207. Exclusion code: 6. [pmid: 17099779].
Kraev A, Rassias D, Vetto J, et al. Wedge resection vs lobectomy: 10-year survival in stage I primary lung cancer. Chest. 2007;131(1):136-140. Exclusion code: 10. [pmid: 17218567].
Kramer BS. Spiral computed tomography screening. J. Med. Screen. 2000;7(3):121-122. Exclusion code: 2. [pmid: 11126157].
Kramer BS. Spiral computed tomography screening: study begins to determine its efficacy in lung cancer prevention. West. J. Med. 2001;174(4):230-231. Exclusion code: 5. [pmid: 11290662].
Kramer BS, Berg CD, Aberle DR, Prorok PC. Lung cancer screening with low-dose helical CT: results from the National Lung Screening Trial (NLST). J. Med. Screen. 2011;18(3):109-111. Exclusion code: 2. [pmid: 22045816].
Kramer BS, Brawley OW. Cancer screening. Hematology - Oncology Clinics of North America. 2000;14(4):831-848. Exclusion code: 4. [pmid: 10949776].
Krotz D. Low-dose CT screening reduces lung cancer deaths. Diagn. Imaging. 2000;(Suppl):7-9. Exclusion code: 5. [pmid: 10848422].
Krupinski EA, Jiang Y. Anniversary Paper: Evaluation of medical imaging systems. Med. Phys. 2008;35(2):645-659. Exclusion code: 5. [pmid: 18383686].
Kubik A, Parkin DM, Khlat M, Erban J, Polak J, Adamec M. Lack of benefit from semi-annual screening for cancer of the lung: follow-up report of a randomized controlled trial on a population of high-risk males in Czechoslovakia. Int. J. Cancer. 1990;45(1):26-33. Exclusion code: 5. [pmid: 2404878].
Kubik A, Polak J. Lung cancer detection. Results of a randomized prospective study in Czechoslovakia. Cancer. 1986;57(12):2427-2437. Exclusion code: 5. [pmid: 3697941].
Kubik AK, Parkin DM, Zatloukal P. Czech Study on Lung Cancer Screening: post-trial follow-up of lung cancer deaths up to year 15 since enrollment. Cancer. 2000;89(11 Suppl):2363-2368. Exclusion code: 8. [pmid: 11147613].
Kucharczyk MJ, Menezes RJ, McGregor A, Paul NS, Roberts HC. Assessing the impact of incidental findings in a lung cancer screening study by using low-dose computed tomography. Can. Assoc. Radiol. J. 2011;62(2):141-145. Exclusion code: 2. [pmid: 20382501].
Kulaga S, Karp I. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):744. author reply 746-747. Exclusion code: 5. [pmid: 17310520].
Kuller LH, Ockene JK, Meilahn E, Wentworth DN, Svendsen KH, Neaton JD. Cigarette smoking and mortality. MRFIT Research Group. Prev. Med. 1991;20(5):638-654. Exclusion code: 4. [pmid: 1758843].
Kurishima K, Kagohashi K, Nakayama H, Satoh H. Incidentally detected lung cancer. South. Med. J. 2009;102(9):986. Exclusion code: 5. [pmid: 19668041].
Kuroda H, Kawamura M. The management of post operative chylothorax. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(8 Suppl):700-704. Exclusion code: 6. [pmid: 20715413].
Kusano S, Nakagawa T, Aoki T, et al. Efficacy of computer-aided diagnosis in lung cancer screening with low-dose spiral computed tomography: receiver operating characteristic analysis of radiologists' performance. Jpn J Radiol. 2010;28(9):649-655. Exclusion code: 3. [pmid: 21113748].
Kuschner WG, Hsu JL, Banerjee D. Understanding and identifying bias and confounding in the medical literature. South. Med. J. 2008;101(12):1240-1245. Exclusion code: 5. [pmid: 19005435].
Kusunoki Y, Imamura F, Uda H, Mano M, Horai T. Early detection of lung cancer with laser-induced fluorescence endoscopy and spectrofluorometry. Chest. 2000;118(6):1776-1782. Exclusion code: 7. [pmid: 11115472].
Kusunoki Y, Nakayama T. CT diagnosis of lung cancer--current topics. Nippon Rinsho - Japanese Journal of Clinical Medicine. Suppl 5. 2002;60:170-173. Exclusion code: 6. [pmid: 12101649].
Kuzniar T, Masters GA, Ray DW. Screening for lung cancer--a review. Med Sci Monit. 2004;10(2):RA21-30. Exclusion code: 5. [pmid: 14737058].
Lacroix J, Becker HD, Woerner SM, Rittgen W, Drings P, von Knebel Doeberitz M. Sensitive detection of rare cancer cells in sputum and peripheral blood samples of patients with lung cancer by preproGRP-specific RT-PCR. Int. J. Cancer. 2001;92(1):1-8. Exclusion code: 2. [pmid: 11279599].
Lafata JE, Simpkins J, Lamerato L, Poisson L, Divine G, Johnson CC. The economic impact of false-positive cancer screens. Cancer Epidemiol. Biomarkers Prev. 2004;13(12):2126-2132. Exclusion code: 2. [pmid: 15598770].
The economic impact of false-positive cancer screens (Brief record). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 5.
Lam B, Lam SY, Wong MP, et al. Sputum cytology examination followed by autofluorescence bronchoscopy: a practical way of identifying early stage lung cancer in central airway. Lung Cancer. 2009;64(3):289-294. Exclusion code: 4. [pmid: 19010567].
Lam S, Lam B, Petty TL. Early detection for lung cancer. New tools for casefinding. Can. Fam. Physician. 2001;47:537-544. Exclusion code: 5. [pmid: 11281087].
Lam S, MacAulay C, leRiche JC, Palcic B. Detection and localization of early lung cancer by fluorescence bronchoscopy. Cancer. 2000;89(11 Suppl):2468-2473. Exclusion code: 7. [pmid: 11147629].
Lamerato LE, Marcus PM, Jacobsen G, Johnson CC. Recruitment in the prostate, lung, colorectal, and ovarian (PLCO) cancer screening trial: the first phase of recruitment at Henry Ford Health System. Cancer Epidemiol. Biomarkers Prev. 2008;17(4):827-833. Exclusion code: 2. [pmid: 18398023].
Landrum MB, Keating NL, Lamont EB, et al. Survival of older patients with cancer in the Veterans Health Administration versus fee-for-service Medicare. J. Clin. Oncol. 2012;30(10):1072-1079. Exclusion code: 3. [pmid: 22393093].
Lange P, Nyboe J, Appleyard M, Jensen G, Schnohr P. Relation of ventilatory impairment and of chronic mucus hypersecretion to mortality from obstructive lung disease and from all causes. Thorax. 1990;45(8):579-585. Exclusion code: 8. [pmid: 2402719].
Larke FJ, Kruger RL, Cagnon CH, et al. Estimated radiation dose associated with low-dose chest CT of average-size participants in the National Lung Screening Trial. AJR. Am. J. Roentgenol. 2011;197(5):1165-1169. Exclusion code: 2. [pmid: 22021510].
LaRocca RV, Falk R, Cerrito P, Lord R, Goldman S. Early results of a randomized prospective screening trial of annual low-dose spiral chest computed tomography scanning versus annual chest radiography of Kentucky patients at increased risk for lung cancer: Jewish Hospital Lung Cancer Screening and Early Detection Study [abstract]. Paper presented at: Proceedings of the American Society of Clinical Oncology. 2002. Exclusion code: 5.
Larsen IK, Grotmol T, Almendingen K, Hoff G. Impact of Colorectal Cancer Screening on Future Lifestyle Choices: A Three-Year Randomized Controlled Trial. Clinical Gastroenterology and Hepatology. 2007;5(4):477-483. Exclusion code: 4. [pmid: 17363335].
Lau K, Rathinam S, Waller D, Peake M. The Effects of Increased Provision of Thoracic Surgical Specialists on the Variation in Lung Cancer Resection Rate in England. J Thorac Onc. 2013;8(1):68-71. Exclusion code: 2. [pmid: 23242439].
Lauer MS, Murthy SC, Blackstone EH, Okereke IC, Rice TW. [18F]Fluorodeoxyglucose uptake by positron emission tomography for diagnosis of suspected lung cancer: impact of verification bias. Arch. Intern. Med. 2007;167(2):161-165. Exclusion code: 6. [pmid: 17242317].
Lautin EM, Novick MK, Jean-Baptiste R. Tailored CT: Primum non nocere. Br. J. Radiol. 2008;81(966):442-443. Exclusion code: 5. [pmid: 18347029].
Lawson JD, Sandhu A, Jiang S, Mundt AJ. Emerging role of stereotactic radiotherapy (SRT) in the treatment of early stage non-small cell lung cancer. Current Cancer Therapy Reviews. 2009;5(4):281-287. [PMID:. Exclusion code: 4.
Lazoura O, Vassiou K, Kanavou T, Vlychou M, Arvanitis DL, Fezoulidis IV. Incidental non-cardiac findings of a coronary angiography with a 128-slice multi-detector CT scanner: Should we only concentrate on the heart?. Korean Journal of Radiology. 2010;11(1):60-68. Exclusion code: 5. [pmid: 20046496].
Lazzeroni M, Guerrieri-Gonzaga A, Serrano D, et al. Budesonide versus placebo in high-risk population with screen-detected lung nodules: rationale, design and methodology. Contemp Clin Trials. 2010;31(6):612-619. Exclusion code: 4. [pmid: 20719253].
Le Chevalier T. Adjuvant chemotherapy in the early stages of non-small cell bronchial cancers. Rev. Pneumol. Clin. 2002;58(5 Pt 2):3S31-32. Exclusion code: 6. [pmid: 12538932].
Leader JK, Warfel TE, Fuhrman CR, et al. Pulmonary nodule detection with low-dose CT of the lung: agreement among radiologists. AJR. Am. J. Roentgenol. 2005;185(4):973-978. Exclusion code: 2. [pmid: 16177418].
Lee CI, Forman HP. CT screening for lung cancer: implications on social responsibility. AJR. Am. J. Roentgenol. 2007;188(2):297-298. Exclusion code: 5. [pmid: 17242233].
Lee JY, Chung MJ, Yi CA, Lee KS. Ultra-low-dose MDCT of the chest: influence on automated lung nodule detection. Korean Journal of Radiology. 2008;9(2):95-101. Exclusion code: 2. [pmid: 18385555].
Lee P, Colt HG. Bronchoscopy in lung cancer: appraisal of current technology and for the future. J Thorac Oncol. 2010;5(8):1290-1300. Exclusion code: 7. [pmid: 20661089].
Lee P, Postmus PE, Sutedja TG. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):745. author reply 746-747. Exclusion code: 5. [pmid: 17310516].
Lee P, Sutedja TG. Lung cancer screening: has there been any progress? Computed tomography and autofluorescence bronchoscopy. Curr. Opin. Pulm. Med. 2007;13(4):243-248. Exclusion code: 5. [pmid: 17534167].
Lee P, Sutedja TG. Population screening for lung cancer using CT. Thorax. 2008;63(1):87. Exclusion code: 5. [pmid: 18156577].
Lee P, van den Berg RM, Lam S, et al. Color fluorescence ratio for detection of bronchial dysplasia and carcinoma in situ. Clin. Cancer Res. 2009;15(14):4700-4705. Exclusion code: 3. [pmid: 19584169].
Lee PC, Korst RJ, Port JL, Kerem Y, Kansler AL, Altorki NK. Long-term survival and recurrence in patients with resected non-small cell lung cancer 1 cm or less in size. J. Thorac. Cardiovasc. Surg. 2006;132(6):1382-1389. Exclusion code: 10. [pmid: 17140961].
Lee SM, Park CM, Goo JM, et al. Transient part-solid nodules detected at screening thin-section CT for lung cancer: comparison with persistent part-solid nodules. Radiology. 2010;255(1):242-251. Exclusion code: 4. [pmid: 20173104].
Lee TH, Brennan TA. Direct-to-consumer marketing of high-technology screening tests. N. Engl. J. Med. 2002;346(7):529-531. Exclusion code: 5. [pmid: 11844859].
Lehman SJ, Abbara S, Cury RC, et al. Significance of Cardiac Computed Tomography Incidental Findings in Acute Chest Pain. Am. J. Med. 2009;122(6):543-549. Exclusion code: 3. [pmid: 19486717].
Lehrer S. Inhaled insulin for the early detection of lung cancer. Med. Hypotheses. 2008;71(4):615-616. Exclusion code: 5. [pmid: 18602221].
Leidinger P, Keller A, Heisel S, et al. Identification of lung cancer with high sensitivity and specificity by blood testing. Respir Res. 2010;11:18. Exclusion code: 2. [pmid: 20146812].
Lenzer J, Brownlee S. Knowing me, knowing you. BMJ. 2008;336(7649):858-860. Exclusion code: 5. [pmid: 18420689].
Lester RG. Risk versus benefit in mammography. Radiol. 1977;124(1):1-6. Exclusion code: 2. [pmid: 866625].
Levin ML, Tockman MS, Frost JK, Ball WC Jr. Lung cancer mortality in males screened by chest X-ray and cytologic sputum examination: a preliminary report. Recent Results Cancer Res. 1982;82:138-146. Exclusion code: 5. [pmid: 7111836].
Lew WJ, Jung YJ, Song JW, et al. Combined use of QuantiFERON®-TB gold assay and chest computed tomography in a tuberculosis outbreak. Int. J. Tuberc. Lung Dis. 2009;13(5):633-639. Exclusion code: 5. [pmid: 19383198].
Lewis PD, Lewis KE, Ghosal R, et al. Evaluation of FTIR spectroscopy as a diagnostic tool for lung cancer using sputum. BMC Cancer. 2010;10:640. Exclusion code: 7. [pmid: 21092279].
Li C, Zhang R. Lung cancer: new staging system and prognosis. Chung-Hua Wai Ko Tsa Chih. Chinese Journal of Surgery. 2000;38(3):189-191. Exclusion code: 6. [pmid: 11832024].
Li F, Sone S, Abe H, MacMahon H, Armato SG 3rd, Doi K. Lung cancers missed at low-dose helical CT screening in a general population: comparison of clinical, histopathologic, and imaging findings. Radiology. 2002;225(3):673-683. Exclusion code: 3. [pmid: 12461245].
Li F, Sone S, Abe H, MacMahon H, Doi K. Low-dose computed tomography screening for lung cancer in a general population: characteristics of cancer in non-smokers versus smokers. Acad. Radiol. 2003;10(9):1013-1020. Exclusion code: 2. [pmid: 13678090].
Li F, Sone S, Abe H, Macmahon H, Doi K. Malignant versus benign nodules at CT screening for lung cancer: comparison of thin-section CT findings. Radiology. 2004;233(3):793-798. Exclusion code: 3. [pmid: 15498895].
Li Gh, Wu Y, Zhang Xj, Cui Ys. A comparative study of survival time of surgery combined with chemotherapy and non-surgical chemotherapy in SCLC. Chung Hua I Hsueh Tsa Chih. 2010;90(31):2212-2214. Exclusion code: 6. [pmid: 21029664].
Li Hh, Zhang Qz, Xu L, Chen L, Wei Yx, Wang Yh. Diagnosis and treatment for postoperative lobar torsion. Chung Hua I Hsueh Tsa Chih. 2007;87(27):1915-1917. Exclusion code: 6. [pmid: 17923017].
Li Q, Li F, Doi K. Computerized detection of lung nodules in thin-section CT images by use of selective enhancement filters and an automated rule-based classifier. Acad. Radiol. 2008;15(2):165-175. Exclusion code: 4. [pmid: 18206615].
Li Y, Swensen SJ, Karabekmez LG, et al. Effect of emphysema on lung cancer risk in smokers: a computed tomography-based assessment. Cancer Prev Res (Phila Pa). 2011;4(1):43-50. Exclusion code: 2. [pmid: 21119049].
Libby DM, Wu N, Lee IJ, et al. CT screening for lung cancer: the value of short-term CT follow-up. Chest. 2006;129(4):1039-1042. Exclusion code: 7. [pmid: 16608955].
Licker MJ, Widikker I, Robert J, et al. Operative mortality and respiratory complications after lung resection for cancer: impact of chronic obstructive pulmonary disease and time trends. Ann. Thorac. Surg. 2006;81(5):1830-1837. Exclusion code: 7. [pmid: 16631680].
Lieberman DA, Weiss DG, Bond JH, Ahnen DJ, Garewal H, Chejfec G. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. N. Engl. J. Med. 2000;343(3):162-168. Exclusion code: 8. [pmid: 10900274].
Lillington GA. Lung cancer. Curr. Opin. Pulm. Med. 2003;9(4):298-300. Exclusion code: 5. [pmid: 12806243].
Lin Dm, Ma Y, Liu Xy, et al. Prognostic significance of micropapillary pattern in pulmonary adenocarcinoma. Chung-Hua Ping Li Hsueh Tsa Chih - Chinese Journal of Pathology. 2006;35(3):151-154. Exclusion code: 6. [pmid: 16630503].
Lin RS, Plevritis SK. Comparing the benefits of screening for breast cancer and lung cancer using a novel natural history model. Cancer Causes Control. 2012;23(1):175-185. Exclusion code: 7. [pmid: 22116537].
Lin Xl, Yang Sy, Du J, et al. Detection of lung adenocarcinoma using magnetic beads based matrix-assisted laser desorption/ionization time-of-flight mass spectrometry serum protein profiling. Chin. Med. J. (Engl). 2010;123(1):34-39. Exclusion code: 2. [pmid: 20137572].
Lin ZC, Long H, Rong TH, et al. Surgical treatment efficacy of bronchioloalveolar carcinoma: a retrospective analysis of 130 patients. Ai Zheng. 2006;25(9):1123-1126. Exclusion code: 6. [pmid: 16965654].
Lindell RM, Hartman TE, Swensen SJ, et al. Lung cancer screening experience: a retrospective review of PET in 22 non-small cell lung carcinomas detected on screening chest CT in a high-risk population. AJR. Am. J. Roentgenol. 2005;185(1):126-131. Exclusion code: 2. [pmid: 15972412].
Lindell RM, Hartman TE, Swensen SJ, et al. Five-year lung cancer screening experience: CT appearance, growth rate, location, and histologic features of 61 lung cancers. Radiology. 2007;242(2):555-562. Exclusion code: 2. [pmid: 17255425].
Littman AJ, Thornquist MD, White E, Jackson LA, Goodman GE, Vaughan TL. Prior lung disease and risk of lung cancer in a large prospective study. Cancer Causes Control. 2004;15(8):819-827. Exclusion code: 2. [pmid: 15456995].
Liu B, Liu L, Li Y, et al. Survival after radiofrequency ablation for 100 cases of lung neoplasms. Zhongguo Fei Ai Za Zhi. 2011;14(4):335-339. Exclusion code: 6. [pmid: 21496432].
Liu D, Awai K, Funama Y, et al. Identification and characterization of focal ground-glass opacity in the lungs by high-resolution CT using thin-section multidetector helical CT: Experimental study using a chest CT phantom. Radiation Medicine - Medical Imaging and Radiation Oncology. 2008;26(1):21-27. [pmid: 18236130].
Liu Xb, Yuan Zy, Song Yc, et al. An initial report of cyberknife radiosurgery for primary hepatic carcinoma. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2010;32(3):229-233. Exclusion code: 6. [pmid: 20450595].
Liu Y, Wang M. Advances in early diagnosis of lung cancer. Zhongguo Fei Ai Za Zhi. 2011;14(5):429-434. Exclusion code: 5. [pmid: 21569649].
Lo DS, Zeldin RA, Skrastins R, et al. Time to treat: a system redesign focusing on decreasing the time from suspicion of lung cancer to diagnosis. J Thorac Oncol. 2007;2(11):1001-1006. Exclusion code: 3. [pmid: 17975490].
Lobrano MB. Partnerships in oncology and radiology: the role of radiology in the detection, staging, and follow-up of lung cancer. Oncologist. 2006;11(7):774-779. Exclusion code: 5. [pmid: 16880236].
Loewen G, Reid M, Tan D, et al. Bimodality lung cancer screening in high-risk patients: a preliminary report. Chest. 2004;125(5 Suppl):163S-164S. Exclusion code: 5. [pmid: 15136489].
Loewen GL, Natarajan N, Tan D, et al. Autoflorescence bronchoscopy for lung cancer surveillance based on risk assessment. Thorax. 2007;62(4):335-340. Exclusion code: 4. [pmid: 17101735].
Long H, Lin ZC, Lin YB, Situ DR, Wang YN, Rong TH. Quality of life after lobectomy for early stage non-small cell lung cancer--video-assisted thoracoscopic surgery versus minimal incision thoracotomy. Ai Zheng. 2007;26(6):624-628. Exclusion code: 6. [pmid: 17562269].
Long H, Lin Zc, Situ Dr. Injuries after lobectomy: a prospective randomized comparison of video-assisted thoracoscopic surgery and mini-thoracotomy. Chung-Hua Wai Ko Tsa Chih. Chinese Journal of Surgery. 2008;46(6):401-404. Exclusion code: 6. [pmid: 18785569].
Lopes Pegna A, Picozzi G. Lung cancer screening update. Curr. Opin. Pulm. Med. 2009;15(4):327-333. Exclusion code: 2. [pmid: 19395971].
Lopez Diaz M, Anton-Pacheco Sanchez JL, Tejedor Sanchez R, et al. Primary lung tumors. Cir. Pediatr. 2006;19(4):223-227. Exclusion code: 6. [pmid: 17352111].
Lotti M, Bergamo L, Murer B. Occupational toxicology of asbestos-related malignancies. Clinical Toxicology: The Official Journal of the American Academy of Clinical Toxicology & European Association of Poisons Centres & Clinical Toxicologists. 2010;48(6):485-496. Exclusion code: 5. [pmid: 20849338].
Lou W, Zhan X, Xiang X, Guan W. Effect of VATS wedge resection and mediastinal lymph node sampling in elderly patients with early peripheral lung cancer. Zhongguo Fei Ai Za Zhi. 2012;15(1):49-51. Exclusion code: 6. [pmid: 22237125].
Lovgren M, Levealahti H, Tishelman C, Runesdotter S, Hamberg K. Time spans from first symptom to treatment in patients with lung cancer--the influence of symptoms and demographic characteristics. Acta Oncol. 2008;47(3):397-405. Exclusion code: 7. [pmid: 17882556].
Luboldt W, Wetter A, Eichler K, Vogl TJ, Wagner TOF, Seemann MD. Determination of the optimal MRI sequence for the detection of malignant lung nodules. Eur. J. Med. Res. 2006;11(8):336-342. Exclusion code: 7. [pmid: 17052969].
Ludovini V, Pistola L, Gregorc V, et al. Plasma DNA, microsatellite alterations, and p53 tumor mutations are associated with disease-free survival in radically resected non-small cell lung cancer patients: a study of the perugia multidisciplinary team for thoracic oncology. J Thorac Oncol. 2008;3(4):365-373. Exclusion code: 4. [pmid: 18379354].
Ludwig C, Stoelben E, Olschewski M, Hasse J. Comparison of morbidity, 30-day mortality, and long-term survival after pneumonectomy and sleeve lobectomy for non-small cell lung carcinoma. Ann. Thorac. Surg. 2005;79(3):968-973. Exclusion code: 3. [pmid: 15734415].
Lumbreras B, Aguado IH. Enthusiasm for diagnostic tests: Health effects and their surveillance. 2008 SESPAS report. El entusiasmo por las pruebas diagnósticas: Efectos en la salud y formas de control. Informe SESPAS 2008. 2008;22(SUPPL. 1):216-222. Exclusion code: 5. [pmid: 18405573].
Lumbreras B, Hernández-Aguado I. Latrogeny attributable to diagnostic tests. Revista de Calidad Asistencial. 2007;22(6):272-276. [PMID:. Exclusion code: 6.
Lung Cancer Alliance. Screen for Lung Cancer. Rights and Expectations for Excellence in Lung Cancer Screening and Continuum of Care. http://www.screenforlungcancer.org/national-framework/. 19 September 2012. 2012. Exclusion code: 2.
Lyons G, Quadrelli S, Chimondegy D, Iotti A, Silva C. Bronchioalveolar carcinoma: five year survival. Medicina (Mex). 2006;66(4):313-318. Exclusion code: 6. [pmid: 16977966].
Lyons G, Quadrelli S, Chimondegy D, Iotti A, Silva C. Tumor size and survival in lung cancer, stage IA. Medicina (Mex). 2008;68(1):23-30. Exclusion code: 6. [pmid: 18416316].
Machado RF, Laskowski D, Deffenderfer O, et al. Detection of lung cancer by sensor array analyses of exhaled breath. Am. J. Respir. Crit. Care Med. 2005;171(11):1286-1291. Exclusion code: 3. [pmid: 15750044].
MacMahon H, Austin JH, Gamsu G, et al. Guidelines for Management of Small Pulmonary Nodules Detected on CT Scans: A Statement from the Fleischner Society. Radiol. 2005;237:395-400. Exclusion code: 2. [pmid: 16244247].
MacRedmond R, Logan PM, Lee M, Kenny D, Foley C, Costello RW. Screening for lung cancer using low dose CT scanning. Thorax. 2004;59(3):237-241. Exclusion code: 5. [pmid: 14985561].
Maeda M. Tracheobronchoplasty for lung cancer: operative indications by limited category. Nippon Geka Gakkai Zasshi. 2000;101(7):503-508. Exclusion code: 6. [pmid: 10944771].
Maeda R, Yoshida J. Lung cancer -- CT screening for lung cancer dramatically improved survival after surgical resection. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2011;38(2):197-201. Exclusion code: 6. [pmid: 21368484].
Maeda R, Yoshida J, Ishii G, et al. Long-term outcome and late recurrence in patients with completely resected stage IA non-small cell lung cancer. J Thorac Oncol. 2010;5(8):1246-1250. Exclusion code: 7. [pmid: 20559152].
Maggi F. Lung cancer screening with spiral CT. Rays. 2004;29(4):377-382. Exclusion code: 5. [pmid: 15852723].
Mahadevia P, Fleisher LA, Frick KD, Eng J, Goodman SN, Powe NR. Lung cancer screening with helical computed tomography in older adult smokers: A decision and cost-effectiveness analysis. JAMA. 2003;289(3):313-322. Exclusion code: 7. [pmid: 12525232].
Mahon SM. Screening for lung cancer: what is the evidence?. Clin. J. Oncol. Nurs. 2004;8(2):188-189. Exclusion code: 5. [pmid: 15108420].
Maisonneuve P, Bagnardi V, Bellomi M, et al. Lung cancer risk prediction to select smokers for screening CT - A model based on the Italian COSMOS trial. Cancer Prev Res (Phila Pa). 2011;4(11):1778-1789. Exclusion code: 4. [pmid: 21813406].
Maldonado A, Gonzalez-Alenda FJ, Alonso M, Sierra JM. PET-CT in clinical oncology. Clin Transl Oncol. 2007;9(8):494-505. Exclusion code: 5. [pmid: 17720652].
Maldonado F, Bartholmai BJ, Swensen SJ, Midthun DE, Decker PA, Jett JR. Are airflow obstruction and radiographic evidence of emphysema risk factors for lung cancer? A nested case-control study using quantitative emphysema analysis. Chest. 2010;138(6):1295-1302. Exclusion code: 2. [pmid: 20348193].
Manning DJ, Ethell SC, Donovan T. Detection or decision errors? Missed lung cancer from the posteroanterior chest radiograph. Br. J. Radiol. 2004;77(915):231-235. Exclusion code: 4. [pmid: 15020365].
Manser R. Screening for lung cancer: a review. Curr. Opin. Pulm. Med. 2004;10(4):266-271. Exclusion code: 5. [pmid: 15220750].
Cost-effectiveness analysis of screening for lung cancer with low dose spiral CT (computed tomography) in the Australian setting (Structured abstract). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 7.
Manser RL, Dodd M, Byrnes G, Irving LB, Campbell DA. Incidental lung cancers identified at coronial autopsy: implications for overdiagnosis of lung cancer by screening. Respir. Med. 2005;99(4):501-507. Exclusion code: 4. [pmid: 15763458].
Manser RL, Irving LB, Byrnes G, Abramson MJ, Stone CA, Campbell DA. Screening for lung cancer: a systematic review and meta-analysis of controlled trials. Thorax. 2003;58(9):784-789. Exclusion code: 2. [pmid: 12947138].
Manser RL, Irving LB, de Campo MP, et al. Overview of observational studies of low-dose helical computed tomography screening for lung cancer. Respirology. 2005;10(1):97-104. Exclusion code: 5. [pmid: 15691245].
Manser RL, Irving LB, Stone C, Byrnes G, Abramson M, Campbell D. Screening for lung cancer. Cochrane Database of Systematic Reviews. 2010;(CD001991). Exclusion code: 2.
Mao Y, Zhang D, Zhang R, et al. Surgical treatment for lung cancer patients with poor pulmonary function. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2002;24(3):300-302. Exclusion code: 6. [pmid: 12515633].
Marchiano A, Calabro E, Civelli E, et al. Pulmonary nodules: volume repeatability at multidetector CT lung cancer screening. Radiology. 2009;251(3):919-925. Exclusion code: 2. [pmid: 19380692].
Marcus PM. Lung cancer screening, once again. Chest. 2002;122(1):3-4. Exclusion code: 5. [pmid: 12114327].
Marcus PM, Bergstralh EJ, Fagerstrom RM, et al. Lung cancer mortality in the Mayo Lung Project: impact of extended follow-up. J. Natl. Cancer Inst. 2000;92(16):1308-1316. Exclusion code: 2. [pmid: 10944552].
Marek W, Kotschy-Lang N, Muti A, et al. Can semi-automated image cytometry on induced sputum become a screening tool for lung cancer? Evaluation of quantitative semi-automated sputum cytometry on radon- and uranium-exposed workers. Eur. Respir. J. 2001;18(6):942-950. Exclusion code: 2. [pmid: 11829100].
Marek W, Richartz G, Philippou S, Marek L, Kotschy-Lang N. Sputum screening for lung cancer in radon exposed uranium miners: a comparison of semi-automated sputum cytometry and conventional cytology. J. Physiol. Pharmacol. Suppl 5. 2007;58(Pt 1):349-361. Exclusion code: 2. [pmid: 18204147].
Marel M, Stranska P, Mericka O, et al. Diagnostics and indications of surgical treatment of patients with lung carcinoma at the first clinic of TRN of the first faculty of medicine and the VFN Prague in years 2004 to 2005. Cas. Lek. Cesk. 2006;145(11):849-854. Exclusion code: 6. [pmid: 17168418].
Markowitz SB, Miller A, Miller J, et al. Ability of low-dose helical CT to distinguish between benign and malignant noncalcified lung nodules. Chest. 2007;131(4):1028-1034. Exclusion code: 2. [pmid: 17426206].
Márquez-Calderón S. Negative effects of individual-based preventive interventions. 2008 SESPAS Report. Los efectos negativos de las intervenciones preventivas basadas en el individuo. Informe SESPAS 2008. 2008;22(SUPPL. 1):205-215. Exclusion code: 5. [pmid: 18405572].
Marshall D, Simpson KN, Earle CC, Chu CW. Economic decision analysis model of screening for lung cancer. Eur. J. Cancer. 2001;37(14):1759-1767. Exclusion code: 2. [pmid: 11549429].
Marshall E. Medicine. A bumper crop of conflicts. Science. 2008;320(5876):602-603. Exclusion code: 5. [pmid: 18451276].
Marten K, Engelke C. Computer-aided detection and automated CT volumetry of pulmonary nodules. Eur. Radiol. 2007;17(4):888-901. Exclusion code: 2. [pmid: 17047961].
Martini N. Results of the Memorial Sloan-Kettering study in screening for early lung cancer. Chest. 1986;89(4 Suppl):S325. Exclusion code: 5. [pmid: 6734291].
Marugame T, Sobue T, Satoh H, et al. Lung cancer death rates by smoking status: Comparison of the three-prefecture cohort study in Japan to the cancer prevention study II in the USA. Cancer Science. 2005;96(2):120-126. Exclusion code: 2. [pmid: 15723657].
Mascaux C, Peled N, Garg K, Kato Y, Wynes MW, Hirsch FR. Early detection and screening of lung cancer. Expert Review of Molecular Diagnostics. 2010;10(6):799-815. Exclusion code: 2. [pmid: 20843203].
Massion PP, Zou Y, Uner H, et al. Recurrent genomic gains in preinvasive lesions as a biomarker of risk for lung cancer. PLoS ONE. 2009;4(6). Exclusion code: 3. [pmid: 19547694].
Mastrangelo G, Ballarin MN, Bellini E, et al. Feasibility of a screening programme for lung cancer in former asbestos workers. Occupational Medicine (Oxford). 2008;58(3):175-180. Exclusion code: 2. [pmid: 18346953].
Matsumoto K, Ohno Y, Koyama H, et al. 3D automatic exposure control for 64-detector row CT: Radiation dose reduction in chest phantom study. Eur. J. Radiol. 2011;77(3):522-527. Exclusion code: 5. [pmid: 19836179].
Matsumura K, Opiekun M, Oka H, et al. Urinary volatile compounds as biomarkers for lung cancer: A proof of principle study using odor signatures in mouse models of lung cancer. PLoS ONE. 2010;5(1). Exclusion code: 4. [pmid: 20111698].
Matsuura N, Nakashima N, Igai H, et al. Prognosis of surgically treated large cell neuroendocrine carcinoma. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2011;64(3):187-190. Exclusion code: 6. [pmid: 21404553].
Matz R. Lung cancer screening. JAMA. 2001;285(2):163-164. Exclusion code: 5. [pmid: 11176797].
Maurel M, Stoufflet A, Thorel L, et al. Factors associated with cancer distress in the Asbestos Post-Exposure Survey (APEXS). Am. J. Ind. Med. 2009;52(4):288-296. Exclusion code: 2. [pmid: 19152347].
Mazzone P. Analysis of volatile organic compounds in the exhaled breath for the diagnosis of lung cancer. J Thorac Oncol. 2008;3(7):774-780. Exclusion code: 5. [pmid: 18594325].
Mazzone P, Obuchowski N, Mekhail T, Meziane M, Ahmad M. Lung cancer screening: is it time for a change in policy?. Cleve. Clin. J. Med. 2007;74(6):441-448. Exclusion code: 5. [pmid: 17569202].
Mazzone PJ, Mekhail T. Lung cancer screening. Curr Oncol Rep. 2007;9(4):265-274. Exclusion code: 2. [pmid: 17588350].
McBride D. Early detection with computed tomography scans can detect lung cancer, may save lives. ONS Connect. 2007;22(2):24. Exclusion code: 5. [pmid: 17393640].
McCarthy PM, Jelsing NC. An advocacy perspective on screening and early diagnosis of lung cancer. Cancer. 2000;89(11 Suppl):2510-2514. Exclusion code: 5. [pmid: 11147638].
McCulloch M, Jezierski T, Broffman M, Hubbard A, Turner K, Janecki T. Diagnostic accuracy of canine scent detection in early- and late-stage lung and breast cancers. Integ Cancer Ther. 2006;5(1):30-39. Exclusion code: 2. [pmid: 16484712].
McCulloch M, Turner K, Broffman M. Lung cancer detection by canine scent: will there be a lab in the lab?. Eur. Respir. J. 2012;39(3):511-512. Exclusion code: 2. [pmid: 22379142].
McCunney RJ. Should we screen for occupational lung cancer with low-dose computed tomography?. J. Occup. Environ. Med. 2006;48(12):1328-1333. Exclusion code: 2. [pmid: 17159649].
McFarlane MJ, Feinstein AR, Wells CK. Clinical features of lung cancers discovered as a postmortem “surprise”. Chest. 1986;90(4):520-523. Exclusion code: 2. [pmid: 3757562].
McGovern PM, Gross CR, Krueger RA, Engelhard DA, Cordes JE, Church TR. False-positive cancer screens and health-related quality of life. Cancer Nurs. 2004;27(5):347-352. Exclusion code: 2. [pmid: 15525861].
McKenna RJ Jr., Fischel RJ, Brenner M, Gelb AF. Combined operations for lung volume reduction surgery and lung cancer. Chest. 1996;110:885-888. Exclusion code: 4. [pmid: 8874240].
McMahon PM, Christiani DC. Computed tomography screening for lung cancer. BMJ. 2007;334(7588):271. Exclusion code: 5. [pmid: 17289689].
McMahon PM, Gazelle SG. Response to “comentary: lung cancer screening--progress or peril. Oncologist. 2008;13(6):733. Exclusion code: 5. [pmid: 18649407].
McMahon PM, Kong CY, Bouzan C, et al. Cost-effectiveness of computed tomography screening for lung cancer in the United States. Journal of Thoracic Oncology. 2011;6(11):1841-1848. Exclusion code: 7. [pmid: 21892105].
McMahon PM, Kong CY, Johnson BE, et al. Estimating long-term effectiveness of lung cancer screening in the Mayo CT screening study. Radiology. 2008;248(1):278-287. Exclusion code: 2. [pmid: 18458247].
McMahon PM, Kong CY, Weinstein MC, et al. Adopting helical CT screening for lung cancer: potential health consequences during a 15-year period. Cancer. 2008;113(12):3440-3449. Exclusion code: 2. [pmid: 18988293].
McNiel A, Blackmon S. VATS lobectomy to treat early-stage non-small cell lung cancer. Jaapa. 2008;21(9):31-33. 37. Exclusion code: 5. [pmid: 18822588].
McWilliams A, Lam S. Lung cancer screening. Curr. Opin. Pulm. Med. 2005;11(4):272-277. Exclusion code: 5. [pmid: 15928490].
McWilliams A, Mayo J. Computed tomography-detected noncalcified pulmonary nodules: a review of evidence for significance and management. Proc. 2008;5(9):900-904. Exclusion code: 5. [pmid: 19056713].
McWilliams A, Mayo J, MacDonald S, et al. Lung cancer screening: a different paradigm. Am. J. Respir. Crit. Care Med. 2003;168(10):1167-1173. Exclusion code: 4. [pmid: 12882756].
McWilliams AM, Mayo JR, Ahn MI, MacDonald SLS, Lam SC. Lung cancer screening using multi-slice thin-section computed tomography and autofluorescence bronchoscopy. J Thorac Oncol. 2006;1(1):61-68. Exclusion code: 2. [pmid: 17409828].
Mehta P, Smith-Bindman R. Airport full-body screening: What is the risk?. Arch. Intern. Med. 2011;171(12):1112-1115. Exclusion code: 5. [pmid: 21444831].
Melamed MR. Lung cancer screening results in the National Cancer Institute New York study. Cancer. 2000;89(11 Suppl):2356-2362. Exclusion code: 5. [pmid: 11147612].
Melamed MR, Flehinger BJ, Zaman MB, Heelan RT, Perchick WA, Martini N. Screening for early lung cancer. Results of the Memorial Sloan-Kettering study in New York. Chest. 1984;86(1):44-53. Exclusion code: 5. [pmid: 6734291].
Mendez D, Warner KE. Setting a challenging yet realistic smoking prevalence target for healthy people 2020: Learning from the California experience. Am. J. Public Health. 2008;98(3):556-559. Exclusion code: 5. [pmid: 17901429].
Merget R, Johnen G, Pesch B, Bruning T. Lung cancer screening revisited -- are we merely combing a giraffe?. Pneumologie. 2005;59(3):165-166. Exclusion code: 6. [pmid: 15756628].
Merget R, Straif K. Screening for bronchial carcinoma still not recommended. Pneumologie. 2001;55(9):445-446. Exclusion code: 6. [pmid: 11536069].
Merkx MAW, Boustahji AH, Kaanders JHAM, et al. A half-yearly chest radiograph for early detection of lung cancer following oral cancer. Int. J. Oral Maxillofac. Surg. 2002;31(4):378-382. Exclusion code: 3. [pmid: 12361070].
Mery CM, Pappas AN, Bueno R, et al. Similar long-term survival of elderly patients with non-small cell lung cancer treated with lobectomy or wedge resection within the surveillance, epidemiology, and end results database. Chest. 2005;128(1):237-245. Exclusion code: 3. [pmid: 16002941].
Mets OM, Buckens CFM, Zanen P, et al. Identification of chronic obstructive pulmonary disease in lung cancer screening computed tomographic scans. JAMA. 2011;306(16):1775-1781. Exclusion code: 2. [pmid: 22028353].
Mettler F, Huda W, Yoshizumi T, Mahesh M. Effective doses in radiology and diagnostic nuclear medicine: a catalog. Radiol. Manage. 2008;248(1):254. [PMID:. Exclusion code: 2.
Meyer G, Besse B, Friard S, et al. Effect of tinzaparin on survival in non-small-cell lung cancer after surgery. TILT: tinzaparin in lung tumours. Rev. Mal. Respir. 2011;28(5):654-659. Exclusion code: 6. [pmid: 21645836].
Meziane M, Decamp M. Low-dose spiral CT for lung cancer screening. Cleve. Clin. J. Med. 2001;68(1):84. Exclusion code: 5. [pmid: 11204370].
Mhaskar AR, Quinn G, Vadaparampil S, Djulbegovic B, Gwede CK, Kumar A. Timing of first-line cancer treatments - early versus late - a systematic review of phase III randomized trials. Cancer Treat. Rev. 2010;36(8):621-628. Exclusion code: 2. [pmid: 20444550].
Michetti G, Pugliese C, Mandalà M. Low-dose CT screening for an early diagnosing of lung cancer. All that glitters is not gold?. Rassegna di Patologia dell'Apparato Respiratorio. 2007;22(2):86-88. [PMID:. Exclusion code: 6.
Midthun DE. Caution: Screening for lung cancer. Expert Rev Respir Med. 2009;3(3):203-205. Exclusion code: 5. [pmid: 20477313].
Midthun DE. Screening for Lung Cancer. Clin. Chest Med. 2011;32(4):659-668. Exclusion code: 5. [pmid: 22054878].
Midthun DE, Jett JR. Update on screening for lung cancer. Semin. 2008;29(3):233-240. Exclusion code: 5. [pmid: 18506661].
Midthun DE, Swensen SJ, Hartman TE, Jett JR. Lung cancer screening results: easily misunderstood. Mayo Clin. Proc. 2007;82(1):14-15. Exclusion code: 5. [pmid: 17285781].
Miettinen OS. Screening for lung cancer. Radiol. Clin. North Am. 2000;38(3):479-486. Exclusion code: 5. [pmid: 10855255].
Miettinen OS, Henschke CI. CT screening for lung cancer: coping with nihilistic recommendations. Radiology. 2001;221(3):592-596. discussion 597. Exclusion code: 5. [pmid: 11719649].
Miettinen OS, Yankelevitz DF, Henschke CI. Screening for lung cancer. N. Engl. J. Med. 2001;344(12):935. author reply 936. Exclusion code: 5. [pmid: 11263430].
Miksad RA. When a decision must be made: Role of computer modeling in clinical cancer research. J. Clin. Oncol. 2011;29(35):4602-4604. Exclusion code: 5. [pmid: 22067392].
Miller A, Markowitz S, Manowitz A, Miller JA. Lung cancer screening using low-dose high-resolution CT scanning in a high-risk workforce: 3500 nuclear fuel workers in three US states. Chest. 2004;125(5 Suppl):152S-153S. Exclusion code: 5. [pmid: 15136477].
Miller A, Markowitz S, Miller JA. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):745. author reply 746-747. Exclusion code: 5. [pmid: 17310517].
Miller A, Markowitz SB, Miller JA. Follow-up diagnostic procedures in lung cancer screening. Am. J. Respir. Crit. Care Med. 2009;180(1):102-103. author reply 103. Exclusion code: 5. [pmid: 19535669].
Health-related quality of life and cost-effectiveness studies in the European randomised study of screening for prostate cancer and the US Prostate, Lung, Colon and Ovary trial (Brief record). John Wiley & Sons, Ltd. Chichester, UK. 2011. http://dx.doi.org/10.1002/14651858. Exclusion code: 5.
Miller AB, Yurgalevitch S, Weissfeld JL, Prostate LC, Ovarian Cancer Screening Trial Project T. Death review process in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control. Clin. Trials. 2000;21(6 Suppl):400S-406S. Exclusion code: 2. [pmid: 11189691].
Miller DL, Rowland CM, Deschamps C, Allen MS, Trastek VF, Pairolero PC. Surgical treatment of non-small cell lung cancer 1 cm or less in diameter. Ann. Thorac. Surg. 2002;73(5):1545-1550. discussion 1550-1541. Exclusion code: 4. [pmid: 12022547].
Miller YE. Minimizing unintended consequences of detecting lung nodules by computed tomography. Am. J. Respir. Crit. Care Med. 2008;178(9):891-892. Exclusion code: 5. [pmid: 18945870].
Milleron B. Screening for lung cancer. Rev. Pneumol. Clin. 2004;60(5 Pt 2):3S11-15. Exclusion code: 6. [pmid: 15536346].
Milleron B. Screening for lung cancer: Feasibility study of a randomized trial comparing low dose spiral CT and chest X-ray [abstract]. Paper presented at: Annual Meeting Proceedings of the American Society of Clinical Oncology. 658p. 2004. Exclusion code: 5.
Milleron B, Mornex F, Martin E, Epaud C, Massiani MA. Preoperative chemotherapy and chemoradiotherapy for non-small-cell bronchial cancers. Cancer Radiother. Suppl 1. 2002;6:105s-113s. Exclusion code: 6. [pmid: 12587388].
Milleron B, Westeel V, Depierre A. Neo-adjuvant chemotherapy of non-small cell bronchial cancers (NSCLC). Presse Med. 2002;31(17):797-801. Exclusion code: 6. [pmid: 12148364].
Mimura T, Ito A, Sakuma T, et al. Novel marker D2-40, combined with calretinin, CEA, and TTF-1: an optimal set of immunodiagnostic markers for pleural mesothelioma. Cancer. 2007;109(5):933-938. Exclusion code: 2. [pmid: 17279584].
Mina K, Byrne MJ, Ryan G, et al. Surgical management of lung cancer in Western Australia in 1996 and its outcomes. ANZ J Surg. 2004;74(12):1076-1081. Exclusion code: 10. [pmid: 15574152].
Minai OA, Shah S, Mazzone P, et al. Bronchogenic carcinoma after lung transplantation: Characteristics and outcomes. Journal of Thoracic Oncology. 2008;3(12):1404-1409. Exclusion code: 7. [pmid: 19057264].
Minami H, Yoshimura M, Matsuoka H, Toshihiko S, Tsubota N. Lung cancer treated surgically in patients <50 years of age. Chest. 2001;120(1):32-36. Exclusion code: 3. [pmid: 11451812].
Miser WF. Cancer screening in the primary care setting: the role of the primary care physician in screening for breast, cervical, colorectal, lung, ovarian, and prostate cancers. Prim. Care. 2007;34(1):137-167. Exclusion code: 5. [pmid: 17481991].
Mitas M, Cole DJ, Hoover L, et al. Real-time reverse transcription PCR detects KS1/4 mRNA in mediatinal lymph nodes from patients with non-small cell lung cancer. Clin. Chem. 2003;49(2):312-315. Exclusion code: 5. [pmid: 12560358].
Miyazawa M, Shiina T, Kurai M, et al. Assessment of the new TNM classification for resected lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(11):915-918. Exclusion code: 6. [pmid: 11048441].
Moghissi K, Dixon K, Stringer MR. Current indications and future perspective of fluorescence bronchoscopy: a review study. Photodiagnosis Photodyn Ther. 2008;5(4):238-246. Exclusion code: 5. [pmid: 19356663].
Moghissi K, Thorpe JA. Screening for lung cancer. J. R. Soc. Med. 2001;94(4):206. Exclusion code: 5. [pmid: 11317631].
Mohammadi S, Bonnet N, Leprince P, et al. Long-term survival of heart transplant recipients with lung cancer: the role of chest computed tomography screening. Thorac. Cardiovasc. Surg. 2007;55(7):438-441. Exclusion code: 3. [pmid: 17902066].
Monari E, Casali C, Cuoghi A, et al. Enriched sera protein profiling for detection of non-small cell lung cancer biomarkers. Proteome Sci. 2011;9(1):55. Exclusion code: 4. [pmid: 21929752].
Mondello B, Sibilio M, Pavone A, et al. “Intentionally” limited pulmonary resection versus lobectomy for the treatment of peripheral stage IA non-small cell lung cancers. G. Chir. 2007;28(1-2):7-12. Exclusion code: 6. [pmid: 17313726].
Montes U, Seijo LM, Campo A, Alcaide AB, Bastarrika G, Zulueta JJ. Factors determining early adherence to a lung cancer screening protocol. Eur. Respir. J. 2007;30(3):532-537. Exclusion code: 4. [pmid: 17567671].
Montuenga LM, Mulshine JL. New molecular strategies for early lung cancer detection. Cancer Invest. 2000;18(6):555-563. Exclusion code: 5. [pmid: 10923104].
Morabia A, Markowitz S. Re: Extended lung cancer incidence follow-up in the Mayo Lung Project and overdiagnosis. J. Natl. Cancer Inst. 2007;99(11):898-899. author reply 899. Exclusion code: 2. [pmid: 17551151].
Mornex F, Loubeyre P, Giraud P, et al. Gross tumor volume and clinical target volume in radiotherapy: lung cancer. Cancer Radiother. 2001;5(5):659-670. Exclusion code: 6. [pmid: 11715317].
Moro D. Neoadjuvant treatment for early stages of non-small-cell lung carcinoma (NSCLC). Rev. Pneumol. Clin. 2001;57(5 Pt 2):S22-24. Exclusion code: 6. [pmid: 11924237].
Motas N, Motas C, Davidescu M, et al. Solitary pulmonary nodule--150 resected cases. Chirurgia (Bucuresti). 2010;105(2):195-201. Exclusion code: 6. [pmid: 20540232].
Motohiro A, Ueda H, Komatsu H, Yanai N, Mori T, National Chest Hospital Study Group for Lung C. Prognosis of non-surgically treated, clinical stage I lung cancer patients in Japan. Lung Cancer. 2002;36(1):65-69. Exclusion code: 2. [pmid: 11891035].
Moy B. Medical integrity up in smoke? Conflicts of interest and the lung cancer screening controversy. Oncologist. 2008;13(5):474-476. Exclusion code: 5. [pmid: 18515732].
Mulshine JL. Screening for lung cancer: in pursuit of pre-metastatic disease. Nature Reviews. Cancer. 2003;3(1):65-73. Exclusion code: 5. [pmid: 12509768].
Mulshine JL. Current issues in lung cancer screening. Oncology (Williston). 2005;19(13):1724-1730. discussion 1730-1721. Exclusion code: 5. [pmid: 16425524].
Mulshine JL. Commentary: lung cancer screening--progress or peril. Oncologist. 2008;13(4):435-438. Exclusion code: 5. [pmid: 18448558].
Mulshine JL, Day RW. Screening for lung cancer. N. Engl. J. Med. 2001;344(12):935-936. Exclusion code: 5. [pmid: 11263428].
Mulshine JL, Hong S, Martinez A, et al. Moving to the routine management of pre symptomatic lung cancer. Lung Cancer. Suppl 2. 2001;34:S1-5. Exclusion code: 5. [pmid: 11720735].
Mulshine JL, Jablons DM. Volume CT for diagnosis of nodules found in lung-cancer screening. N. Engl. J. Med. 2009;361(23):2281-2282. Exclusion code: 5. [pmid: 19955529].
Mulshine JL, Smith RA. Lung cancer. 2: screening and early diagnosis of lung cancer. Thorax. 2002;57(12):1071-1078. Exclusion code: 5. [pmid: 12454304].
Mulshine JL, Weinstein JN. Is the gene expression pattern of lung cancer detected by screening with spiral computed tomography different from that of symptom-detected lung cancer?. Clin. Cancer Res. 2004;10(18 Pt 1):5973-5974. Exclusion code: 5. [pmid: 15447979].
Murakami T, Yasuhara Y, Yoshioka S, Uemura M, Mochizuki T, Ikezoe J. Pulmonary lesions detected in population-based CT screening for lung cancer: reliable findings of benign lesions. Radiat. Med. 2004;22(5):287-295. Exclusion code: 4. [pmid: 15553008].
Murray CP, Wong PM, Louw J, Waterer GW. Western Australian cigarette smokers have fewer small lung nodules than North Americans on CT screening for lung cancer. Journal of Medical Imaging & Radiation Oncology. 2009;53(4):339-344. Exclusion code: 4. [pmid: 19695039].
Mutti A. Molecular diagnosis of lung cancer: an overview of recent developments. Acta Biomed. Ateneo Parmense. Suppl 1. 2008;79:11-23. Exclusion code: 5. [pmid: 18924306].
Nackaerts K, Vansteenkiste J. Low-dose CT screening for lung cancer: trial and error?. J Thorac Oncol. 2009;4(5):563-564. Exclusion code: 5. [pmid: 19395908].
Nagahiro I, Miyamoto M, Sugiyama H, et al. A case of drug-induced eosinophilic pneumonia due to tegafur-uracil. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2011;38(10):1679-1682. Exclusion code: 6. [pmid: 21996966].
Nagahiro I, Nouso H, Kawai T, et al. Pulmonary mucosa-associated lymphoid tissue (MALT) lymphoma accompanied with cystic change. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(4):332-335. Exclusion code: 6. [pmid: 20387510].
Nair A, Hansell DM. European and North American lung cancer screening experience and implications for pulmonary nodule management. Eur. Radiol. 2011;21(12):2445-2454. Exclusion code: 2. [pmid: 21830100].
Nakamura H, Kawasaki N, Taguchi M, Kabasawa K. Survival following lobectomy vs limited resection for stage I lung cancer: a meta-analysis. Br. J. Cancer. 2005;92(6):1033-1037. Exclusion code: 10. [pmid: 15756281].
Nakamura H, Taniguchi Y, Miwa K, et al. Comparison of the surgical outcomes of thoracoscopic lobectomy, segmentectomy, and wedge resection for clinical stage I non-small cell lung cancer. Thorac. Cardiovasc. Surg. 2011;59(3):137-141. Exclusion code: 10. [pmid: 21480132].
Nakanishi R, Nakagawa M, Tokufuchi H, Okumura T, Kuboi S, Kido M. Effects of smoking on video-assisted thoracic surgery lobectomy for lung cancer. J Uoeh. 2010;32(1):45-52. Exclusion code: 6. [pmid: 20232646].
Nakayama T, Baba T, Suzuki T, Sagawa M, Kaneko M. An evaluation of chest X-ray screening for lung cancer in gunma prefecture, Japan: a population-based case-control study. Eur. J. Cancer. 2002;38(10):1380-1387. Exclusion code: 2. [pmid: 12091070].
Nam HS, Yang DH, Kim JS, et al. Clinical characteristics of slowly growing lung cancer: 6 Case-series evaluation. Tuberculosis and Respiratory Diseases. 2010;68(3):180-184. Exclusion code: 5.
National Cancer Institute. Lung cancer trial results show mortality benefit with low-dose CT: Twenty percent fewer lung cancer deaths seen among those who were screened with low-dose spiral CT than with chest X-ray. National Cancer Institute at the National Institutes of Health. 2010. http://www.cancer.gov/newscenter/pressreleases/2010/NLSTresultsRelease. May 20, 2011. Exclusion code: 5.
National Cancer Institute. What Do the 2006-2007 TUS Data Say about Tobacco Use?. 2012. http://riskfactor.cancer.gov/studies/tus-cps/results/data0607/. 27 June 2012. Exclusion code: 5.
National Cancer Institute. Cancer Trends Progress Report - 2011/2012 Update. Person-Years of Life Lost. 2012. http://progressreport.cancer.gov/doc_detail.asp?pid=1&did=2009&chid=96&coid=930&mid. 28 Jan 2012. Exclusion code: 2.
National Comprehensive Cancer Network. NCCN Clinical Practice Guidelines In Oncology: Lung Cancer Screening. NCCN Guidelines. 2012. http://www.nccn.org/professionals/physician_gls/pdf/lung_screening.pdf. 30 Sept 2012. Exclusion code: 2.
National Lung Cancer Partnership. Lung Cancer Screening Trial, Options. http://www.nationallungcancerpartnership.org/news-center/press-releases/screening. 19 September 2012. Exclusion code: 2.
National Lung Screening Trial Research T. Aberle DR, Berg CD, et al. The National Lung Screening Trial: overview and study design. Radiology. 2011;258(1):243-253. Exclusion code: 2. [pmid: 21045183].
Nawa T, Nakagawa T, Kusano S, Kawaski Y, Sugawara Y, Nakata H. Lung cancer screening using low-dose spiral CT: results of baseline and 1-year follow-up studies. Chest. 2002;122(1):15-20. Exclusion code: 2. [pmid: 12114333].
Nawa T, Nakagawa T, Mizoue T, et al. Long-term prognosis of patients with lung cancer detected on low-dose chest computed tomography screening. Lung Cancer. 2012;75(2):197-202. Exclusion code: 3. [pmid: 21813201].
Neal RD, Allgar VL, Ali N, et al. Stage, survival and delays in lung, colorectal, prostate and ovarian cancer: comparison between diagnostic routes. Br. J. Gen. Pract. 2007;57(536):212-219. Exclusion code: 2. [pmid: 17359608].
Negrin-Dastis S, Butenda D, Dorzee J, Fastrez J, d-Odement JP. Complete disappearance of lung abnormalities on high resolution computed tomography: a case of histiocytosis X. Can. Respir. J. 2007;14(4):235-237. Exclusion code: 5. [pmid: 17551600].
Nelson H, Tyne K, Naik A, et al. Screening for Breast Cancer: Systematic Evidence Review Update for the U. S. Preventive Services Task Force. Rockville, MD. 2009. Exclusion code: 2.
Neugut AI, Murray T, Santos J, et al. Increased risk of lung cancer after breast cancer radiation therapy in cigarette smokers. Cancer. 1994;73(6):1615-1620. Exclusion code: 7. [pmid: 8156488].
New York Early Lung Cancer Action Project I. CT Screening for lung cancer: diagnoses resulting from the New York Early Lung Cancer Action Project. Radiology. 2007;243(1):239-249. Exclusion code: 4. [pmid: 17392256].
Newcomb PA, Norfleet RG, Storer BE, Surawicz TS, Marcus PM. Screening sigmoidoscopy and colorectal cancer mortality. J. Natl. Cancer Inst. 1992;84(20):1572-1575. Exclusion code: 7. [pmid: 1404450].
Noel G, Mazeron JJ. A randomized trial of postoperative adjuvant therapy in patients with completely resected stage II or IIIa non-small-cell lung cancer. Cancer Radiother. 2001;5(2):195-196. Exclusion code: 6. [pmid: 11355584].
Nojo T, Imanaka Y, Ishizaki T, et al. Lung cancer incidence in middle-aged men estimated by low-dose computed tomography screening. Lung Cancer. 2009;65(1):56-61. Exclusion code: 4. [pmid: 19019487].
Novello S, Fava C, Borasio P, et al. Three-year findings of an early lung cancer detection feasibility study with low-dose spiral computed tomography in heavy smokers. Ann. Oncol. 2005;16(10):1662-1666. Exclusion code: 4. [pmid: 16006584].
Nowak D, Ochmann U, Huber RM, Diederich S. Lung cancer screening -- state of the art. Pneumologie. 2005;59(3):178-191. Exclusion code: 6. [pmid: 15756631].
O'Brien B, Nichaman L, Browne JE, et al. Coordination and management of a large multicenter screening trial: the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control. Clin. Trials. 2000;21(6 Suppl):310S-328S. Exclusion code: 2. [pmid: 11189685].
Obuchowski NA. Estimating sample size for a randomized clinical trial of lung cancer screening. Contemp Clin Trials. 2008;29(4):466-477. Exclusion code: 4. [pmid: 18088564].
Obuchowski NA, Graham RJ, Baker ME, Powell KA. Ten criteria for effective screening: their application to multislice CT screening for pulmonary and colorectal cancers. AJR. Am. J. Roentgenol. 2001;176(6):1357-1362. Exclusion code: 5. [pmid: 11373191].
O'Connor GT, Hatabu H. Lung Cancer Screening, Radiation, Risks, Benefits, and Uncertainty. JAMA. 2012;307:2434-2435. Exclusion code: 2. [pmid: 22692175].
Oda M, Kanamori T, Marukawa Y, et al. Evaluation of new TNM classification for lung cancer, especially T3N0M0, stage IIIA, stage IIIB, and pm. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(11):905-909. Exclusion code: 6. [pmid: 11048439].
Oda M, Matsumoto I, Tamura M, et al. Video-assisted thoracic surgery for clinical stage I lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2009;62(4):281-284. Exclusion code: 6. [pmid: 19348211].
Oertel S, Debus J, Hof H, Bischof M. Radiation therapy of lung carcinoma. Radiologe. 2010;50(8):669-674. Exclusion code: 6. [pmid: 20628725].
Ohmatsu H, Kakinuma R. Lung cancer screening using low-dose helical CT. Nippon Rinsho - Japanese Journal of Clinical Medicine. Suppl 5. 2002;60:653-656. Exclusion code: 6. [pmid: 12101756].
Ohno Y, Koyama H, Kono A, et al. Influence of detector collimation and beam pitch for identification and image quality of ground-glass attenuation and nodules on 16- and 64-detector row CT systems: Experimental study using chest phantom. Eur. J. Radiol. 2007;64(3):406-413. Exclusion code: 5. [pmid: 17884323].
Ohta S, Hirose M, Ishibashi H, Muro H. Is adjuvant chemotherapy necessary for the peripherally located stage I adenocarcinoma of the lung?. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2007;60(7):519-522. discussion 522-515. Exclusion code: 6. [pmid: 17642210].
Oji Y, Kitamura Y, Kamino E, et al. WT1 IgG antibody for early detection of nonsmall cell lung cancer and as its prognostic factor. Int. J. Cancer. 2009;125(2):381-387. Exclusion code: 2. [pmid: 19384943].
Okada M, Nishio W, Sakamoto T, et al. Effect of tumor size on prognosis in patients with non-small cell lung cancer: the role of segmentectomy as a type of lesser resection. J. Thorac. Cardiovasc. Surg. 2005;129(1):87-93. Exclusion code: 3. [pmid: 15632829].
Okada M, Sakamoto T, Nishio W, Uchino K, Tsubota N. Characteristics and prognosis of patients after resection of nonsmall cell lung carcinoma measuring 2 cm or less in greatest dimension. Cancer. 2003;98(3):535-541. Exclusion code: 10. [pmid: 12879471].
Okada S, Ishimori S, Sato M, Sato S. Thoracoscopic lung resection for a peripheral lung cancer by a single surgeon with a voice-controlled robot. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2001;54(11):968-971. Exclusion code: 6. [pmid: 11593737].
Okada Y, Kondo T. Thoracoscopic surgery for elderly patients. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2005;58(8 Suppl):751-755. Exclusion code: 6. [pmid: 16097631].
Okami J, Higashiyama M, Asamura H, et al. Pulmonary resection in patients aged 80 years or over with clinical stage I non-small cell lung cancer: prognostic factors for overall survival and risk factors for postoperative complications. J Thorac Oncol. 2009;4(10):1247-1253. Exclusion code: 10. [pmid: 19609223].
Okami J, Ito Y, Higashiyama M, et al. Sublobar resection provides an equivalent survival after lobectomy in elderly patients with early lung cancer. Ann. Thorac. Surg. 2010;90(5):1651-1656. Exclusion code: 10. [pmid: 20971281].
Okamoto N. Cost-effectiveness of lung cancer screening in Japan. Cancer. 2000;89(11 Suppl):2489-2493. Exclusion code: 7. [pmid: 11147633].
Okamoto N, Suzuki T, Hasegawa H. Evaluation of a clinic-based screening program for lung cancer with a case-control design in Kanagawa, Japan. Lung Cancer. 1999;25(2):77-85. Exclusion code: 5. [pmid: 10470841].
Okamoto T, Ichinose Y. Adjuvant chemotherapy for non-small cell lung cancer. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2006;33(13):1985-1990. Exclusion code: 6. [pmid: 17197740].
Oken MM, Marcus PM, Hu P, et al. Baseline chest radiograph for lung cancer detection in the randomized Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial. J. Natl. Cancer Inst. 2005;97(24):1832-1839. Exclusion code: 4. [pmid: 16368945].
Omatsu H, Kakinuma R, Kaneko M, Moriyama N, Kusumoto M, Eguchi K. Successful lung cancer screening with low-dose helical CT in addition to chest x-ray and sputum cytology: the comparison of two screening periods with or without helical CT. Radiology. 2000;217(Suppl):242. Exclusion code: 5.
Omori H, Sata K, Saitoh R, et al. Case report of intralobar pulmonary sequestration detected by lung cancer screening with low-dose spiral CT. J Uoeh. 2007;29(3):259-263. Exclusion code: 5. [pmid: 17900005].
Onaitis MW, Petersen RP, Balderson SS, et al. Thoracoscopic lobectomy is a safe and versatile procedure: experience with 500 consecutive patients. Ann. Surg. 2006;244(3):420-425. Exclusion code: 3. [pmid: 16926568].
Osaki T, Oyama T, Takenoyama M, et al. Results of surgical treatment for primary lung cancer; time trends of survival and clinicopathologic features. J Uoeh. 2001;23(3):277-283. Exclusion code: 6. [pmid: 11570051].
Osako T, Shiraishi I, Oorui H. Video-assisted thoracic surgery for lung cancer at Kyoto City Hospital. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2009;62(4):271-276. Exclusion code: 6. [pmid: 19348209].
Osann K. Lung cancer in women: the importance of smoking, family history of cancer, and medical history of respiratory disease. Cancer Res. 1991;51(18):4893-4897. Exclusion code: 2. [pmid: 1654203].
Osann KE, Anton-Culver H, Kurosaki T, Taylor T. Sex differences in lung-cancer risk associated with cigarette smoking. Int. J. Cancer. 1993;54(1):44-48. Exclusion code: 5. [pmid: 8386708].
Oshima A. Prevention of lung cancer through smoking control activities in Japan. Nihon Kyobu Shikkan Gakkai Zasshi. 1995;33(Suppl):13-16. Exclusion code: 6. [pmid: 8752476].
Oskarsdottir GN, Skuladottir R, Isaksson HJ, Jonsson S, Thorsteinsson H, Gudbjartsson T. Factors predictive of survival after lobectomy for non-small cell lung cancer in Iceland during 1999-2008. Laeknabladid. 2010;96(4):251-257. Exclusion code: 6. [pmid: 20339164].
Ostroff JS, Buckshee N, Mancuso CA, Yankelevitz DF, Henschke CI. Smoking cessation following CT screening for early detection of lung cancer. Prev. Med. 2001;33(6):613-6221. Exclusion code: 5. [pmid: 11716658].
Osuch-Wojcikiewicz E, Rzepakowska A, Bruzgielewicz A, Wieczorek J. Follicular (nodular) non Hodgkin's lymphoma of tonsil--case report. Otolaryngol. Pol. 2007;61(2):203-206. Exclusion code: 6. [pmid: 17668812].
Oura H, Hirose M, Aikawa H, Ishiki M. Abdominal organ infarction encountered immediately after surgery of primary lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2005;58(2):137-142. Exclusion code: 6. [pmid: 15724477].
Oura H, Hirose M, Ishiki M. Diplopia and blepharoptosis associated with orbital emphysema following thoracotomy with lung cancer; report of a case. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2004;57(6):501-504. Exclusion code: 6. [pmid: 15202274].
Oura H, Hirose M, Ishiki M, Takeuchi K, Hirano H, Tomichi N. Conservative therapy for recurrent bronchial stump fistula occurred after surgery for lung cancer with cerebrovascular disease. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2003;56(10):829-833. Exclusion code: 6. [pmid: 13677917].
Oura H, Ueda S, Sawada T, Watanabe Y, Handa M, Tomichi N. Reoperation for left main bronchial stump fistula developing after pneumonectomy. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(6):466-469. Exclusion code: 6. [pmid: 18536295].
Ozols RF, Herbst RS, Colson YL, et al. Clinical cancer advances 2006: major research advances in cancer treatment, prevention, and screening--a report from the American Society of Clinical Oncology. J. Clin. Oncol. 2007;25(1):146-162. Exclusion code: 5. [pmid: 17158528].
Paci E. Observational, one-arm studies and randomized population-based trials for evaluation of the efficacy of lung cancer screening. J Thorac Oncol. 2007;2(5 Suppl):S45-46. Exclusion code: 5. [pmid: 17457234].
Padilla J, Penalver JC, Calvo V, et al. Small-cell nonanaplastic bronchogenic carcinoma. The new stage I. Arch. Bronconeumol. 2000;36(2):68-72. Exclusion code: 6. [pmid: 10726193].
Padilla J, Penalver JC, Jorda C, et al. Non-small cell bronchogenic cancer in stage IA: mortality patterns after surgery. Arch. Bronconeumol. 2005;41(4):180-184. Exclusion code: 6. [pmid: 15826526].
Padley SP. Thoracic radiology. Clin. Radiol. 2001;56(3):191-192. Exclusion code: 5. [pmid: 11247694].
Paleari L, Cesario A, Granone P, D'Angelillo RM, Russo P. Early detection of cancer: lessons from lung cancer CT screening. [Erratum appears in Thorax. 2008 Sep;63(9):844]. Thorax. 2008;63(6):566. Exclusion code: 5. [pmid: 18511643].
Paleari L, Granone P, Cesario A, Russo P. Re: Computed tomography screening for lung cancer: review of screening principles and update on current status. Cancer. 2008;112(11):2520-2521. author reply 2521. Exclusion code: 5. [pmid: 18438783].
Paleari L, Granone P, Grozio A, Cesario A, Russo P. Commentary: early diagnosis of lung cancer: where do we stand?. Oncologist. 2007;12(12):1433-1436. Exclusion code: 5. [pmid: 18165620].
Palussiere J, Descat E, Fonck M, et al. Radiofrequency ablation in the treatment of liver and lung tumors. Bull. Cancer (Paris). 2009;96(11):1099-1109. Exclusion code: 6. [pmid: 19858044].
Pan H, Li L, Zuo CT, et al. Relationship between combined multigene detection and response to adjuvant chemotherapy in early-stage non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2008;30(7):528-531. Exclusion code: 6. [pmid: 19062721].
Pandharipande PV, Gazelle GS. Comparative effectiveness research: What it means for radiology. Radiology. 2009;253(3):600-605. Exclusion code: 5. [pmid: 19952024].
Paoletti L, Pastis N, Denlinger C, Silvestri G. A Decade of Advances in Treatment of Early-Stage Lung Cancer. Clin. Chest Med. 2011;32(4):827-838. Exclusion code: 5. [pmid: 22054889].
Papadakis E. Adjuvant treatment for early stages of non-small-cell lung carcinoma (NSCLC). Rev. Pneumol. Clin. 2001;57(5 Pt 2):S25-28. Exclusion code: 6. [pmid: 11924238].
Parissis H, Leotsinidis M, Hughes A, McGovern E, Luke D, Young V. Comparative analysis and outcomes of sleeve resection versus pneumonectomy. Asian Cardiovasc Thorac Ann. 2009;17(2):175-182. Exclusion code: 10. [pmid: 19592550].
Park BJ, Altorki NK. Diagnosis and management of early lung cancer. Surg. Clin. North Am. 2002;82(3):457-476. v. Exclusion code: 5. [pmid: 12371580].
Park BJ, Melfi F, Mussi A, et al. Robotic lobectomy for non-small cell lung cancer (NSCLC): long-term oncologic results. J. Thorac. Cardiovasc. Surg. 2012;143(2):383-389. Exclusion code: 10. [pmid: 22104677].
Park ER, Ostroff JS, Rakowski W, et al. Risk perceptions among participants undergoing lung cancer screening: baseline results from the National Lung Screening Trial. _nn. Behav. Med. 2009;37(3):268-279. Exclusion code: 2. [pmid: 19711141].
Parles K. Low-dose spiral CT screening. Chest. 2001;120(3):1042-1043. Exclusion code: 2. [pmid: 11555555].
Parshin VD, Belov IV, Tarabrin EA, Komarov RN, Parshin VV, Khovrin VV. Resection and aorta replacement in extended and combined operations for lung cancer. Vestnik Khirurgii Imeni i - i - Grekova. 2011;170(1):66-69. Exclusion code: 6. [pmid: 21506360].
Parshin VD, Grigor'eva SP, Mirzoian OS, et al. Surgery for lung cancer in elderly. Khirurgiia (Sofiia). 2010;(10):11-16. Exclusion code: 6. [pmid: 21169924].
Partain CL. Focus on thoracic imaging. J. Magn. Reson. Imaging. 2010;32(6):1271-1272. Exclusion code: 5. [pmid: 21105133].
Pasini F, Verlato G, Durante E, et al. Persistent excess mortality from lung cancer in patients with stage I non-small-cell lung cancer, disease-free after 5 years. Br. J. Cancer. 2003;88(11):1666-1668. Exclusion code: 10. [pmid: 12771977].
Pass HI, Altorki NK. Computerized tomographic nodule heterogeneity: present and future impact on indications for sublobar resections. Clin Lung Cancer. 2004;6(1):20-27. Exclusion code: 5. [pmid: 15310413].
Pastorino U. Lung cancer: diagnosis and surgery. Eur. J. Cancer. Suppl 7. 2001;37:S75-90. Exclusion code: 2. [pmid: 11888008].
Pastorino U. Early detection of lung cancer. Respiration. 2006;73(1):5-13. Exclusion code: 5. [pmid: 16498267].
Pastorino U. Lung cancer screening. Br. J. Cancer. 2010;102(12):1681-1686. Exclusion code: 5. [pmid: 20424610].
Pastorino U, Andreola S, Tagliabue E, et al. Immunocytochemical markers in stage I lung cancer: relevance to prognosis. J. Clin. Oncol. 1997;15(8):2858-2865. Exclusion code: 10. [pmid: 9256129].
Pastorino U, Bellomi M, Landoni C, et al. Early lung-cancer detection with spiral CT and positron emission tomography in heavy smokers: 2-year results. Lancet. 2003;362(9384):593-597. Exclusion code: 4. [pmid: 12944057].
Pastorino U, Borasio P, Francese M, et al. Lung cancer stage is an independent risk factor for surgical mortality. Tumori. 2008;94(3):362-369. Exclusion code: 7. [pmid: 18705405].
Pastorino U, Landoni C, Marchiano A, et al. Fluorodeoxyglucose uptake measured by positron emission tomography and standardized uptake value predicts long-term survival of CT screening detected lung cancer in heavy smokers. J Thorac Oncol. 2009;4(11):1352-1356. Exclusion code: 4. [pmid: 19861905].
Patz EF Jr. Lung cancer screening, overdiagnosis bias, and reevaluation of the Mayo Lung Project. J. Natl. Cancer Inst. 2006;98(11):724-725. Exclusion code: 2. [pmid: 16757691].
Patz EF Jr., Black WC, Goodman PC. CT screening for lung cancer: not ready for routine practice. Radiology. 2001;221(3):587-591. discussion 598-589. Exclusion code: 5. [pmid: 11719648].
Patz EF Jr., Caporaso NE, Dubinett SM, et al. National Lung Cancer Screening Trial American College of Radiology Imaging Network Specimen Biorepository originating from the Contemporary Screening for the Detection of Lung Cancer Trial (NLST, ACRIN 6654): design, intent, and availability of specimens for validation of lung cancer biomarkers. J Thorac Oncol. 2010;5(10):1502-1506. Exclusion code: 5. [pmid: 20871260].
Patz EF Jr., Goodman PC. Low-dose spiral computed tomography screening for lung cancer: not ready for prime time. Am. J. Respir. Crit. Care Med. 2001;163(4):813-814. Exclusion code: 5. [pmid: 11282746].
Patz EF Jr., Goodman PC, Bepler G. Screening for lung cancer. N. Engl. J. Med. 2000;343(22):1627-1633. Exclusion code: 5. [pmid: 11096172].
Patz EF Jr., Rossi S, Harpole DH Jr., Herndon JE, Goodman PC. Correlation of tumor size and survival in patients with stage IA non-small cell lung cancer. Chest. 2000;117(6):1568-1571. Exclusion code: 4. [pmid: 10858384].
Patz EF Jr., Swensen SJ, Herndon JE 2nd. Estimate of lung cancer mortality from low-dose spiral computed tomography screening trials: implications for current mass screening recommendations. J. Clin. Oncol. 2004;22(11):2202-2206. Exclusion code: 2. [pmid: 15169809].
Patz J EF, Campa MJ, Gottlin EB, Kusmartseva I, Xiang RG, Herndon Ii JE. Panel of serum biomarkers for the diagnosis of lung cancer. J. Clin. Oncol. 2007;25(35):5578-5583. Exclusion code: 4. [pmid: 18065730].
Pedersen JH, Dirksen A, Olsen JH. Screening for lung cancer with low-dosage CT. Ugeskr. Laeger. 2002;164(2):167-170. Exclusion code: 6. [pmid: 11831081].
Peek LJ. Immunology for detection of early-stage lung cancer. MLO. Med. Lab. Obs. 2010;42(10):16. Exclusion code: 5. [pmid: 21090050].
Pegna AL, Picozzi G. Lung cancer screening update. Curr. Opin. Pulm. Med. 2009;15(4):327-333. Exclusion code: 5. [pmid: 19395971].
Pei J, Han B, Zhang J, Gu A. Multivariate survival analysis of patients with stage I NSCLC. Zhongguo Fei Ai Za Zhi. 2011;14(12):926-932. Exclusion code: 6. [pmid: 22152692].
Pelosi G, Sonzogni A, Veronesi G, et al. Pathologic and molecular features of screening low-dose computed tomography (LDCT)-detected lung cancer: a baseline and 2-year repeat study. Lung Cancer. 2008;62(2):202-214. Exclusion code: 2. [pmid: 18450320].
Penalver JC, Padilla J, Jorda C, et al. Use of blood products in patients treated surgically for stage I non-small cell lung cancer. Arch. Bronconeumol. 2005;41(9):484-488. Exclusion code: 6. [pmid: 16194510].
Pepe MS, Feng Z, Janes H, Bossuyt PM, Potter JD. Pivotal evaluation of the accuracy of a biomarker used for classification or prediction: Standards for study design. J. Natl. Cancer Inst. 2008;100(20):1432-1438. Exclusion code: 2. [pmid: 18840817].
Petersen RH, Hansen HJ, Dirksen A, Pedersen JH. Lung cancer screening and video-assisted thoracic surgery. J Thorac Oncol. 2012;7(6):1026-1031. Exclusion code: 7. [pmid: 22588154].
Petkova E, Grudeva V, Hadzhidekova V. Low doses of ionizing radiation - Medical application and possible effects. General Medicine. 2011;13(2):37-40. [PMID:. Exclusion code: 5.
Peto R, Lopez AD, Boreham J, Thun M, Heath CJ. Mortality from Smoking in Developed Countries 1950-2000. Indirect Estimates from National Vital Statistics. New York. Oxford University Press. 1994. Exclusion code: 8.
Petrov D, Vlasov V, Stanoev V, Kostadinov M, Danon S, Kirova G. Results of the operative treatment of primary pulmonary sarcomas. Khirurgiia (Sofiia). 2008;(1-2):13-17. Exclusion code: 6. [pmid: 18983003].
Petty TL. The early identification of lung carcinoma by sputum cytology. Cancer. 2000;89(11 Suppl):2461-2464. Exclusion code: 2. [pmid: 11147627].
Petty TL. The early diagnosis of lung cancer. Dis. Mon. 2001;47(6):204-264. Exclusion code: 5. [pmid: 11473242].
Petty TL. Lung cancer detection: a new challenge for Irish medicine. Ir. Med. J. 2001;94(2):36-37. Exclusion code: 5. [pmid: 11321167].
Petty TL. Sputum cytology for the detection of early lung cancer. Curr. Opin. Pulm. Med. 2003;9(4):309-312. Exclusion code: 5. [pmid: 12806245].
Petty TL. Screening for lung cancer. Ann. Intern. Med. 2004;141(8):649-650. Exclusion code: 5. [pmid: 15492350].
Pfannschmidt J, Muley T, Bulzebruck H, Hoffmann H, Dienemann H. Prognostic assessment after surgical resection for non-small cell lung cancer: experiences in 2083 patients. Lung Cancer. 2007;55(3):371-377. Exclusion code: 7. [pmid: 17123661].
Pfannschmidt J, Muley T, Hoffmann H, Bulzebruck H, Dienemann H. Prognosis after complete surgical resection for non-small cell lung cancer based on the staging classification. Dtsch. Med. Wochenschr. 2006;131(47):2643-2648. Exclusion code: 6. [pmid: 17109272].
Phelps RM, Smith DK, Heilig CM, et al. Cancer incidence in women with or at risk for HIV. Int. J. Cancer. 2001;94(5):753-757. Exclusion code: 5. [pmid: 11745473].
Phillips M, Altorki N, Austin JHM, et al. Prediction of lung cancer using volatile biomarkers in breath. Cancer Biomark. 2007;3(2):95-109. Exclusion code: 2. [pmid: 17522431].
Picozzi G, Paci E, Lopez Pegna A, et al. Screening of lung cancer with low dose spiral CT: results of a three year pilot study and design of the randomised controlled trial “Italung-CT”. Radiol. Med. (Torino). 2005;109(1-2):17-26. Exclusion code: 3. [pmid: 15729183].
Pierce DA, Sharp GB, Mabuchi K. Joint effects of radiation and smoking on lung cancer risk among Atomic bomb survivors. Radiat. Res. 2005;163(6):694-695. Exclusion code: 3. [pmid: 16044494].
Pigula FA, Keenan RJ, Ferson PF, Landreneau RJ. Unsuspected lung cancer found in work-up for lung reduction operation. Ann. Thorac. Surg. 1996;61(1):174-176. Exclusion code: 4. [pmid: 8561548].
Pilgram TK, Quirk JD, Bierhals AJ, et al. Accuracy of emphysema quantification performed with reduced numbers of CT sections. AJR. Am. J. Roentgenol. 2010;194(3):585-591. Exclusion code: 7. [pmid: 20173132].
Pinsky PF, Freedman M, Kvale P, Oken M, Caporaso N, Gohagan J. Abnormalities on chest radiograph reported in subjects in a cancer screening trial. Chest. 2006;130(3):688-693. Exclusion code: 2. [pmid: 16963664].
Pistelli F, Aquilini F, Tavanti L, et al. Smoking cessation over the first year of follow up in a lung cancer screening with spiral chest CT scan (Italung CT study) [Abstract]. Eur. Respir. J. 2007;30(Suppl 51):503s. Exclusion code: 5.
Pizzocaro G, Schiavo M, Solima S, Vitellaro M, Biasoni N, Nicolai N. Long-term results of laparoscopic retroperitoneal lymph node dissection (RPLND) in low-stage nonseminomatous germ-cell testicular tumors (NSGCTT) performed by a senior surgeon: 1999-2003. Urologia. Suppl 17. 2010;77:50-56. Exclusion code: 6. [pmid: 21308676].
Plickova K, Spidlen V, Pesek M, Mukensnabl P. Patient survival analysis in surgery of bronchogenic carcinoma from 1986 to 1997. Rozhl. Chir. 2003;82(6):293-299. Exclusion code: 6. [pmid: 12898778].
Ploeg AJ, Kappetein AP, van Tongeren RB, Pahlplatz PV, Kastelein GW, Breslau PJ. Factors associated with perioperative complications and long-term results after pulmonary resection for primary carcinoma of the lung. Eur. J. Cardiothorac. Surg. 2003;23(1):26-29. Exclusion code: 3. [pmid: 12493499].
Poghosyan H, Kennedy Sheldon L, Cooley ME. The impact of computed tomography screening for lung cancer on smoking behaviors: A teachable moment?. Cancer Nurs. 2011. Exclusion code: 2. [pmid: 22209869].
Popescu I. Pre-neoplastic bronchial lesions: possibilities of diagnosis and chemo-prevention. Pneumologia. 2008;57(4):201-208. Exclusion code: 6. [pmid: 19186682].
Porrello C, Alifano M, Forti Parri SN, et al. Surgical treatment of stage I lung cancer. Results and prognostic factors. J. Cardiovasc. Surg. (Torino). 2002;43(5):723-727. Exclusion code: 10. [pmid: 12386592].
Port JL, Kent M, Altorki NK. Early lung cancer detection and treatment strategies. Surg. Oncol. 2002;11(4):191-199. Exclusion code: 5. [pmid: 12450555].
Portalone L. Low dose spiral computed tomography. Monaldi Archives for Chest Disease. 2002;57(5-6):291-292. Exclusion code: 5. [pmid: 12814044].
Porter JC, Spiro SG. Detection of early lung cancer. Thorax. Suppl 1. 2000;55:S56-62. Exclusion code: 5. [pmid: 10943641].
Postmus PE. Screening and early diagnosis in lung cancer. Expert Rev Anticancer Ther. 2008;8(10):1529-1531. Exclusion code: 5. [pmid: 18925844].
Postmus PE. Screening for lung cancer, an ongoing debate. Ann. Oncol. Suppl 7. 2008;19:vii25-27. Exclusion code: 5. [pmid: 18790961].
Prasse A, Waller C, Passlick B, Muller-Quernheim J. Lung cancer from the perspective of internal medicine and surgery. Radiologe. 2010;50(8):662-668. Exclusion code: 6. [pmid: 20652215].
Prorok PC, Andriole GL, Bresalier RS, et al. Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control. Clin. Trials. 2000;21(6 Suppl):273S-309S. Exclusion code: 8. [pmid: 11189684].
Pu Q, Liu LX, Che GW, et al. The learning curve of single-direction complete video-assisted thoracoscopic surgery for lung cancer. Chung-Hua Wai Ko Tsa Chih. Chinese Journal of Surgery. 2010;48(15):1161-1165. Exclusion code: 6. [pmid: 21055011].
Pyenson BS, Sander MS, Jiang Y, Khan H, Mulshine JL. An Actuarial Analysis Shows That Offering Lung Cancer Screening As An Insurance Benefit Would Save Lives At Relatively Low Cost. Health Aff. (Millwood). 2012;31(4):770-779. Exclusion code: 2. [pmid: 22492894].
Qiao M, Pardee AB. Biomarkers, regerons, and pathways to lethal cancer. J. Cell. Biochem. 2007;102(5):1076-1086. Exclusion code: 5. [pmid: 17957698].
Qin M, Fu Y, Yu D, Xu S, Han M, Wang Z. Diagnosis and treatment of tracheal or bronchuotracheal adenoid cystic carcinoma. Zhongguo Fei Ai Za Zhi. 2010;13(6):628-631. Exclusion code: 6. [pmid: 20681452].
Qiu Q, Todd NW, Li R, et al. Magnetic enrichment of bronchial epithelial cells from sputum for lung cancer diagnosis. Cancer. 2008;114(4):275-283. Exclusion code: 2. [pmid: 18484646].
Quekel LG, Kessels AG, Goei R, Van Engelshoven JM. Miss rate of lung cancer on the chest radiograph in clinical practice. Chest. 1999;115(3):720-724. Exclusion code: 5. [pmid: 10084482].
Raji OY, Duffy SW, Agbaje OF, et al. Predictive Accuracy of the Liverpool Lung Project Risk Model for Stratifying Patients for Computed Tomography Screening for Lung CancerA Case–Control and Cohort Validation Study. Ann. Intern. Med. 2012;157(4):242-250. Exclusion code: 2. [pmid: 22910935].
Ram SF, RodriguezRoisin R, GranadosNavarrete A, GarciaAymerich J, Barnes NC. Antibiotics for exacerbations of chronic obstructive pulmonary disease [Systematic Review]. Cochrane Database of Systematic Reviews. 2011. Exclusion code: 4.
Ravenel JG, Costello P, Silvestri GA. Screening for lung cancer. AJR. Am. J. Roentgenol. 2008;190(3):755-761. Exclusion code: 2. [pmid: 18287449].
Raynaud C, Le Caer H, Borget I, et al. Comprehensive geriatric assessment and complications after resection for lung cancer. Rev. Mal. Respir. 2010;27(5):483-488. Exclusion code: 6. [pmid: 20569881].
Read C, Janes S, George J, Spiro S. Early lung cancer: screening and detection. Prim. 2006;15(6):332-336. Exclusion code: 5. [pmid: 17088104].
Reed MF, Molloy M, Dalton EL, Howington JA. Survival after resection for lung cancer is the outcome that matters. Am. J. Surg. 2004;188(5):598-602. Exclusion code: 10. [pmid: 15546578].
Reich J. Hazards of lung cancer screening: three vignettes and a critique. Chest. 2001;119(2):659-660. Exclusion code: 5. [pmid: 11171757].
Reich JM. Improved survival and higher mortality: the conundrum of lung cancer screening. Chest. 2002;122(1):329-337. Exclusion code: 5. [pmid: 12114377].
Reich JM. Lung-cancer screening. N. Engl. J. Med. 2005;353(20):2194-2195. author reply 2194-2195. Exclusion code: 5. [pmid: 16291993].
Reich JM. Estimated impact of LDCT-identified stage IA non-small-cell lung cancer on screening efficacy. Lung Cancer. 2006;52(3):265-271. Exclusion code: 5. [pmid: 16616394].
Reich JM. A critical appraisal of overdiagnosis: estimates of its magnitude and implications for lung cancer screening. Thorax. 2008;63(4):377-383. Exclusion code: 2. [pmid: 18364449].
Reich JM. Lung cancer screening outcomes. Radiology. 2009;253(1):277. Exclusion code: 5. [pmid: 19789261].
Reich JM, Kim JS. Lung cancer growth dynamics. Eur. J. Radiol. 2011;80(3):e458-e461. Exclusion code: 5. [pmid: 20810232].
Resnick EM, Keitt SK, Marts SA. A report from the Society for Women's Health Research. Lung Cancer. 2005;47(3):427-433. Exclusion code: 2. [pmid: 15782441].
Retico A, Delogu P, Fantacci ME, Gori I, Preite Martinez A. Lung nodule detection in low-dose and thin-slice computed tomography. Comput. Biol. Med. 2008;38(4):525-534. Exclusion code: 2. [pmid: 18342844].
Rice D, Kim HW, Sabichi A, et al. The risk of second primary tumors after resection of stage I nonsmall cell lung cancer. Ann. Thorac. Surg. 2003;76(4):1001-1007. discussion 1007-1008. Exclusion code: 4. [pmid: 14529975].
Rino Y, Sekino Y, Yamada T, et al. Irinotecan+cisplatin and irradiation are effective for brain metastases of gastric cancer--two case reports. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2007;34(7):1095-1098. Exclusion code: 6. [pmid: 17637547].
Riquet M, Le Pimpec Barthes F, Scotte F, et al. Relevance of surgery in small cell lung cancer. Rev. Pneumol. Clin. 2009;65(3):129-135. Exclusion code: 6. [pmid: 19524800].
Risch A, Plass C. Lung cancer epigenetics and genetics. Int. J. Cancer. 2008;123(1):1-7. Exclusion code: 2. [pmid: 18425819].
Rivera C, Dahan M, Bernard A, Falcoz PE, Thomas P. Surgical treatment of lung cancer in the octogenarians: results of a nationwide audit. Eur. J. Cardiothorac. Surg. 2011;39(6):981-986. Exclusion code: 3. [pmid: 21030267].
Rivera C, Falcoz PE, Bernard A, Thomas PA, Dahan M. Surgical management and outcomes of elderly patients with early stage non-small cell lung cancer: a nested case-control study. Chest. 2011;140(4):874-880. Exclusion code: 3. [pmid: 21436251].
Rivera MP, Stover DE. Gender and lung cancer. Clin. Chest Med. 2004;25(2):391-400. Exclusion code: 2. [pmid: 15099898].
Rizvi N, Hayes DF. A “breathalyser” for lung cancer? [comment]. Lancet. 1999;353(9168):1897-1898. Exclusion code: 5. [pmid: 10371562].
Roberts HC, Patsios D, Paul NS, et al. Lung cancer screening with low-dose computed tomography: Canadian experience. Can. Assoc. Radiol. J. 2007;58(4):225-235. Exclusion code: 5. [pmid: 18186434].
Roberts HC, Patsios DA, Paul NS, et al. Screening for malignant pleural mesothelioma and lung cancer in individuals with a history of asbestos exposure. J Thorac Oncol. 2009;4(5):620-628. Exclusion code: 2. [pmid: 19357540].
Rodondi N, Cornuz J. Potential pitfalls in reading medical articles for primary care physicians. Lecture d'articles médicaux: Quelques pièges à éviter. 2007;3(135):2718-2723. Exclusion code: 5. [pmid: 18214225].
Rodríguez Lajusticia L. Epidemiology of lung cancer. Revisiones en Cancer. 2009;23(4):125-130. [PMID:. Exclusion code: 6.
Rosell R, Wei J, Taron M. Circulating MicroRNA Signatures of Tumor-Derived Exosomes for Early Diagnosis of Non-Small-Cell Lung Cancer. Clin Lung Cancer. 2009;10(1):8-9. Exclusion code: 2. [pmid: 19289365].
Rosenbaum DH, Bhojani RA, Dikmen E, et al. Routine computed tomography screening of the chest in high-risk cardiac transplant recipients may improve survival. J. Heart Lung Transplant. 2005;24(12):2043-2047. Exclusion code: 3. [pmid: 16364847].
Rotunno M, Hu N, Su H, et al. A gene expression signature from peripheral whole blood for stage I lung adenocarcinoma. Cancer Prev Res (Phila Pa). 2011;4(10):1599-1608. Exclusion code: 2. [pmid: 21742797].
Roviaro G, Varoli F, Vergani C, Nucca O, Maciocco M, Grignani F. Long-term survival after videothoracoscopic lobectomy for stage I lung cancer. Chest. 2004;126(3):725-732. Exclusion code: 10. [pmid: 15364748].
Rozenshtein A, White CS, Austin JHM. Incidental lung carcinoma detected at CT in patients selected for lung volume reduction surgery to treat severe pulmonary emphysema. Radiology. 1998;207:487-490. Exclusion code: 3. [pmid: 9577499].
Rubin RN. Asymptomatic smoker who requests lung cancer screening. Consultant. 2007;47(6):575-576. Exclusion code: 5.
Rubin RN. A 69-year-old former smoker with cough. Consultant. 2010;50(10). Exclusion code: 5.
Rueth NM, Andrade RS. Is VATS lobectomy better: perioperatively, biologically and oncologically?. Ann. Thorac. Surg. 2010;89(6):S2107-2111. Exclusion code: 2. [pmid: 20493991].
Rueth NM, Parsons HM, Habermann EB, et al. The long-term impact of surgical complications after resection of stage I nonsmall cell lung cancer: a population-based survival analysis. Ann. Surg. 2011;254(2):368-374. Exclusion code: 3. [pmid: 21617585].
Rueth NM, Parsons HM, Habermann EB, et al. Surgical treatment of lung cancer: predicting postoperative morbidity in the elderly population. J. Thorac. Cardiovasc. Surg. 2012;143(6):1314-1323. Exclusion code: 2. [pmid: 22341420].
Ruiz M. Early lung cancer detection in HIV: the role of CT screening in high risk cases. HIV Clinician. 2010;22(1):1-5. Exclusion code: 5. [pmid: 20333820].
Russo P, Paleari L, Granone P, Cesario A, Pastorino U. Computed tomography screening for lung cancer in a high-risk population: update on current status. J. Natl. Cancer Inst. 2008;100(14):1043-1044. Exclusion code: 2. [pmid: 18612133].
Rzechonek A, Kołodziej J, Kołodziej M. Multirow computed X-ray tomography in surgical treatment of lung tumors. Family Medicine and Primary Care Review. 2008;10(3):1052-1060. Exclusion code: 6.
Sadovnikov AA, Panchenko KI. Infiltrative tuberculosis and lung cancer. Probl. 2007;(1):55-60. Exclusion code: 6. [pmid: 17338357].
Sagawa M, Nakayama T, Tsukada H, et al. The efficacy of lung cancer screening conducted in 1990s: four case-control studies in Japan. Lung Cancer. 2003;41(1):29-36. Exclusion code: 5. [pmid: 12826309].
Sagawa M, Saito Y, Sato M, et al. The efficacy of sputum cytology in mass screening program for early detection of lung cancer. Anticancer Res. 2003;23(1B):597-600. Exclusion code: 2. [pmid: 12680153].
Saghir Z, Ashraf H, Dirksen A, Brodersen J, Pedersen JH. Contamination during 4 years of annual CT screening in the Danish Lung Cancer Screening Trial (DLCST). Lung Cancer. 2011;71(3):323-327. Exclusion code: 2. [pmid: 20619924].
Saito G, Takasuna K, Yoshida K, Nishimura H. Acute pulmonary embolism following lung resection: report of two cases. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2007;60(10):946-949. Exclusion code: 6. [pmid: 17877019].
Saito M, Miura T, Furukawa K, Kato H. Reevaluation of the surgical indications for lung cancer based on the N factor. Nippon Geka Gakkai Zasshi. 2001;102(7):511-516. Exclusion code: 6. [pmid: 11505502].
Sakamoto S, Homma S, Kawabata M, et al. Fatal acute exacerbation of idiopathic pulmonary fibrosis/usual interstitial pneumonia initially in the right lung after surgery lobectomy for left lung cancer. Nihon Kokyuki Gakkai Zasshi. 2004;42(8):760-766. Exclusion code: 6. [pmid: 15455951].
Sakhelashvili MI, Soldatenko OI, Pritula EI, Lutsyshin TV. Diagnostic features of tuberculosis and cancer of the lung detected in patients during planned screening. Probl. Tuberk. 2002;(5):27-29. Exclusion code: 6. [pmid: 12164115].
Sakurai H, Asamura H, Goya T, et al. Survival differences by gender for resected non-small cell lung cancer: a retrospective analysis of 12,509 cases in a Japanese Lung Cancer Registry study. J Thorac Oncol. 2010;5(10):1594-1601. Exclusion code: 5. [pmid: 20736855].
Sakurai H, Dobashi Y, Mizutani E, et al. Prognosis of resected stage I bronchioloalveolar carcinoma of the lung. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2004;57(6):440-443. Exclusion code: 6. [pmid: 15202261].
Salomaa ER. Does the early detection of lung carcinoma improve prognosis? The Turku Study. Cancer. 2000;89(11 Suppl):2387-2391. Exclusion code: 8. [pmid: 11147616].
Samet JM, Crowell RE, Estepar RSJ, et al. Providing Guidance for Lung Cancer Screening: The American Lung Association Interim Report on Lung Cancer Screening. 2012. Exclusion code: 2.
Samet JM, Thun MJ, De Gonzalez AB. Models of smoking and lung cancer risk: A means to an end. Epidemiology. 2007;18(5):649-651. Exclusion code: 5. [pmid: 17700254].
Sánchez De Cos Escuín J. Lung Cancer in Spain. Current Epidemiology, Survival, and Treatment. Arch. Bronconeumol. 2009;45(7):341-348. Exclusion code: 6. [pmid: 19324488].
Sanderson DR, Fontana R. Results of Mayo Lung Project: an interim report. Recent Results Cancer Res. 1982;82:179-186. Exclusion code: 5. [pmid: 6287546].
Sandler DP, Weinberg CR, Shore DL, et al. Indoor radon and lung cancer risk in connecticut and utah. J Toxicol Environ Health A. 2006;69(7):633-654. Exclusion code: 2. [pmid: 16608830].
Sano I, Hara S, Matsumoto K, Hatachi G, Nakamura A, Minami H. Clinical analysis of resected pulmonary pleomorphic carcinoma. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2009;62(3):187-191. Exclusion code: 6. [pmid: 19280947].
Sant M, Allemani C, Santaquilani M, Knijn A, Marchesi F, Capocaccia R. EUROCARE-4. Survival of cancer patients diagnosed in 1995-1999. Results and commentary. Eur. J. Cancer. 2009;45(6):931-991. Exclusion code: 5. [pmid: 19171476].
Santo A, Genestreti G, Fiorio E, et al. Non-small cell lung cancer (NSCLC): the evolution of neo-adjuvant chemotherapy in the last 15 years. Recenti Prog. Med. 2006;97(4):211-218. Exclusion code: 6. [pmid: 16729492].
Sasaki Y, Abe K, Tabei M, Katsuragawa S, Kurosaki A, Matsuoka S. Clinical usefulness of temporal subtraction method in screening digital chest radiography with a mobile computed radiography system. Radiol Phys Technol. 2011;4(1):84-90. Exclusion code: 4. [pmid: 21170689].
Sato A, Sueoka-Aragane N, Saitoh J, et al. Establishment of a new method, transcription-reverse transcription concerted reaction, for detection of plasma hnRNP B1 mRNA, a biomarker of lung cancer. J. Cancer Res. Clin. Oncol. 2008;134(11):1191-1197. Exclusion code: 7. [pmid: 18461365].
Sato M, Saito Y, Endo C, et al. The natural history of radiographically occult bronchogenic squamous cell carcinoma: a retrospective study of overdiagnosis bias. Chest. 2004;126(1):108-113. Exclusion code: 3. [pmid: 15249450].
Sato M, Sakurada A, Sagawa M, et al. Diagnostic results before and after introduction of autofluorescence bronchoscopy in patients suspected of having lung cancer detected by sputum cytology in lung cancer mass screening. Lung Cancer. 2001;32(3):247-253. Exclusion code: 7. [pmid: 11390006].
Sato M, Shames DS, Gazdar AF, Minna JD. A translational view of the molecular pathogenesis of lung cancer. J Thorac Oncol. 2007;2(4):327-343. Exclusion code: 7. [pmid: 17409807].
Sawada S, Komori E, Yamashita M, et al. Comparison in prognosis after VATS lobectomy and open lobectomy for stage I lung cancer: retrospective analysis focused on a histological subgroup. Surg. Endosc. 2007;21(9):1607-1611. Exclusion code: 10. [pmid: 17762957].
Schaberg FJ Jr., Prinz RA, Chen EL, et al. Incidental findings at surgery-part 2. Curr. Probl. Surg. 2008;45(6):388-439. Exclusion code: 5. [pmid: 18452760].
Schachter EN, Neuman T. Targeted therapies for the prevention of lung cancer. Drugs of Today. 2007;43(12):897-936. Exclusion code: 5. [pmid: 18174975].
Schaefer-Prokop C, Prokop M. New imaging techniques in the treatment guidelines for lung cancer. European Respiratory Journal - Supplement. 2002;35:71s-83s. Exclusion code: 5. [pmid: 12064683].
Schilling FH, Spix C, Berthold F, et al. Neuroblastoma screening at one year of age. N. Engl. J. Med. 2002;346(14):1047-1053. Exclusion code: 3. [pmid: 11932471].
Schirrmeister H, Glatting G, Hetzel J, et al. Prospective evaluation of the clinical value of planar bone scans, SPECT, and (18)F-labeled NaF PET in newly diagnosed lung cancer. J. Nucl. Med. 2001;42(12):1800-1804. Exclusion code: 7. [pmid: 11752076].
Schmidt B, Liebers U, Witt C. Screening for bronchial carcinoma -- pro. Dtsch. Med. Wochenschr. 2005;130(9):466. Exclusion code: 6. [pmid: 15731960].
Schneider J. Early detection of lung cancers - Comparison of computed tomography, cytology and fuzzy-based tumor markers panels. Cancer Biomark. 2010;6(3-4):149-162. Exclusion code: 5. [pmid: 20660961].
Schneider J, Morr H, Velcovsky HG, Weisse G, Eigenbrodt E. Quantitative detection of tumor M2-pyruvate kinase in plasma of patients with lung cancer in comparison to other lung diseases. Cancer Detect. Prev. 2000;24(6):531-535. Exclusion code: 4. [pmid: 11198266].
Schneider J, Presek P, Braun A, Loffler S, Woitowitz HJ. Serum ras (p21) as a marker for occupationally derived lung cancer?. Clin. Chem. Lab. Med. 2000;38(4):301-305. Exclusion code: 4. [pmid: 10928648].
Schnipper LE. Update in oncology. Ann. Intern. Med. 2007;147(11):775-782. Exclusion code: 5. [pmid: 18056661].
Schnoll RA, Bradley P, Miller SM, Unger M, Babb J, Cornfeld M. Psychological issues related to the use of spiral CT for lung cancer early detection. Lung Cancer. 2003;39(3):315-325. Exclusion code: 2. [pmid: 12609570].
Schnoll RA, Miller SM, Unger M, McAleer C, Halbherr T, Bradley P. Characteristics of female smokers attending a lung cancer screening program: a pilot study with implications for program development. Lung Cancer. 2002;37(3):257-265. Exclusion code: 10. [pmid: 12234693].
Schnoll RA, Wileyto EP, Hornik R, Schiller J, Lerman C. Spiral computed tomography and lung cancer: Science, the media, and public opinion. J. Clin. Oncol. 2007;25(36):5695-5697. Exclusion code: 5. [pmid: 18089863].
Schoen RE, Pinsky PF, Weissfeld JL, et al. Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N. Engl. J. Med. 2012;366(25):2345-2357. Exclusion code: 2. [pmid: 22612596].
Schoepf UJ, Becker CR, Obuchowski NA, et al. Multi-slice computed tomography as a screening tool for colon cancer, lung cancer and coronary artery disease. Eur. Radiol. 2001;11(10):1975-1985. Exclusion code: 5. [pmid: 11702131].
Schrieber G, McCrory DC. Performance characteristics of different modalities for diagnosis of suspected lung cancer. Summary of published evidence. Chest. 2003;123(Supplement):115s-128s. Exclusion code: 5. [pmid: 12527571].
Schultz EM, Silvestri GA, Gould MK. Variation in experts' beliefs about lung cancer growth, progression, and prognosis. J Thorac Onc. 2008;3(4):422-426. Exclusion code: 2. [pmid: 18379363].
Schwartz AM, Henson DE, American College of Chest P. Diagnostic surgical pathology in lung cancer: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):78S-93S. Exclusion code: 7. [pmid: 17873162].
Scott WJ, Allen MS, Darling G, et al. Video-assisted thoracic surgery versus open lobectomy for lung cancer: a secondary analysis of data from the American College of Surgeons Oncology Group Z0030 randomized clinical trial. J. Thorac. Cardiovasc. Surg. 2010;139(4):976-981. discussion 981-973. Exclusion code: 3. [pmid: 20172539].
Scott WJ, Howington J, Feigenberg S, Movsas B, Pisters K. Treatment of non-small cell lung cancer stage I and stage II: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 SUPPL):234S-242S. Exclusion code: 2. [pmid: 17873171].
Sedjo RL, Byers T, Barrera E Jr, et al. A midpoint assessment of the American Cancer Society challenge goal to decrease cancer incidence by 25% between 1992 and 2015. CA Cancer Journal for Clinicians. 2007;57(6):326-340. Exclusion code: 5. [pmid: 17989128].
Seijo LM, Montuenga LM, Zulueta JJ. Re: Inconsistencies in findings from the early lung cancer action project studies of lung cancer screening. J. Natl. Cancer Inst. 2012;104(3):254. Exclusion code: 5. [pmid: 22275407].
Seki N, Eguchi K, Kaneko M, et al. The adenocarcinoma-specific stage shift in the Anti-lung Cancer Association project: significance of repeated screening for lung cancer for more than 5 years with low-dose helical computed tomography in a high-risk cohort. Lung Cancer. 2010;67(3):318-324. Exclusion code: 2. [pmid: 19481832].
Sekine Y, Fujisawa T. Prognostic factors on surgical treatment for lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2003;56(8 Suppl):722-727. Exclusion code: 6. [pmid: 12910959].
Sekine Y, Yamada Y, Chiyo M, et al. Association of chronic obstructive pulmonary disease and tumor recurrence in patients with stage IA lung cancer after complete resection. Ann. Thorac. Surg. 2007;84(3):946-950. Exclusion code: 7. [pmid: 17720404].
Selby JV, Friedman GD, Quesenberry CP, Weiss NS. A case control study of screening sigmoidoscopy and mortality from colorectal cancer. N Eng J Med. 1992;326(10):653-657. Exclusion code: 5. [pmid: 1736103].
Selva A, Puig T, López Alcalde J, Bonfill X. Efficacy of screening for lung cancer. Systematic review. Revisión sistemática sobre la eficacia del cribado del cáncer de pulmón. 2011;137(12):565-571. Exclusion code: 5. [pmid: 21316716].
Sen S, Guleria R, Singh N. Screening for lung cancer in India. Natl. Med. J. India. 2002;15(4):210-212. Exclusion code: 5. [pmid: 12296476].
Sequist LV, Nagrath S, Toner M, Haber DA, Lynch TJ. The CTC-chip: an exciting new tool to detect circulating tumor cells in lung cancer patients. J Thorac Oncol. 2009;4(3):281-283. Exclusion code: 2. [pmid: 19247082].
Serke M, Kollmeier J. Multimodal therapy of small cell and non-small cell lung carcinoma. Dtsch. Med. Wochenschr. 2007;132(22):1221-1224. Exclusion code: 6. [pmid: 17520508].
Serke M, Schonfeld N. Diagnosis and staging of lung cancer. Dtsch. Med. Wochenschr. 2007;132(21):1165-1169. Exclusion code: 6. [pmid: 17506012].
Sestini P. Reduced lung-cancer mortality with CT screening. N. Engl. J. Med. 2011;365(21):2037. author reply 2037-2038. Exclusion code: 5. [pmid: 22111732].
Shah SI, Applebaum EL. Lung cancer after head and neck cancer: role of chest radiography. Laryngoscope. 2000;110(12):2033-2036. Exclusion code: 3. [pmid: 11129015].
Shaham D, Goitein O, Yankelevitz DF, Vazquez M, Reeves AP, Henschke C. Screening for lung cancer using low-radiation dose computed tomography. Imaging Decisions MRI. 2002;6(4):4-13. Exclusion code: 5.
Shaikh U, Lewis-Jones H. Commercial CT scans: VOMIT victim of medical investigative technology. BMJ. 2008;336(7634):8. Exclusion code: 5. [pmid: 18174573].
Shao F, Yang R, Xu D, et al. Bronchial sleeve lobectomy and carinal resection in the treatment of central lung cancer: a report of 92 cases. Zhongguo Fei Ai Za Zhi. 2010;13(11):1056-1058. Exclusion code: 6. [pmid: 21081048].
Shaw AS, Williams MV. The cancer reform strategy. Clin. Radiol. 2008;63(12):1292-1296. Exclusion code: 5. [pmid: 18996258].
Shen L, Li Zm, Lu S. Clinical significance of C-reactive protein in patients with stage I non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2011;33(6):442-446. Exclusion code: 6. [pmid: 21875485].
Shepherd FA. A targeted approach to reducing lung cancer mortality. J. Clin. Oncol. 2005;23(14):3173-3174. Exclusion code: 5. [pmid: 15886303].
Shevchenko VE, Arnotskaya NE, Zaridze DG. Detection of lung cancer using plasma protein profiling by matrix-assisted laser desorption/ionization mass spectrometry. European Journal of Mass Spectrometry. 2010;16(4):539-549. Exclusion code: 2. [pmid: 20625202].
Shimizu T, Shigemasa Y, Kajiwara K, et al. A case of radiation therapy successfully treated liver and lung tumors arising from postoperative cecum cancer. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2009;36(12):2149-2151. Exclusion code: 6. [pmid: 20037352].
Shinohara H, Tsuchida M, Hashimoto T, Hayashi J. Surgical treatment for metachronous lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(11):952-955. Exclusion code: 6. [pmid: 20954349].
Shiraishi T, Yoshinaga Y, Yoneda S, et al. Clinical evaluation of VATS lobectomy for lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(1):4-7. Exclusion code: 6. [pmid: 10639784].
Shirakusa T. Lung cancer in elderly patients: clinicopathological features. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2005;58(8 Suppl):734-738. Exclusion code: 6. [pmid: 16097628].
Shundo Y, Takahashi T, Itaya T, et al. Clinical study of forty-two patients who underwent resection for pulmonary adenosquamous carcinoma. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2011;64(10):871-876. discussion 876-879. Exclusion code: 6. [pmid: 21899122].
Shuryak I, Sachs RK, Brenner DJ. Cancer risks after radiation exposure in middle age. J. Natl. Cancer Inst. 2010;102(21):1628-1636. Exclusion code: 5. [pmid: 20975037].
Siddiq S, Pamphilon D, Brunskill S, Doree C, Hyde C, Stanworth S. Bone marrow harvest versus peripheral stem cell collection for haemopoietic stem cell donation in healthy donors. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion code: 4. [pmid: 19160282].
Sieren JC, Ohno Y, Koyama H, Sugimura K, McLennan G. Recent technological and application developments in computed tomography and magnetic resonance imaging for improved pulmonary nodule detection and lung cancer staging. J. Magn. Reson. Imaging. 2010;32(6):1353-1369. Exclusion code: 2. [pmid: 21105140].
Sigel K, Bonomi M, Packer S, Wisnivesky J. Effect of age on survival of clinical stage I non-small-cell lung cancer. Ann. Surg. Oncol. 2009;16(7):1912-1917. Exclusion code: 3. [pmid: 19408051].
Sigurdardottir JM, Isaksson HJ, Johannsson KB, Jonsson S, Gudbjartsson T. Histology does not accurately predict the clinical behaviour of bronchopulmonary carcinoids - results from an Icelandic population-based study. Laeknabladid. 2008;94(2):125-130. Exclusion code: 6. [pmid: 18310777].
Sigurdson AJ, Jones IM, Wei Q, et al. Prospective analysis of DNA damage and repair markers of lung cancer risk from the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Carcinogenesis. 2011;32(1):69-73. Exclusion code: 2. [pmid: 20929901].
Sikora K. Cancer screening. Medicine (Baltimore). 2008;36(1):45-49. [PMID:. Exclusion code: 5.
Sikora K. Cancer screening. Medicine (Baltimore). 2012;40(1):24-28. [PMID:. Exclusion code: 5.
Silvestri GA. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):745. author reply 746-747. Exclusion code: 2. [pmid: 17310518].
Silvestri GA. Deaths among patients with screen-detected lung cancer. Clin. Cancer Res. 2008;14(8):2511. author reply 2511-2512. Exclusion code: 2. [pmid: 18413845].
Silvestri GA, Nietert PJ, Zoller J, Carter C, Bradford D. Attitudes towards screening for lung cancer among smokers and their non-smoking counterparts. Thorax. 2007;62(2):126-130. Exclusion code: 7. [pmid: 17101739].
Silvestri GA, Tanoue LT. Lung cancer: evolving concepts. Semin. 2008;29(3):221-222. Exclusion code: 5. [pmid: 18506659].
Simpson NK, Johnson CC, Ogden SL, et al. Recruitment strategies in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial: the first six years. Control. Clin. Trials. 2000;21(6 Suppl):356S-378S. Exclusion code: 5. [pmid: 11189688].
Singh S, Pinsky P, Fineberg NS, et al. Evaluation of reader variability in the interpretation of follow-up CT scans at lung cancer screening. Radiology. 2011;259(1):263-270. Exclusion code: 2. [pmid: 21248232].
Sirbu H, Schreiner W, Dalichau H, Busch T. Surgery for non-small cell carcinoma in geriatric patients: 15-year experience. Asian Cardiovasc Thorac Ann. 2005;13(4):330-336. Exclusion code: 3. [pmid: 16304220].
Skillrud D, Offord K, Miller R. Higher risk of lung cancer in chronic obstructive pulmonary disease: a prospective, matched, controlled study. Ann. Intern. Med. 1986;105(4):503-507. Exclusion code: 2. [pmid: 3752756].
Skuladottir R, Oskarsdottir GN, Isaksson HJ, Jonsson S, Thorsteinsson H, Gudbjartsson T. Postoperative complications following lobectomy for lung cancer in Iceland during 1999-2008. Laeknabladid. 2010;96(4):243-249. Exclusion code: 6. [pmid: 20339163].
Slatore CG, Au DH, Gould MK. An official American Thoracic Society systematic review: Insurance status and disparities in lung cancer practices and outcomes. Am. J. Respir. Crit. Care Med. 2010;182(9):1195-1205. Exclusion code: 2. [pmid: 21041563].
Slatore CG, Gould MK, Au DH, Deffebach ME, White E. Lung cancer stage at diagnosis: Individual associations in the prospective VITamins and lifestyle (VITAL) cohort. BMC Cancer. 2011;11:228. Exclusion code: 7. [pmid: 21649915].
Slatore CG, Littman AJ, Au DH, Satia JA, White E. Long-term use of supplemental multivitamins, vitamin C, vitamin E, and folate does not reduce the risk of lung cancer. Am. J. Respir. Crit. Care Med. 2008;177(5):524-530. Exclusion code: 5. [pmid: 17989343].
Smith D, Spanel P, Sule-Suso J. Advantages of breath testing for the early diagnosis of lung cancer. Expert Review of Molecular Diagnostics. 2010;10(3):255-257. Exclusion code: 2. [pmid: 20370582].
Smith JJ, Berg CD. Lung cancer screening: promise and pitfalls. Semin. Oncol. Nurs. 2008;24(1):9-15. Exclusion code: 5. [pmid: 18222147].
Smith RA, Cokkinides V, Brawley OW. Cancer screening in the United States, 2009: a review of current American Cancer Society guidelines and issues in cancer screening. CA. Cancer J. Clin. 2009;59(1):27-41. Exclusion code: 5. [pmid: 19147867].
Smith RA, Cokkinides V, Eyre HJ. Cancer screening in the United States, 2007: a review of current guidelines, practices, and prospects. CA. Cancer J. Clin. 2007;57(2):90-104. Exclusion code: 5. [pmid: 17392386].
Smith RA, Cokkinides V, Eyre HJ, American Cancer Society. American Cancer Society guidelines for the early detection of cancer, 2006. CA. Cancer J. Clin. 2006;56(1):11-25. Exclusion code: 5. [pmid: 16449183].
Smith RA, Cokkinides V, von Eschenbach AC, et al. American Cancer Society guidelines for the early detection of cancer. CA. Cancer J. Clin. 2002;52(1):8-22. Exclusion code: 5. [pmid: 11814067].
Smith RA, Field JK, Duffy SW. A global approach to cancer-screening trials. Lancet Oncol. 2008;9(10):908-909. Exclusion code: 2. [pmid: 18805732].
Smith RA, von Eschenbach AC, Wender R, et al. American Cancer Society guidelines for the early detection of cancer: update of early detection guidelines for prostate, colorectal, and endometrial cancers. Also: update 2001--testing for early lung cancer detection. [Erratum appears in CA Cancer J Clin 2001 May-Jun;51(3):150]. CA. Cancer J. Clin. 2001;51(1):38-75. quiz 77-80. Exclusion code: 5. [pmid: 11577479].
Smith-Bindman R. Is Computed Tomography Safe?. N. Engl. J. Med. 2010;363(1):1-4. Exclusion code: 5. [pmid: 20573919].
Smith-Bindman R. Environmental causes of breast cancer and radiation from medical imaging: Findings from the Institute of Medicine report. Arch. Intern. Med. 2012;172(13):1023-1027. Exclusion code: 5. [pmid: 22688684].
Smith-Bindman R, Lipson J, Marcus R, et al. Radiation dose associated with common coputed tomography examinations and the associated lifetime attributable risk of cancer. Arch. Intern. Med. 2009;169(22):2078-2086. Exclusion code: 2. [pmid: 20008690].
Smith-Bindman R, Miglioretti DL. CTDI vol, DLP, and effective dose are excellent measures for use in CT quality improvement. Radiology. 2011;261(3):999. Exclusion code: 5. [pmid: 22096003].
Smith-Bindman R, Miglioretti DL, Johnson E, et al. Use of diagnostic imaging studies and associated radiation exposure for patients enrolled in large integrated health care systems, 1996-2010. JAMA - Journal of the American Medical Association. 2012;307(22):2400-2409. Exclusion code: 5. [pmid: 22692172].
Smythe WR, American College of Chest P. Treatment of stage I non-small cell lung carcinoma. Chest. 2003;123(1 Suppl):181S-187S. Exclusion code: 2. [pmid: 12527578].
Sobue T. A case-control study for evaluating lung cancer screening in Japan. Cancer. 2000;89(11 Suppl):2392-2396. Exclusion code: 5. [pmid: 11147617].
Sobue T, Moriyama N, Kaneko M, et al. Screening for lung cancer with low-dose helical computed tomography: anti-lung cancer association project. J. Clin. Oncol. 2002;20(4):911-920. Exclusion code: 3. [pmid: 11844811].
Sobue T, Suzuki T, Matsuda M, Kuroishi T, Ikeda S, Naruke T. Survival for clinical stage I lung cancer not surgically treated. Comparison between screen-detected and symptom-detected cases. The Japanese Lung Cancer Screening Research Group. Cancer. 1992;69(3):685-692. Exclusion code: 2. [pmid: 1730119].
Sone S, Li F, Yang ZG, et al. Results of three-year mass screening programme for lung cancer using mobile low-dose spiral computed tomography scanner. Br. J. Cancer. 2001;84(1):25-32. Exclusion code: 5. [pmid: 11139308].
Sone S, Li F, Yang ZG, et al. Characteristics of small lung cancers invisible on conventional chest radiography and detected by population based screening using spiral CT. Br. J. Radiol. 2000;73(866):137-145. Exclusion code: 2. [pmid: 10884725].
Sone S, Matsumoto T, Honda T, et al. HRCT features of small peripheral lung carcinomas detected in a low-dose CT screening program. Acad. Radiol. 2010;17(1):75-83. Exclusion code: 4. [pmid: 19879779].
Sone S, Nakayama T, Honda T, et al. CT findings of early-stage small cell lung cancer in a low-dose CT screening programme. Lung Cancer. 2007;56(1):207-215. Exclusion code: 2. [pmid: 17258349].
Sone S, Nakayama T, Honda T, et al. Long-term follow-up study of a population-based 1996-1998 mass screening programme for lung cancer using mobile low-dose spiral computed tomography. Lung Cancer. 2007;58(3):329-341. Exclusion code: 4. [pmid: 17675180].
Song Y, Yang L, Ma Jh, Liu Xf, Wang Jw. Long-term outcome of testicular seminoma in 294 patients. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2008;30(8):626-629. Exclusion code: 6. [pmid: 19102945].
Sortini D, Maravegias K, Sortini A. Difficulty of early diagnosis in patients with solitary pulmonary nodule. J. Thorac. Cardiovasc. Surg. 2005;129(5):1196. author reply 1196-1197. Exclusion code: 2. [pmid: 15867812].
Souquet PJ, Geriniere L. Combinations of platinum salts and gemcitabine in the treatment of non-small-cell lung cancer. Bull. Cancer (Paris). 2002;89. Spec No:S80-84. Exclusion code: 6. [pmid: 12449035].
Sox HC. Screening for Lung Cancer With Chest Radiographs. JAMA - Journal of the American Medical Association. 2011;306(17):1916-1918. Exclusion code: 2. [pmid: 22031727].
Sox HC. Better evidence about screening for lung cancer. N. Engl. J. Med. 2011;365(5):455-457. Exclusion code: 2. [pmid: 21714644].
Sozzi G, Roz L, Conte D, et al. Plasma DNA quantification in lung cancer computed tomography screening: five-year results of a prospective study. Am. J. Respir. Crit. Care Med. 2009;179(1):69-74. Exclusion code: 2. [pmid: 18787214].
Spaggiari L, Veronesi G, Bellomi M, Maisonneuve P. Computed tomography screening for lung cancer. JAMA. 2007;298(5):514. author reply 515-516. Exclusion code: 5. [pmid: 17666670].
Spigno F, Gentile R, Valente T, Capannelli G. Diagnosis in related pathologic asbestosis, clinical case of a suspected occupational neoplasm. G. Ital. Med. Lav. Ergon. 2008;30(4):324-328. Exclusion code: 6. [pmid: 19344083].
Spira A, Beane JE, Shah V, et al. Airway epithelial gene expression in the diagnostic evaluation of smokers with suspect lung cancer. Nat. Med. 2007;13(3):361-366. Exclusion code: 4. [pmid: 17334370].
Spiro SG. Screening for lung cancer: yet another problem. Thorax. 2007;62(2):105-106. Exclusion code: 5. [pmid: 17287303].
Spiro SG, Navani N. Screening for lung cancer: Is this the way forward?. Respirology. 2012;17(2):237-246. Exclusion code: 5. [pmid: 22142440].
Spiro SG, Tanner NT, Silvestri GA, et al. Lung cancer: progress in diagnosis, staging and therapy. Respirology. 2010;15(1):44-50. Exclusion code: 2. [pmid: 20199634].
Spitz MR, Hong WK, Amos CI, et al. A risk model for prediction of lung cancer. J. Natl. Cancer Inst. 2007;99(9):715-726. Exclusion code: 5. [pmid: 17470739].
Sreseli RT, Binder H, Kuhn M, et al. Identification of a 17-protein signature in the serum of lung cancer patients. Oncol. Rep. 2010;24(1):263-270. Exclusion code: 3. [pmid: 20514471].
Sriram KB, Larsen JE, Yang IA, Bowman RV, Fong KM. Genomic medicine in non-small cell lung cancer: Paving the path to personalized care. Respirology. 2011;16(2):257-263. Exclusion code: 5. [pmid: 21044232].
Stabile LP, Siegfried JM. Sex and gender differences in lung cancer. Journal of Gender-Specific Medicine. 2003;6(1):37-48. Exclusion code: 2. [pmid: 12661176].
Stanbrook MB, Flegel K. A pause for thought on lung cancer screening. CMAJ Canadian Medical Association Journal. 2009;180(8):793. Exclusion code: 5. [pmid: 19364781].
Stanley RJ. Inherent dangers in radiologic screening. AJR. Am. J. Roentgenol. 2001;177(5):989-992. Exclusion code: 5. [pmid: 11641152].
Stanzel F. Fluorescent bronchoscopy: contribution for lung cancer screening?. Lung Cancer. Suppl 2. 2004;45:S29-37. Exclusion code: 5. [pmid: 15552779].
Staring M, Pluim JPW, de Hoop B, et al. Image subtraction facilitates assessment of volume and density change in ground-glass opacities in chest CT. Invest. Radiol. 2009;44(2):61-66. Exclusion code: 3. [pmid: 19104438].
Starnes SL, Reed MF, Meyer CA, et al. Can lung cancer screening by computed tomography be effective in areas with endemic histoplasmosis?. J. Thorac. Cardiovasc. Surg. 2011;141(3):688-693. Exclusion code: 2. [pmid: 20933243].
Stearman RS, Dwyer-Nield L, Grady MC, Malkinson AM, Geraci MW. A macrophage gene expression signature defines a field effect in the lung tumor microenvironment. Cancer Res. 2008;68(1):34-43. Exclusion code: 5. [pmid: 18172294].
Steeghs MML, Cristescu SM, Munnik P, Zanen P, Harren FJM. An off-line breath sampling and analysis method suitable for large screening studies. Physiol. Meas. 2007;28(5):503-514. Exclusion code: 4. [pmid: 17470984].
Stellman SD, Takezaki T, Wang L, et al. Smoking and lung cancer risk in American and Japanese men: An international case-control study. Cancer Epidemiology Biomarkers and Prevention. 2001;10(11):1193-1199. Exclusion code: 2. [pmid: 11700268].
Stempfer R, Syed P, Vierlinger K, et al. Tumour auto-antibody screening: performance of protein microarrays using SEREX derived antigens. BMC Cancer. 2010;10:627. Exclusion code: 4. [pmid: 21078204].
Stengel JW, Webb EM, Poder L, Yeh BM, Smith-Bindman R, Coakley FV. Acute appendicitis: Clinical outcome in patients with an initial false-positive CT diagnosis. Radiology. 2010;256(1):119-126. Exclusion code: 5. [pmid: 20505066].
Stephan F, Boucheseiche S, Hollande J, et al. Pulmonary complications following lung resection: A comprehensive analysis of incidence and possible risk factors. Chest. 2000;118(5):1263-1270. Exclusion code: 8. [pmid: 11083673].
Stephenson SM, Mech KF, Sardi A. Lung cancer screening with low-dose spiral computed tomography. Am. Surg. 2005;71(12):1015-1017. Exclusion code: 3. [pmid: 16447470].
Stewart SL, King JB, Thompson TD, Friedman C, Wingo PA. Cancer mortality surveillance--United States, 1990-2000. Morbidity & Mortality Weekly Report. Surveillance Summaries. 2004;53(3):1-108. Exclusion code: 2. [pmid: 15179359].
Stiles BM, Altorki NK. Screening for Lung Cancer: Challenges for the Thoracic Surgeon. Surg. Oncol. Clin. N. Am. 2011;20(4):619-635. Exclusion code: 5. [pmid: 21986261].
Stoelben E, Sauerbrei W, Ludwig C, Hasse J. Tumor stage and early mortality for surgical resections in lung cancer. Langenbecks Arch. Surg. 2003;388(2):116-121. Exclusion code: 3. [pmid: 12712342].
Strauss G, Gleason R, Sugarbaker D. Screening for lung cancer (LC) re-examined: a reinterpretation of the Mayo Lung Project (MLP) randomized trial for screening for the early detection of lung cancer [abstract]. Paper presented at: Proceedings of the American Society of Clinical Oncology. 1992. Exclusion code:5.
Strauss GM. Screening for lung cancer: An evidence-based synthesis. Surg. Oncol. Clin. N. Am. 1999;8(4):747-774. viii. Exclusion code: 2. [pmid: 10452939].
Strauss GM. Randomized population trials and screening for lung cancer: breaking the cure barrier. Cancer. 2000;89(11 Suppl):2399-2421. Exclusion code: 2. [pmid: 11147619].
Strauss GM. The Mayo Lung Cohort: a regression analysis focusing on lung cancer incidence and mortality. J. Clin. Oncol. 2002;20(8):1973-1983. Exclusion code: 5. [pmid: 11956255].
Su X, Wang X, Long H, et al. Mediastinal lymph node dissection affects survival in patients with stage I non-small cell lung cancer. Thorac. Cardiovasc. Surg. 2008;56(4):226-230. Exclusion code: 5. [pmid: 18481243].
Su XD, Huang ZF, Rong TH, Yang MT. Combined surgical treatment for limited small cell lung cancer: clinical analysis of 51 cases. Ai Zheng. 2003;22(10):1099-1101. Exclusion code: 6. [pmid: 14558961].
Su XD, Long H, Wang X, et al. Impact of visceral pleural invasion on the prognosis of stage Ib non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2008;30(5):368-371. Exclusion code: 6. [pmid: 18953838].
Su Xd, Wang X, Rong Th, et al. Prognostic effect of mediastinal lymph node dissection in patients with stage I non-small cell lung cancer. Chung-Hua Wai Ko Tsa Chih. Chinese Journal of Surgery. 2007;45(22):1543-1545. Exclusion code: 6. [pmid: 18282391].
Suemitsu R, Yamaguchi M, Takeo S, et al. Favorable surgical results for patients with nonsmall cell lung cancer over 80 years old: a multicenter survey. Ann. Thorac. Cardiovasc. Surg. 2008;14(3):154-160. Exclusion code: 3. [pmid: 18577893].
Suemitsu R, Yoshino I, Tomiyasu M, Fukuyama S, Okamoto T, Maehara Y. Serum tissue inhibitors of metalloproteinase-1 and -2 in patients with non-small cell lung cancer. Surg. Today. 2004;34(11):896-901. Exclusion code: 2. [pmid: 15526122].
Sugarbaker DJ. Lung cancer. 6: The case for limited surgical resection in non-small cell lung cancer. Thorax. 2003;58(7):639-641. Exclusion code: 5. [pmid: 12832686].
Sugi K, Kobayashi S, Sudou M, et al. Video-assisted thoracic surgery (VATS) for clinical stage I lung cancer in consideration of the diameters and characteristcs of each tumor and the technical limitations of VATS. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2009;62(4):277-280. Exclusion code: 6. [pmid: 19348210].
Sugio K, Sugaya M, Hanagiri T, Yasumoto K. Tumor marker in primary lung cancer. J Uoeh. 2004;26(4):473-479. Exclusion code: 6. [pmid: 15624359].
Sugiura Y, Takeuchi K, Kakizaki T, Kaseda S. Complete response by S-1 with multiple pulmonary metastases 4 years after lung resection-a case report. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2009;36(13):2611-2614. Exclusion code: 6. [pmid: 20009464].
Sullivan DC. Congressional update: Report from the biomedical imaging program of the National Cancer Institute. Research recommendations from a lung cancer screening workshop. Acad. Radiol. 2001;8(9):942-943. Exclusion code: 5. [pmid: 11724050].
Sumitani M, Takifuji N, Nanjyo S, et al. Clinical relevance of sputum cytology and chest X-ray in patients with suspected lung tumors. Intern. Med. 2008;47(13):1199-1205. Exclusion code: 2. [pmid: 18591840].
Sun SS, Hsieh JF, Tsai SC, Ho YJ, Lee JK, Kao CH. Cytokeratin fragment 19 and squamous cell carcinoma antigen for early prediction of recurrence of squamous cell lung carcinoma. Am. J. Clin. Oncol. 2000;23(3):241-243. Exclusion code: 7. [pmid: 10857885].
Sun SS, Schiller JH, Gazdar AF. Lung cancer in never smokers - a different disease. Nat Rev Cancer. 2007;7:778-790. Exclusion code: 2. [pmid: 17882278].
Sutedja G. New techniques for early detection of lung cancer. European Respiratory Journal - Supplement. 2003;39:57s-66s. Exclusion code: 2. [pmid: 12572703].
Sutedja TG, Venmans BJ, Smit EF, Postmus PE. Fluorescence bronchoscopy for early detection of lung cancer: a clinical perspective. Lung Cancer. 2001;34(2):157-168. Exclusion code: 5. [pmid: 11679174].
Suzuki T, Horio H, Sakaguchi K, Yamamoto M. Lobectomy for local recurrence of lung cancer after 3-dimensional-conformal radiotherapy. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2007;60(9):830-833. Exclusion code: 6. [pmid: 17703623].
Sverzellati N, Cademartiri F, Bravi F, et al. Relationship and prognostic value of modified coronary artery calcium score, FEV 1, and emphysema in lung cancer screening population: The MILD trial. Radiology. 2012;262(2):460-467. Exclusion code: 7. [pmid: 22114241].
Sverzellati N, Guerci L, Randi G, et al. Interstitial lung diseases in a lung cancer screening trial. Eur. Respir. J. 2011;38(2):392-400. Exclusion code: 5. [pmid: 21233262].
Sverzellati N, Ingegnoli A, Calabrò E, et al. Bronchial diverticula in smokers on thin-section CT. Eur. Radiol. 2010;20(1):88-94. Exclusion code: 5. [pmid: 19597819].
Swellam M, Ragab HM, Abdalla NA, El-Asmar ABH. Soluble cytokeratin-19 and E-selectin biomarkers: their relevance for lung cancer detection when tested independently or in combinations. Cancer Biomark. 2008;4(1):43-54. Exclusion code: 7. [pmid: 18334733].
Swensen SJ. CT screening for lung cancer. AJR. Am. J. Roentgenol. 2002;179(4):833-836. Exclusion code: 2. [pmid: 12239020].
Swensen SJ. Screening for cancer with computed tomography. BMJ. 2003;326(7395):894-895. Exclusion code: 2. [pmid: 12714453].
Swensen SJ, Jett JR, Hartmen TE, et al. Lung Cancer Screening with CT: Mayo Clinic Experience. Radiology. 2003;226(3):756-761. Exclusion code: 5. [pmid: 12601181].
Swensen SJ, Jett JR, Sloan JA, et al. Screening for lung cancer with low dose spiral computed tomography. Am. J. Respir. Crit. Care Med. 2002;165(4):508-513. Exclusion code: 5. [pmid: 11850344].
Takahashi I, Matsuzaka M, Umeda T, et al. Differences in the influence of tobacco smoking on lung cancer between Japan and the USA: possible explanations for the ‘smoking paradox’ in Japan. Public Health. 2008;122(9):891-896. Exclusion code: 2. [pmid: 18420238].
Takahashi K, Matsumoto H, Nakano D, et al. Is it necessary to carry out hepatic resection and pulmonary resection to obtain a cure for liver and lung metastases from colorectal cancer ?. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2011;38(2):187-192. Exclusion code: 6. [pmid: 21368482].
Takao M, Inoue K, Watanabe F, et al. A rational approach of limited resection for small peripheral lung adenocarcinoma with curative intent; analyses of multiple primary adenocarcinomas. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2004;57(1):9-13. Exclusion code: 6. [pmid: 14733092].
Takashima S, Sone S, Li F, Maruyama Y, Hasegawa M, Kadoya M. Indeterminate solitary pulmonary nodules revealed at population-based CT screening of the lung: using first follow-up diagnostic CT to differentiate benign and malignant lesions. AJR. Am. J. Roentgenol. 2003;180(5):1255-1263. Exclusion code: 2. [pmid: 12704034].
Takashima S, Sone S, Li F, et al. Small solitary pulmonary nodules (< or =1 cm) detected at population-based CT screening for lung cancer: Reliable high-resolution CT features of benign lesions. AJR. Am. J. Roentgenol. 2003;180(4):955-964. Exclusion code: 2. [pmid: 12646435].
Takizawa M, Sone S, Hanamura K, Asakura K. Telemedicine system using computed tomography van of high-speed telecommunication vehicle. IEEE Transactions on Information Technology in Biomedicine. 2001;5(1):2-9. Exclusion code: 4. [pmid: 11300213].
Tammemagi MC, Freedman MT, Pinsky PF, et al. Prediction of true positive lung cancers in individuals with abnormal suspicious chest radiographs: a prostate, lung, colorectal, and ovarian cancer screening trial study. J Thorac Oncol. 2009;4(6):710-721. Exclusion code: 2. [pmid: 19404219].
Tan C, Chen H, Xia C. Early prediction of lung cancer based on the combination of trace element analysis in urine and an Adaboost algorithm. J. Pharm. Biomed. Anal. 2009;49(3):746-752. Exclusion code: 4. [pmid: 19150588].
Tan S, Yu F, Hu W, Tang J, Wang X, Zou M. Clinical application of completed video-assisted thoracic surgery lobectomy (with 186 cases report). Zhong Nan Da Xue Xue Bao Yi Xue Ban. 2011;36(1):80-83. Exclusion code: 6. [pmid: 21311144].
Tang XJ, Zhou QH, Zhang SF, Liu LX. Expressions of Nm23, E-cadherin, and beta-catenin in non-small cell lung cancer and their correlations with metastasis and prognosis. Ai Zheng. 2005;24(5):616-621. Exclusion code: 6. [pmid: 15890109].
Tanino M, Nishimura M, Betsuyaku T, et al. A comparative study of computed tomographic techniques for the detection of emphysema in middle-aged and older patient populations. Nihon Kokyuki Gakkai Zasshi. 2000;38(5):368-372. Exclusion code: 6. [pmid: 10921283].
Tanner NT, Mehta H, Silvestri GA. New testing for lung cancer screening. Oncology. 2012;26(2):1-12. Exclusion code: 5. [pmid: 22489353].
Tanner NT, Silvestri GA. An up to date look at lung cancer screening. Cell Adhesion & Migration. 2010;4(1):96-99. Exclusion code: 5. [pmid: 20139695].
Tanoue LT, Gettinger S. Treatment of Lung Cancer in Older Patients. Clin. Chest Med. 2007;28(4):735-749. Exclusion code: 5. [pmid: 17967291].
Tao C, Gierada DS, Zhu F, Pilgram TK, Wang JH, Bae KT. Automated matching of pulmonary nodules: evaluation in serial screening chest CT. AJR. Am. J. Roentgenol. 2009;192(3):624-628. Exclusion code: 4. [pmid: 19234256].
Tarro G, Perna A, Esposito C. Early diagnosis of lung cancer by detection of tumor liberated protein. J. Cell. Physiol. 2005;203(1):1-5. Exclusion code: 2. [pmid: 15389637].
Taylor KL, Shelby R, Gelmann E, McGuire C. Quality of life and trial adherence among participants in the prostate, lung, colorectal, and ovarian cancer screening trial. J. Natl. Cancer Inst. 2004;96(14):1083-1094. Exclusion code: 3. [pmid: 15265970].
Taylor WF, Fontana RS. Biometric design of the Mayo Lung project for early detection and localization of bronchogenic carcinoma. Cancer. 1972;30(5):1344-1347. Exclusion code: 5. [pmid: 5083070].
Taylor WF, Fontana RS, Uhlenhopp MA, Davis CS. Some results of screening for early lung cancer. Cancer. 1981;47:1114-1120. Exclusion code: 5. [pmid: 6263442].
Teschner M, Starp F, Lullig H. Resection of bronchial carcinoma combined with lung volume reduction. Pneumologie. 2003;57(7):367-372. Exclusion code: 6. [pmid: 12861492].
The Canadian Coordinating Office for Health Technology Assessment. Multi-slice/Helical Computed Tomography for Lung Cancer Screening. Health Technol Assess. 2003;(43). http://www.cadth.ca/media/pdf/213_ct_cetap_e.pdf. 30 Jan 2013. Exclusion code: 5.
The Group for the Study on the Accuracy Management and Accurate Evaluation in Lung Cancer Mass Screening. The Manual of Clinic-based Lung Cancer Screening Program. 1992. Exclusion code: 8.
The Japan Lung Cancer Society. The Manual of Mass Screenong for Lung Cancer. Kanehara & Co., Ltd. 1987. Exclusion code: 8.
The National Lung Screening Trial Research Team, Aberle DR, Adams AM, et al. Baseline characteristics of participants in the randomized national lung screening trial. J. Natl. Cancer Inst. 2010;102(23):1771-1779. Exclusion code: 2. [pmid: 21119104].
Thiis-Evensen E, Hoff GS, Sauar J, Langmark F, Majak BM, Vatn MH. Population-based surveillance by colonoscopy: Effect on the incidence of colorectal cancer: Telemark Polyp Study I. Scand. J. Gastroenterol. 1999;34(4):414-420. Exclusion code: 8. [pmid: 10365903].
Thomas L, Doyle LA, Edelman MJ. Lung cancer in women: emerging differences in epidemiology, biology, and therapy. Chest. 2005;128(1):370-381. Exclusion code: 2. [pmid: 16002959].
Thomas P, Doddoli C, Thirion X, et al. Stage I non-small cell lung cancer: a pragmatic approach to prognosis after complete resection. Ann. Thorac. Surg. 2002;73(4):1065-1070. Exclusion code: 10. [pmid: 11996242].
Thorsteinsson H, Jonsson S, Alfredsson H, Isaksson HJ, Gudbjartsson T. Results of pneumonectomy for non-small cell lung cancer in Iceland. Laeknabladid. 2009;95(12):823-829. Exclusion code: 6. [pmid: 19996469].
Thunnissen FB, Kerr KM, Brambilla E, et al. EU-USA pathology panel for uniform diagnosis in randomised controlled trials for HRCT screening in lung cancer. Eur. Respir. J. 2006;28(6):1186-1189. Exclusion code: 7. [pmid: 16899486].
Thunnissen FBJM. Sputum examination for early detection of lung cancer. J. Clin. Pathol. 2003;56(11):805-810. Exclusion code: 5. [pmid: 14600122].
Tieu B, Schipper P. Specialty Matters in the Treatment of Lung Cancer. Semin Thoracic Surg. 2012;24:99-105. Exclusion code: 2. [pmid: 22920525].
Tiitola M, Kivisaari L, Huuskonen MS, et al. Computed tomography screening for lung cancer in asbestos-exposed workers. Lung Cancer. 2002;35(1):17-22. Exclusion code: 2. [pmid: 11750708].
Tino G. Clinical year in review I: Lung cancer, interventional pulmonology, pediatric pulmonary disease, and pulmonary vascular disease. Proc. 2007;4(6):478-481. Exclusion code: 5. [pmid: 17761962].
Tino G, Ware LB, Moss M. Clinical year in review IV: Chronic obstructive pulmonary disease, nonpulmonary critical care, diagnostic imaging, and mycobacterial disease. Proc. 2007;4(6):494-498. Exclusion code: 5. [pmid: 17761965].
Tockman MS. Advances in sputum analysis for screening and early detection of lung cancer. Cancer Control. 2000;7(1):19-24. Exclusion code: 5. [pmid: 10740657].
Tockman MS. Lung cancer: chemoprevention and intermediate effect markers. IARC Sci. Publ. 2001;154:257-270. Exclusion code: 5. [pmid: 11220665].
Tockman MS. Improbable estimate of lung cancer mortality from screening trials. J. Clin. Oncol. 2005;23(9):2106-2107. author reply 2107-2108. Exclusion code: 2. [pmid: 15774802].
Tockman MS, Hazelton T, Coppage L. Lung cancer screening with helical CT: Evidence for a stage shift. Paper presented at: 10th International Congress on Lung Cancer. 2003. Exclusion code:5.
Togashi K, Hirahara H, Sugawara M, Miyamura H, Sato Y. Surgery for synchronous primary lung cancers and intrapulmonary metastases. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2002;55(1):30-33. Exclusion code: 6. [pmid: 11797405].
Togashi K, Hirahara H, Sugawara M, Miyamura H, Satoh Y. Surgery for intrathoracic recurrence and second primary tumors in resected lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2002;55(5):383-387. Exclusion code: 6. [pmid: 11995320].
Togashi K, Hosaka Y, Okada A, Sato S. Iterative surgical resections for second primary and local recurrent lung cancer; comparison of lobectomy and limited resection. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(11):963-968. Exclusion code: 6. [pmid: 20954351].
Togashi K, Koike T, Emura I, Usuda H. Indication for limited surgery on small lung cancer tumors measuring 1cm or less in diameter on preoperative computed tomography and long-term results. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(7):519-522. discussion 522-514. Exclusion code: 6. [pmid: 18616092].
Togashi Ki, Koike T. Surgical treatment for patients aged 80 years or older with primary lung cancer and differences in outcomes according to sex. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(5):347-351. discussion 351-344. Exclusion code: 6. [pmid: 18464476].
Togashi Ki, Saito M, Asami F, Sato H, Niyoshi S, Tanba H. Long-term results after recurrence of completely resected primary lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2006;59(13):1137-1140. discussion 1140-1133. Exclusion code: 6. [pmid: 17163204].
Tokarskaya ZB, Scott BR, Zhuntova GV, et al. Interaction of radiation and smoking in lung cancer induction among workers at the Mayak nuclear enterprise. Health Phys. 2002;83(6):833-846. Exclusion code: 3. [pmid: 12467291].
Tong L, Spitz MR, Fueger JJ, Amos CA. Lung carcinoma in former smokers. Cancer. 1996;78(5):1004-1010. Exclusion code: 2. [pmid: 8780538].
Torok S, Hegedus B, Laszlo V, et al. Lung cancer in never smokers. Future Oncology. 2011;7(10):1195-1211. Exclusion code: 2. [pmid: 21992731].
Touboul E, Deniaud-Alexandre E, Pereira R, Deluen F. Postoperative radiotherapy after complete resection of stage II (N1) non-small-cell lung cancer: reasons for not proposing it. Rev. Pneumol. Clin. 2000;56(5):287-292. Exclusion code: 6. [pmid: 11139758].
Travis K. Lung cancer screening for all? Not yet, panel says. J. Natl. Cancer Inst. 2004;96(12):900-901. Exclusion code: 5. [pmid: 15199105].
Travis K. Cancer in Europe: new report, recent efforts take continent-wide perspective. J. Natl. Cancer Inst. 2008;100(18):1274-1275. Exclusion code: 5. [pmid: 18780856].
Travis WD, Brambilla E, Noguchi M, et al. International Association for the Study of Lung Cancer/American Thoracic Society/European Respiratory Society International Multidisciplinary Classification of Lung Adenocarcinoma. J Thorac Oncol. 2011;6(2):244-285. Exclusion code: 2. [pmid: 21252716].
Trejos AL, Lin AW, Mohan S, et al. MIRA V: An integrated system for minimally invasive robot-assisted lung brachytherapy. Conference proceedings. 2008. Exclusion code: 5.
Trejos AL, Mohan S, Bassan H, et al. An experimental test-bed for robot-assisted image-guided minimally invasive lung braehytherapy. Conference proceedings. 2007. Exclusion code: 5.
Trichopoulos D, Mollo F, Tomatis L, Agapitos E, Delsedime L, Zavitsanos X. Active and passive smoking and pathological indicators of lung cancer risk in an autopsy study. JAMA. 1992;268(13):1697-1701. Exclusion code: 5. [pmid: 1527879].
Truong MT, Munden RF. Lung cancer screening. Curr Oncol Rep. 2003;5(4):309-312. Exclusion code: 5. [pmid: 12781073].
Tsou JA, Galler JS, Siegmund KD, et al. Identification of a panel of sensitive and specific DNA methylation markers for lung adenocarcinoma. Molecular Cancer. 2007;6:70. Exclusion code: 4. [pmid: 17967182].
Tsuboi M, Ikeda N, Kato H. Experience with surgical intervention for screening-detected lung cancer. Chest. 2004;125(5 Suppl):167S. Exclusion code: 2. [pmid: 15136491].
Tsuchiya R. Surgery for stage I NSCLC in Japan. J Thorac Oncol. 2007;2(7 Suppl 3):S113-114. Exclusion code: 5. [pmid: 17603305].
Tsuchiya Y, Kodera Y, Tanaka R, Sanada S. Quantitative kinetic analysis of lung nodules using the temporal subtraction technique in dynamic chest radiographies performed with a flat panel detector. J. Digit. Imaging. 2009;22(2):126-135. Exclusion code: 4. [pmid: 18415648].
Tsunezuka Y, Oda M, Moriyama H. A case of a second cancer of metachronous multiple primary non-small cell lung cancer successfully treated with TS-1 and CDDP chemotherapy. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2006;33(5):651-653. Exclusion code: 6. [pmid: 16685165].
Tsushima Y, Tateishi U, Uno H, et al. Diagnostic performance of PET/CT in differentiation of malignant and benign non-solid solitary pulmonary nodules. Ann. Nucl. Med. 2008;22(7):571-577. Exclusion code: 3. [pmid: 18756359].
Tunn PU, Schlag PM. Giant cell tumor of bone. An evaluation of 87 patients. Z. Orthop. Ihre Grenzgeb. 2003;141(6):690-698. Exclusion code: 6. [pmid: 14679436].
Turetz ML, O'Connor TP, Tilley AE, et al. Trachea epithelium as a “Canary” for cigarette smoking-induced biologic phenotype of the small airway epithelium. Clinical and Translational Science. 2009;2(4):260-272. Exclusion code: 5. [pmid: 20443905].
Twombly R. Full-body CT screening: preventing or producing cancer?. J. Natl. Cancer Inst. 2004;96(22):1650-1651. Exclusion code: 5. [pmid: 15547173].
Twombly R. Lung cancer screening debate continues despite international CT study results. J. Natl. Cancer Inst. 2007;99(3):190-195. Exclusion code: 2. [pmid: 17284710].
U. S. Preventive Services Task Force. Lung cancer screening: recommendation statement. Ann. Intern. Med. 2004;140(9):738-739. Exclusion code: 2. [pmid: 15126258].
U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999-2007 Incidence and Mortality Web-based Report. Atlanta. U.S. Department of Health and Human Services Center for Disease Control and Prevention and National Cancer Institute. 2010. Exclusion code: 2.
Uchikov A, Batashki I, Paskalev G, et al. Postoperative and remote outcome of non small cell pulmonary carcinoma in patients over 70 years old. Khirurgiia (Sofiia). 2006;(1):35-37. Exclusion code: 6. [pmid: 18771135].
Uchikov A, Dimitrov I, Hadjiev B, et al. Extent of resection as a prognostic factor in patients with non-small cell lung cancer. Khirurgiia (Sofiia). 2010;(2-3):15-18. Exclusion code: 6. [pmid: 21972689].
Uematsu M. Stereotactic radiation therapy for non small cell lung cancer. Nippon Geka Gakkai Zasshi. 2002;103(2):256-257. Exclusion code: 6. [pmid: 11904990].
Ueno K, Kusunoki Y, Imamura F, et al. Clinical experience with autofluorescence imaging system in patients with lung cancers and precancerous lesions. Respiration. 2007;74(3):304-308. Exclusion code: 4. [pmid: 16679756].
Ullrich RT, Zander T, Neumaier B, et al. Early detection of erlotinib treatment response in NSCLC by 3'-deoxy-3'-[F]-fluoro-L-thymidine ([F]FLT) positron emission tomography (PET). PLoS ONE. 2008;3(12):e3908. Exclusion code: 4. [pmid: 19079597].
Unoki M, Daigo Y, Koinuma J, Tsuchiya E, Hamamoto R, Nakamura Y. UHRF1 is a novel diagnostic marker of lung cancer. Br. J. Cancer. 2010;103(2):217-222. Exclusion code: 3. [pmid: 20517312].
Utsumi T, Inoue M, Kadota Y, et al. Outcomes of bronchoplasty procedures for lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2008;61(11):945-949. Exclusion code: 6. [pmid: 18939430].
van de Wiel JCM, Wang Y, Xu DM, et al. Neglectable benefit of searching for incidental findings in the Dutch-Belgian lung cancer screening trial (NELSON) using low-dose multidetector CT. Eur. Radiol. 2007;17(6):1474-1482. Exclusion code: 2. [pmid: 17206426].
van den Bergh KAM, Essink-Bot ML, van Klaveren R, de Koning HJ. Informed decision making does not affect health-related quality of life in lung cancer screening (NELSON trial). Eur. J. Cancer. 2010;46(18):3300-3306. Exclusion code: 7. [pmid: 20580546].
van den Bergh KAM, Essink-Bot ML, Bunge EM, et al. Impact of computed tomography screening for lung cancer on participants in a randomized controlled trial (NELSON trial). Cancer. 2008;113(2):396-404. Exclusion code: 2. [pmid: 18484588].
van der Aalst CM, de Koning HJ, van den Bergh KAM, Willemsen MC, van Klaveren RJ. The effectiveness of a computer-tailored smoking cessation intervention for participants in lung cancer screening: A randomised controlled trial. Lung Cancer. 2012;76(2):204-210. Exclusion code: 2. [pmid: 22054915].
van der Aalst CM, van Iersel CA, van Klaveren RJ, et al. Generalisability of the results of the Dutch-Belgian randomised controlled lung cancer CT screening trial (NELSON): does self-selection play a role?. Lung Cancer. 2012;77(1):51-57. Exclusion code: 2. [pmid: 22459203].
van der Aalst CM, van Klaveren RJ, de Koning HJ. Does participation to screening unintentionally influence lifestyle behaviour and thus lifestyle-related morbidity?. Best Practice & Research in Clinical Gastroenterology. 2010;24(4):465-478. Exclusion code: 2. [pmid: 20833350].
van Geel AN, van der Pol C, Notenboom A, et al. Long-term results of the multidisciplinary surgical treatment of non-small-cell bronchial carcinoma in the superior sulcus (Pancoast tumour): a retrospective study. Ned. Tijdschr. Geneeskd. 2007;151(25):1406-1411. Exclusion code: 6. [pmid: 17668607].
van Ginneken B, Armato SG 3rd, de Hoop B, et al. Comparing and combining algorithms for computer-aided detection of pulmonary nodules in computed tomography scans: The ANODE09 study. Med. Image Anal. 2010;14(6):707-722. Exclusion code: 7. [pmid: 20573538].
van Klaveren RJ. Lung cancer screening. Eur. J. Cancer. 2011;47(Suppl 3):S147-155. Exclusion code: 5. [pmid: 21943968].
van Klaveren RJ, Habbema JD, de Koning HJ, Oudkerk M, Damhuis RA, Hoogsteden HC. Screening for lung cancer in the Netherlands: the role of spiral CT scan. Ned. Tijdschr. Geneeskd. 2001;145(11):521-526. Exclusion code: 6. [pmid: 11284285].
van Klaveren RJ, Habbema JDF, Pedersen JH, de Koning HJ, Oudkerk M, Hoogsteden HC. Lung cancer screening by low-dose spiral computed tomography. Eur. Respir. J. 2001;18(5):857-866. Exclusion code: 2. [pmid: 11757637].
Van Klaveren RJ, Oudkerk M, Mali WPTM, De Koning HJ. Multi-detector CT screening for lung cancer is still to be discouraged for the time being. Nederlands Tijdschrift voor Geneeskunde. 2008;152(3):125-128. Exclusion code: 5. [pmid: 18271456].
van Klaveren RJ, van't Westeinde SC, de Hoop BJ, Hoogsteden HC. Stem cells and the natural history of lung cancer: implications for lung cancer screening. Clin. Cancer Res. 2009;15(7):2215-2218. Exclusion code: 2. [pmid: 19293258].
van Klaveren RV, Oudkerk M, Mali W, et al. Baseline and second round results from the population based Dutch-Belgian randomized lung cancer screening trial (NELSON) [abstract no. 1508]. Journal of Clinical Oncology: ASCO annual meeting proceedings. 2008;26(15S part I):78. Exclusion code: 5. [pmid: 17131307].
van Loon J, Grutters J, Wanders R, et al. Follow-up with 18FDG-PET-CT after radical radiotherapy with or without chemotherapy allows the detection of potentially curable progressive disease in non-small cell lung cancer patients: a prospective study. Eur. J. Cancer. 2009;45(4):588-595. Exclusion code: 3. [pmid: 19046631].
van Meerbeeck JP, Tournoy KG. Screening and diagnosis of NSCLC. Ann. Oncol. Suppl 4. 2004;15:iv65-70. Exclusion code: 5. [pmid: 15477337].
van Rens MT, de la Riviere AB, Elbers HR, van Den Bosch JM. Prognostic assessment of 2,361 patients who underwent pulmonary resection for non-small cell lung cancer, stage I, II, and IIIA. Chest. 2000;117(2):374-379. Exclusion code: 8. [pmid: 10669677].
van Rikxoort EM, de Hoop B, van de Vorst S, Prokop M, van Ginneken B. Automatic segmentation of pulmonary segments from volumetric chest CT scans. IEEE Trans. Med. Imaging. 2009;28(4):621-630. Exclusion code: 4. [pmid: 19211346].
Van Schil PE, Hendriks JM, Hertoghs M, Lauwers P, Choong C. Current surgical treatment of non-small-cell lung cancer. Expert Rev Anticancer Ther. 2011;11(10):1577-1585. Exclusion code: 5. [pmid: 21999131].
Vansteenkiste JF. Imaging in lung cancer: positron emission tomography scan. European Respiratory Journal - Supplement. 2002;35:49s-60s. Exclusion code: 4. [pmid: 12064681].
Vansteenkiste JF, Stroobants SS. PET scan in lung cancer: current recommendations and innovation. J Thorac Oncol. 2006;1(1):71-73. Exclusion code: 4. [pmid: 17409830].
Van't Westeinde SC, van Klaveren RJ. Screening and early detection of lung cancer. Cancer J. 2011;17(1):3-10. Exclusion code: 2. [pmid: 21263260].
Varella-Garcia M, Schulte AP, Wolf HJ, et al. The detection of chromosomal aneusomy by fluorescence in situ hybridization in sputum predicts lung cancer incidence. Cancer Prev Res (Phila Pa). 2010;3(4):447-453. Exclusion code: 2. [pmid: 20332298].
Varlotto JM, Recht A, Flickinger JC, Medford-Davis LN, Dyer AM, DeCamp MM. Lobectomy leads to optimal survival in early-stage small cell lung cancer: a retrospective analysis. J. Thorac. Cardiovasc. Surg. 2011;142(3):538-546. Exclusion code: 3. [pmid: 21684554].
Varlotto JM, Recht A, Nikolov M, Flickinger JC, Decamp MM. Extent of lymphadenectomy and outcome for patients with stage I nonsmall cell lung cancer. Cancer. 2009;115(4):851-858. Exclusion code: 3. [pmid: 19140203].
Vassallo F, Imperatori A, Rovera F, Pericelli A, Antonini C, Dominioni L. The PRE.DI.CA. project for radiographic lung cancer screening in cigarette smokers. Rays. 2004;29(4):383-385. Exclusion code: 4. [pmid: 15852724].
Vastag B. Lung screening study to test popular CT scans. JAMA. 2002;288(14):1705-1706. Exclusion code: 5. [pmid: 12365935].
Vazquez M, Carter D, Brambilla E, et al. Solitary and multiple resected adenocarcinomas after CT screening for lung cancer: histopathologic features and their prognostic implications. Lung Cancer. 2009;64(2):148-154. Exclusion code: 2. [pmid: 18951650].
Vazquez M, Flieder D, Travis W, et al. Early lung cancer action project pathology protocol. Lung Cancer. 2003;39(2):231-232. Exclusion code: 2. [pmid: 12581579].
Vazquez MF, Flieder DB. Small peripheral glandular lesions detected by screening CT for lung cancer. A diagnostic dilemma for the pathologist. Radiol. Clin. North Am. 2000;38(3):579-589. Exclusion code: 7. [pmid: 10855263].
Vazquez MF, Koizumi JH, Henschke CI, Yankelevitz DF. Reliability of cytologic diagnosis of early lung cancer. Cancer. 2007;111(4):252-258. Exclusion code: 2. [pmid: 17614298].
Vegi SR, Boovanahalli SK, Patro B, Mukkanti K. SPF32629A and SPF32629B: Enantioselective synthesis, determination of absolute configuration, cytotoxicity and antibacterial evaluation. Eur J Med Chem. 2011;46(5):1803-1812. Exclusion code: 5. [pmid: 21397370].
Veglia F, Vineis P, Overvad K, et al. Occupational exposures, environmental tobacco smoke, and lung cancer. Epidemiology. 2007;18(6):769-775. Exclusion code: 2. [pmid: 18062064].
Vehmas T. Factors influencing the prevalence of pulmonary nodules in lung cancer screening trials: re-evaluation of a CT study. Ups. J. Med. Sci. 2008;113(3):279-286. Exclusion code: 2. [pmid: 18991240].
Veronesi G, Bellomi M, Spaggiari L. The rate of incidental findings in lung cancer screening trials is not negligible. Eur. Radiol. 2008;18(3):529. Exclusion code: 5. [pmid: 17994239].
Veronesi G, Bellomi M, Spaggiari L, et al. Low dose spiral computed tomography for early diagnosis of lung cancer. Results of baseline screening in 5,000 high-risk volunteers. J. Clin. Oncol. 2006;24(18s):7029. Exclusion code: 5.
Veronesi G, Bellomi M, Veronesi U, et al. Role of positron emission tomography scanning in the management of lung nodules detected at baseline computed tomography screening. Ann. Thorac. Surg. 2007;84(3):959-965. discussion 965-956. Exclusion code: 3. [pmid: 17720408].
Veronesi G, Maisonneuve P, De Pas TM, Bellomi M. Does lung cancer screening with low-dose CT remain promising despite disappointing DANTE results?. Am. J. Respir. Crit. Care Med. 2010;182(5):720-721. author reply 721. Exclusion code: 5. [pmid: 20802172].
Veronesi G, Maisonneuve P, Spaggiari L, et al. Long-term outcomes of a pilot CT screening for lung cancer. ecancermedicalscience. 2010;4(1). Exclusion code: 5. [pmid: 22276037].
Veronesi G, Szabo E, Decensi A, et al. Randomized phase II trial of inhaled budesonide versus placebo in high-risk individuals with CT screen-detected lung nodules. Cancer Prev Res (Phila Pa). 2011;4(1):34-42. Exclusion code: 2. [pmid: 21163939].
Vidal Serrano S, Méndez AL. CT screening for lung cancer; sistematic review. Cribado de cáncer de pulmón con TC de tórax: Revisión sistemática. 2007;129(15):582-587. Exclusion code: 5. [pmid: 17988617].
Vierikko T, Jarvenpaa R, Autti T. Chest CT screening of asbestos-exposed workers: lung lesions and incidental findings. Eur. Respir. J. 2007;29(1):78-84. Exclusion code: 5. [pmid: 17050560].
Vierikko T, Kivisto S, Jarvenpaa R, et al. Psychological impact of computed tomography screening for lung cancer and occupational pulmonary disease among asbestos-exposed workers. Eur. J. Cancer Prev. 2009;18(3):203-206. Exclusion code: 3. [pmid: 19728402].
Viñes JJ. Effectiveness of early detection of diseases. La efectividad de la detección precoz de las enfermedades. 2007;30(1):11-27. Exclusion code: 5. [pmid: 17491604].
Vollset S, Tverdal A, Gjessing H. Smoking and Deaths between 40 and 70 years of age in women and men. Ann. Intern. Med. 2006;144:381-389. Exclusion code: 2. [pmid: 16549850].
Wahidi MM, Govert JA, Goudar RK, Gould MK, McCrory DC, American College of Chest P. Evidence for the treatment of patients with pulmonary nodules: when is it lung cancer?: ACCP evidence-based clinical practice guidelines (2nd edition). Chest. 2007;132(3 Suppl):94S-107S. Exclusion code: 5. [pmid: 17873163].
Wakelee HA, Gomez SL, Chang ET. Sex differences in lung-cancer susceptibility: a smoke screen?. Lancet Oncol. 2008;9(7):609-610. Exclusion code: 2. [pmid: 18598927].
Waldman MJ, Neher JO, Harper A, Huber T. Does screening reduce lung cancer mortality?. J. Fam. Pract. 2008;57(1):49-50. Exclusion code: 5. [pmid: 18171571].
Waldman MJ, Neher JO, Harper A, Huber TE. Clinical inquiries. Does screening reduce lung cancer mortality?. J. Fam. Pract. 2008;57(1):49-50. Exclusion code: 5. [pmid: 18171571].
Wallace GMF, Winter JH, Winter JE, Taylor A, Taylor TW, Cameron RC. Chest X-rays in COPD screening: are they worthwhile?. Respir. Med. 2009;103(12):1862-1865. Exclusion code: 3. [pmid: 19631518].
Wang B, Li L, Yao L, Liu L, Zhu Y. Detection of p53 gene mutations in sputum samples and their implications in the early diagnosis of lung cancer in suspicious patients. Chin. Med. J. (Engl). 2001;114(7):694-697. Exclusion code: 3. [pmid: 11780329].
Wang BY, Hung JJ, Jeng WJ, et al. Surgical Outcomes in Resected Non-small Cell Lung Cancer ≤ 1 cm in Diameter. Journal of the Chinese Medical Association. 2010;73(6):308-313. Exclusion code: 10. [pmid: 20603088].
Wang DF, Zeng CG, Lin YB, Hou JH, Zhu ZH. Expression and clinical significance of apoptosis-related oncogenes in stage I-II non-small cell lung cancer. Ai Zheng. 2006;25(3):359-362. Exclusion code: 6. [pmid: 16536995].
Wang H, Guo XH, Jia ZW, et al. Multilevel binomial logistic prediction model for malignant pulmonary nodules based on texture features of CT image. Eur. J. Radiol. 2010;74(1):124-129. Exclusion code: 7. [pmid: 19261415].
Wang HJ, Sun KL, Zhang XR, Sun Y, Shi YK. Combined modality therapy for small cell lung cancer patient with limited stage disease. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2007;29(9):701-703. Exclusion code: 6. [pmid: 18246803].
Wang Hw, Zhang Yq, Luo J, Yan X, Lu Hy. Percutaneous lung cancer cryotherapy guided by computer tomography. Chung-Hua Chieh Ho Ho Hu Hsi Tsa Chih Chinese Journal of Tuberculosis & Respiratory Diseases. 2004;27(5):311-314. Exclusion code: 6. [pmid: 15196339].
Wang J, Wu N, Zheng Qf, Feng Y, Yan S, Yang Y. Application of the 2007 lung cancer staging system by International Association for the Study of Lung Cancer. Beijing Da Xue Xue Bao. 2009;41(4):442-446. Exclusion code: 6. [pmid: 19727235].
Wang JC, Sone S, Feng L, et al. Rapidly growing small peripheral lung cancers detected by screening CT: correlation between radiological appearance and pathological features. Br. J. Radiol. 2000;73(873):930-937. Exclusion code: 2. [pmid: 11064644].
Wang Jw, Yang L, Wang Jy, et al. Long-term results of multimodality therapy of testicular germ cell tumor. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2003;25(4):382-385. Exclusion code: 6. [pmid: 12921572].
Wang Q, Takashima S, Wang JC, Zheng LM, Sone S. Prevalence of emphysema in individuals who underwent screening CT for lung cancer in Nagano prefecture of Japan. Respiration. 2001;68(4):352-356. Exclusion code: 7. [pmid: 11464080].
Wang Q, Wang S, Wang H, Li P, Ma Z. MicroRNAs: Novel biomarkers for lung cancer diagnosis, prediction and treatment. Exp. Biol. Med. 2012;237(3):227-235. Exclusion code: 4. [pmid: 22345301].
Wang SY, Zhu ZZ, Peng DF, et al. Efficacy of modified radical operation of preserving nipple-areolar complex on early stage breast cancer. Ai Zheng. 2009;28(4):408-411. Exclusion code: 6. [pmid: 19622302].
Wang X, Chorley BN, Pittman GS, et al. Genetic variation and antioxidant response gene expression in the bronchial airway epithelium of smokers at risk for lung cancer. PLoS ONE. 2010;5(8):e11934. Exclusion code: 3. [pmid: 20689807].
Wang Y, Chen J. Bronchogenic carcinoma after lung transplantation: a case report and literature review. Zhongguo Fei Ai Za Zhi. 2011;14(1):75-78. Exclusion code: 6. [pmid: 21219838].
Wang Y, Zhang Xr, Fu J, Tan W, Zhang W. Prognostic value of expression of FASE, HER-2/neu, bcl-2 and p53 in stage I non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2004;26(6):369-372. Exclusion code: 6. [pmid: 15312350].
Wang YZ, Boudreaux JP, Dowling A, Woltering EA. Percutaneous localisation of pulmonary nodules prior to video-assisted thoracoscopic surgery using methylene blue and TC-99. Eur. J. Cardiothorac. Surg. 2010;37(1):237-238. Exclusion code: 4. [pmid: 19700335].
Wardwell NR, Massion PP. Novel strategies for the early detection and prevention of lung cancer. Semin. Oncol. 2005;32(3):259-268. Exclusion code: 5. [pmid: 15988680].
Warner E, Jotkowitz A, Maimon N. Lung cancer screening--are we there yet?. European Journal of Internal Medicine. 2010;21(1):6-11. Exclusion code: 5. [pmid: 20122605].
Warner EE, Mulshine JL. Lung cancer screening with spiral CT: toward a working strategy. Oncology (Williston). 2004;18(5):564-575. discussion 578, 583-564, 587. Exclusion code: 5. [pmid: 15209187].
Watanabe A, Koyanagi T, Osawa H, et al. Lung cancer in patients with idiopathic interstitial pneumonia. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2005;58(1):9-14. Exclusion code: 6. [pmid: 15678959].
Watanabe A, Tabata A, Ingu A, et al. The validity and problems of a new staging system for lung cancer from the point of view of surgical results. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(11):929-932. Exclusion code: 6. [pmid: 11048444].
Watanabe S, Shimokawa S, Sakasegawa K, et al. Simultaneous operation for lung tumor and cardiovascular disease. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2000;53(5):353-357. discussion 357-359. Exclusion code: 6. [pmid: 10808281].
Watanabe T, Motono N, Hirono T. Surgical results for second primary lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2010;63(11):940-943. Exclusion code: 6. [pmid: 20954347].
Watson PM, Miller SW, Fraig M, Cole DJ, Watson DK, Boylan AM. CaSm (LSm-1) overexpression in lung cancer and mesothelioma is required for transformed phenotypes. Am. J. Respir. Cell Mol. Biol. 2008;38(6):671-678. Exclusion code: 5. [pmid: 18218995].
Weber M. Screening for lung cancer with computed tomography: an examination of the evidence. Jaapa. 2004;17(8):14-18. Exclusion code: 2. [pmid: 15357166].
Weder W, Hillinger S. Tumor surveillance after resection of lung cancer. Ther. Umsch. 2008;65(6):315-318. Exclusion code: 6. [pmid: 18622953].
Wei L, Chen MY, Chen Z, Wu S, Jia JZ. Clinical study of lymphadenectomy of lung cancer by video-assisted thoracic small incision surgery. Chung Hua I Hsueh Tsa Chih. 2009;89(33):2346-2348. Exclusion code: 6. [pmid: 20095358].
Wei WD, Wen ZS, Su XD, Lin P, Rong TH, Chen LK. Multivariate survival analysis of 899 patients with non-small cell lung cancer after complete resection. Ai Zheng. 2007;26(11):1231-1236. Exclusion code: 6. [pmid: 17991324].
Weissfeld JL, Fagerstrom RM, O'Brien B, Prostate LC, Ovarian Cancer Screening Trial Project T. Quality control of cancer screening examination procedures in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control. Clin. Trials. 2000;21(6 Suppl):390S-399S. Exclusion code: 5. [pmid: 11189690].
Welch HG, Black WC. Overdiagnosis in cancer. J. Natl. Cancer Inst. 2010;102(9):605-613. Exclusion code: 2. [pmid: 20413742].
Welch HG, Woloshin S, Schwartz LM, et al. Overstating the evidence for lung cancer screening: the International Early Lung Cancer Action Program (I-ELCAP) study. Arch. Intern. Med. 2007;167(21):2289-2295. Exclusion code: 2. [pmid: 18039986].
Wender R, Fontham ETH, Barrera E, et al. American Cancer Society Lung cancer Screening guidelines. CA. Cancer J. Clin. 2013. Exclusion code: 2. [pmid: 23315954].
Wender RC, Smith R, Harper D. Cancer screening. Prim. Care. 2002;29(3):697-725. Exclusion code: 2. [pmid: 12529905].
Wex P, Utta E, Haas V. What can thoracic surgery accomplish in recurrent/second carcinoma of non-small-cell bronchial carcinoma?. Kongressbd Dtsch Ges Chir Kongr. 2002;119:785-791. Exclusion code: 6. [pmid: 12704929].
White CS. National Lung Screening Trial: a breakthrough in lung cancer screening?. J. Thorac. Imaging. 2011;26(2):86-87. Exclusion code: 5. [pmid: 21508730].
Whitson BA, D'Cunha J. The National Lung Cancer Screening Trial: the ripple effect begins?. Semin. Thorac. Cardiovasc. Surg. 2010;22(4):274-275. Exclusion code: 5. [pmid: 21549266].
Whitson BA, Groth SS, Andrade RS, Maddaus MA, Habermann EB, D'Cunha J. Survival after lobectomy versus segmentectomy for stage I non-small cell lung cancer: a population-based analysis. Ann. Thorac. Surg. 2011;92(6):1943-1950. Exclusion code: 5. [pmid: 21962268].
Whitson BA, Groth SS, Andrade RS, Mitiek MO, Maddaus MA, D'Cunha J. Invasive adenocarcinoma with bronchoalveolar features: a population-based evaluation of the extent of resection in bronchoalveolar cell carcinoma. J. Thorac. Cardiovasc. Surg. 2012;143(3):591-600.e591. Exclusion code: 3. [pmid: 22177098].
Wiener RS, Gould MK, Woloshin S, Schwartz LM, Clark JA. “What do you mean, a spot?”: A qualitative analysis of patients' reactions to discussions with their doctors about pulmonary nodules. Chest. 2012. [doi: 10.1378/chest.12-1095]. [Epub ahead of print],. Exclusion code: 2. [pmid: 22814873].
Wilck EJ. Computed tomography screening for lung cancer. Ann. Thorac. Surg. 2008;85(2):S699-700. Exclusion code: 5. [pmid: 18222199].
Wilde JA. A 10 year follow up of semiannual screening for early detection of lung cancer in the Erfurt country, GDR. Eur. Respir. J. 1989;2:656-662. Exclusion code: 5. [pmid: 2776873].
Wilkinson NW, Loewen GM, Klippenstein DL, Litwin AM, Anderson TM. The evolution of lung cancer screening. J. Surg. Oncol. 2003;84(4):234-238. Exclusion code: 5. [pmid: 14756435].
Williams DE, Pairolero PC, Davis CS, et al. Survival of patients surgically treated for stage I lung cancer. J. Thorac. Cardiovasc. Surg. 1981;82(1):70-76. Exclusion code: 5. [pmid: 7242135].
Willmore-Payne C, Holden JA, Wittwer CT, Layfield LJ. The use of EGFR exon 19 and 21 unlabeled DNA probes to screen for activating mutations in non-small cell lung cancer. Journal of Biomolecular Techniques: JBT. 2008;19(3):217-224. Exclusion code: 3. [pmid: 19137110].
Wilson DO, Leader JK, Fuhrman CR, Reilly JJ, Sciurba FC, Weissfeld JL. Quantitative computed tomography analysis, airflow obstruction, and lung cancer in the pittsburgh lung screening study. J Thorac Oncol. 2011;6(7):1200-1205. Exclusion code: 7. [pmid: 21610523].
Wilson DO, Ryan A, Fuhrman CR, et al. Doubling times and CT screen-detected lung cancers in the Pittsburgh Lung Screening Study. Am. J. Respir. Crit. Care Med. 2012;185(1):85-89. Exclusion code: 2. [pmid: 21997335].
Wilson DO, Weissfeld JL, Balkan A, et al. Association of radiographic emphysema and airflow obstruction with lung cancer. Am. J. Respir. Crit. Care Med. 2008;178(7):738-744. Exclusion code: 2. [pmid: 18565949].
Winawer SJ, Zauber AG, May Nah H, et al. Prevention of colorectal cancer by colonoscopic polypectomy. N. Engl. J. Med. 1993;329(27):1977-1981. Exclusion code: 8. [pmid: 8247072].
Winer E, Gralow J, Diller L, et al. Clinical cancer advances 2008: major research advances in cancer treatment, prevention, and screening--a report from the American Society of Clinical Oncology. [Erratum appears in J Clin Oncol. 2009 Jun 20;27(18):3070-1]. J. Clin. Oncol. 2009;27(5):812-826. Exclusion code: 5. [pmid: 19103723].
Winkler V, Ng N, Tesfaye F, Becher H. Predicting lung cancer deaths from smoking prevalence data. Lung Cancer. 2011;74:170-177. Exclusion code: 2. [pmid: 21420756].
Wisnivesky JP, Henschke CI, Swanson S, et al. Limited resection for the treatment of patients with stage IA lung cancer. Ann. Surg. 2010;251(3):550-554. Exclusion code: 10. [pmid: 20160639].
Wisnivesky JP, Mushlin AI, Sicherman N, Henschke C. The cost-effectiveness of low-dose CT screening for lung cancer: preliminary results of baseline screening. Chest. 2003;124(2):614-621. Exclusion code: 7. [pmid: 12907551].
Wisnivesky JP, Szwarcberg JB, McGinn TG. Lung cancer. Screening, counseling, and treating long-term smokers. Geriatrics. 2002;57(11):28-32. Exclusion code: 5. [pmid: 12442566].
Woloshin S, Schwartz LM, Black WC, Kramer BS. Cancer screening campaigns--getting past uninformative persuasion. N. Engl. J. Med. 2012;367(18):1677-1679. Exclusion code: 2. [pmid: 23113476].
Wood DE, Eapen GA, Ettinger DS, et al. Lung cancer screening: Clinical practice guidelines in oncology. JNCCN Journal of the National Comprehensive Cancer Network. 2012;10(2):240-265. Exclusion code: 2. [pmid: 22308518].
Woods WG, Gao RN, Shuster JJ, et al. Screening of infants and mortality due to neuroblastoma. N. Engl. J. Med. 2002;346(14):1041-1046. Exclusion code: 3. [pmid: 11932470].
Woolner LB, Fontana RS, Sanderson DR, Miller WE, Muhm JR, Taylor WF. Mayo Lung Project: evaluation of lung cancer screening through December 1979. Mayo Clin. Proc. 1981;56(9):544-555. Exclusion code: 5. [pmid: 6267386].
Wormanns D, Fiebich M, Saidi M, Diederich S, Heindel W. Automatic detection of pulmonary nodules at spiral CT: clinical application of a computer-aided diagnosis system. Eur. Radiol. 2002;12(5):1052-1057. Exclusion code: 7. [pmid: 11976846].
Wright G, Manser RL, Byrnes G, Hart D, Campbell DA. Surgery for non-small cell lung cancer: systematic review and meta-analysis of randomised controlled trials. Thorax. 2006;61(7):597-603. Exclusion code: 5. [pmid: 16449262].
Wu GP, Wang EH, Li JH, Fu ZM, Han S. Clinical application of the liquid-based cytological test in cytological screening of sputum for the diagnosis of lung cancer. Respirology. 2009;14(1):124-128. Exclusion code: 5. [pmid: 19144056].
Wu MH, Gotway MB, Lee TJ, et al. Features of non-small cell lung carcinomas overlooked at digital chest radiography. Clin. Radiol. 2008;63(5):518-528. Exclusion code: 3. [pmid: 18374715].
Wu MT, Yang P, Huang YL, et al. Coronary arterial calcification on low-dose ungated MDCT for lung cancer screening: concordance study with dedicated cardiac CT. AJR. Am. J. Roentgenol. 2008;190(4):923-928. Exclusion code: 7. [pmid: 18356438].
Wu Y, Wang S, Huang Z. Extent of lymphadenectomy in stage I-IIIA non-small cell lung cancer: a randomized clinical trial. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2001;23(1):43-45. Exclusion code: 6. [pmid: 11783068].
Wu Yl, Huang Zf, Wang Sy, Yang Xn, Ou W. A randomized trial of systematic nodal dissection in resectable non-small cell lung cancer. Lung Cancer. 2002;36(1):1-6. Exclusion code: 3. [pmid: 11891025].
Wu Z, Zhou Q. Molecular diagnostics and molecular staging of lung cancer. Zhongguo Fei Ai Za Zhi. 2008;11(1):34-39. Exclusion code: 4. [pmid: 20727263].
Xie Gs, Hou Ar, Li Ly, Gao Yn, Cheng Sj. Quantification of plasma DNA as a screening tool for lung cancer. Chin. Med. J. (Engl). 2004;117(10):1485-1488. Exclusion code: 3. [pmid: 15498370].
Xing L, Todd NW, Yu L, Fang H, Jiang F. Early detection of squamous cell lung cancer in sputum by a panel of microRNA markers. Mod. Pathol. 2010;23(8):1157-1164. Exclusion code: 4. [pmid: 20526284].
Xing S, Khanavkar B, Nakhosteen JA, et al. Predictive value of image cytometry for diagnosis of lung cancer in heavy smokers. Eur. Respir. J. 2005;25(6):956-963. Exclusion code: 2. [pmid: 15929948].
Xing T, Brattstrom D, Bergqvist M, Isaksson U, Wagenius G, Brodin O. Radiation responsiveness of human lung cancer cell lines measured with a short term semiautomatic assay. Anticancer Res. 2001;21(6A):3925-3928. Exclusion code: 4. [pmid: 11911271].
Xiong T, Richardson M, Woodroffe R, Halligan S, Morton D, Lilford RJ. Incidental lesions found on CT colonography: their nature and frequency. Br. J. Radiol. 2005;78(925):22-29. Exclusion code: 4. [pmid: 15673525].
Xu DM, van der Zaag-Loonen HJ, Oudkerk M, et al. Smooth or attached solid indeterminate nodules detected at baseline CT screening in the NELSON study: cancer risk during 1 year of follow-up. Radiol. 2009;250(1):264-272. Exclusion code: 2. [pmid: 18984780].
Xu DM, van Klaveren RJ, de Bock GH, et al. Limited value of shape, margin and CT density in the discrimination between benign and malignant screen detected solid pulmonary nodules of the NELSON trial. Eur. J. Radiol. 2008;68(2):347-352. Exclusion code: 2. [pmid: 17920800].
Xu DM, van Klaveren RJ, de Bock GH, et al. Role of baseline nodule density and changes in density and nodule features in the discrimination between benign and malignant solid indeterminate pulmonary nodules. Eur. J. Radiol. 2009;70(3):492-498. Exclusion code: 2. [pmid: 18417311].
Xue Z, Wong K, Wong S. Joint registration and segmentation of serial lung CT images in microendoscopy molecular image-guided therapy. Comput. Med. Imaging Graph. 2008;34(1):55-60. Exclusion code: 4. [pmid: 19709855].
Xue Z, Wong K, Wong STC. Joint registration and segmentation of serial lung CT images for image-guided lung cancer diagnosis and therapy. Comput. Med. Imaging Graph. 2010;34(1):55-60. Exclusion code: 4. [pmid: 19709855].
Yamaguchi M, Bessho Y, Inoue T, Asai Y, Matsumoto T, Murase K. Investigation of optimal viewing size for detecting nodular ground-glass opacity on high-resolution computed tomography with cine-mode display. Radiol Phys Technol. 2011;4(1):13-18. Exclusion code: 2. [pmid: 20820964].
Yamakawa Y, Saitou Y, Kiriyama M, et al. Surgery for multiple primary lung cancers. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2002;55(1):10-14. Exclusion code: 6. [pmid: 11797401].
Yamamoto K, Ohsumi A, Kojima F, et al. Long-term survival after video-assisted thoracic surgery lobectomy for primary lung cancer. Ann. Thorac. Surg. 2010;89(2):353-359. Exclusion code: 10. [pmid: 20103297].
Yamamoto K, Padilla Alarcon J, Calvo Medina V, et al. Surgical results of stage I non-small cell lung cancer: comparison between elderly and younger patients. Eur. J. Cardiothorac. Surg. 2003;23(1):21-25. Exclusion code: 10. [pmid: 12493498].
Yan TD, Black D, Bannon PG, McCaughan BC. Systematic review and meta-analysis of randomized and nonrandomized trials on safety and efficacy of video-assisted thoracic surgery lobectomy for early-stage non-small-cell lung cancer. J. Clin. Oncol. 2009;27(15):2553-2562. Exclusion code: 10. [pmid: 19289625].
Yang J, Yang SY, Hu XY, et al. Serum peptidome profiling in patients with lung cancer. Anatomical Record (Hoboken, N.J.: 2007). 2010;293(12):2027-2033. Exclusion code: 3. [pmid: 21082738].
Yang SY. The status quo, confusion and prospect of early diagnosis for lung cancer. Journal of Xi'an Jiaotong University (Medical Sciences). 2011;32(1):1-5. Exclusion code: 6.
Yang Sy, Xiao Xy, Zhang Wg, et al. Application of serum SELDI proteomic patterns in diagnosis of lung cancer. BMC Cancer. 2005;5:83. Exclusion code: 4. [pmid: 16029516].
Yang ZG, Sone S, Li F, et al. Visibility of small peripheral lung cancers on chest radiographs: influence of densitometric parameters, CT values and tumour type. Br. J. Radiol. 2001;74(877):32-41. Exclusion code: 2. [pmid: 11227774].
Yang ZG, Sone S, Takashima S, et al. High-resolution CT analysis of small peripheral lung adenocarcinomas revealed on screening helical CT. AJR. Am. J. Roentgenol. 2001;176(6):1399-1407. Exclusion code: 7. [pmid: 11373200].
Yangui I, Msaad S, Fouzi S, Ayoub A. Toward optimization of small cell lung cancer management. Tunis. Med. 2007;85(12):1050-1057. Exclusion code: 6. [pmid: 19170386].
Yankelevitz D. CT screening for lung cancer. AJR. Am. J. Roentgenol. 2003;180(6):1736-1737. author reply 1737. Exclusion code: 5. [pmid: 12760953].
Yankelevitz D, Henschke CI. State-of-the-art screening for lung cancer: (part 2): CT scanning. Thorac Surg Clin. 2004;14(1):53-59. Exclusion code: 5. [pmid: 15382308].
Yankelevitz DF. Randomized controlled trials and cancer screening. Radiology. 2003;229(2):603. author reply 603-604. Exclusion code: 5. [pmid: 14595156].
Yankelevitz DF. Perhaps it is time for a change in policy on lung cancer screening. Cleve. Clin. J. Med. 2007;74(6):438-440. Exclusion code: 2. [pmid: 17569201].
Yankelevitz DF. CT screening for lung cancer: editorials can be deceiving. J. 2007;4(6):429-430. author reply 430. Exclusion code: 5. [pmid: 17544148].
Yankelevitz DF. Screening for a cancer: acting on social responsibility. AJR. Am. J. Roentgenol. 2007;188(5):1171-1172. Exclusion code: 2. [pmid: 17449753].
Yankelevitz DF. In reply [4]. Cleve. Clin. J. Med. 2007;74(11):770. Exclusion code: 5.
Yankelevitz DF. Will the national lung screening trial be able to demonstrate a mortality reduction?. Radiology. 2008;246(2):653. author reply 653-654. Exclusion code: 2. [pmid: 18227565].
Yankelevitz DF. Quantifying “overdiagnosis” in lung cancer screening. Radiology. 2008;246(1):332-333. author reply 332-333. Exclusion code: 2. [pmid: 18096549].
Yankelevitz DF, Kostis WJ, Henschke CI, et al. Overdiagnosis in chest radiographic screening for lung carcinoma: frequency. Cancer. 2003;97(5):1271-1275. Exclusion code: 5. [pmid: 12599235].
Yankelevitz DF, Reeves AP, Kostis WJ, Zhao B, Henschke CI. Small pulmonary nodules: Volumetrically determined growth rates based on CT evaluation. Radiology. 2000;217(1):251-256. Exclusion code: 8. [pmid: 11012453].
Yasufuku K. Early diagnosis of lung cancer. Clin. Chest Med. 2010;31(1):39-47. Table of Contents. Exclusion code: 2. [pmid: 20172431].
Yau G, Lock M, Rodrigues G. Systematic review of baseline low-dose CT lung cancer screening. Lung Cancer. 2007;58(2):161-170. Exclusion code: 2. [pmid: 17723250].
Yee AJ, Lynch TJ. CT screening for lung cancer. N. Engl. J. Med. 2007;356(7):744-745. author reply 746-747. Exclusion code: 2. [pmid: 17310519].
Yee J, Sadar MD, Sin DD, et al. Connective tissue-activating peptide III: a novel blood biomarker for early lung cancer detection. J. Clin. Oncol. 2009;27(17):2787-2792. Exclusion code: 2. [pmid: 19414677].
Yi SZ, Zhang DC, Wang YG, Sun KL. Clinical features and prognosis of multiple primary tumors of lung combined with other organs--report of 281 cases. Ai Zheng. 2006;25(6):731-735. Exclusion code: 6. [pmid: 16764770].
Yilmaz HH, Yazihan N, Tunca D, et al. Cancer trends and incidence and mortality patterns in Turkey. Jpn. J. Clin. Oncol. 2011;41(1):10-16. Exclusion code: 5. [pmid: 20558464].
Yokoi K, Matsuguma H, Nakahara R. Extrapleural pneumonectomy for thoracic malignancies. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2004;57(11):1000-1004. Exclusion code: 6. [pmid: 15510811].
Yoneda S, Okabayashi K, Kawahara K, et al. Result of surgical treatment to early stage peripheral non-small cell lung cancer. Kyobu Geka - Japanese Journal of Thoracic Surgery. 2001;54(11):932-937. Exclusion code: 6. [pmid: 11593730].
Yoo DS, Wong TZ, Brizel DM. The role of adaptive and functional imaging modalities in radiation therapy: Approach and application from a radiation oncology perspective. Seminars in Ultrasound, CT and MRI. 2010;31(6):444-461. Exclusion code: 4. [pmid: 21147372].
Yoshida M, Kondo K, Tada T. The relation between the cancer screening rate and the cancer mortality rate in Japan. J. Med. Invest. 2010;57(3-4):251-259. Exclusion code: 3. [pmid: 20847525].
Yoshimoto A, Tsuji H, Takazakura E, et al. Reasons for the delays in the definitive diagnosis of lung cancer for more than one year from the recognition of abnormal chest shadows. Intern. Med. 2002;41(2):95-102. Exclusion code: 3. [pmid: 11868615].
Yoshino I, Yamaguchi M, Yamazaki K, Shoji F, Hamatake M, Maehara Y. Surgical outcome of an anatomical resection of clinical stage IA non-small cell lung cancer assisted with a video-thoracoscopy. Surg. Today. 2010;40(8):719-724. Exclusion code: 10. [pmid: 20676854].
Younes RN, Deutsch F, Badra C, Gross J, Haddad F, Deheinzelin D. Nonsmall cell lung cancer: evaluation of 737 consecutive patients in a single institution. Rev. Hosp. Clin. Fac. Med. Sao Paulo. 2004;59(3):119-127. Exclusion code: 3. [pmid: 15286831].
Yu Ch, Wang Yx, Chu Xy, Sun Ye, Wang T. Long-term outcome of bronchoplastic procedures in the treatment of lung cancer. Chung Hua I Hsueh Tsa Chih. 2003;83(19):1668-1670. Exclusion code: 6. [pmid: 14642100].
Yuan R, Vos PM, Cooperberg PL. Computer-aided detection in screening CT for pulmonary nodules. AJR. Am. J. Roentgenol. 2006;186(5):1280-1287. Exclusion code: 2. [pmid: 16632719].
Yuan Zy Wang Ss Zhu Mq Clinical characteristics and prognosis of different subtypes of breast cancer Chung-Hua Chung Liu Tsa Chih Chinese Journal of Oncology=2008 30 6 456 461 Exclusion code: 6 19024523
Yung RC, Zeng MY, Stoddard GJ, Garff M, Callahan K. Transcutaneous computed bioconductance measurement in lung cancer: A treatment enabling technology useful for adjunctive risk stratification in the evaluation of suspicious pulmonary lesions. Journal of Thoracic Oncology. 2012;7(4):681-689. Exclusion code: 4. [pmid: 22425917].
Zeng H, Fawzy YS, Short MA, et al. Combining field imaging endoscopy with point analysis spectroscopy for improving early lung cancer detection. Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2008;2008:1849-1850. Exclusion code: 4. [pmid: 19163043].
Zhang J, Chen C, Zheng H, Chen G. Clinicopathologic analysis of 57 cases of primary pulmonary mucinous adenocarcinoma. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2009;31(1):66-68. Exclusion code: 6. [pmid: 19538874].
Zhang J, Fu Y, Mei Y, Jiang F, Lakowicz JR. Fluorescent metal nanoshell probe to detect single miRNA in lung cancer cell. Anal. Chem. 2010;82(11):4464-4471. Exclusion code: 4. [pmid: 20433154].
Zhang Lb, Sun Ye, Yu Ch, Liu Y. Clinical diagnosis and surgical treatment of primary pulmonary lymphoma. Chung-Hua Wai Ko Tsa Chih. Chinese Journal of Surgery. 2006;44(2):97-99. Exclusion code: 6. [pmid: 16620666].
Zhang P, Xu Bh, Ma F, Li Q. Clinicopathological characteristics and prognostic significance of young patients with triple-negative breast cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2010;32(2):128-131. Exclusion code: 6. [pmid: 20403244].
Zhang R, Shao F, Wu X, Ying K. Value of quantitative analysis of circulating cell free DNA as a screening tool for lung cancer: a meta-analysis. Lung Cancer. 2010;69(2):225-231. Exclusion code: 4. [pmid: 20004997].
Zhang Z, Liu D, Guo Y, et al. The common causes of conversion of VATS during operation for 248 non-small cell lung cancers. Zhongguo Fei Ai Za Zhi. 2011;14(6):523-528. Exclusion code: 6. [pmid: 21645457].
Zhang Z, Wang Y. Clinical experiences of bronchopleural fistula-related fatal hemoptysis after the resection of lung cancer: a report of 7 cases. Zhongguo Fei Ai Za Zhi. 2012;15(1):39-43. Exclusion code: 6. [pmid: 22237123].
Zhao ZL, Song N, Huang QY, Liu YP, Zhao HR. Clinicopathologic features of lung pleomorphic (spindle/giant cell) carcinoma--a report of 17 cases. Ai Zheng. 2007;26(2):183-188. Exclusion code: 6. [pmid: 17298750].
Zheng D, Haddadin S, Wang Y, et al. Plasma microRNAs as novel biomarkers for early detection of lung cancer. Int J Clin Exp Pathol. 2011;4(6):575-586. Exclusion code: 2. [pmid: 21904633].
Zhong L, Hidalgo GE, Stromberg AJ, Khattar NH, Jett JR, Hirschowitz EA. Using protein microarray as a diagnostic assay for non-small cell lung cancer. Am. J. Respir. Crit. Care Med. 2005;172(10):1308-1314. Exclusion code: 3. [pmid: 16109979].
Zhong XJ, Li DT, Li XL, Mu DB, Zhang XG, Luo JY. Comparison of the characteristics in recurrence and metastasis between bronchioloalveolar carcinoma and other lung adenocarcinomas. Ai Zheng. 2007;26(7):785-789. Exclusion code: 6. [pmid: 17626761].
Zhou SJ, Xu SF, Zhang HQ, Liu ZD. Expression of HDGF and its implication in stage I non-small cell lung cancer. Chung-Hua Chung Liu Tsa Chih. Chinese Journal of Oncology. 2007;29(12):927-930. Exclusion code: 6. [pmid: 18478933].
Zhu M, Fu XN, Chen X. Lobectomy by video-assisted thoracoscopic surgery (VATS) for early stage of non-small cell lung cancer. Frontiers of Medicine in China. 2011;5(1):53-60. Exclusion code: 5. [pmid: 21681675].
Zochbauer-Muller S, Minna JD. The biology of lung cancer including potential clinical applications. Chest Surg. Clin. N. Am. 2000;10(4):691-708. Exclusion code: 5. [pmid: 11091920].
Zompatori M, Battista G, Sciascia N, Di Scioscio V, Canini R. Screening for bronchogenic carcinoma using computed tomography. More questions than answers. Radiol. Med. (Torino). 2001;101(5):313-320. Exclusion code: 6. [pmid: 11438781].
Zona A, Bruno C. Health surveillance for subjects with past exposure to asbestos: From international experience and Italian regional practices to a proposed operational model. Annali dell'Istituto Superiore di Sanita. 2009;45(2):147-161. Exclusion code: 4. [pmid: 19636166].
Zorn GL 3rd, Nesbitt JC. Surgical management of early stage lung cancer. Semin. Surg. Oncol. 2000;18(2):124-136. Exclusion code: 5. [pmid: 10657914].
Zudaire I, Lozano MD, Vazquez MF, et al. Molecular characterization of small peripheral lung tumors based on the analysis of fine needle aspirates. Histol. Histopathol. 2008;23(1):33-40. Exclusion code: 7. [pmid: 17952855].
Zullig LL, Jackson GL, Dorn RA, et al. Cancer incidence among patients of the U.S. Veterans Affairs Health Care System. Mil. Med. 2012;177(6):693-701. Exclusion code: 7. [pmid: 22730846].
Zulueta J, Montuenga LM. Early detection of lung cancer: the right time. Med. Clin. (Barc). 2002;118(12):460-462. Exclusion code: 6. [pmid: 11958764].