# References

1 Calonge N, U.S. Preventive Services Task Force. Prevention of dental caries in preschool children: recommendations and rationale. Am J Prev Med. 2004;26(4):326-9. [pmid: 15110060].
2 Beltran-Aguilar ED, Barker LK, Dye BA. Prevalence and severity of dental fluorosis in the United States, 1999-2004. NCHS Data Brief. 2010;(53):1-8. [pmid: 21211168].
3 Bader JD, Rozier RG, Lohr KN, et al. Physicians' roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004;26(4):315-25. [pmid: 15110059].
4 Centers for Disease Control and Prevention. Hygiene-Related Diseases: Dental Caries (Tooth Decay). 2009. www.cdc.gov/healthywater/hygiene/disease/dental_caries.html. May 23, 2012.
5 Selwitz RH, Ismail AI, Pitts NB. Dental caries. Lancet. 2007;369(9555):51-9. [pmid: 17208642].
6 American Dental Association. Statement on Early Childhood Caries. 2000. www.ada.org/2057.aspx. December 13, 2012.
7 National Center for Health Statistics. Healthy People 2010 Final Review. Hyattsville, MD. 2012.
8 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD. National Institute of Dental and Craniofacial Research, National Institutes of Health. 2000.
9 Dye BA, Tan S, Smith V, et al. Trends in oral health status: United States, 1988–1994 and 1999–2004. Vital Health Stat. 2007;1(248). [pmid: 17633507].
10 Kawashita Y, Kitamura M, Saito T. Early childhood caries. Int J Dent. 2011;2011:725320. [pmid: 22007218].
11 Casamassimo PS, Thikkurissy S, Edelstein BL, et al. Beyond the dmft: the human and economic cost of early childhood caries. J Am Dent Assoc. 2009;140(6):650-7. [pmid: 19491160].
12 Jackson SL, Vann WF Jr, Kotch JB, et al. Impact of poor oral health on children's school attendance and performance. Am J Public Health. 2011;101(10):1900-6. [pmid: 21330579].
13 Caufield PW, Griffen AL. Dental caries: an infectious and transmissible disease. Pediatr Clin North Am. 2000;47(5):1001-19. [pmid: 11059347].
14 Centers for Disease Control and Prevention. Recommendations for using fluoride to prevent and control dental caries in the United States. MMWR. 2001;50(RR-14):1-42. [pmid: 11521913].
15 Tinanoff N, Reisine S. Update on early childhood caries since the Surgeon General's Report. Acad Pediatr. 2009;9(6):396-403. [pmid: 19945074].
16 American Academy of Pediatrics. Profile of Pediatric Visits: Annualized Estimates 2000-2004. Elk Grove Village, IL. 2007.
17 Edelstein BL, Chinn CH. Update on disparities in oral health and access to dental care for America's children. Acad Pediatr. 2009;9(6):415-9. [pmid: 19945076].
18 Lewis CW, Boulter S, Keels MA, et al. Oral health and pediatricians: results of a national survey. Acad Pediatr. 2009;9(6):457-61. [pmid: 19945080].
19 Task Force on Community Preventive Services. Recommendations on selected interventions to prevent dental caries, oral and pharyngeal cancers, and sports-related craniofacial injuries. Am J Prev Med. 2002;23(1 Suppl):16-20. [pmid: 12091092].
20 Ekstrand J, Koch G, Lindgren LE, et al. Pharmacokinetics of fluoride gels in children and adults. Caries Res. 1981;15(3):213-20. [pmid: 6938306].
21 Ekstrand J, Koch G, Petersson LG. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res. 1980;14(4):185-9. [pmid: 6929729].
22 American Academy of Pediatric Dentistry. Guideline on Xylitol Use in Caries Prevention. American Academy of Pediatric Dentistry Reference Manual. Clinical Guidelines. 2012/2013;34(6):166-9.
23 American Academy of Pediatrics. Oral Health Risk Assessment Tool. 2011. www2.aap.org/oralhealth/docs/RiskAssessmentTool.pdf. December 13, 2012.
24 American Academy on Pediatric Dentistry Council on Clinical Affairs. Policy on use of a caries-risk assessment tool (CAT) for infants, children, and adolescents. Pediatr Dent. 2008;30(7 Suppl):29-33. [pmid: 19216377].
25 Hale KJ, American Academy of Pediatrics Section on Pediatric Dentistry. Oral health risk assessment timing and establishment of the dental home. Pediatrics. 2003;111(5 Pt 1):1113-6. [pmid: 12728101].
26 American Academy of Pediatrics. Policy Statement—AAP Publications Retired and Reaffirmed. http://pediatrics.aappublications.org/content/124/2/845.full. January12, 2013.
27 American Academy of Pediatrics. Recommendations for Preventive Pediatric Health Care. 2008. http://www.aap.org/en-us/professional-resources/practice-support/Periodicity/Periodicity%20Schedule_FINAL.pdf. April 17, 2014.
28 American Academy of Pediatrics. Preventive oral health intervention for pediatricians: Section on Pediatric Dentistry and Oral Health. Pediatrics. 2008;122(6):1387-94. [pmid: 19015205].
29 American Dental Association Council on Scientific Affairs. Professionally applied topical fluoride: evidence-based clinical recommendations. J Dent Educ. 2007;71(3):393-402. [pmid: 17389574].
30 American Academy of Family Physicians. Fluoridation of Public Water Supplies. Policies. 2008. www.aafp.org/online/en/home/policy/policies/f/fluoridationofpublicwatersupplies.html. January 12, 2013.
31 Rozier RG, Adair S, Graham F, et al. Evidence-based clinical recommendations on the prescription of dietary fluoride supplements for caries prevention: a report of the American Dental Association Council on Scientific Affairs. J Am Dent Assoc. 2010;141(12):1480-9. [pmid: 21158195].
32 American Academy of Pediatric Dentistry. Guideline on Fluoride Therapy. American Academy of Pediatric Dentistry Reference Manual. Clinical Guidelines. 2012/2013;34(6):162-165.
33 Rethman MP, Beltran-Aguilar ED, Billings RJ, et al. Nonfluoride caries-preventive agents: executive summary of evidence-based clinical recommendations. J Am Dent Assoc. 2011;142(9):1065-71. [pmid: 21987836].
34 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3, Suppl 1):21-35. [pmid: 11306229].
35 U.S. Preventive Services Task Force. Procedure Manual. 2011. www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. April 3, 2013.
36 Community Preventive Services Task Force. Improving Oral Health: Dental Caries (Cavities). 2010. www.thecommunityguide.org/oral/caries.html. March 27, 2013.
37 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999;27(1):48-56. [pmid: 10086926].
38 Ismail AI, Hasson H. Fluoride supplements, dental caries and fluorosis: a systematic review. J Am Dent Assoc. 2008;139(11):1457-68. [pmid: 18978383].
39 Pierce KM, Rozier RG, Vann WF Jr. Accuracy of pediatric primary care providers' screening and referral for early childhood caries. Pediatrics. 2002;109(5):E82-2. [pmid: 11986488].
40 Serwint JR, Mungo R, Negrete VF, et al. Child-rearing practices and nursing caries. Pediatrics. 1993;92(2 I):233-7. [pmid: 8337022].
41 Beltrán ED, Malvitz DM, Eklund SA. Validity of two methods for assessing oral health status of populations. J Public Health Dent. 1997;57(4):206-14. [pmid: 9558624].
42 American Dental Association. Caries Risk Assessment Form (Age 0-6). 2011. www.ada.org/sections/professionalResources/pdfs/topics_caries_educational_under6.pdf. March 27, 2013.
43 Davies GM, Duxbury JT, Boothman NJ, et al. A staged intervention dental health promotion programme to reduce early childhood caries. Community Dent Health. 2005;22(2):118-22. [pmid: 15984138].
44 Davies GM, Duxbury JT, Boothman NJ, et al. Challenges associated with the evaluation of a dental health promotion programme in a deprived urban area. Community Dent Health. 2007;24(2):117-21. [pmid: 17615828].
45 Kressin NR, Nunn ME, Singh H, et al. Pediatric clinicians can help reduce rates of early childhood caries: effects of a practice based intervention. Med Care. 2009;47(11):1121-8. [pmid: 19786919].
46 Beil H, Rozier RG, Preisser JS, et al. Effect of early preventive dental visits on subsequent dental treatment and expenditures. Med Care. 2012;50(9):749-56. [pmid: 22525611].
47 Lawrence HP, Binguis D, Douglas J, et al. A 2-year community-randomized controlled trial of fluoride varnish to prevent early childhood caries in Aboriginal children. Community Dent Oral Epidemiol. 2008;36(6):503-16. [pmid: 18422711].
48 Slade GD, Bailie RS, Roberts-Thomson K, et al. Effect of health promotion and fluoride varnish on dental caries among Australian Aboriginal children: results from a community-randomized controlled trial. Community Dent Oral Epidemiol. 2011;39(1):29-43. [pmid: 20707872].
49 Weintraub JA, Ramos-Gomez F, Jue B, et al. Fluoride varnish efficacy in preventing early childhood caries. J Dent Res. 2006;85(2):172-6. [pmid: 16434737].
50 Zhan L, Cheng J, Chang P, et al. Effects of xylitol wipes on cariogenic bacteria and caries in young children. J Dent Res. 2012;91(7 Suppl):85S-90S. [pmid: 22699675].
51 Kovari H, Pienihakkinen K, Alanen P. Use of xylitol chewing gum in daycare centers: a follow-up study in Savonlinna, Finland. Acta Odontol Scand. 2003;61(6):367-70. [pmid: 14960009].
52 Oscarson P, Lif Holgerson P, Sjostrom I, et al. Influence of a low xylitol-dose on mutans streptococci colonisation and caries development in preschool children. Eur Arch Paediatr Dent. 2006;7(3):142-7. [pmid: 17140543].
53 Seki M, Karakama F, Kawato T, et al. Effect of xylitol gum on the level of oral mutans streptococci of preschoolers: block-randomised trial. Int Dent J. 2011;61(5):274-80. [pmid: 21995376].
54 Du MQ, Tai BJ, Jiang H, et al. A two-year randomized clinical trial of chlorhexidine varnish on dental caries in Chinese preschool children. J Dent Res. 2006;85(6):557-9. [pmid: 16723655].
55 Lopez L, Berkowitz R, Spiekerman C, et al. Topical antimicrobial therapy in the prevention of early childhood caries: a follow-up report. Pediatr Dent. 2002;24(3):204-6. [pmid: 12064491].
56 Hamberg L. Controlled trial of fluoride in vitamin drops for prevention of caries in children. Lancet. 1971;1(7696):441-2. [pmid: 4100412].
57 Hennon DK, Stookey GK, Beiswanger BB. Fluoride-vitamin supplements: effects on dental caries and fluorosis when used in areas with suboptimum fluoride in the water supply. J Am Dent Assoc. 1977;95(5):965-71. [pmid: 269878].
58 Hennon DK, Stookey GK, Muhler JC. Prophylaxis of dental caries: relative effectiveness of chewable fluoride preparations with and without added vitamins. J Pediatr. 1972;80(6):1018-21. [pmid: 5026023].
59 Hu D, Wan H, Li S. The caries-inhibiting effect of a fluoride drop program: a 3-year study on Chinese kindergarten children. Chin J Dent Res. 1998;1(3):17-20. [pmid: 10557167].
60 Lin YTJ, Tsai CL. Comparative anti-caries effects of tablet and liquid fluorides in cleft children. J Clin Dent. 2000;11(4):104-6. [pmid: 11460274].
61 Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967;113(6):670-2. [pmid: 4381737].
62 Margolis FJ, Reames HR, Freshman E, et al. Fluoride. Ten-year prospective study of deciduous and permanent dentition. Am J Dis Child. 1975;129(7):794-800. [pmid: 1096595].
63 Autio-Gold JT, Courts F. Assessing the effect of fluoride varnish on early enamel carious lesions in the primary dentition. J Am Dent Assoc. 2001;132(9):1247-53. [pmid: 11665349].
64 Frostell G, Birkhed D, Edwardsson S, et al. Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo Study. Caries Res. 1991;25(4):304-10. [pmid: 1913770].
65 Grodzka K, Augustyniak L, Budny J. Caries increment in primary teeth after application of Duraphat fluoride varnish. Community Dent Oral Epidemiol. 1982;10(2):55-9. [pmid: 6952970].
66 Holm AK. Effect of a fluoride varnish (Duraphat) in preschool children. Community Dent Oral Epidemiol. 1979;7(5):241-5. [pmid: 295702].
67 Petersson LG, Twetman S, Pakhomov GN. The efficiency of semiannual silane fluoride varnish applications: a two-year clinical study in preschool children. J Public Health Dent. 1998;58(1):57-60. [pmid: 9608447].
68 Twetman S, Petersson LG, Pakhomov GN. Caries incidence in relation to salivary mutans streptococci and fluoride varnish applications in preschool children from low- and optimal-fluoride areas. Caries Res. 1996;30(5):347-53. [pmid: 8877088].
69 Chu CH, Lo ECM, Lin HC. Effectiveness of silver diamine fluoride and sodium fluoride varnish in arresting dentin caries in Chinese pre-school children. J Dent Res. 2002;81(11):767-70. [pmid: 12407092].
70 Jiang H, Bian Z, Tai BJ, et al. The effect of a bi-annual professional application of APF foam on dental caries increment in primary teeth: 24-month clinical trial. J Dent Res. 2005;84(3):265-8. [pmid: 15723868].
71 Weinstein P, Riedy CA, Kaakko T, et al. Equivalence between massive versus standard fluoride varnish treatments in high caries children aged 3-5 years. Eur J Paediatr Dent. 2001;2:91-6.
72 Weinstein P, Spiekerman C, Milgrom P. Randomized equivalence trial of intensive and semiannual applications of fluoride varnish in the primary dentition. Caries Res. 2009;43(6):484-90. [pmid: 20016179].
73 Milgrom P, Ly KA, Tut OK, et al. Xylitol pediatric topical oral syrup to prevent dental caries: a double-blind randomized clinical trial of efficacy. Arch Pediatr Adolesc Med. 2009;163(7):601-7. [pmid: 19581542].
74 Alamoudi NM, Hanno AG, Masoud MI, et al. Effects of xylitol on salivary mutans streptococcus, plaque level, and caries activity in a group of Saudi mother-child pairs. An 18-month clinical trial. Saudi Med J. 2012;33(2):186-92. [pmid: 22327761].
75 Bottenberg P, Declerck D, Ghidey W, et al. Prevalence and determinants of enamel fluorosis in Flemish schoolchildren. Caries Res. 2004;38(1):20-8. [pmid: 14684973].
76 Hiller KA, Wilfart G, Schmalz G. Developmental enamel defects in children with different fluoride supplementation - a follow-up study. Caries Res. 1998;32(6):405-11. [pmid: 9745112].
77 Pendrys DG. Risk of enamel fluorosis in nonfluoridated and optimally fluoridated populations: considerations for the dental professional. J Am Dent Assoc. 2000;131(6):746-55. [pmid: 10860326].
78 Pendrys DG, Katz RV. Risk factors for enamel fluorosis in optimally fluoridated children born after the US manufacturers' decision to reduce the fluoride concentration of infant formula. Am J Epidemiol. 1998;148(10):967-74. [pmid: 9829868].
79 Wang NJ, Gropen AM, Øgaard B. Risk factors associated with fluorosis in a non-fluoridated population in Norway. Community Dent Oral Epidemiol. 1997;25(6):396-401. [pmid: 9429811].
80 Liu J, Probst JC, Martin AB, et al. Disparities in dental insurance coverage and dental care among US children: the National Survey of Children's Health. Pediatrics. Suppl 1. 2007;119:S12-21. [pmid: 17272579].
81 Beil HA, Rozier RG. Primary health care providers' advice for a dental checkup and dental use in children. Pediatrics. 2010;126(2):e435-41. [pmid: 20660547].
82 Agency for Healthcare Research and Quality. Medical Expenditure Panel Survey, MEPS HC-126B: 2009 Dental Visits. 2011. http://meps.ahrq.gov/data_stats/download_data_files_detail.jsp?cboPufNumber=HC-126B. March 27, 2013.
83 Kaakko T, Skaret E, Getz T, et al. An ABCD program to increase access to dental care for children enrolled in Medicaid in a rural county. J Public Health Dent. 2002;62(1):45-50. [pmid: 14700089].
84 Lave JR, Keane CR, Lin CJ, et al. The impact of dental benefits on the utilization of dental services by low-income children in western Pennsylvania. Pediatr Dent. 2002;24(3):234-40. [pmid: 12064498].
85 Liao CC, Ganz ML, Jiang H, et al. The impact of the public insurance expansions on children's use of preventive dental care. Matern Child Health J. 2010;14(1):58-66. [pmid: 19067137].
86 Decker SL. Medicaid payment levels to dentists and access to dental care among children and adolescents. JAMA. 2011;306(2):187-93. [pmid: 21750296].
87 Autio-Gold J. Recommendations for fluoride varnish use in caries management. Dent Today. 2008;27(1):64-7. quiz 7, 58. [pmid: 18240633].
88 Bawden JW. Fluoride varnish: a useful new tool for public health dentistry. J Public Health Dent. 1998;58(4):266-9. [pmid: 10390707].
89 Hong L, Levy SM, Broffitt B, et al. Timing of fluoride intake in relation to development of fluorosis on maxillary central incisors. Community Dent Oral Epidemiol. 2006;34(4):299-309. [pmid: 16856950].
90 Beltran-Aguilar ED, Barker LK, Canto MT, et al. Surveillance for dental caries, dental sealants, tooth retention, edentulism, and enamel fluorosis--United States, 1988-1994 and 1999-2002. MMWR Surveill Summ. 2005;54(3):1-43. [pmid: 16121123].
91 Pendrys DG. The fluorosis risk index: a method for investigating risk factors. J Public Health Dent. 1990;50(5):291-8. [pmid: 2231522].
92 Bratthall D, Hansel Petersson G. Cariogram--a multifactorial risk assessment model for a multifactorial disease. Community Dent Oral Epidemiol. 2005;33(4):256-64. [pmid: 16008632].
93 MacRitchie HM, Longbottom C, Robertson M, et al. Development of the Dundee Caries Risk Assessment Model (DCRAM)--risk model development using a novel application of CHAID analysis. Community Dent Oral Epidemiol. 2012;40(1):37-45. [pmid: 21838824].
94 Harris R, Nicoll AD, Adair PM, et al. Risk factors for dental caries in young children: a systematic review of the literature. Community Dent Health. 2004;21(1 Suppl):71-85. [pmid: 15072476].
95 Holgerson PL, Twetman S, Stecksen-Blicks C. Validation of an age-modified caries risk assessment program (Cariogram) in preschool children. Acta Odontol Scand. 2009;67(2):106-12. [pmid: 19152150].