# Discussion

## Summary of Review Findings

Dental caries is highly prevalent in children younger than age 5 years. A high proportion of children in this age group do not receive recommended dental care,80 suggesting a potential role for primary care providers in dental caries prevention. However, as in the 2004 USPSTF review,3 we found no direct evidence on the effects of screening for dental caries by primary care clinicians in children younger than age 5 years versus no screening on caries incidence and related outcomes. Other evidence reviewed for this update is summarized in Table 4. Newer evidence identified for this update was consistent with findings from the 2004 USPSTF review in showing that fluoride varnish in children younger than age 5 years is effective at reducing caries incidence.47-49 Because trials were primarily conducted in higher risk children (based on community water fluoride levels or socioeconomic status), the applicability of these findings to children not at increased risk may be limited, particularly for studies conducted in countries and settings in which sources of fluoride and health behaviors differ markedly from the United States. In all trials the varnish was applied by dental personnel, although fluoride varnish is believed to be easily applied with minimal training.87,88

Table 4 Summary of Evidence

Main Findings From 2004 USPSTF Review | Number and Type of Studies Identified for Update Overall Quality^*^ | Limitations | Consistency | Applicability | Summary of Findings
Key Question 1. How effective is oral screening (including risk assessment) by the primary care clinician in preventing dental caries in children younger than age 5 years?
No evidence | No studies | No studies | No studies | No studies | No randomized trial or observational study compared clinical outcomes between children younger than 5 years of age screened and not screened by primary care clinicians.
Key Question 2a. How accurate is screening by the primary care clinician in identifying children younger than age 5 years who have cavitated or noncavitated caries lesions?
One study found pediatrician examination following 4 hours of oral health education associated with a sensitivity of 1.0 and specificity of 0.87 for identifying nursing caries in children 18-36 months of age. | 1 cohort study Overall quality: Fair | Evidence limited to 1 study | N/A | Study conducted in a primary care setting | One study found primary care pediatrician examination following 2 hours of oral health education associated with a sensitivity of 0.76 for identifying a child with 1 or more cavities and 0.63 for identifying children <36 months of age in need of a dental referral, compared with a pediatric dentist evaluation.
Key Question 2b. How accurate is screening by the primary care clinician in identifying children younger than age 5 years who are at increased risk for future dental caries?
No evidence | No studies | No studies | No studies | No studies | No study evaluated the accuracy of risk-assessment tools applied by primary care clinicians to identify children at increased risk for future dental caries.
Key Question 3. What are the harms of oral health screening by the primary care clinician?
No evidence | No studies | No studies | No studies | No studies | No randomized trial or observational study compared harms between children younger than 5 years of age screened and not screened by primary care clinicians.
Key Question 4. How effective is parental or caregiver oral health education by the primary care clinician in preventing dental caries in children younger than age 5 years?
No evidence | 1 randomized trial, 1 nonrandomized trial Overall quality: Poor | Nonrandomized design, high attrition, failure to adjust for confounders | Moderate inconsistency | Education evaluated as part of a multifactorial intervention | No trial specifically evaluated an educational or counseling intervention to prevent dental caries. Two studies found multifactorial interventions that included an educational component associated with decreased incidence or prevalence of cavities in underserved children younger than 5 years of age.
Key Question 5. How effective is referral by a primary care clinician to a dentist in preventing dental caries in children younger than age 5 years?
No evidence | 1 cohort study Overall quality: Poor | Study not designed to determine whether a primary care referral was the source of the initial preventive visit | N/A | Medicaid population, higher risk children | No study directly evaluated the effects of referral by a primary care clinician to a dentist on caries incidence. One study found a first dental preventive visit after 18 months of age in children with existing dental disease associated with increased risk of subsequent dental procedures compared with a first visit before 18 months of age, but was not designed to determine referral source.
Key Question 6. How effective is preventive treatment with dietary fluoride supplementation in preventing dental caries in children younger than age 5 years?
Six trials of dietary fluoride supplements. One randomized trial and 4 other trials found oral fluoride supplementation in settings with water fluoridation levels below 0.6 ppm F associated with decreased caries incidence vs. no fluoridation (ranges of 48- 72% for primary teeth and 51- 81% for primary tooth surface). | No studies Overall quality: Fair | Limitations in previously reviewed studies include use of nonrandomized design, not controlling for confounders, inadequate blinding, and high or unreported attrition | N/A | No studies | We identified no new trials on the effects of dietary fluoride supplementation in children younger than 5 years of age on dental caries incidence.
Key Question 6. How effective is preventive treatment with topical fluoride application (fluoride varnish) in preventing dental caries in children younger than age 5 years?
Three randomized trials found fluoride varnish more effective than no fluoride varnish in reducing caries incidence (percent reduction 37-63%, with an absolute reduction in the mean number of cavities per child of 0.67-1.24 per year). | 6 randomized trials, 1 trial using alternate allocation Overall quality: Fair | High loss to followup, failure to describe adequate blinding, and failure to describe adequate allocation concealment | Consistent | Rural settings with inadequate fluoridation or low socioeconomic status settings | Three randomized trials published since the prior review found fluoride varnish more effective than no fluoride varnish in reducing caries incidence (percent reduction in caries increment 18-59%). Other trials evaluated methods of topical fluoride application not used in the United States or compared different doses or frequencies of topical fluoride.
Key Question 6. How effective is preventive treatment with xylitol in preventing dental caries in children younger than 5 years of age?
No studies (not included in the prior review). | 5 randomized trials; 1 nonrandomized Overall quality: Fair | Variability in xylitol formulation and dosing | Some inconsistency | Children from settings in which water was not fluoridated or fluoridation limited | Three trials reported no clear effects of xylitol vs. no xylitol on caries incidence in children younger than 5 years, with the most promising results from a small (n=37) trial of xylitol wipes. One trial found no difference between xylitol and toothbrushing.
Key Question 7. What are the harms of specific oral health interventions for prevention of dental caries in children younger than 5 years of age (parental or caregiver oral health education, referral to a dentist, and preventive treatments)?
One systematic review of 14 observational studies found dietary fluoride supplementation in early childhood associated with increased risk of fluorosis; odd ratios ranged from 1.3-15.6 and prevalence ranged from 10-67%. | 5 observational studies in an updated systematic review Overall quality: Fair | Use of retrospective parental recall to determine exposures | Consistent | Doses of fluoride generally higher than currently recommended | Five observational studies in an updated systemic review were consistent with previously reported findings in showing an association between early childhood ingestion of systemic fluoride and enamel fluorosis. Other than diarrhea reported in 2 trials of xylitol, harms were poorly reported in trials of caries prevention interventions in children younger than 5 years of age.

* “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

Abbreviations: USPSTF = U.S. Preventive Services Task Force.

We identified no new trials on the effectiveness of dietary fluoride supplementation in children younger than age 5 years. Although the 2004 USPSTF review found dietary fluoride supplementation to be effective at reducing caries incidence in children younger than age 5 years primarily in settings with water fluoridation levels less than 0.6 ppm F, conclusions were mostly based on nonrandomized trials.3 Newer observational studies were consistent with the 2004 USPSTF review in finding an association between early childhood intake of dietary fluoride supplementation and risk of enamel fluorosis.38 Risk of enamel fluorosis appears to be impacted by total intake of fluoride (from supplements, drinking water, other dietary sources, and dentifrices), as well as age at intake, with intake before age 2 to 3 years appearing to confer the highest risk.89 Although the prevalence of enamel fluorosis has increased in the United States, severe fluorosis is uncommon, with a prevalence of less than 1 percent.2,90,91

Trials of xylitol in children younger than age 5 years found no clear effects on caries incidence, although studies differed in the doses and formulations evaluated.50,52,53 The most promising results were from a small trial of xylitol wipes that reported a marked decrease in caries incidence, but they require confirmation.50 Evidence on the effectiveness of other interventions not in common use in the United States in young children, such as chlorhexidine varnish and povidone-iodine solution, is limited to single trials, precluding reliable conclusions.54,55

Evidence remains limited on the accuracy of primary care clinicians in identifying caries lesions in children younger than age 5 years or in predicting caries incidence. One study not included in the prior USPSTF review found that primary care pediatricians missed 37 percent of children in need of a dental referral and 24 percent of children with a cavity compared with a pediatric dentist exam, although specificity was high.39 No study evaluated the diagnostic accuracy of caries risk-assessment instruments administered by primary care clinicians, despite the availability of instruments designed for use in primary care settings.24 Some studies have assessed caries risk-assessment instruments in children younger than age 5 years, but the instruments were not administered by primary care providers or in primary care settings. In addition, these instruments often incorporate findings from an oral examination by dental personnel and include tests not commonly obtained in primary care (such as mutans streptococci levels, saliva secretion level, or saliva buffer capacity),92,93 potentially limiting applicability of findings to primary care settings.94,95

No trial specifically evaluated the effectiveness of parental or caregiver/guardian education on caries outcomes, although limited evidence from two trials suggests that multifactorial interventions in which education is a component could be effective.43-45 Although some evidence indicates that health care providers' recommendation for dental care increases the likelihood of subsequent dental visits in young children,81 no trial evaluated the effectiveness of primary care referral to a dentist on caries outcomes. One retrospective cohort study found an association between an early (prior to age 18 months) dental visit and fewer subsequent dental procedures in children with dental disease at baseline.46

## Limitations

We excluded non–English-language articles, which could result in language bias, although we identified no non–English-language studies that would have met inclusion criteria. We did not search for studies published only as abstracts, and we could not formally assess for publication bias with graphical or statistical methods because of small numbers of studies for each Key Question and differences in the study design, populations, and outcomes assessed. We found few or no randomized trials for a number of Key Questions. Therefore, we included nonrandomized trials, as well as observational studies (for harms), which are more susceptible to bias and confounding than are well-conducted randomized trials.

## Emerging Issues

The increasing prevalence of dental caries in young children is an important emerging issue.9 The reasons for this trend are not completely understood but could include changes in dietary patterns, access to dental care, demographics, or socioeconomic status.

## Future Research

Research is needed to identify effective oral health educational and counseling interventions for parents and caregivers and guardians of young children. Research is also needed to validate the accuracy and utility of caries risk-assessment instruments for use in primary care settings and to determine how referral by primary care clinicians of young children for dental care affects caries outcomes. Additional trials would strengthen conclusions regarding the effectiveness of dietary fluoride supplementation in young children, especially in the current U.S. context of exposure to multiple sources of fluoride, and trials are needed to demonstrate that results from trials of fluoride varnish applied by dental personnel can be reproduced in primary care settings.

## Conclusions

Dietary fluoride supplementation and fluoride varnish appear to be effective at preventing caries outcomes in higher risk children younger than age 5 years. Dietary fluoride supplementation in early childhood is associated with risk of enamel fluorosis, which is usually mild. More research is needed to understand the accuracy of oral health examination and caries risk assessment by primary care clinicians, primary care referral for dental care, and effective parental or caregiver educational and counseling interventions.