# Results

## Key Question 1 How Effective Is Oral Screening (Including Risk Assessment) by the Primary Care Clinician in Preventing Dental Caries in Children Younger Than Age 5 Years?

No randomized trial or observational study compared clinical outcomes between children younger than 5 years of age screened and not screened by primary care clinicians.

## Key Question 2a How Accurate Is Screening by the Primary Care Clinician in Identifying Children Younger Than Age 5 Years Who Have Cavitated or Noncavitated Caries Lesions?

### Summary

One good-quality study found primary care pediatrician examination of children younger than age 36 months following 2 hours of oral health education associated with a sensitivity of 0.76 for identifying a child with one or more cavities and 0.63 for identifying children in need of a dental referral compared with a pediatric dentist evaluation.39 Specificity was 0.95 for identifying children with cavities and 0.98 for identifying children who needed a dental referral. A study included in the 2004 USPSTF review found pediatrician examination following 4 hours of oral health education associated with a sensitivity of 1.0 and specificity of 0.87 for identifying nursing caries (defined as caries involving one or more of the maxillary central or lateral incisors or the primary molars, but excluding the mandibular incisors) in children age 18 to 36 months.40

### Evidence

The 2004 USPSTF review3 included one fair-quality study that found a pediatrician oral health exam of children age 18 to 36 months following 4 hours of training associated with a sensitivity of 1.0 and specificity of 0.87 for identifying nursing caries compared with a pediatric dentist exam.40 A second study included in the prior USPSTF review found a non–dental nurse exam associated with high sensitivity and specificity, but it enrolled children age 5 to 12 years and is therefore of limited applicability to younger children.41

One good-quality study not included in the prior USPSTF review evaluated the accuracy of caries screening of children younger than age 36 months (n=258) by primary care pediatricians following 2 hours of oral health education (Appendixes B1 and B2).39 The study enrolled Medicaid-eligible children (9.7 percent with a cavity at baseline; mean, 0.3 cavities/child) attending a private pediatric group practice in North Carolina. Compared with a pediatric dentist evaluation, it found a sensitivity of 0.76 (19/25) and specificity of 0.95 (222/233) for identifying a child with one or more cavities, a sensitivity of 0.49 (39/80) and specificity of 0.99 (3,210/3,235) for identifying a tooth with a cavity, and a sensitivity of 0.63 (17/27) and specificity of 0.98 (225/231) for identifying children in need of a dental referral. The need for referral was determined by the presence of a cavity, soft tissue pathology, or evidence of tooth or mouth trauma.

No study evaluated the accuracy of primary care screening for noncavitated caries (e.g., white spot) lesions.

## Key Question 2b How Accurate Is Screening by the Primary Care Clinician in Identifying Children Younger Than Age 5 Years Who Are at Increased Risk for Future Dental Caries?

The prior USPSTF review found no study on the accuracy of assessment by primary care clinicians in identifying children at risk for future dental caries.3 Although risk-assessment tools for use in primary care settings are available from the AAP,24 the AAPD,24 and the ADA,42 we found no study on the accuracy of risk assessment by primary care clinicians using these or other instruments.

## Key Question 3 What Are the Harms of Oral Health Screening by the Primary Care Clinician?

No randomized trial or observational study compared harms between children age 5 years or younger screened and not screened by primary care clinicians.

## Key Question 4 How Effective Is Parental or Caregiver Oral Health Education by the Primary Care Clinician in Preventing Dental Caries in Children Younger Than Age 5 Years?

### Summary

No trial specifically evaluated an educational or counseling intervention by a primary care clinician to prevent dental caries. One fair-quality and one poor-quality nonrandomized trial found multifactorial interventions that included an educational component associated with decreased caries outcomes in underserved children younger than age 5 years.43-45

### Evidence

The 2004 USPSTF review found no studies on the effectiveness of oral health educational or counseling interventions administered by a primary care clinician.3 We identified no trials published since the 2004 review that specifically evaluated an educational or counseling intervention, although two nonrandomized, controlled clinical trials (reported in three publications) evaluated oral health educational interventions as a part of multicomponent interventions (Appendixes B3 and B4).43-45 One study was rated fair quality45 and the other poor quality.43,44 In addition to using a nonrandomized design, other methodological shortcomings in the poor-quality study were high attrition and failure to adjust for confounders.

The fair-quality trial found a multicomponent intervention including additional pediatrician training, provision of an educational brochure, and electronic medical record reminders associated with decreased incidence of cavities versus usual care after 1 year: 18 versus 32 percent; adjusted hazard ratio (HR), 0.23; 95-percent confidence interval (CI), 0.09 to 0.62.^45^ Children were age 6 months to 5 years at enrollment and recruited from an urban underserved setting. Results were adjusted for age, race/ethnicity, socioeconomic status, and dietary and oral health risk. The trial used a cluster design, with one intervention and one demographically similar control clinic. Baseline caries prevalence was about 6 percent.

The poor-quality trial also found a multicomponent intervention (including provision of educational materials, counseling on oral hygiene, and provision of toothbrush and toothpaste) associated with a lower prevalence of caries compared with usual care (54 vs. 64%; p=0.03), dental extraction (3 vs. 12%; p<0.0001), and mean dmft score (2.2 vs. 3.7; p<0.001).43,44 The intervention was administered to children between age 8 months and 32 months recruited from primary care clinics in an urban deprived setting, and outcomes were assessed at age 5 years. The intervention was administered by health visitors (registered nurses with further training in child health, health promotion, prevention, and education) at healthy-child visits.

## Key Question 5 How Effective Is Referral by a Primary Care Clinician to a Dentist in Preventing Dental Caries in Children Younger Than Age 5 Years?

### Summary

No study directly evaluated the effects of referral by a primary care clinician to a dentist on caries incidence. A fair-quality retrospective cohort study (n=14,389) found that having a first dental preventive visit after age 18 months in children with existing dental disease was associated with increased risk of subsequent dental procedures compared with having a first visit before age 18 months, but the study was not designed to determine referral source.46

### Evidence

The 2004 USPSTF report identified no studies on the effects of referral by a primary care clinician to a dentist on dental caries outcomes.3 We identified no study published since the 2004 USPSTF report that specifically evaluated effects of primary care referral on dental caries outcomes. However, one study may provide indirect evidence on the effects of earlier referral for untreated dental disease. It was a fair-quality retrospective cohort study that found that, among Medicaid children with existing dental disease (n=14,389), having a first dental visit after age 18 months was associated with increased risk of subsequent dental procedures between age 43 and 72 months compared with having an earlier first visit (before age 18 months) after adjusting for sex, race, number of well-child visits, and other factors (Appendixes B5 and B6); the incidence density ratio ranged from 1.1 to 1.4, depending on time of first dental visit.46 There was no difference in risk of subsequent dental procedures among children without existing dental disease at baseline. The study does not directly address the Key Question because it was not designed to determine whether a primary care referral was the source of the initial preventive visit.

## Key Question 6 How Effective Is Preventive Treatment (Dietary Fluoride Supplementation, Topical Fluoride Application, or Xylitol) in Preventing Dental Caries in Children Younger Than Age 5 Years?

### Summary

We identified no trials published since the 2004 USPSTF review on effects of dietary fluoride supplementation on dental caries incidence in children younger than age 5 years. One randomized trial and four other trials included in the 2004 USPSTF review found dietary fluoride supplementation in settings with water fluoridation levels below 0.6 ppm F associated with decreased caries incidence versus no fluoridation: percent reduction in caries increment ranged from 48 to 72 percent for primary teeth and from 51 to 81 percent for tooth surfaces.3

We identified three randomized trials published since the 2004 USPSTF review that found fluoride varnish more effective than no fluoride varnish in reducing caries incidence: percent reduction in caries increment, 18 to 59 percent.47-49 Results were consistent with those of three randomized trials included in the prior USPSTF review: percent reduction in caries increment, 37 to 63 percent.3 Most trials were conducted in low socioeconomic status settings with low community water fluoridation levels, but benefits were also observed in studies conducted in adequately fluoridated settings.

Three trials reported no clear effects of xylitol versus no xylitol on caries outcomes in children younger than age 5 years, and one trial found no difference between xylitol and tooth brushing, but the trials varied with respect to dosing and formulation of xylitol.50-53 The most promising results were from a single small trial of xylitol wipes.50 Evidence from single trials of chlorhexidine varnish or povidone-iodine solution in children younger than age 5 years was too limited to determine effectiveness.54,55

### Evidence

#### Dietary Fluoride Supplementation

We identified no trials published since the 2004 USPSTF review on effects of dietary fluoride supplementation on dental caries outcomes in children younger than age 5 years. The 2004 USPSTF review3 included six trials56-61 of dietary fluoride supplements. Sample sizes ranged from 140 to 815 children. Only one of the trials was clearly randomized.60 None of the nonrandomized trials adjusted for potential confounders. Other methodological limitations were inadequate blinding and high or unreported attrition. The trials were also clinically heterogeneous and varied with respect to age at enrollment (ranging from 2–3 weeks to 18–39 months), duration of followup (range, 2 to 6 years), dose of fluoride (range, 0.25 to 1.0 mg, varying in part based on child's age), and setting, including one Chinese trial that recruited 2-year-old children from kindergarten.59

The single randomized trial (n=140; fluoridation <0.1 ppm F) found use of 0.25 mg fluoride drops or chews associated with decreased incidence of caries versus no fluoride supplementation in Taiwanese children 2 years of age at enrollment.60 Percentage reduction in incidence ranged from 52 to 72 percent for dmft and from 51 to 81 percent for dmfs, depending on whether fluoride was given as tablets or drops. Across all six trials, percentage reductions in incidence with fluoride supplementation ranged from 32 to 72 percent for dmft and 38 to 81 percent for dmfs versus placebo (vitamin drops) or no supplementation. Five trials were conducted in settings with water fluoridation levels below current thresholds for supplementation (<0.6 ppm F).32,56,58-61 Excluding the trial conducted in a setting above this fluoridation threshold, incidence reductions were from 48 to 72 percent for dmft and 51 to 81 percent for dmfs.57 Two trials with extended followup also found dietary fluoride supplementation in early childhood associated with decreased incidence of caries at 7 to 10 years of age: reductions ranged from 33 to 80 percent.56,62

#### Topical Fluoride

The 2004 USPSTF review included six trials63-68 on the effectiveness of professionally applied fluoride varnish in preventing dental caries in primary teeth. Two trials63,64 were randomized and one66 used alternate allocation. The other three were not randomized, with sample sizes ranging from 142 to 225. All of the trials enrolled children between age 3 and 5 years and followed patients for 2 years64,66 or 9 months.63 Community water fluoridation status met recommended thresholds in one trial63 and was not reported in the other two. Fluoride varnish was applied as 2.26 percent fluoride (Duraphat^®^) for two applications separated by 4^63^ or 6 months,66 or as four applications over 2 years.64 No trial used a placebo or control treatment, and only one63 clearly reported blinded outcomes assessment. The percent reduction in incident caries lesions ranged from 37 to 63 percent (p<0.01 in all trials), with an absolute reduction in the mean number of cavities per child of 0.67 to 1.24 per year.

We identified seven trials published since the 2004 USPSTF review on professionally applied topical fluoride in children younger than age 5 years (Table 1 and Appendix B7).47-49,69-72 We rated three trials good quality,47,48,70 three fair quality,49,71,72 and one poor quality69 (Appendix B4). Six trials were randomized; the poor-quality trial used alternate allocation. Shortcomings in the fair-quality trials included high loss to followup, failure to describe adequate blinding, and failure to describe adequate allocation concealment.

Table 1 Summary of Topical Fluoride Preventive Treatments

Author, Year, Quality | Study Design | Interventions | Country; Setting; Fluoridation Status | Age at Enrollment | Sample Size | Followup (Years ) | Mean Caries Increment | Absolute Reduction in Caries Increment | Reduction in Caries Increment | Other Dental Caries Outcomes
Chu et al., 2002^69^ Poor | Controlled clinical trial | A: Removal of carious tissue plus 38% silver diamine fluoride solution every 12 months B: 38% silver diamine fluoride solution every 12 months C: Removal of carious tissue plus 5% sodium fluoride varnish every 3 months D: 5% sodium fluoride varnish every 3 months E: Placebo (water) | China; Kindergarten; Water fluoridation status: <0.2 ppm | 4 years | 308 | 2.5 | New caries surfaces: A: 0.26 B: 0.47 C: 0.89 D: 0.70 E: 1.58 p for ANOVA <0.001, E vs. others | A: 1.32 B: 1.11 C: 0.69 D: 0.88 E vs. others | A: 84% B: 70% C: 44% D: 56% E vs. others | Arrested caries surfaces: A: 2.49 B: 2.82 C: 1.45 D: 1.54 E: 1.27 p for ANOVA <0.001, E vs. others
Jiang et al., 2005^70^ Good | Cluster RCT (15 clusters) | A: 0.6-0.8 g of 1.23% acidulated phosphate fluoride foam applied every 6 months, max 4 applications B: Placebo foam | China; Kindergarten; Water fluoridation status: 0.1-0.3 ppm | 3.5-3.6 years | 318 | 2 | dmfs A: 3.8 B: 5.0 p=0.03 | 1.2 | 24% | A vs. B No increase in dmfs: 38% (64/167) vs. 26% (40/151) dmfs Increase of 1 to 5: 34% (56/167) vs. 38% (58/151) dmfs Increase of 6 to 10: 17% (28/167) vs. 18% (27/151) dmfs Increase of >10: 11% (19/167) vs. 17% (26/151)
Lawrence et al., 2008^47^ Good | Cluster RCT (20 clusters) | A: 0.3-0.5 ml 5% sodium fluoride varnish applied to full primary dentition every 6 months B: No fluoride varnish | Canada; Rural Aboriginal communities; Water fluoridation status: No fluoridation | 2.5 years | 1146 | 2 | dmfs A: 11.0 (4.3)^*^ B: 13.4 (6.1)^*^ p=0.24 (p=0.18)^*^ | 2.4 (1.8)^*^ | 18% (29%)^*^ | A vs. B Dental caries in aboriginal cohort: 72% (595/832) vs. 75% (247/328), adjusted OR 0.72 (95% CI 0.42 to 1.25); NNT 26 Dental caries in those caries free at baseline: 44% (157/354) vs. 58% (73/126); adjusted OR 0.63 (95% CI 0.33 to 1.1); NNT 7.4
Slade et al., 2011^48^ Good | Cluster RCT (30 clusters) | A: 0.25 ml of 5% sodium fluoride varnish to maxillary anterior teeth/molars, mandibular molars/incisors every 6 months, education/advice to caregiver with toothbrush/paste provided, community oral health promotion program B: No interventions | Australia; Rural Aboriginal communities; Water fluoridation status: 81-92% had <0.6 ppm F | 2.8 years | 666 | 2 | dmfs A: 7.3 B: 9.6^†^ p<0.05 | 2.3 | 24%
Weinstein et al., 2001^71^ Fair | RCT with 3 treatment groups | A: One application of 5% fluoride varnish at baseline and 6 months B: Three applications of 5% fluoride varnish within 2 weeks of baseline C: Three applications of 5% fluoride varnish within 2 weeks of baseline and 6 months | United States; Head Start programs; Water fluoridation status: NR | 3-5 years | 111 | 1 | Clinical dmfs: A: 4.6 B: 3.2 C: 4.7 p=0.65 Radiographic mean dmfs: A: 0.9 B: 0.5 C: 0.1 p=0.28 | Not calculated | Not calculated
Weinstein et al., 2009^72^ Fair | RCT with 2 treatment groups | A: One 5% fluoride varnish treatment and 2 placebo treatments every 6 months B: One set of three 5% fluoride varnish treatments over 2 weeks once per year and 3 placebo treatments over 2 weeks 6 months later | United States Recruitment setting: Head Start programs Water fluoridation status: NR (Yakima voters approved fluoridation in 1999) | 55-56 months | 515 | 3 | dmfs A: 7.4 B: 9.8 p=0.001 | 2.4 | 24% | Adjusted rate ratio of new tooth decay in primary surfaces 1.13 (95% CI 0.94 to 1.37)
Weintraub et al., 2006^49, ‡^ Fair | RCT | A: 0.1 mL of 5% sodium fluoride varnish per arch applied twice per year with 4 intended applications B: 0.1 mL of 5% sodium fluoride varnish per arch applied once per year with 2 intended applications C: No fluoride varnish | United States; Family dental center and public health center serving primarily low-income, underserved Hispanic and Chinese populations; Water fluoridation status: ∼1 ppm | 1.8 years | 280 | 2 | d_2+_fs^§^ A: 0.7 B: 0.7 C: 1.7 p<0.01 for A or B vs. C | 1.0 | 59% (A + B vs. C) | A vs. B vs. C Caries lesions at 12 months: 13% (11/83) vs. 15% (13/86) vs. 29% (27/92); RR 0.45 (95% CI 0.24 to 0.85); NNT 7 for A vs. C and 0.52 (95% CI 0.28 to 0.93); NNT 8 for B vs. C Caries lesions at 24 months: 4.3% (3/70) vs. 14% (10/69) vs. 24% (15/63); RR 0.18 (95% CI 0.06 to 0.59); NNT 6 for A vs. C and 0.61 (95% CI 0.30 to 1.26); NNT 11 for B vs. C

* Children caries free at baseline.

† Adjusted.

‡ In the fluoride varnish treatment group some children received a placebo varnish instead of fluoride varnish due to protocol errors.

§ Participants caries free at baseline.

Abbreviations: ANOVA = Analysis of Variance; CI = confidence interval; d_2+_fs = number of decayed or filled surfaces; dmfs = number of decayed, missing and filled surfaces; F = fluoride; g = gram; mL = milliliter; NNT = number needed to treat; NR = not reported; OR = odds ratio; ppm = parts per million; RCT = randomized controlled trial; RR = relative risk.

Three trials (two good quality and one fair quality) evaluated fluoride varnish (2.26% fluoride) applied every 6 months versus no fluoride varnish.47-49 Sample sizes ranged from 280 to 1,146 children. Two trials conducted in rural aboriginal populations in Canada (no fluoridation)47 and Australia (<0.6 ppm F for >90% of children) had baseline dmfs scores of 3.8 and 11^48^ and used a cluster design. The third trial enrolled underserved, primarily Hispanic and Chinese, children in an urban U.S. setting with adequate fluoridation (1 ppm F) who were caries free at baseline.49 As in the trials included in the 2004 USPSTF review, fluoride varnish was applied by dental personnel in all studies.

All three trials found use of fluoride varnish associated with decreased incidence of caries after 2 years, although the difference was not statistically significant in the Canadian study.47 Percent reductions in dmfs increment were 18 and 24 percent in the studies of rural aboriginal populations47,48 and 59 percent in the U.S. trial.49 Absolute mean reductions in the number of affected surfaces ranged from 1.0 to 2.4. Fluoride varnish was also associated with decreased risk of having any cavity. The poor-quality trial, which evaluated 2.26 percent fluoride varnish applied every 3 months in Chinese children (with or without removal of carious tissue), reported findings consistent with those of the fair-quality trials.69

Two trials evaluated effectiveness of other methods for administering topical fluoride.69,70 Both were conducted in China. One good-quality trial found 1.23-percent acidulated phosphate fluoride foam applied every 6 months more effective (p=0.03) than placebo (mean percent reduction in dmfs increment, 24%; absolute mean reduction in affected surfaces, 1.2).70 A poor-quality trial found 38-percent silver diamine fluoride solution every 12 months somewhat more effective than 2.26-percent fluoride varnish every 3 months.69

Two trials found multiple fluoride varnish applications within a 2-week period associated with no clear differences versus a standard application schedule of every 6 months,71,72 and one trial found no clear difference between a once versus twice yearly schedule.49

#### Xylitol

Xylitol was not an included intervention in the 2004 USPSTF review. We identified four fair-quality50-52,73 and two poor-quality trials53,74 of xylitol in children age 6 months to 5 years (Table 2 and Appendixes B4 and B7). Two trials enrolled children from settings in which water was not fluoridated73 or inadequately fluoridated,53 and the other four did not report water fluoridation status. Five trials were randomized50-52,73,74 and one used a nonrandomized design.53

Table 2 Summary of Xylitol Preventive Treatments

Author, Year, Quality | Study Design | Interventions | Country; Setting; Fluoridation Status | Age at Enrollment | Sample Size | Followup (Years ) | Mean Caries Increment | Absolute Reduction in Caries Increment | Reduction in Caries Increment | Other Dental Caries Outcomes
Alamoudi et al., 2012^74^ Poor | RCT | A: Xylitol chewable tablets (1.2 g, 84% xylitol) chewed for 5 minutes 3 times daily B: Fluoride varnish every 6 months throughout study | Saudi Arabia Recruitment setting: Well baby clinics and dental clinics Water fluoridation status: NR | 2 to 5 years | 34 | 1.5 | dmft A: 0.8 B: 4.4 p=not reported | 3.6 | 82% | A vs. B dmft at baseline: 8.4 vs. 10.3 (p=0.19) dmft at 18 months: 9.2 vs. 14.7 (p=0.001)
Kovari et al., 2003^51, *^ Fair | Cluster RCT (11 clusters) | A: 65% Xylitol gum 3 times per day, chewed for 3-5 minutes, for total of 2.5 g/day B: Tooth brushing with 0.05% NaF toothpaste after lunch | Finland Recruitment setting: Daycare centers Water fluoridation status: NR | 3 to 6 years | 786 | 3-6 | NR | NR | NR | A vs. B Caries at 7 years old: 31% (98/316) vs. 35% (149/427), RR 0.88 (95% CI 0.72 to 1.10) Caries at 9 years old: 43% (133/310) vs. 51% (221/434), RR 0.84 (95% CI 0.72 to 0.99) dmft: 1.1 vs. 1.0 at 7 years, 1.2 vs. 1.6 at 9 years
Milgrom et al., 2009^73, *^ Fair | RCT | A: Xylitol 8 g per day syrup, divided into 2 doses (4 g per dose) B: Xylitol 8 g per day syrup, divided into 3 doses (2.67 g per dose) C: Xylitol 2.67 g dose syrup, 1 dose per day | Marshall Islands Recruitment setting: Community based Water fluoridation status: Drinking water not fluoridated (supplemental and topical fluoride not available) | 14 to 16 months | 94 | 1 | Number of decayed teeth A: 0.6 B: 1.0 C: 1.9 p<0.05 for A or B vs. C | A: 1.3 B: 0.9 vs. C | A: 68% B: 47% vs. C | A vs. B vs. C Tooth decay: 24.2% (8/33) vs. 40.6% (13/32) vs. 51.7% (15/29), RR 0.47 (95% CI 0.23 to 0.94) for A vs. C and 0.79 (95% CI 0.45 to 0.1.4) for B vs. C Incidence rates for decayed primary teeth per year: 0.66 vs. 1.10 vs. 2.20
Oscarson et al., 2006^52^ Fair | RCT | A: One 0.48 g xylitol tablet at bedtime after brushing for 6 months; then 1 tablet twice daily to age 3 years and 6 months B: No tablets | Sweden Recruitment setting: Public dental clinic;] Water fluoridation status: Not reported | 25 months | 115 | 2 | dmfs A: 0.38 B: 0.80 p>0.05 | 0.42 | 52% | A vs. B Dental caries: 18% (10/55) vs. 25% (16/63), OR 0.65 (95% CI 0.27 to 1.59)
Seki et al., 2011^53^ Poor | Cluster, nonrandomized controlled clinical trial (3 clusters) | A: Xylitol chewing gum (100% xylitol, 1.33 g); 1 pellet chewed 5 minutes 4 times daily B: No intervention | Japan Recruitment setting: Preschool Water fluoridation status: NR (states fluoridation “limited” in Japan) | 66-72% 4 years old | 161 | 1 | dfs A: 3.3 B: 3.4 p>0.05 | 0.1 | 3% | A vs. B Development of caries from baseline to 6 months: 1.7 vs. 1.6 (p>0.05) Development of caries from 6 months to 1 year: 1.6 vs. 1.8 (p>0.05)
Zhan et al., 2012^50^ Fair | RCT | A: Xylitol wipes, 2 at a time, 3 times per day (estimated daily dosage 4.2 g) every 3 months B: Placebo wipes | United States. Recruitment setting: University pediatric clinic Water fluoridation status: Not reported | 6-35 months | 37 | 1 | dmfs^†^ A: 0.05 B: 0.53 p=0.01 | 0.48 | 91% | A vs. B New caries lesions at 1 year:^†^ 5% vs. 40% (p=0.03); NNT 3 ITT analysis of new caries lesions at 1 year: 5% vs. 32%; RR 0.14 (95% CI 0.02 to 1.07); NNT 4

* Baseline caries status not defined.

† Numbers based on per protocol analysis.

Abbreviations: CI = confidence interval; dfs = decayed and filled surfaces; dmfs = decayed, missing, and filled surfaces; dmft = decayed, missing, and filled teeth; g = grams; ITT = intention-to-treat; NaF = sodium fluoride; NNT = number needed to treat; NR = not reported; OR = odds ratio; RCT = randomized, controlled trial; RR = relative risk.

Three trials compared xylitol with no xylitol.50,52,53 They varied with respect to dosing and formulation of xylitol. A fair-quality randomized trial (n=115) found xylitol tablets (0.48 g) associated with reduced dmfs increment after 2 years, but the difference was not statistically significant (mean percent reduction, 52%; absolute mean reduction in affected surfaces, 0.42).52 The trial enrolled 2-year-old Swedish children, with the intervention consisting of a xylitol tablet at bedtime for 6 months, followed by two tablets daily. One small (n=37) fair-quality randomized trial found xylitol wipes used three times per day for 1 year markedly more effective than placebo wipes in reducing caries among children age 6 months to 35 months (reduction in dmfs increment, 91%; p<0.05).50 A poor-quality nonrandomized trial found no effect of xylitol chewing gum (1.33 g) four times daily on incidence of caries in 4-year-old children in Japan.53

Two studies compared xylitol with topical fluoride.51,74 A cluster randomized trial found no difference between 65-percent xylitol gum three times per day versus tooth brushing with fluoride, but it was conducted in a supervised daycare setting and enrolled children up to age 6 years, potentially limiting its applicability to younger children.51 A poor-quality trial found xylitol chewable tablets (1.2 g three times daily) more effective than fluoride varnish once every 6 months.74

One fair-quality randomized trial found xylitol syrup 8 g per day in two or three divided doses more effective than one 2.67 g dose daily in reducing incidence of caries outcomes.73

#### Other Interventions

One fair-quality cluster randomized trial (n=290) of children age 4 to 5 years in rural China found 40-percent chlorhexidine acetate varnish associated with decreased caries outcomes versus placebo varnish, with a 37-percent reduction in dmfs incidence in the molar teeth and mean absolute dmfs-molar reduction of 0.6 (Table 3 and Appendixes B4 and B7).54

Table 3 Summary of Other Preventive Treatments

Author, Year, Quality | Study Design | Interventions | Country; Setting; Fluoridation Status | Age at Enrollment | Sample Size | Followup (Years ) | Mean Caries Increment | Absolute Reduction in Caries Increment | Reduction in Caries Increment | Other Dental Caries Outcomes
Du et al., 2006^54^ Fair | Cluster RCT (14 clusters) | A: 40% w/w chlorhexidine acetate varnish every 6 months B: Placebo varnish | China Kindergartens in rural communities; Water fluoridation status: 0.1-0.3 ppm | 4-5 years | 290 | 2 | dmfs-molar: A: 1.0 B: 1.6 p=0.036 | 0.6 | 37%
Lopez et al., 2002^55^ Fair | RCT | A: 0.2 ml of 10% povidone-iodine solution every 2 months B: Placebo solution | United States Women, infants, and children clinic in Puerto Rico; Water fluoridation status: NR | 16 months | 83 | 1 | NR | NR | NR | A vs. B^*^ White spot lesions -maxillary primary incisors: 8% (3/39) vs. 32% (14/44); RR 0.24 (95% CI 0.1 to 0.8)

* Participants were caries free at baseline.

Abbreviations: CI = confidence interval; dmfs = decayed, missing, filled surfaces; mL = milliliter; NR = not reported; ppm = parts per million; RCT = randomized, controlled trial; RR = relative risk; w/w = weight/weight.

A fair-quality randomized trial (n=83) of high-risk children age 16 months in Puerto Rico found 0.2 ml of 10-percent povidone-iodine solution applied every 2 months associated with decreased incidence of white spot lesions on maxillary teeth after 1 year (8 vs. 32%; relative risk [RR], 0.24; 95% CI, 0.1 to 0.8).55

## Key Question 7 What Are the Harms of Specific Oral Health Interventions for Prevention of Dental Caries in Children Younger Than Age 5 Years (Parental or Caregiver Oral Health Education, Referral to a Dentist, and Preventive Treatments)?

### Summary

Five new studies in an updated systematic review were consistent with previous studies in finding an association between early childhood ingestion of systemic fluoride and enamel fluorosis of the permanent dentition.38 Studies were observational and had methodological shortcomings, including use of retrospective recall to determine exposures. Other than diarrhea, reported in two trials of xylitol,53,73 harms were poorly reported in trials of caries prevention interventions, and no trials reported incidence or prevalence of fluorosis with fluoride varnish.

### Evidence

No trial reported risk of dental fluorosis associated with early childhood ingestion of dietary fluoride supplements. The 2004 USPSTF review included a systematic review of 14 observational studies on risk of fluorosis, based on literature searches conducted through September 1997.^37^ Ten of the studies relied on retrospective parental recall of early childhood fluoride ingestion to determine subsequent risk of fluorosis in the permanent dentition. In the other four, early childhood supplemental fluoride use had been recorded at the time of exposure. The dosages of fluoride supplementation in the studies generally exceeded current recommendations. Prevalence of fluorosis ranged from 10 to 49 percent in the studies that relied on retrospective parental recall, and from 15 (on central incisors only) to 67 percent in the studies that recorded supplement use during early childhood. The odds ratios (ORs) for dental fluorosis associated with regular early childhood use ranged from 1.3 to 10.7 in the studies that relied on retrospective recall, and RRs ranged from 4.2 to 15.6 in the studies that recorded supplement use at the time of exposure.

The systematic review included in the 2004 USPSTF review has subsequently been updated with searches conducted through June 2006 (Appendixes B8 and B9).38 The update included five additional observational studies on the association between early childhood intake of fluoride supplements and risk of fluorosis.75-79 Determinations of early childhood exposures were all based on retrospective parental recall, with fluorosis assessed at age 8 to 14 years. Results of the new studies were consistent with those from the original systematic review, with intake of fluoride supplements prior to 7 years of age (primarily before 3 years of age) associated with increased risk of fluorosis. Risk estimates ranged from an OR of 10.8 (95% CI, 1.9 to 62) with intake during the first 2 years of life78 to a slight increase in risk (OR, 1.1 to 1.7, depending on comparison).75 One study reported a dose-dependent association, with an OR of 1.8 (95% CI, 1.4 to 2.4) for each year of supplementation.79 We identified no studies published since the updated systematic review on the association between early childhood intake of dietary fluoride supplements and risk of enamel fluorosis.

No study reported the risk of fluorosis associated with use of fluoride varnish. However, the degree of systemic exposure following application of fluoride varnish is believed to be low.

Two trials reported diarrhea in 11 percent of children allocated to xylitol chewing gum53 or syrup.73 Other trials of xylitol50-52,74 did not report rates of diarrhea.

## Contextual Question. What Percentage of Children Younger Than Age 5 Years in the United States Have Access to Dental Care, and What Factors Are Associated With Access to Dental Care in This Population?

Based on a national telephone survey (n=89,071) of parents performed in 2003 to 2004, 23 percent of children age 1 to 5 years lacked dental insurance coverage in the previous year, 51 percent did not receive dental care, and 3.5 percent had a perceived unmet dental need.80 Children who lacked dental insurance were also less likely to receive preventive care and more likely to have a perceived unmet need for care. In multivariate analyses, factors associated with lack of dental insurance coverage among all children age 1 to 17 years were being a foreign-born Hispanic, having a non-English primary language spoken at home, having three or more children in the family, lower socioeconomic status, rural residence, living in the South, and lower household education level. An analysis based on 2004 Medical Expenditure Panel Survey (MEPS) data also found that a primary care provider's recommendation for dental care was associated with a threefold increased likelihood (OR, 2.9; 95% CI, 2.2 to 3.9) of having a subsequent dental visit.81 In 2009, based on MEPS data, the proportion of children age 1 to 5 years with a dental visit in the prior year was 31 percent (95% CI, 28 to 34%).82

Several studies have shown that expanding access to dental coverage for low-income families through the State Children's Health Insurance Program (SCHIP) and Medicaid programs was associated with an increase in preventive dental visits in eligible children.83-85 Higher Medicaid payment levels were associated with higher rates of receipt of care.86