# Methods

## Key Questions and Analytic Framework

Using methods developed by the USPSTF,34,35 representatives from the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and Key Questions for this review. Investigators created an analytic framework with the Key Questions and the patient population, interventions, and outcomes reviewed (Figure 1). The target population was asymptomatic children younger than age 5 years, including children with existing dental caries who need additional preventive or restorative interventions for untreated disease. Community interventions for prevention of dental caries and school-based interventions for older children are addressed elsewhere by the U.S. Community Services Task Force.36

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts the events that children ages 0 to 5 years may experience during a clinician visit. The figure shows that children may undergo an oral screening and risk factor assessment. This could cause them to have adverse effects. This will lead to them being placed into one of two categories: either average risk for dental caries, or at increased risk for dental caries. Children at average risk for dental caries may experience one of two intervetnions. The interventions are parental or caregiver/guardian oral health education; or referral to a dentist. These interventions may cause adverse effects. Children at increased risk for dental caries may experience one of three interventions. The interventions are parental or caregiver/guardian oral health education; referral to a dentist; or preventive treatments. These interventions may cause adverse effects. The outcomes of interest for both children at average and increased risk of dental caries are decreased dental caries and associated complications.

We also addressed a “contextual question” requested by the USPSTF to help inform the report. Contextual questions address background areas deemed important by the USPSTF for informing its recommendations. Contextual questions are not reviewed using systematic review methodology, but rather summarize the evidence from key informative studies.

### Key Questions

1. How effective is oral screening (including risk assessment) by the primary care clinician in preventing dental caries in children younger than 5 years of age?
2. How accurate is screening by the primary care clinician in identifying children younger than 5 years of age who:
  a. Have cavitated or noncavitated caries lesions?
  b. Are at increased risk for future dental caries?
3. What are the harms of oral health screening by the primary care clinician?
4. How effective is parental or caregiver oral health education by the primary care clinician in preventing dental caries in children younger than 5 years of age?
5. How effective is referral by a primary care clinician to a dentist in preventing dental caries in children younger than 5 years of age?
6. How effective is preventive treatment (dietary fluoride supplementation, topical fluoride application, or xylitol) in preventing dental caries in children younger than 5 years of age?
7. What are the harms of specific oral health interventions for prevention of dental caries in children younger than 5 years of age (parental or caregiver oral health education, referral to a dentist, and preventive treatments)?

### Contextual Question

What percentage of children younger than 5 years of age in the United States have access to dental care, and what factors are associated with access to dental care in this population? (Access to dental care is defined as the ability of a child to receive dental care services, based on availability of dental care providers and/or ability to pay for those services.)

Key Question 1 focuses on direct evidence on the effectiveness of oral screening (defined to include oral examination as well as risk assessment for future caries) by medical primary care clinicians in preventing future dental caries and associated complications compared with not screening. Such direct evidence on the effectiveness of screening interventions may be limited. Therefore, the remainder of the analytic framework (Key Questions 2 through 7) evaluates the chain of indirect evidence needed to link screening with improvement in important health outcomes. Links in the chain of indirect evidence include the accuracy of screening by primary care clinicians in identifying children with dental caries or at increased risk of developing caries, the effectiveness of primary care interventions for reducing the incidence of dental caries and associated complications, and harms (including dental fluorosis) associated with screening and preventive treatments. It is implicit in the indirect chain of evidence that, to understand benefits and harms of screening, it is necessary but not sufficient to show that children at risk for dental caries can be identified; it is also necessary to show that there are effective treatments for those identified.

## Search Strategies

We searched Ovid MEDLINE^®^ (January 1999 to March 8, 2013) and the Cochrane Library Database (through the first quarter of 2013) for relevant articles. Search strategies are shown in Appendix A1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2). Articles were selected for full review if they were about dental caries in preschool children, were relevant to a Key Question, and met the predefined inclusion criteria. We restricted inclusion to English-language articles and excluded studies published only as abstracts. Studies of nonhuman subjects were also excluded, and studies had to report original data.

For all Key Questions, we included studies of children younger than age 5 years, including those with dental caries at baseline. We focused on studies of screening or diagnostic accuracy performed in primary care settings. For preventive treatments (Key Question 6), we also included studies of treatments feasible in primary care (treatments not requiring extensive dental-specific training) that were performed in non–primary care settings, but noted whether the treatment was administered by people with dental training. Interventions were parental or caregiver education, referral to a dentist by a primary care clinician, and preventive treatments, including dietary fluoride supplementation, topical fluoride application, xylitol, and antimicrobial rinses and varnishes. Outcomes were decreased incidence of dental caries and associated complications, and harms, including dental fluorosis. We included randomized, controlled trials, nonrandomized, controlled clinical trials, and cohort studies for all Key Questions. We also included an updated systematic review of observational studies on risk of enamel fluorosis that was originally included in the 2004 USPSTF review.37,38 Appendix A3 shows the results of our literature search and selection process, and Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about each article's study design, patient population, setting, screening method, treatment regimen, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Two investigators independently applied criteria developed by the USPSTF34,35 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, poor) using methods developed by the USPSTF based on the number, quality, and size of studies; consistency of results among studies; and directness of evidence.34,35 Meta-analysis was not attempted due to methodological shortcomings in the studies and differences across studies in design, interventions, populations, and other factors.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners, and revised prior to finalization (Appendix A6).

## Response to Comments Received During the Public Comment Period

This evidence report was posted for public comment from May 21 to June 20, 2013. The systematic review team reviewed and considered comments relevant to the report and referred comments relevant to the recommendation statement to the USPSTF. No comments pointed out missing studies that met inclusion criteria or errors in the evidence reviewed. Therefore, the public comment process resulted in no changes to the findings or the conclusion of the evidence report.