# Evidence Tables and Quality Tables

Appendix B1 Diagnostic Accuracy Studies for the Prevention of Dental Caries

Appendix B2 Quality Ratings for Diagnostic Accuracy Studies

Appendix B3 Trials of Educational Interventions for the Prevention of Dental Caries

Appendix B4 Quality Ratings of Randomized, Controlled Trials

Appendix B5 Cohort Study of Dental Referral From a Primary Care Clinician for the Prevention of Dental Caries

Appendix B6 Quality Rating of Included Cohort Study

Appendix B7 Trials of Treatments for the Prevention of Dental Caries

Appendix B8 Systematic Review of Fluorosis Due to Fluoride Supplements

Appendix B9 Quality Rating of Systematic Review