# Detailed Methods

## Appendix A1 Search Strategies

Database: Ovid MEDLINE^®^ without Revisions <1999 to March 8, 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. exp physicians/
2. exp pediatrics/ or pediatrician$.mp.
3. exp nurse practitioners/
4. exp nurse's aides/
5. exp physician assistants/
6. exp nurse clinicians/
7. nurses/
8. Primary care physician$.mp.
9. General practitioner$.mp.
10. Primary care clinician$.mp.
11. exp ambulatory care facilities/
12. exp primary health care/
13. exp physician's role/
14. exp physician's practice patterns/
15. exp mass screening/
16. exp health behavior/
17. exp health promotion/
18. exp infant welfare/
19. exp health services accessibility/
20. exp child health services/
21. exp “referral and consultation”/
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. limit 22 to (english language and humans)
24. limit 23 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies)
25. exp epidemiologic study characteristics/
26. exp epidemiologic research design/
27. exp questionnaires/
28. (25 or 26 or 27) and 23
29. 24 or 28
30. exp dental caries/
31. Dental screening.mp. or exp dental care for children/
32. dental care/ or dental examination.mp. or exp diagnosis, oral/
33. 30 or 31 or 32
34. 29 and 33
35. limit 34 to (infant <1 to 23 months> or preschool child <2 to 5 years>)

Database: Ovid MEDLINE^®^ without Revisions <1999 to March 8, 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. exp physicians/
2. exp pediatrics/ or pediatrician$.mp.
3. exp nurse practitioners/
4. exp nurse's aides/
5. exp physician assistants/
6. exp nurse clinicians/
7. nurses/
8. Primary care physician$.mp.
9. General practitioner$.mp.
10. Primary care clinician$.mp.
11. exp ambulatory care facilities/
12. exp primary health care/
13. exp physician's role/
14. exp physician's practice patterns/
15. exp mass screening/
16. exp health behavior/
17. exp health promotion/
18. exp infant welfare/
19. exp health services accessibility/
20. exp child health services/
21. exp “referral and consultation”/
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. limit 22 to (english language and humans)
24. limit 23 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies)
25. exp epidemiologic study characteristics/
26. exp epidemiologic research design/
27. exp questionnaires/
28. (25 or 26 or 27) and 23
29. 24 or 28
30. exp MOTHERS/
31. exp PARENTS/
32. 30 or 31
33. exp dental health services/ or dental utilization.mp. or exp dental care/
34. 29 and 33
35. limit 34 to (infant <1 to 23 months> or preschool child <2 to 5 years>)

Database: Ovid MEDLINE^®^ without Revisions <1999 to March 8, 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. exp physicians/
2. exp pediatrics/ or pediatrician$.mp.
3. exp nurse practitioners/
4. exp nurse's aides/
5. exp physician assistants/
6. exp nurse clinicians/
7. nurses/
8. Primary care physician$.mp.
9. General practitioner$.mp.
10. Primary care clinician$.mp.
11. exp ambulatory care facilities/
12. exp primary health care/
13. exp physician's role/
14. exp physician's practice patterns/
15. exp mass screening/
16. exp health behavior/
17. exp health promotion/
18. exp infant welfare/
19. exp health services accessibility/
20. exp child health services/
21. exp “referral and consultation”/
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. limit 22 to (english language and humans)
24. limit 23 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies)
25. exp epidemiologic study characteristics/
26. exp epidemiologic research design/
27. exp questionnaires/
28. (25 or 26 or 27) and 23
29. 24 or 28
30. exp mothers/
31. exp parents/
32. 30 or 31
33. exp fluorides, topical/
34. exp fluorides/
35. exp cariostatic agents/
36. Supplemental fluoride$.mp.
37. Fluoride tab$.mp.
38. Fluoride drop$.mp.
39. Fluoride varnish$.mp.
40. 33 or 34 or 35 or 36 or 37 or 38 or 39
41. 29 and 40
42. limit 41 to (newborn infant <birth to 1 month> or infant <1 to 23 months> or preschool child <2 to 5 years>)

Database: Ovid MEDLINE^®^ without Revisions <1999 to March 8, 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. exp physicians/
2. exp pediatrics/ or pediatrician$.mp.
3. exp nurse practitioners/
4. exp nurse's aides/
5. exp physician assistants/
6. exp nurse clinicians/
7. nurses/
8. Primary care physician$.mp.
9. General practitioner$.mp.
10. Primary care clinician$.mp.
11. exp ambulatory care facilities/
12. exp primary health care/
13. exp physician's role/
14. exp physician's practice patterns/
15. exp mass screening/
16. exp health behavior/
17. exp health promotion/
18. exp infant welfare/
19. exp health services accessibility/
20. exp child health services/
21. exp “referral and consultation”/
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. limit 22 to (english language and humans)
24. limit 23 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or evaluation studies or meta analysis or multicenter study or randomized controlled trial or technical report or validation studies)
25. exp epidemiologic study characteristics/
26. exp epidemiologic research design/
27. exp questionnaires/
28. (25 or 26 or 27) and 23
29. 24 or 28
30. exp MOTHERS/
31. exp PARENTS/
32. 30 or 31
33. exp dental care for children/
34. exp dental caries/
35. exp oral hygiene/
36. exp oral health/
37. exp health education, dental/
38. exp diet, cariogenic/
39. exp dental care/
40. 33 or 34 or 35 or 36 or 37 or 38 or 39
41. 29 and 40
42. limit 41 to (infant <1 to 23 months> or preschool child <2 to 5 years>)

Database: Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^ <1946 to March 8, 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. exp “Pit and Fissure Sealants”/
2. exp Dental Caries/
3. exp fluorosis, dental/
4. 2 or 3
5. 1 and 2
6. limit 5 to “all child (0 to 18 years)”
7. ((tooth or teeth or pit or pits or fissur$) adj5 seal$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
8. 2 and 7
9. limit 8 to “all child (0 to 18 years)”
10. ((tooth or teeth or enamel$ or crown or root or dental$ or molar$ or incisor$ or bicuspid$ or canine$ or premolar$) adj5 (decay$ or carie$ or fluorosis)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
11. 1 and 10
12. limit 11 to “all child (0 to 18 years)”
13. 6 or 9 or 12
14. (201206$ or 201207$ or 201208$ or 201209$ or 20121$).ed.
15. 13 and 14
16. exp Tooth Demineralization/
17. ((tooth or teeth or root$ or crown$ or dental$ or dentist$) adj5 (caries or cario$ or decay$ or cavit$ or fluorosis)).mp.
18. 16 or 17
19. xylitol.mp.
20. 18 and 19
21. limit 20 to “all child (0 to 18 years)”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <February 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. (physician$ or pediatrician$ or general practi$ or primary care or primary health care or nurse or nurses or (nurs$ adj3 (care or caring or cared or cares)) or screen$ or (health$ adj3 (behav$ or promot$ or access$)) or referral$ or consult$ or counsel$ or parent$ or mother$ or father$ or guardian$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (62097)
2. ((dental$ or tooth or teeth$) adj7 (caries or decay$ or fluorid$ or xylitol or sealant$ or sealing or cariostat$ or fluorosis) adj10 (child$ or pediatric$ or infant$ or infancy or toddler$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (968)
3. ((dental or dentist$ or oral) adj7 (screen$ or fluorid$ or checkup$ or (check$ adj up) or exam or exams or examine$ or examination$) adj10 (child$ or pediatric$ or infant$ or infancy or toddler$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (343)
4. ((dental or dentist$ or oral) adj3 (hygien$ or health$ or prophyla$) adj10 (child$ or pediatric$ or infant$ or infancy or toddler$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (384)
5. 2 or 3 or 4 (1263)
6. 1 and 5 (239)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <1999 to February 2013>

Search Strategy:

------------------------------------------------------------------------------------

1. (physician$ or pediatrician$ or general practi$ or primary care or primary health care or nurse or nurses or (nurs$ adj3 (care or caring or cared or cares)) or screen$ or (health$ adj3 (behav$ or promot$ or access$)) or referral$ or consult$ or counsel$ or parent$ or mother$ or father$ or guardian$).mp. [mp=title, abstract, full text, keywords, caption text] (6578)
2. ((dental$ or tooth or teeth$) adj7 (caries or decay$ or fluorid$ or xylitol or sealant$ or sealing or cariostat$ or fluorosis) adj10 (child$ or pediatric$ or infant$ or infancy or toddler$)).mp. [mp=title, abstract, full text, keywords, caption text] (43)
3. ((dental or dentist$ or oral) adj7 (screen$ or fluorid$ or checkup$ or (check$ adj up) or exam or exams or examine$ or examination$) adj10 (child$ or pediatric$ or infant$ or infancy or toddler$)).mp. [mp=title, abstract, full text, keywords, caption text] (39)
4. ((dental or dentist$ or oral) adj3 (hygien$ or health$ or prophyla$) adj10 (child$ or pediatric$ or infant$ or infancy or toddler$)).mp. [mp=title, abstract, full text, keywords, caption text] (47)
5. 2 or 3 or 4 (78)
6. 1 and 5 (75)

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | [underlined: All key questions]: Asymptomatic children less than 5 years of age | [underlined: All key questions] Animal studies, adults, children older than preschool age (>5 years), symptomatic
Interventions | [underlined: Key questions 1-3:] Oral screening and risk factor assessment performed by primary care clinicians [underlined: Key questions 4 and 5]: Parent/caregiver oral health education and/or referral to dentist [underlined: Key questions 6 and 7:] Preventive treatments: including oral fluoride supplementation, topical fluoride application, or xylitol | [underlined: Key questions 1-3:] Community or school-based interventions [underlined: Key questions 4 and 5:] Interventions not performed in primary care settings [underlined: Key questions 6 and 7:] Treatments not available for preschool children or not available in the United States
Outcomes | [underlined: All key questions:] Reduced dental caries and associated outcomes [underlined: Key questions 2 and 3:] Diagnostic accuracy and measures of risk prediction [underlined: Key question 7:] Dental fluorosis, emotional stress, acute toxicity, and other associated complications | [underlined: All key questions] Cost-effectiveness
Study types and designs | [underlined: Key questions 1, 4, 5, and 6:] Randomized controlled trials, non-randomized controlled clinical trials, and cohort studies [underlined: Key question 2:] Studies of diagnostic accuracy or risk prediction [underlined: Key questions 3 and 7:] Randomized controlled trials, cohort studies, case-control studies, and systematic reviews | [underlined: Key questions 1, 2, 4, 5, and 6:] Case-control studies, uncontrolled intervention studies [underlined: All key questions:] Opinion, editorials, or case reports

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, hand searching, suggested by experts, etc.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

§ Studies may have provided data for more than one key question.

Appendix A3 is a flow chart that summarizes the search and selection of articles. There were 1215 citations identified by searching MEDLINE, Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and other sources including reference lists, hand searching, and suggestions by experts. Of these 676 were excluded at the abstract level because they did address a key question. The remaining 539 articles were pulled for review at the full-text level to further review for inclusion. There were 519 full-text articles excluded for the following reasons: did not address a key question or meet inclusion criteria, but pulled to provide background information only, wrong population, wrong intervention, wrong publication type, conducted prior to 2000 (except xylitol), foreign language, wrong outcome, wrong setting, not applicable to United States population, or in the prior report. Twenty studies were included in the final report and may have provided data for more than one key question. There were 0 for key question 1, 1 for key question 2, 0 for key question 3, 2 for key question 4, 1 for key question 5, 15 for key question 6, and 3 for key question 7.

## Appendix A4 Excluded Studies List

Key to exclusion codes

2 | Excluded because it doesn't address a key question or meet inclusion criteria, but pulled to provide background information
3 | Wrong population
4 | Wrong intervention
5 | Wrong publication type
6 | Conducted prior to 2000 (except xylitol)
7 | Foreign language, otherwise included
8 | Wrong outcome
9 | Wrong setting
10 | Not applicable to United States population
11 | In prior report

### List of excluded studies

Diet, nutrition, and oral health: a rational approach for the dental practice. J Am Dent Assoc. 1984;109(1):20-32. Exclusion code: 5. [pmid: 6589288].
NIH Consensus Development Conference on Diagnosis and Management of Dental Caries Throughout Life. Bethesda, MD. March 26-28, 2001. Conference Papers. J Dent Educ. 2001;65(10):935-1179. [pmid: 11706839]. Exclusion code: 11.
The endless learning curve: 2005 Table Clinic winners. Northwest Dent. 2005;84(3):23-27. Exclusion code: 2. [pmid: 16044850].
Xylitol-containing oral syrup may prevent caries in children. J Am Dent Assoc. 2009;140(8):972. Exclusion code: 5. [pmid: 19654247].
Aaltonen AS, Suhonen JT, Tenovuo J, Inkila-Saari I. Efficacy of a slow-release device containing fluoride, xylitol and sorbitol in preventing infant caries. Acta Odontol Scand. 2000;58(6):285-292. Exclusion code: 4. [pmid: 11196405].
Aasenden R, DePaola PF, Brudevold F. Effects of daily rinsing and ingestion of fluoride solutions upon dental caries and enamel fluoride. Archives of Oral Biology. 1972;17(12):1705-1714. Exclusion code: 3. [pmid: 4405216].
Ad Hoc Committee on Fluoride, Committee to Coordinate Environmental Health and Related Programs. Review of Fluoride: Benefits and Risks. Washington, DC. US Department of Health and Human Services. 1991. http://health.gov/environment/ReviewofFluoride/. Exclusion code: 11.
Adair PM, Pine CM, Burnside G, et al. Familial and cultural perceptions and beliefs of oral hygiene and dietary practices among ethnically and socio-economically diverse groups. Community Dent Health. 2004;21(1 Suppl):102-111. Exclusion code: 4. [pmid: 15072479].
Adams SH, Hyde S, Gansky SA. Caregiver acceptability and preferences for early childhood caries preventive treatments for Hispanic children. J Public Health Dent. 2009;69(4):217-224. Exclusion code: 8. [pmid: 19486461].
Agency for Healthcare Research and Quality. Medical Expenditure Panel Survey. 2011. http://meps.ahrq.gov/data_stats/download_data_files_detail.jsp?cboPufNumber=HC-126B. 27 March, 2013. Exclusion code: 2.
Akerblom HK, Koivukangas T, Puukka R, Mononen M. The tolerance of increasing amounts of dietary xylitol in children. International journal for vitamin and nutrition research. Supplement. 1982;22:53-66. Exclusion code: 3. [pmid: 6802776].
Al Ghanim NA, Adenubi JO, Wyne AA, Khan NB. Caries prediction model in pre-school children in Riyadh, Saudi Arabia. Int J Paediatr Dent. 1998;8(2):115-122. Exclusion code: 8. [pmid: 9728096].
Alaluusua S, Malmivirta R. Early plaque accumulation – a sign for caries risk in young children. Comm Dent Oral Epidemiol. 1994;22:273-276. Exclusion code: 8. [pmid: 7813174].
Alanen P, Holsti ML, Pienihakkinen K. Sealants and xylitol chewing gum are equal in caries prevention. Acta Odontol Scand. 2000;58(6):279-284. Exclusion code: 3. [pmid: 11196404].
Alanen P, Isokangas P, Gutmann K. Xylitol candies in caries prevention: results of a field study in Estonian children. Community Dent Oral Epidemiol. 2000;28(3):218-224. Exclusion code: 3. [pmid: 10830649].
Alonge OK, Williamson DD, Narendran S. Dental fluorosis among third graders in Harris County, Texas--1998 study findings. Texas dental journal. 2000;117(9):22-29. Exclusion code: 3. [pmid: 11857845].
American Academy of Family Physicians. Fluoridation of public water supplies. Policies. 2008. http://www.aafp.org/online/en/home/policy/policies/f/fluoridationofpublicwatersupplies.html. 12 January, 2013. Exclusion code: 2.
American Academy of Pediatric Dentistry. Caries risk assessment for infants, children, and adolescents. Pediatr Dent. 2011;33:110-117. Exclusion code: 2.
American Academy of Pediatric Dentistry. Guideline on Caries-risk Assessment and Management for Infants, Children, and Adolescents. American Academy of Pediatric Dentistry Reference Manual. 2011;32(6):101-108. Exclusion code: 2.
American Academy of Pediatric Dentistry. Guideline on fluoride therapy. AAPD 2012-2013 Clinical Guidelines. 2012;34(6). http://www.aapd.org/media/Policies_Guidelines/G_FluorideTherapy.pdf. Exclusion code: 11.
American Academy of Pediatric Dentistry. Guideline on Xylitol Use in Caries Prevention. American Academy of Pediatric Dentistry Reference Manual. 2012/2013;34(6):166-169. Exclusion code: 2.
American Academy of Pediatric Dentistry. Guideline on Fluoride Therapy. 2012/2013. Exclusion code: 2.
American Academy of Pediatric Dentistry. Guideline on Caries-risk Assessment and Management for Infants, Children, and Adolescents. American Academy of Pediatric Dentistry Reference Manual. 2012/2013;34(6):118-125. Exclusion code: 2.
American Academy of Pediatrics. Policy Statement - AAP Publications Retired and Reaffirmed. Policy Statement. http://pediatrics.aappublications.org/content/124/2/845.full. 12 January, 2013. Exclusion code: 2.
American Academy of Pediatrics. Oral health risk assessment timing and establishment of the dental home. 2003. Exclusion code: 2.
American Academy of Pediatrics. Profile of pediatric visits: Annualized estimates 2000-2004. Elk Grove Village, Illinois. 2007. Exclusion code: 2.
American Academy of Pediatrics. Recommendations for Preventive Pediatric Health Care. 2008. Exclusion code: 2.
American Academy of Pediatrics. Preventive oral health intervention for pediatricians: Section on pediatric dentistry and oral health. Pediatrics. 2008;122(6):1387-1394. Exclusion code: 2. [pmid: 19015205].
American Academy of Pediatrics. Oral Health Risk Assessment Tool. 2011. http://www2.aap.org/oralhealth/docs/RiskAssessmentTool.pdf. 13 Dec 2012. Exclusion code: 2.
American Academy on Pediatric Dentistry Council on Clinical Affairs. Policy on use of a caries-risk assessment tool (CAT) in infants, children, and adolescents. Pediatr Dent. 2002;24(Suppl):15-17. Exclusion code: 5.
American Academy on Pediatric Dentistry Council on Clinical Affairs. Policy on Use of a Caries-risk Assessment Tool (CAT) for Infants, Children and Adolescents. Pediatr Dent. 2006;31(6). Exclusion code: 2.
American Academy on Pediatric Dentistry Council on Clinical Affairs. Policy on the use of xylitol in caries prevention. Pediatr Dent. 2008;30(7 Suppl):36-37. Exclusion code: 2. [pmid: 19216379].
American Academy on Pediatric Dentistry Council on Clinical Affairs. Policy on use of a caries-risk assessment tool (CAT) for infants, children, and adolescents. Pediatr Dent. 2008;30(7 Suppl):29-33. Exclusion code: 2. [pmid: 19216377].
American Dental Association. Statement on Early Childhood Caries. 2000. http://www.ada.org/2057.aspx. 13 Dec, 2012. Exclusion code: 2.
American Dental Association. ADA Caries Risk Assessment Forms. 2009. http://www.ada.org/5157.aspx?currentTab=2. 23 Oct 2012. Exclusion code: 2.
American Dental Association. Caries Risk Assessment Form (Age 0-6). 2011. http://www.ada.org/sections/professionalResources/pdfs/topics_caries_under6.pdf. 27 March, 2013. Exclusion code: 2.
American Dental Association Council on Scientific Affairs. Professionally applied topical flouride: Evidence-based clinical recommendations. J Dent Educ. 2007;71(3):393-402. Exclusion code: 2. [pmid: 17389574].
Ammari AB, Bloch-Zupan A, Ashley PF. Systematic review of studies comparing the anti-caries efficacy of children's toothpaste containing 600 ppm of fluoride or less with high fluoride toothpastes of 1,000 ppm or above. Caries Res. 2003;37(2):85-92. Exclusion code: 3. [pmid: 12652045].
Ananaba N, Malcheff S, Briskie D, Inglehart MR. Infant oral health examinations: attitudes and professional behavior of general and pediatric dentists in Michigan and pediatric dentists in the U.S. J Mich Dent Assoc. 2010;92(12):38-43. Exclusion code: 2. [pmid: 21291093].
Andruskeviciene V, Milciuviene S, Bendoraitiene E, et al. Oral health status and effectiveness of caries prevention programme in kindergartens in Kaunas city (Lithuania). Oral health prev. 2008;6(4):343-348. Exclusion code: 4. [pmid: 19178101].
Ansai T, Yamashita Y, Shibata Y, et al. Relationship between dental caries experience of a group of Japanese kindergarten children and the results of two caries activity tests conducted on their saliva and dental plaque. International journal of paediatric dentistry / the British Paedodontic Society [and] the International Association of Dentistry for Children. 1994;4(1):13-17. Exclusion code: 8. [pmid: 7748842].
Anttonen V, Larmas M, Raitio M. Children were guaranteed regular check ups in dental study. BMJ. 1999;319(7222):1432. Exclusion code: 5. [pmid: 10574873].
Armfield JM. Community effectiveness of public water fluoridation in reducing children's dental disease. Public Health Rep. 2010;125(5):655-664. Exclusion code: 4. [pmid: 20873281].
Arora A, Scott JA, Bhole S, Do L, Schwarz E, Blinkhorn AS. Early childhood feeding practices and dental caries in preschool children: a multi-centre birth cohort study. BMC Public Health. 2011;11:28. Exclusion code: 5. [pmid: 21223601].
Arruda AO, Senthamarai Kannan R, Inglehart MR, Rezende CT, Sohn W. Effect of 5% fluoride varnish application on caries among school children in rural Brazil: A randomized controlled trial. Community Dentistry and Oral Epidemiology. 2012;40(3):267-276. Exclusion code: 3. [pmid: 22150341].
Assael LA. Should dentists become ‘oral physicians’? No, dentistry must remain dentistry. J Am Dent Assoc. +441. +443. +445. +447. 2004;135(4):439-449. Exclusion code: 5. [pmid: 15127866].
Autio JT. Effect of xylitol chewing gum on salivary Streptococcus mutans in preschool children. J Dent Child. 2002;69(1):81-86. 13. Exclusion code: 8. [pmid: 12119821].
Autio JT, Courts FJ. Acceptance of the xylitol chewing gum regimen by preschool children and teachers in a Head Start program: a pilot study. Pediatr Dent. 2001;23(1):71-74. Exclusion code: 8. [pmid: 11242737].
Autio-Gold J. Recommendations for fluoride varnish use in caries management. Dent Today. 2008;27(1):64-67. quiz 67, 58. Exclusion code: 2. [pmid: 18240633].
Autio-Gold JT, Courts F. Assessing the effect of fluoride varnish on early enamel carious lesions in the primary dentition. J Am Dent Assoc. 2001;132(9):1247-1253. Exclusion code: 11. [pmid: 11665349].
Azarpazhooh A, Limeback H, Lawrence HP, Shah PS. Xylitol for preventing acute otitis media in children up to 12 years of age. Cochrane Database Syst Rev. 2011;(11):CD007095. Exclusion code: 8. [pmid: 22071833].
Baca P, Muñoz MJ, Bravo M, Junco P, Baca AP. Effectiveness of chlorhexidine-thymol varnish in preventing caries lesions in primary molars. J Dent Child. 2004;71(1):61-65. Exclusion code: 3. [pmid: 15272659].
Bader JD, Rozier RG, Lohr KN, Frame PS. Physicians' roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004;26(4):315-325. Exclusion code: 2. [pmid: 15110059].
Bader JD, Shugars DA, Bonito AJ. Systematic reviews of selected dental caries diagnostic and management methods. J Dent Educ. 2001;65(10):960-968. Exclusion code: 5. [pmid: 11699997].
Badet MC, Richard B, Dorignac G. An in vitro study of the pH-lowering potential of salivary lactobacilli associated with dental caries. J Appl Microbiol. 2001;90(6):1015-1018. Exclusion code: 8. [pmid: 11412333].
Balaban R, Aguiar CM, Da Silva Araújo AC, Dias Filho EBR. Knowledge of paediatricians regarding child oral health. Int J Paediatr Dent. 2012;22(4):286-291. Exclusion code: 3. [pmid: 22092596].
Baldani MH, Antunes JLF. Inequalities in access and utilization of dental services: a cross-sectional study in an area covered by the Family Health Strategy. Cad Saude Publica. Suppl 2. 2011;27:S272-283. Exclusion code: 2. [pmid: 21789419].
Baldani MH, Mendes YBE, Lawder JAdC, de Lara API, Rodrigues MMAdS, Antunes JLF. Inequalities in dental services utilization among Brazilian low-income children: the role of individual determinants. J Public Health Dent. 2011;71(1):46-53. Exclusion code: 2. [pmid: 21667543].
Banoczy J, Scheinin A, Esztari I, Szoke J, Hadas E, Zimmermann P. Caries-preventing action of xylitol-containing sweets, studied in children's institutions. Orv Hetil. 1985;126(40):2447-2451. Exclusion code: 7. [pmid: 4047645].
Banoczy J, Scheinin A, Esztari I, et al. 3-year results of a WHO-supported caries-prevention program, using xylitol, in Hungarian children's homes. I. Clinical caries studies. Fogorv Sz. 1985;78(11):329-338. Exclusion code: 7. [pmid: 3914420].
Bär A. Caries prevention with xylitol. A review of the scientific evidence. World review of nutrition and dietetics. 1988;55:183-209. Exclusion code: 5. [pmid: 3287773].
Barber LR, Wilkins EM. Evidence-based prevention, management, and monitoring of dental caries. J Dent Hyg. 2002;76(4):270-275. Exclusion code: 2. [pmid: 12592918].
Barmes D, Barnaud J, Khambonanda S, Infirri JS. Field trials of preventive regimens in Thailand and French Polynesia. Int Dent J. 1985;35(1):66-72. Exclusion code: 3. [pmid: 3888852].
Bawden JW. Fluoride varnish: a useful new tool for public health dentistry. J Public Health Dent. 1998;58(4):266-269. Exclusion code: 2. [pmid: 10390707].
Beil H, Mayer M, Rozier RG. Dental care utilization and expenditures in children with special health care needs. J Am Dent Assoc. 2009;140(9):1147-1155. Exclusion code: 3. [pmid: 19723949].
Beil HA, Rozier RG. Primary health care providers' advice for a dental checkup and dental use in children. Pediatrics. 2010;126(2):e435-441. Exclusion code: 8. [pmid: 20660547].
Bell JF, Huebner CE, Reed SC. Oral health need and access to dental services: evidence from the National Survey of Children's Health, 2007. Maternal and Child Health Journal. Suppl 1. 2012;16:S27-34. Exclusion code: 2. [pmid: 22456986].
Beltrán ED, Malvitz DM, Eklund SA. Validity of two methods for assessing oral health status of populations. J Public Health Dent. 1997;57(4):206-214. Exclusion code: 6. [pmid: 9558624].
Beltran-Aguilar D, Barker LK, Dye BA. Prevalence and severity of dental fluorosis in the United States, 1999-2004. National Center for Health Statistics Data Brief. Hyattsville, MD. 2010. Exclusion code: 2.
Beltran-Aguilar ED, Barker LK, Canto MT, et al. Surveillance for dental caries, dental sealants, tooth retention, edentulism, and enamel fluorosis--United States, 1988-1994 and 1999-2002. MMWR Surveill Summ. 2005;54(3):1-43. Exclusion code: 4. [pmid: 16121123].
Beltran-Aguilar ED, Goldstein JW, Lockwood SA. Fluoride varnishes. A review of their clinical use, cariostatic mechanism, efficacy and safety. J Am Dent Assoc. 2000;131(5):589-596. Exclusion code: 11. [pmid: 10832252].
Beltran-Aguilar ED, Griffin SO, Lockwood SA. Prevalence and trends in enamel fluorosis in the United States from the 1930s to the 1980s. J Am Dent Assoc. 2002;133(2):157-165. Exclusion code: 11. [pmid: 11868834].
Beltrán-Valladares PR, Cocom-Tun H, Casanova-Rosado JF, Vallejos-Sánchez AA, Medina-Solís CE, Maupomé G. Prevalence of dental fluorosis and additional sources of exposure to fluoride as risk factors to dental fluorosis in schoolchildren of Campeche, Mexico. Rev Invest Clin. 2005;57(4):532-539. Exclusion code: 7. [pmid: 16315637].
Bentley EM, Holloway PJ. An evaluation of the role of health visitors in encouraging dental attendance of infants. Community Dent Health. 1993;10(3):243-249. Exclusion code: 11. [pmid: 8269339].
Berg JH. Early dental caries detection as a part of oral health maintenance in young children. Compend Contin Educ Dent. 2005;26(5 Suppl 1):24-29. Exclusion code: 5. [pmid: 17036541].
Binkley CJ, Garrett B, Johnson KW. Increasing dental care utilization by Medicaid-eligible children: A dental care coordinator intervention. J Public Health Dent. 2010;70(1):76-84. Exclusion code: 2. [pmid: 19765202].
Blackwell DL, Tonthat L. Summary health statistics for U.S. children: National Health Interview Survey, 1999. Vital Health Stat [10]. 2003;(210):1-50. Exclusion code: 2. [pmid: 15789511].
Blair Y, Macpherson L, McCall D, McMahon A. Dental health of 5-year-olds following community-based oral health promotion in Glasgow, UK. Int J Paediatr Dent. 2006;16(6):388-398. Exclusion code: 9. [pmid: 17014536].
Blair Y, Macpherson LMD, McCall DR, McMahon AD, Stephen KW. Glasgow nursery-based caries experience, before and after a community development-based oral health programme's implementation. Community Dent Health. 2004;21(4):291-298. Exclusion code: 9. [pmid: 15617414].
Bloom B, Cohen RA, Freeman G. Summary health statistics for US children: National Health Interview Survey, 2010. Vital and health statistics. Series 10, Data from the National Health Survey. 2011;(250):1-80. Exclusion code: 2. [pmid: 22338334].
Bonanato K, Paiva SM, Pordeus IA, Ramos-Jorge ML, Barbabela D, Allison PJ. Relationship between mothers' sense of coherence and oral health status of preschool children. Caries Res. 2009;43(2):103-109. Exclusion code: 8. [pmid: 19321987].
Bonanato K, Pordeus IA, Moura-Leite FR, Ramos-Jorge ML, Vale MP, Paiva SM. Oral disease and social class in a random sample of five-year-old preschool children in a Brazilian city. Oral health prev. 2010;8(2):125-132. Exclusion code: 4. [pmid: 20589245].
Borutta A, Reuscher G, Hufnagl S, Möbius S. Caries prevention with fluoride varnishes among preschool children. Kariesprophylaxe mit fluoridlacken bei vorschulkindern. 2006;68(11):731-734. Exclusion code: 7. [pmid: 17199209].
Bottenberg P, Declerck D, Ghidey W, Bogaerts K, Vanobbergen J, Martens L. Prevalence and determinants of enamel fluorosis in Flemish schoolchildren. Caries Res. 2004;38(1):20-28. Exclusion code: 8. [pmid: 14684973].
Bottenberg P, Melckebeke LV, Louckx F, Vandenplas Y. Knowledge of Flemish paediatricians about children's oral health - Results of a survey. Acta Paediatrica, International Journal of Paediatrics. 2008;97(7):959-963. Exclusion code: 4. [pmid: 18474066].
Braga MM, Oliveira LB, Bonini GAVC, Bönecker M, Mendes FM. Feasibility of the international caries detection and assessment system (icdas-ii) in epidemiological surveys and comparability with standard world health organization criteria. Caries Res. 2009;43(4):245-249. Exclusion code: 4. [pmid: 19439944].
Bratthall D, Hansel Petersson G. Cariogram--a multifactorial risk assessment model for a multifactorial disease. Community Dent Oral Epidemiol. 2005;33(4):256-264. Exclusion code: 3. [pmid: 16008632].
Brickhouse TH, Unkel JH, Kancitis I, Best AM, Davis RD. Infant oral health care: A survey of general dentists, pediatric dentists, and pediatricians in Virginia. Pediatr Dent. 2008;30(2):147-153. Exclusion code: 2. [pmid: 18481580].
Brown LF. Research in dental health education and health promotion: a review of the literature. Health Educ Q. 1994;21(1):83-102. Exclusion code: 11. [pmid: 8188495].
Bubna S, Perez-Spiess S, Cernigliaro J, Julliard K. Infant oral health care: Beliefs and practices of American Academy of Pediatric Dentistry members. Pediatr Dent. 2012;34(3):203-209. Exclusion code: 3. [pmid: 22795152].
Busuttil Naudi A, Mooney G, El-Bahannasawy E, et al. The dental health and preventative habits of cardiac patients attending the Royal Hospital for Sick Children Glasgow. Eur Arch Paediatr Dent. 2006;7(1):23-30. Exclusion code: 3. [pmid: 17140524].
Calonge N, U.S. Preventive Services Task Force. Prevention of Dental Caries in Preschool Children: Recommendations and Rationale. Am J Prev Med. 2004;26(4):326-329. Exclusion code: 2. [pmid: 15110060].
Campus G, Cagetti MG, Sacco G, Solinas G, Mastroberardino S, Lingstrom P. Six months of daily high-dose xylitol in high-risk schoolchildren: a randomized clinical trial on plaque pH and salivary mutans streptococci. Caries Res. 2009;43(6):455-461. Exclusion code: 3. [pmid: 20016175].
Campus G, Solinas G, Strohmenger L, et al. National pathfinder survey on children's oral health in Italy: pattern and severity of caries disease in 4-year-olds. Caries Res. 2009;43(2):155-162. Exclusion code: 8. [pmid: 19365120].
Carvalho DM, Salazar M, Oliveira BH, Coutinho ES. Fluoride varnishes and decrease in caries incidence in preschool children: a systematic review. Rev Bras Epidemiol. 2010;13(1):139-149. Exclusion code: 5. [pmid: 20683562].
Casamassimo P, Holt K. Bright Futures in Practice: Oral Health—Pocket Guide. Washington, D.C. National Maternal and Child Oral Health Resource Center. 2004. Exclusion code: 5.
Casamassimo PS, Thikkurissy S, Edelstein BL, Maiorini E. Beyond the dmft: the human and economic cost of early childhood caries. J Am Dent Assoc. 2009;140(6):650-657. Exclusion code: 5. [pmid: 19491160].
Caufield PW, Griffen AL. DENTAL CARIES: An Infectious and Transmissible Disease. 2000:0031-3955. Exclusion code: 2.
Centers for Disease Control and Prevention. Recommendations for using fluoride to prevent and control dental caries in the United States. MMWR. 2001;50(RR-14):1-42. Exclusion code: 11. [pmid: 11521913].
Centers for Disease Control and Prevention. Dental Caries: Hygiene-related diseases. 2009. http://www.cdc.gov/healthywater/hygiene/disease/dental_caries.html. May 23, 2012. Exclusion code: 2.
Centers for Medicare & Medicaid Services (CMS). Use of Dental Services in Medicaid and CHIP. Baltimore, MD. CMS.gov. 2011. Exclusion code: 2.
Chan SCL, Tsai JSJ, King NM. Feeding and oral hygiene habits of preschool children in Hong Kong and their caregivers' dental knowledge and attitudes. Int J Paediatr Dent. 2002;12(5):322-331. Exclusion code: 4. [pmid: 12199891].
Chandiwal S, Yoon RK. Assessment of an infant oral health education program on resident physician knowledge. J Dent Child. 2012;79(2):49-52. Exclusion code: 3. [pmid: 22828757].
Clark DC. Trends in prevalence of dental fluorosis in North America. Community Dent Oral Epidemiol. 1994;22(3):148-152. Exclusion code: 11. [pmid: 8070241].
Clark DC, Stamm JW, Quee TC, Robert G. Results of the Sherbrooke-Lac Mégantic fluoride varnish study after 20 months. Community Dentistry and Oral Epidemiology. 1985;13(2):61-64. Exclusion code: 3. [pmid: 3857148].
Clark DC, Stamm JW, Robert G, Tessier C. Results of a 32-month fluoride varnish study in Sherbrooke and Lac-Megantic, Canada. The Journal of the American Dental Association. 1985;111(6):949-953. Exclusion code: 3. [pmid: 3905917].
Clark DC, Stamm JW, Tessier C, Robert G. The final results of the Sherbrooke-Lac Mégantic fluoride varnish study. J Can Dent Assoc. 1987;53(12):919-922. Exclusion code: 3. [pmid: 3319099].
Cleaton-Jones P, Hargreaves JA, Beere D, Matejka J, Hargreaves V. Use of DI-S and CPITN as predictors in dental caries studies in the primary dentition. The Journal of the Dental Association of South Africa. Die Tydskrif van die Tandheelkundige Vereniging van Suid-Afrika. 1991;46(10):503-505. Exclusion code: 8. [pmid: 1820667].
Close K, Rozier RG, Zeldin LP, Gilbert AR. Barriers to the adoption and implementation of preventive dental services in primary medical care. Pediatrics. 2010;125(3):509-517. Exclusion code: 2. [pmid: 20123767].
Collins RJ, Nehring ME, Maas WR, et al. Toward improving the oral health of Americans: An overview of oral health status, resources, and care delivery. Public Health Rep. 1993;108(6):657-672. Exclusion code: 5. [pmid: 8265750].
Committee on Fluoride in Drinking Water NRC. Fluoride in Drinking Water: A Scientific Review of EPA's Standards. The National Academies Press. 2006. Exclusion code: 2.
Community Preventive Services Task Force. Improving Oral Health: Dental Caries (Cavities). 2010. http://www.thecommunityguide.org/oral/caries.html. 27 March, 2013. Exclusion code: 2.
Conway DI, Macpherson LMD, Stephen KW, Gilmour WH, Petersson LG. Prevalence of dental fluorosis in children from non-water-fluoridated Halmstad, Sweden: Fluoride toothpaste use in infancy. Acta Odontol Scand. 2005;63(1):56-63. Exclusion code: 4. [pmid: 16095064].
Cruxen B, Volschan G. Getting to know the early childhood caries through qualitative analysis. J Clin Pediatr Dent. 2006;31(1):48-51. Exclusion code: 8. [pmid: 17091659].
Cutress T, Howell PT, Finidori C, Abdullah F. Caries preventive effect of high fluoride and xylitol containing dentifrices. J Dent Child. 1992;59(4):313-318. Exclusion code: 3. [pmid: 1430505].
da Silva BDM, Forte FDS. Access to dental treatment, mothers perception of oral health and intervention strategies in the city of Mogeiro, PB, Brazil. Pesquisa Brasileira em Odontopediatria e Clinica Integrada. 2009;9(3):313-319. Exclusion code: 10.
Damiano PC, Willard JC, Momany ET, Chowdhury J. The impact of the Iowa S-SCHIP program on access, health status, and the family environment. Ambul Pediatr. 2003;3(5):263-269. Exclusion code: 2. [pmid: 12974660].
Davenport C, Elley K, Salas C, et al. The clinical effectiveness and cost-effectiveness of routine dental checks: a systematic review and economic evaluation. Health Technol Assess. 2003;7(7):iii-v. Exclusion code: 4. [pmid: 12709293].
Davies G, Health CD. A randomised controlled trial of the effectiveness of providing free fluoride toothpaste from the age of 12 months on reducing caries in 5-6 year old children. Community Dent Health. 2002;19:131-136. Exclusion code: 4. [pmid: 12269458].
Davies GM, Duxbury JT, Boothman NJ, Davies RM, Blinkhorn AS. A staged intervention dental health promotion programme to reduce early childhood caries. Community Dent Health. 2005;22(2):118-122. Exclusion code: 5. [pmid: 15984138].
Davies GN. Early childhood caries - A synopsis. Community Dentistry and Oral Epidemiology. 1998;26(1 SUPPL.):106-116. Exclusion code: 5. [pmid: 9671208].
de Silva-Sanigorski AM, Waters E, Calache H, et al. Splash!: a prospective birth cohort study of the impact of environmental, social and family-level influences on child oral health and obesity related risk factors and outcomes. BMC Public Health. 2011;11:505. Exclusion code: 5. [pmid: 21708037].
De Soet JJ, Gruythuysen RJM, Bosch JA, Van Amerongen WE. The effect of 6-monthly application of 40% chlorhexidine varnish on the microflora and dental caries incidence in a population of children in Surinam. Caries Res. 2002;36(6):449-455. Exclusion code: 3. [pmid: 12459619].
Decker SL. Medicaid payment levels to dentists and access to dental care among children and adolescents. JAMA. 2011;306(2):187-193. Exclusion code: 2. [pmid: 21750296].
Declerck D, Leroy R, Martens L, et al. Factors associated with prevalence and severity of caries experience in preschool children. Community Dent Oral Epidemiol. 2008;36(2):168-178. Exclusion code: 8. [pmid: 18333881].
Deinard A, Johnson B. Ending an epidemic: physicians' role in primary caries prevention. Minn Med. 2009;92(3):38-39. Exclusion code: 2. [pmid: 19400385].
dela Cruz GG, Rozier RG, Slade G. Dental screening and referral of young children by pediatric primary care providers. Pediatrics. 2004;114(5):e642-652. Exclusion code: 8. [pmid: 15520094].
Demers M, Brodeur JM, Mouton C, Simard PL, Trahan L, Veilleux G. A multivariate model to predict caries increment in Montreal children aged 5 years. Community Dent Health. 1992;9(3):273-281. Exclusion code: 8. [pmid: 1451000].
DePaola PF, Lax M. The caries-inhibiting effect of acidulated phosphate-fluoride chewable tablets: a two-year double-blind study. The Journal of the American Dental Association. 1968;76(3):554-557. Exclusion code: 3. [pmid: 4865754].
DeVoe JE, Tillotson CJ, Wallace LS, Angier H, Carlson MJ, Gold R. Parent and child usual source of care and children's receipt of health care services. Ann Fam Med. 2011;9(6):504-513. Exclusion code: 2. [pmid: 22084261].
Di Giuseppe G, Nobile CGA, Marinelli A, Angelillo IF. Knowledge, attitude and practices of pediatricians regarding the prevention of oral diseases in Italy. BMC Public Health. 2006;6:176. Exclusion code: 8. [pmid: 16822318].
Dillenberg JS, Levy SM, Schroeder DC, Gerston EN, Andersen CJ. Arizona providers' use and knowledge of fluoride supplements. Clin Prev Dent. 1992;14(5):15-26. Exclusion code: 11. [pmid: 1291183].
Dimitrova MM, Kukleva MP, Stoykova MS. A study of dentists' opinion about caries treatment of 1-3- year-old children. Folia Med (Plovdiv). 2001;43(1-2):25-27. Exclusion code: 8. [pmid: 15354461].
Dincer E, Ligouri AL, Rayman S, Rivera A. Parental perceptions about children's oral health care and toothpaste in New York City neighborhoods. N Y State Dent J. 2009;75(2):44-48. Exclusion code: 8. [pmid: 19418881].
Do LG, Spencer AJ. Decline in the prevalence of dental fluorosis among South Australian children. Community Dentistry and Oral Epidemiology. 2007;35(4):282-291. Exclusion code: 4. [pmid: 17615015].
Doméjean S, White JM, Featherstone JD. Validation of the CDA CAMBRA caries risk assessment--a six-year retrospective study. J Calif Dent Assoc. 2011;39(10):709-715. Exclusion code: 3. [pmid: 22132582].
Donahoe JF, Powers RJ. Xylitol. Clinical pharmacology in normal adult volunteers. Journal of Clinical Pharmacology. 1974;14(5-6):255-260. Exclusion code: 3. [pmid: 4829518].
dos Santos APP, Nadanovsky P, de Oliveira BH. Inconsistencies in recommendations on oral hygiene practices for children by professional dental and paediatric organisations in ten countries. Int J Paediatr Dent. 2011;21(3):223-231. Exclusion code: 8. [pmid: 21332850].
Douglass JM, Douglass AB, Silk HJ. Infant oral health education for pediatric and family practice residents. Pediatr Dent. 2005;27(4):284-291. Exclusion code: 5. [pmid: 16317967].
Douglass JM, Tinanoff N, Tang JM, Altman DS. Dental caries patterns and oral health behaviors in Arizona infants and toddlers. Community Dent Oral Epidemiol. 2001;29(1):14-22. Exclusion code: 2. [pmid: 11153558].
Doull J, Boekelheide K, Farishian BG, et al. Fluoride in drinking water: a scientific review of EPA's standards [Internet]. Washington, DC. The National Academies Press. 2006. Exclusion code: 2.
Driscoll WS, Heifetz SB, Korts DC. Effect of acidulated phosphate-fluoride chewable tablets on dental caries in schoolchildren: results after 30 months. The Journal of the American Dental Association. 1974;89(1):115-120. Exclusion code: 3. [pmid: 4151915].
Dye BA, Barker LK, Li X, Lewis BG, Beltran-Aguilar ED. Overview and quality assurance for the oral health component of the National Health and Nutrition Examination Survey (NHANES), 2005-08. J Public Health Dent. 2011;71(1):54-61. Exclusion code: 3. [pmid: 21667544].
Dye BA, Tan S, Smith V, et al. Trends in oral health status: United States, 1988–1994 and 1999–2004. Vital Health Stat. 2007;1(248). Exclusion code: 2. [pmid: 17633507].
Eckersley AJ, Blinkhorn FA. Dental attendance and dental health behaviour in children from deprived and non-deprived areas of Salford, north-west England. Int J Paediatr Dent. 2001;11(2):103-109. Exclusion code: 8. [pmid: 11310132].
Edelstein BL. Solving the problem of early childhood caries: a challenge for us all. Arch Pediatr Adolesc Med. 2009;163(7):667-668. Exclusion code: 2. [pmid: 19581553].
Edelstein BL, Chinn CH. Update on Disparities in Oral Health and Access to Dental Care for America's Children. Acad Pediatr. 2009;9(6):415-419. Exclusion code: 2. [pmid: 19945076].
Eklund SA, Burt BA, Ismail AI, Calderone JJ. High-fluoride drinking water, fluorosis, and dental caries in adults. J Am Dent Assoc. 1987;114(3):324-328. Exclusion code: 11. [pmid: 3470353].
Ekman A, Persson B. Effect of early dental health education for Finnish immigrant families. Swed Dent J. 1990;14(3):143-151. Exclusion code: 11. [pmid: 2255993].
Ekstrand J, Koch G, Lindgren LE, Petersson LG. Pharmacokinetics of fluoride gels in children and adults. Caries Res. 1981;15(3):213-220. Exclusion code: 11. [pmid: 6938306].
Ekstrand J, Koch G, Petersson LG. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res. 1980;14(4):185-189. Exclusion code: 11. [pmid: 6929729].
Elkind A, Blinkhorn FA, Mackie IC, Tickle M, Duxbury JT, Blinkhorn AS. Service quality implications of dental undergraduate outreach teaching for Primary Care Trusts in England, UK. Community Dent Health. 2006;23(2):75-79. Exclusion code: 3. [pmid: 16800361].
Emerich K, Wyszowski J. Oral health prevention in view of Polish paediatricians. Dental and Medical Problems. 2009;46(2):157-161. Exclusion code: 8.
Englander HR, Mellberg JR, Engler WO. Observations on dental caries in primary teeth after frequent fluoride toplications in a program involving other preventives. J Dent Res. 1978;57(9-10):855-860. Exclusion code: 5. [pmid: 281356].
Fanning EA, Cellier KM, Leadbeater MM, Somerville CM. South Australian kindergarten children: fluoride tablet supplements and dental caries. Aust Dent J. 1975;20(1):7-9. Exclusion code: 11. [pmid: 1057890].
Featherstone JD. Delivery challenges for fluoride, chlorhexidine, and xylitol. BMC Oral Health. Jun. Suppl 1. 2006;6(S8):1-5. Exclusion code: 5. [pmid: 16426455].
Featherstone JD, Adair SM, Anderson MH, et al. Caries management by risk assessment: consensus statement, April 2002. J Calif Dent Assoc. 2003;31(3):257-269. Exclusion code: 5. [pmid: 12693825].
Feldens CA, Giugliani ER, Duncan BB, Drachler Mde L, Vitolo MR. Long-term effectiveness of a nutritional program in reducing early childhood caries: a randomized trial. Community Dent Oral Epidemiol. 2010;38(4):324-332. Exclusion code: 9. [pmid: 20406273].
Feltman R, Kosel G. Prenatal and postnatal ingestion of fluorides – Fourteen years of investigation – Final report. Journal of Dental Medicine. 1961;16:190-199. Exclusion code: 8.
Fennis-Le YL, Verdonschot EH, Burgersdijk RCW, König KG, Van't Hof MA. Effect of 6-monthly applications of chlorhexidine varnish on incidence of occlusal caries in permanent molars: A 3-year study. J Dent. 1998;26(3):233-238. Exclusion code: 3. [pmid: 9594475].
Fisher-Owens S, Platt LJ, Weintraub JA, et al. Influences on children's oral health: a conceptual model. Pediatrics. 2007:e510-520. 510-520. Exclusion code: 5. [pmid: 17766495].
Fontana M, Catt D, Eckert GJ, et al. Xylitol: effects on the acquisition of cariogenic species in infants. Pediatr Dent. 2009;31(3):257-266. Exclusion code: 3. [pmid: 19552232].
Fontana M, Jackson R, Eckert G, et al. Identification of caries risk factors in toddlers. J Dent Res. 2011;90(2):209-214. Exclusion code: 8. [pmid: 21173434].
Fontana M, Wolff M. Translating the caries management paradigm into practice: challenges and opportunities. J Calif Dent Assoc. 2011;39(10):702-708. Exclusion code: 5. [pmid: 22132581].
Franco S, Theriot J, Greenwell A. The influence of early counselling on weaning from a bottle. Community Dent Health. 2008;25(2):115-118. Exclusion code: 4. [pmid: 18637324].
Franzman MR, Levy SM, Warren JJ, Broffitt B. Fluoride dentifrice ingestion and fluorosis of the permanent incisors. J Am Dent Assoc. 2006;137(5):645-652. Exclusion code: 4. [pmid: 16739545].
Frostell G, Birkhed D, Edwardsson S, et al. Effect of partial substitution of invert sugar for sucrose in combination with Duraphat® treatment on caries development in preschool children: The Malmo study. Caries Res. 1991;25(4):304-310. Exclusion code: 11. [pmid: 1913770].
Gabris K, Nyarasdy I, Banoczy J. Significance of assessing risk factors for caries in their prevention. Orv Hetil. 2002;143(24):1467-1473. Exclusion code: 7. [pmid: 12138644].
Gabris K, Pienihakkinen K, Nyarasdy I, Rigo O, Banoczy J, Scheinin A. 3-year results of the WHO xylitol caries-prevention program in Hungarian homes for children. IV. Microbiological studies: changes in salivary Lactobacillus and Candida albicans counts. Fogorv Sz. 1987;80(3):71-76. Exclusion code: 7. [pmid: 3549372].
Gagnon F, Catellier P, Arteau-Gauthier I, et al. Compliance with fluoride supplements provided by a dental hygienist in homes of low-income parents of preschool children in Quebec. J Public Health Dent. 2007;67(1):60-63. Exclusion code: 8. [pmid: 17436981].
Galganny-Almeida A, Queiroz MC, Leite AJ. The effectiveness of a novel infant tooth wipe in high caries-risk babies 8 to15 months old. Pediatr Dent. 2007;29(4):337-342. Exclusion code: 8. [pmid: 17867402].
Gallagher IH, Pearce EI. The sugar alcohols. Non-cariogenic sweeteners. N Z Dent J. 1977;73(334):200-206. Exclusion code: 3. [pmid: 351471].
Gao XL, Hsu CYS, Xu Y, Hwarng HB, Loh T, Koh D. Building caries risk assessment models for children. J Dent Res. 2010;89(6):637-643. Exclusion code: 10. [pmid: 20400721].
Gao XL, Hsu CYS, Xu YC, Loh T, Koh D, Hwarng HB. Behavioral pathways explaining oral health disparity in children. J Dent Res. 2010;89(9):985-990. Exclusion code: 10. [pmid: 20554887].
Garbutt JM, Leege E, Sterkel R, Gentry S, Wallendorf M, Strunk RC. What are parents worried about? Health problems and health concerns for children. Clinical Pediatrics. 2012. July. 26. 2012. Exclusion code: 5. [pmid: 22843294].
Gibbons RJ, van Houte J. Dental caries. Annual Review of Medicine. 1975;26:121-136. Exclusion code: 5. [pmid: 1096752].
Gift HC, Milton B, Walsh V. Physicians and caries prevention. Results of a physician survey on preventive dental services. JAMA. 1984;252(11):1447-1448. Exclusion code: 11. [pmid: 6471271].
Goldberg E, Lewis P, Ferguson F. Oral health status and access-to-care concerns of Suffolk County Head Start children. N Y State Dent J. 2011;77(1):20-22. Exclusion code: 2. [pmid: 21417161].
Gomez SS, Weber AA. Effectiveness of a caries preventive program in pregnant women and new mothers on their offspring. Int J Paediatr Dent. 2001;11(2):117-122. Exclusion code: 2. [pmid: 11310134].
Gomez SS, Weber AA, Emilson CG. A prospective study of a caries prevention program in pregnant women and their children five and six years of age. J Dent Child. 2001;68(3):191-195. 152. Exclusion code: 3. [pmid: 11693012].
Gosnell E, Casamassimo PS. Restoration and Post-Surgical Prevention Will Not Solve Early Childhood Caries. Clinical Dentistry and Research. 2012;36(1):35-40. Exclusion code: 2.
Graber TM, Muller TP, Bhatia VD. The effect of xylitol gum and rinses on plaque acidogenesis in patients with fixed orthodontic appliances. Swedish dental journal. Supplement. 1982;15:41-55. Exclusion code: 3. [pmid: 6963783].
Grant JS, Kotch JB, Quinonez RB, Kerr J, Roberts MW. Evaluation of knowledge, attitudes, and self-reported behaviors among 3-5 year old school children using an oral health and nutrition intervention. J Clin Pediatr Dent. 2010;35(1):59-64. Exclusion code: 8. [pmid: 21189766].
Grant JS, Roberts MW, Brown WD, Quinonez RB. Integrating dental screening and fluoride varnish application into a pediatric residency outpatient program: clinical and financial implications. J Clin Pediatr Dent. 2007;31(3):175-178. Exclusion code: 8. [pmid: 17550042].
Graves RC, Abernathy JR, Disney JA, Stamm JW, Bohannan HM. University of North Carolina caries risk assessment study. III. Multiple factors in caries prevalence. J Public Health Dent. 1991;51(3):134-143. Exclusion code: 8. [pmid: 1920265].
Greene-McIntyre M, Finch MH, Searcy J. Smile Alabama! Initiative: interim results from a program to increase children's access to dental care. J Rural Health. 2003;19(Suppl):407-415. Exclusion code: 2. [pmid: 14526525].
Grembowski D, Spiekerman C, Milgrom P. Linking mother and child access to dental care. Pediatrics. 2008;122(4):e805-814. Exclusion code: 2. [pmid: 18829778].
Grenby TH, Bashaarat AH. A clinical trial to compare the effects of xylitol and sucrose chewing-gums on dental plaque growth. Br Dent J. 1982;152(10):339-343. Exclusion code: 3. [pmid: 6953972].
Grillaud M, Bandon D, Nancy J, Delbos Y, Vaysse F. The polyols in pediatric dentistry: advantages of xylitol. Arch Pediatr. 2005;12(7):1180-1186. Exclusion code: 7. [pmid: 15964535].
Grindefjord M, Dahllöf G, Nilsson B, Modéer T. Prediction of dental caries development in 1-year-old children. Caries Res. 1995;29(5):343-348. Exclusion code: 8. [pmid: 8521434].
Grocholewicz K. The effect of selected prophylactic-educational programs on oral hygiene, periodontium and caries in school children during a 4-year observation. Annales Academiae Medicae Stetinensis. 1999;45:265-283. Exclusion code: 7. [pmid: 10909495].
Grodzka K, Augustyniak L, Budny J. Caries increment in primary teeth after application of Duraphat® fluoride varnish. Community Dentistry and Oral Epidemiology. 1982;10(2):55-59. Exclusion code: 11. [pmid: 6952970].
Günay H, Dmoch-Bockhorn K, Günay Y, Geurtsen W. Effect on caries experience of a long-term preventive program for mothers and children starting during pregnancy. Clin Oral Investig. 1998;2(3):137-142. Exclusion code: 3. [pmid: 9927915].
Hamberg L. Controlled trial of fluoride in vitamin drops for prevention of caries in children. Lancet. 1971;1(7696):441-442. Exclusion code: 11. [pmid: 4100412].
Hamilton FA, Davis KE, Blinkhorn AS. An oral health promotion programme for nursing caries. International journal of paediatric dentistry / the British Paedodontic Society [and] the International Association of Dentistry for Children. 1999;9(3):195-200. Exclusion code: 4. [pmid: 10815576].
Hanno AG, Alamoudi NM, Almushayt AS, Masoud MI, Sabbagh HJ, Farsi NM. Effect of xylitol on dental caries and salivary Streptococcus mutans levels among a group of mother-child pairs. J Clin Pediatr Dent. 2011;36(1):25-30. Exclusion code: 5. [pmid: 22900440].
Hanson J, Campbell L. Xylitol and caries prevention. J Mass Dent Soc. 2011;60(2):18-21. Exclusion code: 2. [pmid: 22128472].
Hardman MC, Davies GM, Duxbury JT, Davies RM. A cluster randomised controlled trial to evaluate the effectiveness of fluoride varnish as a public health measure to reduce caries in children. Caries Res. 2007;41(5):371-376. Exclusion code: 3. [pmid: 17713337].
Harris R, Nicoll AD, Adair PM, Pine CM. Risk factors for dental caries in young children: A systematic review of the literature. Community Dent Health. 2004;21(1 SUPPL.):71-85. Exclusion code: 8. [pmid: 15072476].
Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3, Supplement 1):21-35. Exclusion code: 2. [pmid: 11306229].
Hartlmaier KM. Sweet, yet harmless. Zahnarztl. 1977;67(14):882-883. Exclusion code: 7. [pmid: 268111].
Havenaar R, Huis in 't Veld JHJ, de Stoppelaar JD, Backer Dirks O. Anti-cariogenic and remineralizing properties of xylitol in combination with sucrose in rats inoculated with Streptococcus mutans. Caries Res. 1984;18(3):269-277. Exclusion code: 3. [pmid: 6584218].
Hecksher AS, Luiz RR, Costa AJL, Moraes NM. Reliability analysis of visual examinations carried out by school-teachers and a dental assistant in the detection of dental caries. Community Dent Health. 2010;27(2):89-93. Exclusion code: 3. [pmid: 20648885].
Hefti A. Sugar substitutes in caries prevention. Schweiz Med Wochenschr. 1980;110(7):269-273. Exclusion code: 7. [pmid: 7367846].
Heifetz SB, Horowitz HS, Meyers RJ, Li SH. Evaluation of the comparative effectiveness of fluoride mouthrinsing, fluoride tablets, and both procedures in combination: interim findings after two years. Pediatr Dent. 1987;9(2):121-125. Exclusion code: 3. [pmid: 3475680].
Hennon DK, Stookey GK, Beiswanger BB. Fluoride-vitamin supplements: effects on dental caries and fluorosis when used in areas with suboptimum fluoride in the water supply. J Am Dent Assoc. 1977;95(5):965-971. Exclusion code: 11. [pmid: 269878].
Hennon DK, Stookey GK, Muhler JC. Prophylaxis of dental caries: Relative effectiveness of chewable fluoride preparations with and without added vitamins. J Pediatr. 1972;80(6):1018-1021. Exclusion code: 2. [pmid: 5026023].
Herndon JB, Tomar SL, Lossius MN, Catalanotto FA. Preventive oral health care in early childhood: Knowledge, confidence, and practices of pediatricians and family physicians in Florida. Journal of Pediatrics. 2010;157(6):1018-1024.e1012. Exclusion code: 3. [pmid: 20655542].
Herrmann HJ, Roberts MW. Preventive dental care: The role of the pediatrician. Pediatrics. 1987;80(1):107-110. Exclusion code: 5. [pmid: 3601505].
Hiller KA, Wilfart G, Schmalz G. Developmental Enamel Defects in Children with Different Fluoride Supplementation - A Follow-Up Study. Caries Res. 1998;32(6):405-411. Exclusion code: 4. [pmid: 9745112].
Hochstetter AS, Lombardo MJ, D'eramo L, Piovano S, Bordoni N. Effectiveness of a preventive educational programme on the oral health of preschool children. Promotion & Education. 2007;14(3):155-158. Exclusion code: 9. [pmid: 18154225].
Hoeft KS, Barker JC, Masterson EE. Maternal beliefs and motivations for first dental visit by low-income Mexican American children in California. Pediatr Dent. 2011;33(5):392-398. Exclusion code: 8. [pmid: 22104706].
Holbrook WP, de Soet JJ, de Graaff J. Prediction of dental caries in pre-school children. Caries Res. 1993;27(5):424-430. Exclusion code: 8. [pmid: 8242681].
Holgerson PL, Twetman S, Stecksen-Blicks C. Validation of an age-modified caries risk assessment program (Cariogram) in preschool children. Acta Odontol Scand. 2009;67(2):106-112. Exclusion code: 2. [pmid: 19152150].
Holm AK. Effect of a fluoride varnish (Duraphat ®) in preschool children. Community Dentistry and Oral Epidemiology. 1979;7(5):241-245. Exclusion code: 11. [pmid: 295702].
Holm GB, Holst K, Koch G, Widenheim J. Fluoride chewing tablets--a new aid in caries prevention. Comparative effect of a weekly mouthrinse with 0.2% NaF and daily chewing of a fluoride tablet (Gostrimant (R)). 2. year clinical test in schoolchildren. Tandlakartidningen. 1975;67(6):354-361. Exclusion code: 7. [pmid: 1057274].
Holm GB, Holst K, Mejare I. The caries-preventive effect of a fluoride varnish in the fissures of the first permanent molar. Acta Odontol Scand. 1984;42(4):193-197. Exclusion code: 3. [pmid: 6594021].
Holst A, Braune K. Dental assistants' ability to select caries risk-children and to prevent caries. Swed Dent J. 1994;18(6):243-249. Exclusion code: 9. [pmid: 7725238].
Holst A, Mårtensson I, Laurin M. Identification of caries risk children and prevention of caries in pre-school children. Swed Dent J. 1997;21(5):185-191. Exclusion code: 9. [pmid: 9472147].
Holt RD, Winter GB, Fox B, Askew R. Effects of dental health education for mothers with young children in London. Community Dentistry and Oral Epidemiology. 1985;13(3):148-151. Exclusion code: 4. [pmid: 3860335].
Holt RD, Winter GB, Fox B, Askew R. Second assessment of London children involved in a scheme of dental health education in infancy. Community Dent Oral Epidemiol. 1989;17(4):180-182. Exclusion code: 11. [pmid: 2758790].
Holve S. An observational study of the association of fluoride varnish applied during well child visits and the prevention of early childhood caries in American Indian children. Maternal and Child Health Journal. 2008;12(SUPPL. 1):S64-S67. Exclusion code: 5. [pmid: 17957458].
Hong L, Levy SM, Broffitt B, et al. Timing of fluoride intake in relation to development of fluorosis on maxillary central incisors. Community Dentistry and Oral Epidemiology. 2006;34(4):299-309. Exclusion code: 4. [pmid: 16856950].
Hong L, Levy SM, Warren JJ, Broffitt B, Cavanaugh J. Fluoride intake levels in relation to fluorosis development in permanent maxillary central incisors and first molars. Caries Res. 2006;40(6):494-500. Exclusion code: 4. [pmid: 17063020].
Horowitz HS. Research issues in early childhood caries. Community Dentistry and Oral Epidemiology. 1998;26(1 SUPPL.):67-81. Exclusion code: 5. [pmid: 9671202].
Horowitz HS. The role of dietary fluoride supplements in caries prevention. J Public Health Dent. 1999;59(4):205-210. Exclusion code: 11. [pmid: 10682325].
Howell E, Trenholm C, Dubay L, Hughes D, Hill I. The impact of new health insurance coverage on undocumented and other low-income children: lessons from three California counties. J Health Care Poor Underserved. 2010;21(2 Suppl):109-124. Exclusion code: 2. [pmid: 20453380].
Hu D, Wan H, Li S. The caries-inhibiting effect of a fluoride drop program: a 3-year study on Chinese kindergarten children. Chin J Dent Res. 1998;1(3):17-20. Exclusion code: 11. [pmid: 10557167].
Hujoel PP, Makinen KK, Bennett CA, et al. The optimum time to initiate habitual xylitol gum-chewing for obtaining long-term caries prevention. J Dent Res. 1999;78(3):797-803. Exclusion code: 3. [pmid: 10096456].
Huntington NL, Kim IJ, Hughes CV. Caries-risk factors for Hispanic children affected by early childhood caries. Pediatr Dent. 2002;24(6):536-542. Exclusion code: 8. [pmid: 12528946].
Huston JP. Preventing dental disease. J Calif Dent Assoc. 2006;34(7):491-492. Exclusion code: 5. [pmid: 16995607].
Huttunen JK. Serum lipids, uric acid and glucose during chronic consumption of fructose and xylitol in healthy human subjects. Int Z Vitam Ernahrungsforsch Beih. 1976;15:105-115. Exclusion code: 8. [pmid: 1066327].
Imfeld TN. Clinical caries studies with polyalcohols. A literature review. Schweiz Monatsschr Zahnmed. 1994;104(8):941-945. Exclusion code: 5. [pmid: 8091172].
Institute of Medicine. Dietary Reference Intakes for Calcium, Phosphorus, Magnesium, Vitamin D, and Fluoride. The National Academies Press. 1997. Exclusion code: 2.
Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: A meta-analysis. Community Dent Oral Epidemiol. 1999;27(1):48-56. Exclusion code: 2. [pmid: 10086926].
Ismail AI, Nainar SMH, Sohn W. Children's first dental visit: Attitudes and practices of US pediatricians and family physicians. Pediatr Dent. 2003;25(5):425-430. Exclusion code: 8. [pmid: 14649605].
Ismail AI, Ondersma S, Jedele JMW, Little RJ, Lepkowski JM. Evaluation of a brief tailored motivational intervention to prevent early childhood caries. Community Dent Oral Epidemiol. 2011;39(5):433-448. Exclusion code: 9. [pmid: 21916925].
Ismail AI, Sohn W, Tellez M, et al. The International Caries Detection and Assessment System (ICDAS): an integrated system for measuring dental caries. Community Dent Oral Epidemiol. 2007;35(3):170-178. Exclusion code: 5. [pmid: 17518963].
Ismail AI, Sohn W, Tellez M, Willem JM, Betz J, Lepkowski J. Risk indicators for dental caries using the International Caries Detection and Assessment System (ICDAS). Community Dentistry and Oral Epidemiology. 2008;36(1):56-68. Exclusion code: 3. [pmid: 18205641].
Isogangas P, Makinen KK, Tiekso J, Alanen P. Long-term effect of xylitol chewing gum in the prevention of dental caries: a follow-up 5 years after termination of a prevention program. Caries Res. 1993;27(6):495-498. Exclusion code: 3. [pmid: 8281565].
Isokangas P. Xylitol chewing gum in caries prevention. A longitudinal study on Finnish school children. Proc Finn Dent Soc. 1987;83(5-6):285-288. Exclusion code: 7. [pmid: 3432257].
Isokangas P, Alanen P, Tiekso J. The clinician's ability to identify caries risk subjects without saliva tests--a pilot study. Community Dentistry and Oral Epidemiology. 1993;21(1):8-10. Exclusion code: 5. [pmid: 8432109].
Isokangas P, Alanen P, Tiekso J, Makinen KK. Xylitol chewing gum in caries prevention: a field study in children. J Am Dent Assoc. 1988;117(2):315-320. Exclusion code: 3. [pmid: 3166474].
Isokangas P, Soderling E, Pienihakkinen K, Alanen P. Occurrence of dental decay in children after maternal consumption of xylitol chewing gum, a follow-up from 0 to 5 years of age. J Dent Res. 2000;79(11):1885-1889. Exclusion code: 3. [pmid: 11145360].
Isokangas P, Tenovuo J, Soderling E, Mannisto H, Makinen KK. Dental caries and mutans streptococci in the proximal areas of molars affected by the habitual use of xylitol chewing gum. Caries Res. 1991;25(6):444-448. Exclusion code: 3. [pmid: 1810656].
Isokangas P, Tiekso J, Alanen P, Makinen KK. Long-term effect of xylitol chewing gum on dental caries. Community Dent Oral Epidemiol. 1989;17(4):200-203. Exclusion code: 3. [pmid: 2758793].
Jackson SL, Vann WF Jr., Kotch JB, Pahel BT, Lee JY. Impact of poor oral health on children's school attendance and performance. Am J Public Health. 2011;101(10):1900-1906. Exclusion code: 2. [pmid: 21330579].
Jiang H, Tai B, Du M, Peng B. Effect of professional application of APF foam on caries reduction in permanent first molars in 6-7-year-old children: 24-month clinical trial. J Dent. 2005;33(6):469-473. Exclusion code: 3. [pmid: 15935266].
Joharji RM, Adenubi JO. Prevention of pit and fissure caries using an antimicrobial varnish: 9 month clinical evaluation. J Dent. 2001;29(4):247-254. Exclusion code: 3. [pmid: 11525226].
Johnsen DC. The role of the pediatrician in identifying and treating dental caries. Pediatric Clinics of North America. 1991;38(5):1173-1181. Exclusion code: 5. [pmid: 1886741].
Jones K, Tomar SL. Estimated impact of competing policy recommendations for age of first dental visit. Pediatrics. 2005;115(4):906-914. Exclusion code: 2. [pmid: 15805363].
Jones KF, Berg JH. Fluoride supplementation. A survey of pediatricians and pediatric dentists. Am J Dis Child. 1992;146(12):1488-1491. Exclusion code: 11. [pmid: 1456266].
Juric H, Dukic W, Jankovic B, Karlovic Z, Pavelic B. Suppression of salivary Streptococcus mutans and lactobacilli by topical caries preventive agents. Cent Eur J Public Health. 2003;11(4):219-222. Exclusion code: 8. [pmid: 14768786].
Kaakko T, Skaret E, Getz T, et al. An ABCD program to increase access to dental care for children enrolled in Medicaid in a rural county. J Public Health Dent. 2002;62(1):45-50. Exclusion code: 2. [pmid: 14700089].
Källestål C. Evaluation of caries preventive, measures. Swed Dent J. 2000;24(1-2):1-11. Exclusion code: 5. [pmid: 10997757].
Kandelman D, Bar A, Hefti A. Collaborative WHO xylitol field study in French Polynesia. I. Baseline prevalence and 32-month caries increment. Caries Res. 1988;22(1):55-62. Exclusion code: 3. [pmid: 3422062].
Kandelman D, Gagnon G. Clinical results after 12 months from a study of the incidence and progression of dental caries in relation to consumption of chewing-gum containing xylitol in school preventive programs. J Dent Res. 1987;66(8):1407-1411. Exclusion code: 3. [pmid: 3476611].
Kawashita Y, Fukuda H, Kawasaki K, et al. Pediatrician-recommended use of sports drinks and dental caries in 3-year-old children. Community Dent Health. 2011;28(1):29-33. Exclusion code: 8. [pmid: 21485231].
Kawashita Y, Kitamura M, Saito T. Early childhood caries. Int J Dent. 2011;2011:725320. Exclusion code: 2. [pmid: 22007218].
Kay E, Locker D. A systematic review of the effectiveness of health promotion aimed at improving oral health. Community Dent Health. 1998;15(3):132-144. Exclusion code: 11. [pmid: 10645682].
Kay EJ, Locker D. Is dental health education effective? A systematic review of current evidence. Community Dent Oral Epidemiol. 1996;24(4):231-235. Exclusion code: 11. [pmid: 8871028].
Kebriaei A, Rothe V, Pitner S, Balluff M, Salama F. Effectiveness of a basic training presentation on infant oral health care for pediatric medicine residents. J Clin Pediatr Dent. 2008;33(2):143-146. Exclusion code: 3. [pmid: 19358382].
Kertesz P, Schuder L, Szoke J, et al. 3 years' results of the WHO xylitol caries-preventing program in Hungarian children's homes. VI. Changes in the carbohydrate-protein ratio in dental plaque. Fogorv Sz. 1988;81(2):33-37. Exclusion code: 7. [pmid: 3268440].
Khambanonda S, Chandravejjsmarn R, Barmes DE, Sardo Infirri J, Moller I. Prevention of dental caries in Thailand: 3 fluoridated products submitted for comparative tests. J Biol Buccale. 1983;11(3):255-263. Exclusion code: 7. [pmid: 6581163].
Kobayashi M, Chi D, Coldwell SE, Domoto P, Milgrom P. The effectiveness and estimated costs of the access to baby and child dentistry program in Washington State. J Am Dent Assoc. 2005;136(9):1257-1263. Exclusion code: 3. [pmid: 16196230].
Kopycka-Kedzierawski DT, Bell CH, Billings RJ. Prevalence of dental caries in Early Head Start children as diagnosed using teledentistry. Pediatr Dent. 2008;30(4):329-333. Exclusion code: 4. [pmid: 18767513].
Kopycka-Kedzierawski DT, Billings RJ. Teledentistry in inner-city child-care centres. J Telemed Telecare. 2006;12(4):176-181. Exclusion code: 4. [pmid: 16774697].
Kopycka-Kedzierawski DT, Billings RJ. Prevalence of dental caries and dental care utilisation in preschool urban children enrolled in a comparative-effectiveness study. European Archives of Paediatric Dentistry : Official Journal of the European Academy of Paediatric Dentistry. 2011;12(3):133-138. Exclusion code: 2. [pmid: 21640057].
Kopycka-Kedzierawski DT, Billings RJ, McConnochie KM. Dental screening of preschool children using teledentistry: a feasibility study. Pediatr Dent. 2007;29(3):209-213. Exclusion code: 2. [pmid: 17688017].
Kowash MB, Pinfield A, Smith J, Curzon ME. Effectiveness on oral health of a long-term health education programme for mothers with young children. Br Dent J. 2000;188(4):201-205. Exclusion code: 9. [pmid: 10740903].
Kramer PF, Ardenghi TM, Ferreira S, Fischer LDA, Cardoso L, Feldens CA. Use of dental services by preschool children in Canela, Rio Grande do Sul State, Brazil. Utilização de serviços odontológicos por crianças de 0 a 5 anos de idade no Município de Canela, Rio Grande do Sul, Brasil. 2008;24(1):150-156. Exclusion code: 7. [pmid: 18209843].
Kranz AM, Rozier RG, Zeldin LP, Preisser JS. Oral health activities of early Head Start teachers directed toward children and parents. J Public Health Dent. 2011;71(2):161-169. Exclusion code: 9. [pmid: 21774140].
Kruger E, Dyson K, Tennant M. Pre-school child oral health in rural Western Australia. Aust Dent J. 2005;50(4):258-262. Exclusion code: 8. [pmid: 17016892].
Kumar J, Swango P, Haley V, Green E. Intra-oral distribution of dental fluorosis in Newburgh and Kingston, New York. J Dent Res. 2000;79(7):1508-1513. Exclusion code: 4. [pmid: 11005736].
Kuthy RA, McTigue DJ. Fluoride prescription practices of Ohio physicians. J Public Health Dent. 1987;47(4):172-176. Exclusion code: 11. [pmid: 3478487].
Kutsch VK, Young DA. New directions in the etiology of dental caries disease. J Calif Dent Assoc. 2011;39(10):716-721. Exclusion code: 5. [pmid: 22132583].
Lam M, Riedy CA, Coldwell SE, Milgrom P, Craig R. Children's acceptance of xylitol-based foods. Community Dent Oral Epidemiol. 2000;28(2):97-101. Exclusion code: 8. [pmid: 10730717].
Lave JR, Keane CR, Lin CJ, Ricci EM. The impact of dental benefits on the utilization of dental services by low-income children in western Pennsylvania. Pediatr Dent. 2002;24(3):234-240. Exclusion code: 2. [pmid: 12064498].
Law V, Seow WK. A longitudinal controlled study of factors associated with mutans streptococci infection and caries lesion initiation in children 21 to 72 months old. Pediatr Dent. 2006;28(1):58-65. Exclusion code: 4. [pmid: 16615377].
Law V, Seow WK. A longitudinal study of 0.2% chlorhexidine gel for removal of mutans streptococci infection in preschool children. Aust Dent J. 2007;52(1):26-32. Exclusion code: 8. [pmid: 17500161].
Lawrence A. Dental health educators in general practice have small impact. Evidence-Based Dentistry. 2004;5(1):15. Exclusion code: 5. [pmid: 15238970].
Lee B, Sue D. Xylitol for prevention of dental caries. Dicp. 1989;23(9):691-692. Exclusion code: 5. [pmid: 2800584].
Lee JY, Bouwens TJ, Savage MF, Vann WF Jr. Examining the cost-effectiveness of early dental visits. Pediatr Dent. 2006;28(2):102-105. Exclusion code: 4. [pmid: 16708783].
Lepore LM, Yoon RK, Chinn CH, Chussid S. Evaluation of behavior change goal-setting action plan on oral health activity and status. N Y State Dent J. 2011;77(6):43-47. Exclusion code: 9. [pmid: 22338818].
Levy SM. Systemic fluoride supplementation in an academic family practice setting. J Fam Pract. 1987;24(5):532. 534. 536. Exclusion code: 11. [pmid: 3572325].
Levy SM, Kiritsy MC, Slager SL, Warren JJ. Patterns of dietary fluoride supplement use during infancy. J Public Health Dent. 1998;58(3):228-233. Exclusion code: 11. [pmid: 10101699].
Lewis CW, Boulter S, Keels MA, et al. Oral health and pediatricians: results of a national survey. Acad Pediatr. 2009;9(6):457-461. Exclusion code: 2. [pmid: 19945080].
Lewis CW, Grossman DC, Domoto PK, Deyo RA. The role of the pediatrician in the oral health of children: A national survey. Pediatrics. 2000;106(6):E84. Exclusion code: 11. [pmid: 11099627].
Liao CC, Ganz ML, Jiang H, Chelmow T. The impact of the public insurance expansions on children's use of preventive dental care. Matern Child Health J. 2010;14(1):58-66. Exclusion code: 2. [pmid: 19067137].
Lin DL, Harrison R, Aleksejuniene J. Can a prenatal dental public health program make a difference?. J Can Dent Assoc. 2011;77:b32. Exclusion code: 4. [pmid: 21507285].
Lin YTJ, Tsai CL. Comparative Anti-Caries Effects of Tablet and Liquid Fluorides in Cleft Children. J Clin Dent. 2000;11(4):104-106. Exclusion code: 11. [pmid: 11460274].
Liu J, Probst JC, Martin AB, Wang JY, Salinas CF. Disparities in dental insurance coverage and dental care among US children: the National Survey of Children's Health. Pediatrics. Suppl 1. 2007;119:S12-21. Exclusion code: 2. [pmid: 17272579].
Liu M, Zhu L, Zhang B, Petersen PE. Changing use and knowledge of fluoride toothpaste by schoolchildren, parents and schoolteachers in Beijing, China. Int Dent J. 2007;57(3):187-194. Exclusion code: 8. [pmid: 17695741].
Loesche WJ, Grossman NS, Earnest R, Corpron R. The effect of chewing xylitol gum on the plaque and saliva levels of Streptococcus mutans. The Journal of the American Dental Association. 1984;108(4):587-592. Exclusion code: 3. [pmid: 6427315].
Loftus R. Advancing the practice of dental disease management. J Calif Dent Assoc. 2011;39(10):701-708. Exclusion code: 5.
Ly KA, Milgrom P, Rothen M. The potential of dental-protective chewing gum in oral health interventions. J Am Dent Assoc. 2008;139(5):553-563. Exclusion code: 2. [pmid: 18451371].
Lynch H, Milgrom P. Xylitol and dental caries: an overview for clinicians. J Calif Dent Assoc. 2003;31(3):205-209. Exclusion code: 2. [pmid: 12693818].
Machiulskiene V, Nyvad B, Baelum V. Caries preventive effect of sugar-substituted chewing gum. Community Dent Oral Epidemiol. 2001;29(4):278-288. Exclusion code: 3. [pmid: 11515642].
Machiulskiene V, Nyvad B, Baelum V. Determinants of dropout in a community intervention trial on the caries-preventive effect of chewing gums. J Public Health Dent. 2002;62(1):21-27. Exclusion code: 3. [pmid: 14700085].
MacRitchie HM, Longbottom C, Robertson M, et al. Development of the Dundee Caries Risk Assessment Model (DCRAM)--risk model development using a novel application of CHAID analysis. Community Dent Oral Epidemiol. 2012;40(1):37-45. Exclusion code: 2. [pmid: 21838824].
Maguire A, Rugg-Gunn AJ. Xylitol and caries prevention--is it a magic bullet?. Br Dent J. 2003;194(8):429-436. Exclusion code: 2. [pmid: 12778091].
Makinen KK. Biochemical principles of the use of xylitol in medicine and nutrition with special consideration of dental aspects. Experientia Suppl. 1978;(30):1-160. Exclusion code: 5. [pmid: 357173].
Makinen KK, Chen CY, Makinen PL, et al. Properties of whole saliva and dental plaque in relation to 40-month consumption of chewing gums containing xylitol, sorbitol of sucrose. Caries Res. 1996;30(3):180-188. Exclusion code: 3. [pmid: 8860027].
Makinen KK, Chiego DJ Jr., Allen P, et al. Physical, chemical, and histologic changes in dentin caries lesions of primary teeth induced by regular use of polyol chewing gums. Acta Odontol Scand. 1998;56(3):148-156. Exclusion code: 3. [pmid: 9688223].
Makinen KK, Hujoel PP, Bennett CA, et al. A descriptive report of the effects of a 16-month xylitol chewing-gum programme subsequent to a 40-month sucrose gum programme. Caries Res. 1998;32(2):107-112. Exclusion code: 3. [pmid: 9544858].
Makinen KK, Hujoel PP, Bennett CA, Isotupa KP, Makinen PL, Allen P. Polyol chewing gums and caries rates in primary dentition: a 24-month cohort study. Caries Res. 1996;30(6):408-417. Exclusion code: 3. [pmid: 8946097].
Makinen KK, Isotupa KP, Makinen PL, et al. Six-month polyol chewing-gum programme in kindergarten-age children: a feasibility study focusing on mutans streptococci and dental plaque. Int Dent J. 2005;55(2):81-88. Exclusion code: 8. [pmid: 15880962].
Makinen KK, Makinen PL, Pape HR Jr., et al. Stabilisation of rampant caries: polyol gums and arrest of dentine caries in two long-term cohort studies in young subjects. Int Dent J. 1995;45(1 Suppl 1):93-107. Exclusion code: 3. [pmid: 7607749].
Makinen KK, Scheinin A. Turku sugar studies. II. Preliminary biochemical and general findings. Acta Odontol Scand. 1974;32(6):413-421. Exclusion code: 5. [pmid: 4533573].
Makinen KK, Scheinin A. Turku sugar studies. VI. The administration of the trial and the control of the dietary regimen. Acta Odontol Scand. 1976;34(4):217-239. Exclusion code: 3. [pmid: 795261].
Makinen KK, Soderling E, Hurttia H, Lehtonen OP, Luukkala E. Biochemical, microbiologic, and clinical comparisons between two dentifrices that contain different mixtures of sugar alcohols. The Journal of the American Dental Association. 1985;111(5):745-751. Exclusion code: 3. [pmid: 3905908].
Makinen KK, Soderling E, Isokangas P, Tenovuo J, Tiekso J. Oral biochemical status and depression of Streptococcus mutans in children during 24- to 36-month use of xylitol chewing gum. Caries Res. 1989;23(4):261-267. Exclusion code: 3. [pmid: 2790861].
Makinen KK, Tenovuo J, Scheinin A. Xylitol-induced increase of lactoperoxidase activity. J Dent Res. 1976;55(4):652-660. Exclusion code: 8. [pmid: 777061].
Malcheff S, Pink TC, Sohn W, Inglehart MR, Briskie D. Infant oral health examinations: Pediatric dentists' professional behavior and attitudes. Pediatr Dent. 2009;31(3):202-209. Exclusion code: 3. [pmid: 19552224].
Mamber E. Baby clinic: a comprehensive project to promote oral health in expecting mothers and their babies. Alpha Omegan. 2004;97(3):33-34. Exclusion code: 5. [pmid: 15641758].
Mandel ID. Caries Prevention: Current Strategies, New Directions. J Am Dent Assoc. 1996;127(10):1477-1488. Exclusion code: 5. [pmid: 8908917].
Marcucci M, Bandettini MV, Panattoni E, Nucci N, Patane F. Sugar substitutes and dental caries. Prev Stomatol. 1984;10(1):9-25. Exclusion code: 7. [pmid: 6382242].
Margolis FJ, Burt BA, Schork MA, Bashshur RL, Whittaker BA, Burns TL. Fluoride supplements for children. A survey of physicians' prescription practices. Am J Dis Child. 1980;134(9):865-868. Exclusion code: 11. [pmid: 7416113].
Margolis FJ, Chesney BK, Schork A. Fluoride supplements. Changes in physicians' attitudes and practices following an intensive, multifaceted educational program. Am J Dis Child. 1987;141(1):72-76. Exclusion code: 11. [pmid: 3788885].
Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967;113(6):670-672. Exclusion code: 11. [pmid: 4381737].
Margolis FJ, Reames HR, Freshman E, MaCauley CD, Mehaffey H. Flouride. Ten-year prospective study of deciduous and permanent dentition. American Journal of Diseases of Children. 1975;129(7):794-800. Exclusion code: 2. [pmid: 1096595].
Marinho CV, Higgins PJ, Logan S, Sheiham A. Topical fluoride (toothpastes, mouthrinses, gels or varnishes) for preventing dental caries in children and adolescents [Systematic Review]. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 3. [pmid: 14583954].
Marinho CV, Higgins PJ, Logan S, Sheiham A. Fluoride mouthrinses for preventing dental caries in children and adolescents [Systematic Review]. Cochrane Database Syst Rev. 2009;(4). Exclusion code: 3. [pmid: 12917928].
Marinho CV, Higgins PJ, Logan S, Sheiham A. Fluoride gels for preventing dental caries in children and adolescents [Systematic Review]. Cochrane Database Syst Rev. 2009;(4). Exclusion code: 3. [pmid: 12076446].
Marinho CV, Higgins PJ, Sheiham A, Logan S. One topical fluoride (toothpastes, or mouthrinses, or gels, or varnishes) versus another for preventing dental caries in children and adolescents [Systematic Review]. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 3. [pmid: 14583954].
Marinho CV, Higgins PJ, Sheiham A, Logan S. Combinations of topical fluoride (toothpastes, mouthrinses, gels, varnishes) versus single topical fluoride for preventing dental caries in children and adolescents [Systematic Review]. Cochrane Database Syst Rev. 2009;(1). Exclusion code: 3. [pmid: 14973992].
Marinho VC, Higgins JP, Logan S, Sheiham A. Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews (Online). 2002;(3). Exclusion code: 3. [pmid: 12137653].
Marinho VC, Higgins JP, Logan S, Sheiham A. Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews (Online). 2009. Exclusion code: 6. [pmid: 12137653].
Marshall TA, Levy SM, Broffitt B, et al. Dental caries and beverage consumption in young children. Pediatrics. 2003;112(3 Pt 1):e184-191. Exclusion code: 8. [pmid: 12949310].
Martin AB, Probst J, Wang JY, Hale N. Effect of having a personal healthcare provider on access to dental care among children. J Public Health Manag Pract. 2009;15(3):191-199. Exclusion code: 2. [pmid: 19363398].
Massoth D, Massoth G, Massoth IR, et al. The effect of xylitol on Streptococcus mutans in children. J Calif Dent Assoc. 2006;34(3):231-234. Exclusion code: 3. [pmid: 16895079].
McCunniff MD, Damiano PC, Kanellis MJ, Levy SM. The impact of WIC dental screenings and referrals on utilization of dental services among low-income children. Pediatr Dent. 1998;20(3):181-187. Exclusion code: 11. [pmid: 9635314].
McDonagh MS, Whiting PF, Wilson PM, et al. Systematic review of water fluoridation. BMJ. 2000;321(7265):855-859. Exclusion code: 11. [pmid: 11021861].
Messimer S, Hickner J. Oral fluoride supplementation: improving practitioner compliance by using a protocol. J Fam Pract. 1983;17(5):821-825. Exclusion code: 11. [pmid: 6631346].
Meurman P, Merilainen L, Pienihakkinen K, Alanen P, Trahan L, Soderling E. Xylitol-resistant mutans streptococci strains and the frequency of xylitol consumption in young children. Acta Odontol Scand. 2005;63(5):314-316. Exclusion code: 8. [pmid: 16419438].
Meurman P, Pienihakkinen K, Eriksson AL, Alanen P. Oral health programme for preschool children: a prospective, controlled study. Int J Paediatr Dent. 2009;19(4):263-273. Exclusion code: 4. [pmid: 19320915].
Meyer K, Geurtsen W, Gunay H. An early oral health care program starting during pregnancy: results of a prospective clinical long-term study. Clin Oral Investig. 2010;14(3):257-264. Exclusion code: 3. [pmid: 19543927].
Milgrom P, Chi DL. Prevention-centered caries management strategies during critical periods in early childhood. J Calif Dent Assoc. 2011;39(10):735-741. Exclusion code: 2. [pmid: 22132585].
Milgrom P, Tut OK. Evaluation of Pacific Islands Early Childhood Caries Prevention Project: Republic of the Marshall Islands. J Public Health Dent. 2009;69(3):201-203. Exclusion code: 3. [pmid: 19486466].
Milgrom P, Weinstein P, Huebner C, Graves J, Tut O. Empowering Head Start to improve access to good oral health for children from low income families. Matern Child health. 2011;15:876-882. Exclusion code: 8. [pmid: 18246416].
Milgrom P, Zero DT, Tanzer JM. An examination of the advances in science and technology of prevention of tooth decay in young children since the Surgeon General's Report on Oral Health. Acad Pediatr. 2009;9(6):404-409. Exclusion code: 2. [pmid: 19837019].
Minah G, Lin C, Coors S, Rambob I, Tinanoff N, Grossman LK. Evaluation of an early childhood caries prevention program at an urban pediatric clinic. Pediatr Dent. 2008;30(6):499-504. Exclusion code: 4. [pmid: 19186776].
Mofidi M, Slifkin R, Freeman V, Silberman P. The impact of a state children's health insurance program on access to dental care. J Am Dent Assoc. 2002;133(6):707-714. quiz 767-708. Exclusion code: 2. [pmid: 12083646].
Mohebbi SZ, Virtanen JI, Vahid-Golpayegani M, Vehkalahti MM. A cluster randomised trial of effectiveness of educational intervention in primary health care on early childhood caries. Caries Res. 2009;43(2):110-118. Exclusion code: 4. [pmid: 19321988].
Mouradian WE, Wehr E, Crall JJ. Disparities in children's oral health and access to dental care. Journal of the American Medical Association. 2000;284(20):2625-2631. Exclusion code: 2. [pmid: 11086371].
Nagarkar S, Kumar J, Moss M. Early childhood caries-related visits to emergency departments and ambulatory surgery facilities and associated charges in New York state. JADA. 2012;143:59-65. Exclusion code: 4. [pmid: 22207670].
Nakai Y, Shinga-Ishihara C, Kaji M, Moriya K, Murakami-Yamanaka K, Takimura M. Xylitol gum and maternal transmission of mutans streptococci. J Dent Res. 2010;89(1):56-60. Exclusion code: 3. [pmid: 19948944].
National Center for Health Statistics. Healthy People 2010 Final Review. Healthy People. 2010. Exclusion code: 2.
Newburn E. The potential role of alternative sweeteners in caries prevention. Isr J Dent Sci. 1991;2(4):200-213. Exclusion code: 5. [pmid: 1958328].
Nietert PJ, Bradford WD, Kaste LM. The impact of an innovative reform to the South Carolina dental medicaid system. Health Serv Res. 2005;40(4):1078-1091. Exclusion code: 2. [pmid: 16033493].
Nord A, Haugejorden O. Two-year trial of the fluoride-containing varnishes Duraphat and Carex. Nor Tannlaegeforen Tid. 1991;101(2):46-49. Exclusion code: 7. [pmid: 1861962].
Nordblad A, Suominen-Taipale L, Murtomaa H, Vartiainen E, Koskela K. Smart Habit Xylitol campaign, a new approach in oral health promotion. Community Dent Health. 1995;12(4):230-234. Exclusion code: 3. [pmid: 8536087].
North Carolina Department of Health and Human Services. Medical Providers: Partner with us to improve your child patients' oral health. Into the Mouths of Babes. 2012. http://www.ncdhhs.gov/dph/oralhealth/partners/IMB.htm. 20 Feb, 2013. Exclusion code: 5.
Nowak AJ, PS, C. Using anticipatory guidance in pediatric dentistry: a developmentally paced prevention philosophy. JADA. 1995;126:1156-1164. Exclusion code: 5. [pmid: 7560574].
Ogard B, Seppä L, Rølla G. Professional topical fluoride applications--clinical efficacy and mechanism of action. Adv Dent Res. 1994;8(2):190-201. Exclusion code: 8. [pmid: 7865075].
Okunseri C, Szabo A, Jackson S, Pajewski NM, Garcia RI. Increased children's access to fluoride varnish treatment by involving medical care providers: effect of a Medicaid policy change. Health Serv Res. 2009;44(4):1144-1156. Exclusion code: 2. [pmid: 19453390].
Oliveira M, Paiva S, Martins L, Ramos-Jorge M, Lima Y, Cury J. Fluoride intake by children at risk for the development of dental fluorosis: comparison of regular dentifrices and flavoured dentifrices for children. Caries Res. 2007;41(6):460-466. Exclusion code: 8. [pmid: 17823508].
O'Rourke CA, Attrill M, Holloway PJ. Cost appraisal of a fluoride tablet programme to Manchester primary schoolchildren. Community Dentistry and Oral Epidemiology. 1988;16(6):341-344. Exclusion code: 8. [pmid: 3144446].
Pahel BT, Rozier RG, Stearns SC, Q RB. Effectiveness of preventive dental treatments by physicians for young Medicaid enrollees. Pediatrics. 2011;127(3):e682-689. Exclusion code: 5. [pmid: 21357343].
Passson C. Xylitol: a sugar that fights tooth decay. J Colo Dent Assoc. 1993;71(3):19-23. Exclusion code: 5. [pmid: 8408742].
Peldyak J, Makinen KK. Xylitol for caries prevention. J Dent Hyg. 2002;76(4):276-285. Exclusion code: 2. [pmid: 12592919].
Pendrys DG. The fluorosis risk index: a method for investigating risk factors. J Public Health Dent. 1990;50(5):291-298. Exclusion code: 8. [pmid: 2231522].
Pendrys DG. Risk of enamel fluorosis in nonfluoridated and optimally fluoridated populations: considerations for the dental professional. J Am Dent Assoc. 2000;131(6):746-755. Exclusion code: 11. [pmid: 10860326].
Pendrys DG, Katz RV. Risk factors for enamel fluorosis in optimally fluoridated children born after the US manufacturers' decision to reduce the fluoride concentration of infant formula. Am J Epidemiol. 1998;148(10):967-974. Exclusion code: 8. [pmid: 9829868].
Pereira AC, Da Cunha FL, Meneghim MDC, Werner CW. Dental caries and fluorosis prevalence study in a nonfluoridated Brazilian community: Trend analysis and toothpaste association. J Dent Child. 2000;67(2):132-135. Exclusion code: 3. [pmid: 10826050].
Peretz B, Gluck G. Early childhood caries (ECC): a preventive-conservative treatment mode during a 12-month period. J Clin Pediatr Dent. 2006;30(3):191-194. Exclusion code: 3. [pmid: 16683664].
Petersson LG, Arthursson L, Ostberg C, Jonsson G, Gleerup A. Caries-inhibiting effects of different modes of duraphate varnish reapplication: A 3-year radiographic study. Caries Res. 1991;25(1):70-73. Exclusion code: 3. [pmid: 2070384].
Petersson LG, Birkhed D, Gleerup A, Johansson M, Jonsson G. Caries-preventive effect of dentifrices containing various types and concentrations of fluorides and sugar alcohols. Caries Res. 1991;25(1):74-79. Exclusion code: 3. [pmid: 2070385].
Petersson LG, Twetman S, Pakhomov GN. The efficiency of semiannual silane fluoride varnish applications: A two-year clinical study in preschool children. J Public Health Dent. 1998;58(1):57-60. Exclusion code: 11. [pmid: 9608447].
Peyron M, Matsson L, Birkhed D. Progression of approximal caries in primary molars and the effect of Duraphat treatment. Scand J Dent Res. 1992;100(6):314-318. Exclusion code: 8. [pmid: 1465563].
Pickett FA. Nonfluoride caries-preventive agents: new guidelines. J Contemp Dent Pract. 2011;12(6):469-474. Exclusion code: 2. [pmid: 22269228].
Pienihakkinen K, Jokela J. Clinical outcomes of risk-based caries prevention in preschool-aged children. Community Dent Oral Epidemiol. 2002;30(2):143-150. Exclusion code: 2. [pmid: 12000355].
Pienihäkkinen K, Jokela J, Alanen P. Assessment of Caries Risk in Preschool Children. Caries Res. 2004;38(2):156-162. Exclusion code: 4. [pmid: 14767173].
Pinkerton RE, Tinanoff N, Willms JL, Tapp JT. Resident physician performance in a continuing education format. Does newly acquired knowledge improve patient care?. JAMA. 1980;244(19):2183-2185. Exclusion code: 11. [pmid: 7420722].
Pita-Fernández S, Pombo-Sánchez A, Suárez-Quintanilla J, Novio-Mallón S, Rivas-Mundiña B, Pértega-Díaz S. Clinical relevance of tooth brushing in relation to dental caries. Relevancia clínica del cepillado dental y su relación con la caries. 2010;42(7):372-379. Exclusion code: 7. [pmid: 20116887].
Pitts NB, Boyles J, Nugent ZJ, Thomas N, Pine CM. The dental caries experience of 5-year-old children in Great Britain (2005/6). Surveys co-ordinated by the British Association for the study of community dentistry. Community Dent Health. 2007;24(1):59-63. Exclusion code: 8. [pmid: 17405473].
Plonka KA, Pukallus ML, Barnett A, Holcombe TF, Walsh LJ, Seow WK. A controlled, longitudinal study of home visits compared to telephone contacts to prevent early childhood caries. Int J Paediatr Dent. 2012. Exclusion code: 4. [pmid: 22251427].
Plotzitza B, Kneist S, Berger J, Hetzer G. Efficacy of chlorhexidine varnish applications in the prevention of early childhood caries. European Journal of Paediatric Dentistry: Official Journal of European Academy of Paediatric Dentistry. 2005;6(3):149-154. Exclusion code: 8. [pmid: 16216096].
Plutzer K, Keirse MJNC. Incidence and prevention of early childhood caries in one- and two-parent families. Child Care Health Dev. 2011;37(1):5-10. Exclusion code: 3. [pmid: 20533911].
Plutzer K, Spencer AJ. Efficacy of an oral health promotion intervention in the prevention of early childhood caries. Community Dent Oral Epidemiol. 2008;36(4):335-346. Exclusion code: 3. [pmid: 19145720].
Plutzer K, Spencer AJ, Keirse MJNC. Reassessment at 6-7 years of age of a randomized controlled trial initiated before birth to prevent early childhood caries. Community Dent Oral Epidemiol. 2012;40(2):116-124. Exclusion code: 4. [pmid: 22022927].
Poulsen S, Gadegaard E, Mortensen B. Cariostatic effect of daily use of a fluoride-containing lozenge compared to fortnightly rinses with 0.2% sodium fluoride. Caries Res. 1981;15(3):236-242. Exclusion code: 3. [pmid: 6938308].
Prakash P, Lawrence HP, Harvey BJ, McIsaac WJ, Limeback H, Leake JL. Early childhood caries and infant oral health: Paediatricians' and family physicians' knowledge, practices and training. Paediatrics and Child Health. 2006;11(3):151-157. Exclusion code: 3. [pmid: 19030271].
Pukallus ML, Plonka KA, Barnett AG, Walsh LJ, Holcombes TF, Kim Seow W. A randomised, controlled clinical trial comparing chlorhexidine gel and low-dose fluoride toothpaste to prevent early childhood caries. Int J Paediatr Dent. 2012. (Epub). Exclusion code: 4. [pmid: 22713081].
Raitio M, Mottonen M, Uhari M. Toothbrushing and the occurrence of salivary mutans streptococci children at day care centers. Caries Res. 1995;29(4):280-284. Exclusion code: 4. [pmid: 7656297].
Raitio M, Pienihäkkinen K, Scheinin A. Multifactorial modeling for prediction of caries increment in adolescents. Acta Odontol Scand. 1996;54(2):118-121. Exclusion code: 3. [pmid: 8739144].
Ramirez JH, Arce R, Contreras A. Why must physicians know about oral diseases?. Teaching and Learning in Medicine. 2010;22(2):148-155. Exclusion code: 2. [pmid: 20614382].
Ramos-Gomez F, Crystal YO, Ng MW, Tinanoff N, Featherstone JD. Caries risk assessment, prevention, and management in pediatric dental care. Gen Dent. 2010;58(6):505-517. quiz 518-509. Exclusion code: 5. [pmid: 21062720].
Ramos-Gomez F, Ng MW. Into the future: keeping healthy teeth caries free: pediatric CAMBRA protocols. J Calif Dent Assoc. 2011;39(10):723-733. Exclusion code: 3. [pmid: 22132584].
Ramos-Gomez FJ, Crall J, Gansky SA, Slayton RL, Featherstone JDB. Caries risk assessment appropriate for the age 1 visit (infants and toddlers). J Calif Dent Assoc. 2007;35(10):687-702. Exclusion code: 5. [pmid: 18044377].
Ramos-Gomez FJ, Crystal YO, Ng MW, Crall JJ, Featherstone JDB. Pediatric dental care: prevention and management protocols based on caries risk assessment. [Erratum appears in J Calif Dent Assoc. 2010 Nov;38(11):790]. J Calif Dent Assoc. 2010;38(10):746-761. Exclusion code: 5. [pmid: 21162350].
Ramos-Gomez FJ, Gansky SA, Featherstone JDB, et al. Mother and youth access (MAYA) maternal chlorhexidine, counselling and paediatric fluoride varnish randomized clinical trial to prevent early childhood caries. Int J Paediatr Dent. 2012;22(3):169-179. Exclusion code: 4. [pmid: 21999806].
Ramseier CA, Leiggener I, Lang NP, Bagramian RA, Inglehart MR. Short-term effects of hygiene education for preschool (kindergarten) children: a clinical study. Oral Health Prev. 2007;5(1):19-24. Exclusion code: 9. [pmid: 17366757].
Rayner JA. A dental health education programme, including home visits, for nursery school children. Br Dent J. 1992;172(2):57-62. Exclusion code: 11. [pmid: 1739501].
Reich E, Lussi A, Newbrun E. Caries-risk assessment. Int Dent J. 1999;49(1):15-26. Exclusion code: 5. [pmid: 10887469].
Rethman MP, Beltran-Aguilar ED, Billings RJ, et al. Non-fluoride caries preventive agents: Full report of systematic review and evidence-based recommendations. 5/24/2011. 2011. Exclusion code: 2.
Rethman MP, Beltran-Aguilar ED, Billings RJ, et al. Nonfluoride caries-preventive agents: executive summary of evidence-based clinical recommendations. J Am Dent Assoc. 2011;142(9):1065-1071. Exclusion code: 2. [pmid: 21987836].
Ribelles Llop M, Guinot Jimeno F, Mayne Acien R, Bellet Dalmau LJ. Effects of xylitol chewing gum on salivary flow rate, pH, buffering capacity and presence of Streptococcus mutans in saliva. Eur J Paediatr Dent. 2010;11(1):9-14. Exclusion code: 2. [pmid: 20359274].
Richardson AS. Parental participation in the administration of fluoride supplements. Can J Public Health. 1967;58(11):508-513. Exclusion code: 11. [pmid: 6077085].
Rigilano JC, Friedler EM, Ehemann LJ. Fluoride prescribing patterns among primary care physicians. J Fam Pract. 1985;21(5):381-385. Exclusion code: 11. [pmid: 4056672].
Riordan PJ. Dental fluorosis decline after changes to supplement and toothpaste regimens. Community Dentistry and Oral Epidemiology. 2002;30(3):233-240. Exclusion code: 4. [pmid: 12000347].
Roberts MW. Dental health of children: Where we are today and remaining challenges. J Clin Pediatr Dent. 2008;32(3):231-234. Exclusion code: 2. [pmid: 18524274].
Roberts MW, Keels MA, Sharp MC, Lewis JL Jr. Fluoride supplement prescribing and dental referral patterns among academic pediatricians. Pediatrics. 1998;101(1):E6. Exclusion code: 11. [pmid: 9417170].
Roeters FJ, Verdonschot EH, Bronkhorst EM, van 't Hof MA. Prediction of the need for bitewing radiography in detecting caries in the primary dentition. Community Dentistry and Oral Epidemiology. 1994;22(6):456-460. Exclusion code: 8. [pmid: 7882663].
Rosenblatt A, Stamford TCM, Niederman R. Silver diamine fluoride: A caries “silver-fluoride bullet”. J Dent Res. 2009;88(2):116-125. Exclusion code: 5. [pmid: 19278981].
Rozier RG. The prevalence and severity of enamel fluorosis in North American children. J Public Health Dent. 1999;59(4):239-246. Exclusion code: 11. [pmid: 10682330].
Rozier RG. Effectiveness of methods used by dental professionals for the primary prevention of dental caries. J Dent Educ. 2001;65(10):1063-1072. Exclusion code: 11. [pmid: 11699978].
Rozier RG, Adair S, Graham F, et al. Evidence-based clinical recommendations on the prescription of dietary fluoride supplements for caries prevention: a report of the American Dental Association Council on Scientific Affairs. J Am Dent Assoc. 2010;141(12):1480-1489. Exclusion code: 2. [pmid: 21158195].
Rozier RG, Slade GD, Zeldin LP, Wang H. Parents' satisfaction with preventive dental care for young children provided by nondental primary care providers. Pediatr Dent. 2005;27(4):313-322. Exclusion code: 8. [pmid: 16317972].
Sabbagh H, El-Kateb M, Al Nowaiser A, Hanno A, Alamoudi N. Assessment of pediatricians dental knowledge, attitude and behavior in Jeddah, Saudi Arabia. J Clin Pediatr Dent. 2011;35(4):371-376. Exclusion code: 3. [pmid: 22046694].
Sakuma S, Nakamura M, Miyazaki H. Predictors of dental caries development in 1.5-year-old high-risk children in the Japanese public health service. J Public Health Dent. 2007;67(1):14-19. Exclusion code: 10. [pmid: 17436974].
Scheie AA, Fejerskov OB. Xylitol in caries prevention: what is the evidence for clinical efficacy?. Oral Dis. 1998;4(4):268-278. Exclusion code: 2. [pmid: 10200706].
Scheinin A. Xylitol: an update. Recent studies, indications. Oral Health. 1981;71(8):43-47. Exclusion code: 2. [pmid: 6949112].
Scheinin A. Field studies on sugar substitutes. Int Dent J. 1985;35(3):195-200. Exclusion code: 3. [pmid: 3902660].
Scheinin A, Banoczy J. Collaborative WHO xylitol field studies in Hungary. An overview. Acta Odontol Scand. 1985;43(6):321-325. Exclusion code: 3. [pmid: 3867218].
Scheinin A, Banoczy J. Xylitol and caries: the collaborative WHO oral disease preventive programme in Hungary. Int Dent J. 1985;35(1):50-57. Exclusion code: 3. [pmid: 3858229].
Scheinin A, Banoczy J, Szoke J, et al. Collaborative WHO xylitol field studies in Hungary. I. Three-year caries activity in institutionalized children. Acta Odontol Scand. 1985;43(6):327-347. Exclusion code: 3. [pmid: 3879082].
Scheinin A, Makinen KK, Tammisalo E, Rekola M. Turku sugar studies. XVIII. Incidence of dental caries in relation to 1 year consumption of xylitol chewing gum. Acta Odontol Scand. 1975;33(5):269-278. Exclusion code: 5. [pmid: 1067728].
Scheinin A, Makinen KK, Ylitalo K. Turku sugar studies. I. An intermediate report on the effect of sucrose, fructose and xylitol diets on the caries incidence in man. Acta Odontol Scand. 1974;32(6):383-412. Exclusion code: 3. [pmid: 4156819].
Scheinin A, Makinen KK, Ylitalo K. Turku sugar studies. V. Final report on the effect of sucrose, fructose and xylitol diets on the caries incidence in man. Acta Odontol Scand. 1976;34(4):179-216. Exclusion code: 2. [pmid: 795260].
Scheinin A, Pienihakkinen K, Tiekso J, et al. Collaborative WHO xylitol field studies in Hungary. VII. Two-year caries incidence in 976 institutionalized children. Acta Odontol Scand. 1985;43(6):381-387. Exclusion code: 3. [pmid: 3879087].
Schinder E, Rosenberg M, Zangwill L. Educational approach to modifying dental habits in pre-school children. Review Association Odontologica Argentina. 1992;80(4). Exclusion code: 7.
Schröder U, Granath L. Dietary habits and oral hygiene as predictors of caries in 3-year-old children. Community Dentistry and Oral Epidemiology. 1983;11(5):308-311. Exclusion code: 8. [pmid: 6578900].
Schröder U, Widenheim J, Peyron M, Hägg E. Prediction of caries in 1 1/2-year-old children. Swed Dent J. 1994;18(3):95-104. Exclusion code: 8. [pmid: 8085221].
Schutze HJ Jr, Forrester DJ, Balis SB. Evaluation of a fluoride prophylaxis paste in a fluoridated community. Journal of the Canadian Dental Association. 1974;40(10):675-683. Exclusion code: 4. [pmid: 4154056].
Seale NS, Casamassimo PS. Access to dental care for children in the United States: a survey of general practitioners. J Am Dent Assoc. 2003;134(12):1630-1640. Exclusion code: 2. [pmid: 14719761].
Seale NS, Casamassimo PS. U.S. predoctoral education in pediatric dentistry: its impact on access to dental care. J Dent Educ. 2003;67(1):23-30. Exclusion code: 2. [pmid: 12540102].
Section on Pediatric Dentistry and Oral Health. Preventive oral health intervention for pediatricians. Pediatrics. 2008;122(6):1387-1394. Exclusion code: 2. [pmid: 19015205].
Selwitz RH, Ismail AI, Pitts NB. Dental caries. Lancet. 2007;369(9555):51-59. Exclusion code: 5. [pmid: 17208642].
Seow WK, Cheng E, Wan V. Effects of oral health education and tooth-brushing on mutans streptococci infection in young children. Pediatr Dent. 2003;25(3):223-228. Exclusion code: 8. [pmid: 12889697].
Seppa L, Hausen H, Karkkainen S. Plaque fluoride and mutans streptococci in plaque and saliva before and after discontinuation of water fluoridation. Eur J Oral Sci. 1996;104(4 ( Pt 1)):353-358. Exclusion code: 3. [pmid: 8930582].
Seppa L, Karkkainen S, Hausen H. Caries frequency in permanent teeth before and after discontinuation of water fluoridation in Kuopio, Finland. Community Dent Oral Epidemiol. 1998;26(4):256-262. Exclusion code: 3. [pmid: 9758426].
Seppä L, Leppänen T, Hausen H. Fluoride varnish versus acidulated phosphate fluoride gel: a 3-year clinical trial. Caries Res. 1995;29(5):327-330. Exclusion code: 3. [pmid: 8521431].
Serwint JR, Mungo R, Negrete VF, Duggan AK, Korsch BM. Child-rearing practices and nursing caries. Pediatrics. 1993;92(2 I):233-237. Exclusion code: 6. [pmid: 8337022].
Sgan-Cohen HD, Mansbach IK, Haver D, Gofin R. Community-oriented oral health promotion for infants in Jerusalem: evaluation of a program trial. J Public Health Dent. 2001;61(2):107-113. Exclusion code: 8. [pmid: 11474913].
Shiboski CH, Gansky SA, Ramos-Gomez F, Ngo L, Isman R, Pollick HF. The association of early childhood caries and race/ethnicity among California preschool children. [Erratum appears in J Public Health Dent. 2003 Fall;63(4):264]. J Public Health Dent. 2003;63(1):38-46. Exclusion code: 8. [pmid: 12597584].
Shivaprakash PK, Elango I, Baweja DK, Noorani HH. The state of infant oral healthcare knowledge and awareness: Disparity among parents and healthcare professionals. Journal of Indian Society of Pedodontics and Preventive Dentistry. 2009;27(1):39-43. Exclusion code: 3. [pmid: 19414973].
Siegel C, Gutgesell ME. Fluoride supplementation in Harris County, Texas. Am J Dis Child. 1982;136(1):61-63. Exclusion code: 11. [pmid: 7055110].
Silva PF, Forte FDS, Chaves AMBP, Farias IAP, Castro KS. Reproducibility of caries diagnosis in permanent teeth according to WHO, ICDAS-II and Nyvad criteria. Brazilian Journal of Oral Sciences. 2012;11(1):25-29. Exclusion code: 8.
Silva R, Mendes S, Bernardo M, Barros L. Dental caries related practices and knowledge of pediatricians and family doctors. Revista Portuguesa de Estomatologia, Medicina Dentaria e Cirurgia Maxilofacial. 2012;53(3):135-142. Exclusion code: 8.
Sintes JL, Elias-Boneta A, Stewart B, Volpe AR, Lovett J. Anticaries efficacy of a sodium monofluorophosphate dentifrice containing xylitol in a dicalcium phosphate dihydrate base. A 30-month caries clinical study in Costa Rica. Am J Dent. 2002;15(4):215-219. Exclusion code: 3. [pmid: 12572637].
Sintes JL, Escalante C, Stewart B, et al. Enhanced anticaries efficacy of a 0.243% sodium fluoride/10% xylitol/silica dentifrice: 3-year clinical results. Am J Dent. 1995;8(5):231-235. Exclusion code: 3. [pmid: 8634157].
Slade GD, Rozier RG, Zeldin LP, Margolis PA. Training pediatric health care providers in prevention of dental decay: results from a randomized controlled trial. BMC Health Serv Res. 2007;7:176. Exclusion code: 5. [pmid: 17980021].
Söderling E, Alaräisänen L, Scheinin A, Mäkinen KK. Effect of xylitol and sorbitol on polysaccharide production by and adhesive properties of Streptococcus mutans. Caries Res. 1987;21(2):109-116. Exclusion code: 3. [pmid: 3469026].
Soderling E, Isokangas P, Pienihakkinen K, Tenovuo J. Influence of maternal xylitol consumption on acquisition of mutans streptococci by infants. J Dent Res. 2000;79(3):882-887. Exclusion code: 3. [pmid: 10765964].
Soderling E, Scheinin A. Perspectives on xylitol-induced oral effects. Proc Finn Dent Soc. 1991;87(2):217-229. Exclusion code: 5. [pmid: 1896434].
Soderling EM. Xylitol, mutans streptococci, and dental plaque. Adv Dent Res. 2009;21(1):74-78. Exclusion code: 2. [pmid: 19717413].
Sohn W, Ismail AI, Tellez M. Efficacy of educational interventions targeting primary care providers' practice behaviors: an overview of published systematic reviews. J Public Health Dent. 2004;64(3):164-172. Exclusion code: 2. [pmid: 15341140].
Spittle B. Fluoride poisoning: Is fluoride from your drinking water and other sources making you sick?. International Society for Fluoride Research (New Zealand). 2012. Exclusion code: 5.
Splieth CH, Alkilzy M, Schmitt J, Berndt C, Welk A. Effect of xylitol and sorbitol on plaque acidogenesis. Quintessence Int. 2009;40(4):279-285. Exclusion code: 3. [pmid: 19417872].
Sprod AJ, Anderson R, Treasure ET. Effective oral health promotion: literature review. 1996. http://www.crd.york.ac.uk/crdweb/ShowRecord.asp?LinkFrom=OAI&ID=12000008300. Exclusion code: 11.
Stecksen-Blicks C, Holgerson PL, Twetman S. Effect of xylitol and xylitol-fluoride lozenges on approximal caries development in high-caries-risk children. Int J Paediatr Dent. 2008;18(3):170-177. Exclusion code: 3. [pmid: 18341562].
Stevens GD, Seid M, Tsai KY, West-Wright C, Cousineau MR. Improvements in access to care for vulnerable children in California between 2001 and 2005. Public Health Rep. 2009;124(5):682-691. Exclusion code: 2. [pmid: 19753946].
Stijacic T, Schroth RJ, Lawrence HP. Are Manitoba dentists aware of the recommendation for a first visit to the dentist by age 1 year?. Journal of the Canadian Dental Association. 903a. 2008;74(10):903-903h. Exclusion code: 8. [pmid: 19126358].
Strippel H. Effectiveness of structured comprehensive paediatric oral health education for parents of children less than two years of age in Germany. Community Dent Health. 2010;27(2):74-80. Exclusion code: 8. [pmid: 20648883].
Strohmenger L, Brambilla E. The use of fluoride varnishes in the prevention of dental caries: A short review. Oral Dis. 2001;7(2):71-80. Exclusion code: 5. [pmid: 11355442].
Suhonen J, Sener B, Bucher W, Lutz F. Release of preventive agents from pacifiers in vitro. An introduction to a novel preventive measure. Schweiz Monatsschr Zahnmed. 1994;104(8):946-951. Exclusion code: 8. [pmid: 8091173].
Svenson D, Bridges D. Xylitol: the sugar that prevents tooth decay. Dent Hyg (Chic). 1977;51(9):401. Exclusion code: 2. [pmid: 348510].
Szoke J, Esztari I, Pienihakkinen K, Banoczy J, Scheinin A. 3-year results of the WHO xylitol caries preventive program in Hungarian children's homes. Fogorv Sz. 1986;79(12):368-373. Exclusion code: 7. [pmid: 3466810].
Tabari ED, Ellwood R, Rugg-Gunn AJ, Evans DJ, Davies RM. Dental fluorosis in permanent incisor teeth in relation to water fluoridation, social deprivation and toothpaste use in infancy. Br Dent J. 2000;189(4):216-220. Exclusion code: 4. [pmid: 11036750].
Tanabe Y, Park JH, Tinanoff N, Turng BF, Lilli H, Minah GE. Comparison of chairside microbiological screening systems and conventional selective media in children with and without visible dental caries. Pediatr Dent. 2006;28(4):363-368. Exclusion code: 4. [pmid: 16903447].
Task Force on Community Preventive Services. Recommendations on selected interventions to prevent dental caries, oral and pharyngeal cancers, and sports-related craniofacial injuries. Am J Prev Med. 2002;23(1 Suppl):16-20. Exclusion code: 2. [pmid: 12091092].
Tavener JA, Davies GM, Davies RM, Ellwood RP. The prevalence and severity of fluorosis in children who received toothpaste containing either 440 or 1,450 ppm F from the age of 12 months in deprived and less deprived communities. Caries Res. 2006;40(1):66-72. Exclusion code: 4. [pmid: 16352884].
Tenovuo J, Hakkinen P, Paunio P, Emilson C. Effects of chlorhexidine-fluoride gel treatments in mothers on the establishment of mutans streptococci in primary teeth and the development of dental caries in children. Caries Res. 1992;26(4). Exclusion code: 3. [pmid: 1423442].
Thaweboon S, Thaweboon B, Soo-Ampon S. The effect of xylitol chewing gum on mutans streptococci in saliva and dental plaque. Southeast Asian J Trop Med Public Health. 2004;35(4):1024-1027. Exclusion code: 3. [pmid: 15916109].
Thomas S, Tandon S, Nair S. Effect of dental health education on the oral health status of a rural child population by involving target groups. Journal of the Indian Society of Pedodontics and Preventive Dentistry. 2000;18(3):115-125. Exclusion code: 3. [pmid: 11324201].
Thorild I, Lindau B, Twetman S. Effect of maternal use of chewing gums containing xylitol, chlorhexidine or fluoride on mutans streptococci colonization in the mothers' infant children. Oral Health Prev. 2003;1(1):53-57. Exclusion code: 3. [pmid: 15643749].
Thorild I, Lindau B, Twetman S. Salivary mutans streptococci and dental caries in three-year-old children after maternal exposure to chewing gums containing combinations of xylitol, sorbitol, chlorhexidine, and fluoride. Acta Odontol Scand. 2004;62(5):245-250. Exclusion code: 3. [pmid: 15841810].
Thorild I, Lindau B, Twetman S. Caries in 4-year-old children after maternal chewing of gums containing combinations of xylitol, sorbitol, chlorhexidine and fluoride. Eur Arch Paediatr Dent. 2006;7(4):241-245. Exclusion code: 3. [pmid: 17164069].
Tickle M. The 80:20 phenomenon: help or hindrance to planning caries prevention programmes?. Community Dent Health. 2002;19(1):39-42. Exclusion code: 8. [pmid: 11922411].
Tickle M, Milsom KM, Donaldson M, et al. Protocol for Northern Ireland Caries Prevention in Practice Trial (NIC-PIP) trial: a randomised controlled trial to measure the effects and costs of a dental caries prevention regime for young children attending primary care dental services. BMC Oral Health. 2011;11:27. Exclusion code: 5. [pmid: 21985746].
Tinanoff N. Dental caries risk assessment and prevention. Dent Clin North Am. 1995;39(4):709-719. Exclusion code: 5. [pmid: 8522039].
Tinanoff N, Kanellis MJ, Vargas CM. Current understanding of the epidemiology, mechanisms, and prevention of dental caries in preschool children. Pediatr Dent. 2002;24(6):543-551. Exclusion code: 5. [pmid: 12528947].
Tinanoff N, Reisine S. Update on Early Childhood Caries Since the Surgeon General's Report. 2009. Exclusion code: 2.
Truin GJ, Van't Hof MA. Caries prevention by professional fluoride gel application on enamel and dentinal lesions in low-caries children. Caries Res. 2005;39(3):236-240. Exclusion code: 3. [pmid: 15914987].
Truman BI, Gooch BF, Sulemana I, et al. Reviews of evidence on interventions to prevent dental caries, oral and pharyngeal cancers, and sports-related craniofacial injuries. Am J Prev Med. 2002;23(1 Suppl):21-54. Exclusion code: 4. [pmid: 12091093].
Tubert-Jeannin S, Auclair C, Amsallem E, et al. Fluoride supplements (tablets, drops, lozenges or chewing gums) for preventing dental caries in children. Cochrane Database of Systematic Reviews (Online). 2011:12. Exclusion code: 2. [pmid: 22161414].
Twetman S. Prevention of early childhood caries (ECC)--review of literature published 1998-2007. Eur Arch Paediatr Dent. 2008;9(1):12-18. Exclusion code: 5. [pmid: 18328233].
Twetman S, Petersson LG. Influence of xylitol in dentifrice on salivary microflora of preschool children at caries risk. Swed Dent J. 1995;19(3):103-108. Exclusion code: 8. [pmid: 7676386].
Twetman S, Petersson LG. Prediction of caries in pre-school children in relation to fluoride exposure. Eur J Oral Sci. 1996;104(5-6):523-528. Exclusion code: 4. [pmid: 9021320].
Twetman S, Petersson LG, Pakhomov GN. Caries Incidence in Relation to Salivary Mutans Streptococci and Fluoride Varnish Applications in Preschool Children from Low- and Optimal-Fluoride Areas. Caries Res. 1996;30(5):347-353. Exclusion code: 11. [pmid: 8877088].
Twetman S, Ståhl B, Nederfors T. Use of the strip mutans test in the assessment of caries risk in a group of preschool children. International Journal of Paediatric Dentistry / the British Paedodontic Society [and] the International Association of Dentistry for Children. 1994;4(4):245-250. Exclusion code: 4. [pmid: 7748864].
Twetman S, Stecksen-Blicks C. Effect of xylitol-containing chewing gums on lactic acid production in dental plaque from caries active pre-school children. Oral Health Prev. 2003;1(3):195-199. Exclusion code: 3. [pmid: 15641497].
U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health. 2000. Exclusion code: 2.
U.S. Preventive Services Task Force. Procedure Manual. 2011. http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 3 April, 2013. Exclusion code: 2.
Uhari M, Kontiokari T, Koskela M, Niemelä M. Xylitol chewing gum in prevention of acute otitis media: Double blind randomised trial. British Medical Journal. 1996;313(7066):1180-1184. Exclusion code: 8. [pmid: 8916749].
Ullbro C, Brown A, Twetman S. Preventive periodontal regimen in Papillon-Lefevre syndrome. Pediatr Dent. 2005;27(3):226-232. Exclusion code: 3. [pmid: 16173228].
US Government Accountability Office (GAO). Efforts Under Way to Improve Children's Access to Dental Services, but Sustained Attention Needed to Address Ongoing Concerns. Washington, D.C. Government Accountability Office. 2010. Exclusion code: 5.
Vachirarojpisan T, Shinada K, Kawaguchi Y. The process and outcome of a programme for preventing early childhood caries in Thailand. Community Dent Health. 2005;22(4):253-259. Exclusion code: 4. [pmid: 16379164].
Van Der Hoek W, Ekanayake L, Rajasooriyar L, Karunaratne R. Source of drinking water and other risk factors for dental fluorosis in Sri Lanka. International Journal of Environmental Health Research. 2003;13(3):285-293. Exclusion code: 4. [pmid: 12909559].
Van Rijkom HM, Truin GJ, Van 't Hof MA. Caries-Inhibiting Effect of Professional Fluoride Gel Application in Low-Caries Children Initially Aged 4.5-6.5 Years. Caries Res. 2004;38(2):115-123. Exclusion code: 3. [pmid: 14767168].
Vannier R. Replacement sweetening agents in the prevention of dental caries. Actual Odontostomatol (Paris). 1978;(123):403-415. Exclusion code: 7. [pmid: 735891].
Vargas CM, Monajemy N, Khurana P, Tinanoff N. Oral health status of preschool children attending Head Start in Maryland, 2000. Pediatr Dent. 2002;24(3):257-263. Exclusion code: 8. [pmid: 12064502].
Virtanen JI, Bloigu RS, Larmas MA. Timing of first restorations before, during, and after a preventive xylitol trial. Acta Odontol Scand. 1996;54(4):211-216. Exclusion code: 8. [pmid: 8876730].
Wåler SM, Rölla G. Effect of xylitol on dental plaque in vivo during carbohydrate challenge. Scand J Dent Res. 1983;91(4):256-259. Exclusion code: 3. [pmid: 6579603].
Wan AKL, Seow WK, Purdie DM, Bird PS, Walsh LJ, Tudehope DI. The effects of chlorhexidine gel on Streptococcus mutans infection in 10-month-old infants: a longitudinal, placebo-controlled, double-blind trial. Pediatr Dent. 2003;25(3):215-222. Exclusion code: 8. [pmid: 12889696].
Wang NJ, Gropen AM, Øgaard B. Risk factors associated with fluorosis in a non-fluoridated population in Norway. Community Dentistry and Oral Epidemiology. 1997;25(6):396-401. Exclusion code: 8. [pmid: 9429811].
Warren DP, Henson HA, Chan JT. Dental hygienist and patient comparisons of fluoride varnishes to fluoride gels. J Dent Hyg. 2000;74(2):94-101. Exclusion code: 11. [pmid: 11314061].
Warren JJ, Weber-Gasparoni K, Marshall TA, et al. A longitudinal study of dental caries risk among very young low SES children. Comm Dent Oral Epidemiol. 2009;37:116-122. Exclusion code: 8. [pmid: 19046332].
Washington State Department of Health. Washington State Smile Survey 2010. Olympia, WA. Division of Community and Family Health, Office of Maternal and Child Health, Oral Health Program, Washington State Department of Health. 2010. DOH Pub No 160-099. Exclusion code: 2.
Weinstein P. Public health issues in early childhood caries. Community Dentistry and Oral Epidemiology. 1998;26(1 SUPPL.):84-90. Exclusion code: 5. [pmid: 9671204].
Weinstein P. Motivational interviewing concepts and the relationship to risk management and patient counseling. J Calif Dent Assoc. 2011;39(10):742-745. Exclusion code: 5. [pmid: 22132586].
Weinstein P, Harrison R, Benton T. Motivating parents to prevent caries in their young children: one-year findings. Journal of the American Dental Association (1939). 2004;135(6):731-738. Exclusion code: 4. [pmid: 15270155].
Weinstein P, Harrison R, Benton T. Motivating mothers to prevent caries: confirming the beneficial effect of counseling. J Am Dent Assoc. 2006;137(6):789-793. Exclusion code: 4. [pmid: 16803808].
Weinstein P, Riedy CA. The reliability and validity of the RAPIDD scale: readiness assessment of parents concerning infant dental decay. J Dent Child. 2001;68(2):129-135. 142. Exclusion code: 8. [pmid: 11475689].
Weintraub JA. Prevention of early childhood caries: A public health perspective. Community Dentistry and Oral Epidemiology. 1998;26(1 SUPPL.):62-66. Exclusion code: 5. [pmid: 9671201].
Weintraub JA. Fluoride varnish for caries prevention: comparisons with other preventive agents and recommendations for a community-based protocol. Special Care in Dentistry : official publication of the American Association of Hospital Dentists, the Academy of Dentistry for the Handicapped, and the American Society for Geriatric Dentistry. 2003;23(5):180-186. Exclusion code: 5. [pmid: 14965184].
Wendt L, Carlsson E, Hallonsten A, Birkhed D. Early dental caries risk assessment and prevention in pre-school children: evaluation of a new strategy for dental care in a field study. Acta Odontol Scand. 2001;59(5):261-266. Exclusion code: 9. [pmid: 11680643].
Wendt LK, Hallonsten AL, Koch G. Dental caries in one- and two-year old children living in Sweden: a longitudinal study. Swed Dent J. 1991;15:1-6. Exclusion code: 5. [pmid: 2035146].
Wennhall I, Martensson E, Sjunnesson I, Matsson L, Schroder U, Twetman S. Caries-preventive effect of an oral health program for preschool children in a low socio-economic, multicultural area in Sweden: results after one year. Acta Odontol Scand. 2005;63(3):163-167. Exclusion code: 4. [pmid: 16191910].
Whittle J, Whitehead H, Bishop C. A randomised control trial of oral health education provided by a health visitor to parents of pre-school children. Community Dent Health. 2008;25(1):28-32. Exclusion code: 9. [pmid: 18435231].
Widenheim J. A time-related study of intake pattern of fluoride tablets among Swedish preschoolchildren and parental attitudes. Community Dent Oral Epidemiol. 1982;10(6):296-300. Exclusion code: 11. [pmid: 6961977].
Winter GB, Holt RD, Williams BF. Clinical trial of a low-fluoride toothpaste for young children. Int Dent J. 1989;39(4):227-235. Exclusion code: 4. [pmid: 2691402].
Wong MC, Glenny AM, Tsang BW, Lo EC, Worthington HV, Marinho VC. Topical fluoride as a cause of dental fluorosis in children. Cochrane Database of Systematic Reviews (Online). 2010;(1). Exclusion code: 5. [pmid: 20091645].
World Health Organization. The use of xylitol in the prevention of dental caries. Bulletin of the World Health Organization. 1979;57(2):213-214. http://whqlibdoc.who.int/bulletin/1979/Vol57-No2/bulletin_1979_57%282%29_213-225.pdf. Exclusion code: 5.
Yoder KM, Mallatt ME. The status of kindergarten and middle school entry dental examinations in Indiana. J Indiana Dent Assoc. 2005;84(2):15-18. Exclusion code: 3. [pmid: 16359000].
Yoon RK, Smaldone AM, Edelstein BL. Early childhood caries screening tools: a comparison of four approaches. J Am Dent Assoc. 2012;143(7):756-763. Exclusion code: 9. [pmid: 22751977].
Young D, Ricks CS, Featherstone JD, et al. Changing the face and practice of dentistry: a 10-year plan. J Calif Dent Assoc. 2011;39(10):746-751. Exclusion code: 5. [pmid: 22132587].
Zero D, Fontana M, Lennon AM. Clinical applications and outcomes of using indicators of risk in caries management. J Dent Educ. 2001;65(10):1126-1132. Exclusion code: 2. [pmid: 11699989].

## Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria for Randomized, Controlled Trials and Observational Studies

### Randomized, controlled trials (RCTs)

Criteria
- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of ratings based on above criteria
Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Diagnostic accuracy studies

Criteria
- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test
- Random or consecutive selection of patients
- Screening cutoff pre-determined
- All patients undergo the reference standard

Definition of ratings based on above criteria
Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet inclusion criteria screening cutoffs pre-stated.
Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients (i.e. applicable to most screening settings).
Poor: Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

Sources: Harris et al, 2001^34^ and USPSTF Procedure Manual35

## Appendix A6 List of Reviewers

### Expert reviewers

- Kevin J. Donly, D.D.S., M.S., Professor and Chair, Department of Developmental Dentistry, University of Texas Health Science Center at San Antonio
- William Frese, M.D., M.P.H., Assistant Professor, University of Illinois at Chicago
- David M. Krol, M.D., M.P.H., Senior Program Officer, Robert Wood Johnson Foundation
- Steven M. Levy, D.D.S., M.P.H., Wright-Bush-Shreves Endowed Professor of Research, Department of Preventive and Community Dentistry, College of Dentistry, University of Iowa
- Charlotte W. Lewis, M.D., M.P.H., Associate Professor of Pediatrics, University of Washington School of Medicine
- Amr M. Moursi, D.D.S., Ph.D., Chair, Department of Pediatric Dentistry, New York University, College of Dentistry
- Francisco Ramos-Gomez, D.D.S., M.S., M.P.H., Professor, Section of Pediatric Dentistry, University of California Los Angeles, School of Dentistry

### Federal reviewers

- Joseph Chin, M.D., M.S., Medical Officer, Centers for Medicare & Medicaid Services
- Barbara Gooch, D.M.D., M.P.H., Associate Director for Science, Division of Oral Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention
- Susan Griffin, Ph.D., Health Economist, Division of Oral Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention
- Gary C. Martin, D.D.S, M.P.H., Military Consultant to the United States Air Force Surgeon General for Dental Public Health, United States Air Force, Uniformed Services University of the Health Sciences