# REFERENCES

1 Kessler RC, Borges G, Walters EE. Prevalence of and risk factors for lifetime suicide attempts in the National Comorbidity Survey. Arch Gen Psychiatry. 1999;56(7):617-26. [pmid: 10401507].
2 Crosby AE, Ortega L, Melanson C. Self-directed violence surveillance: uniform definitions and recommended data elements. Atlanta, GA. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2011.
3 Posner K, Oquendo MA, Gould M, et al. Columbia Classification Algorithm of Suicide Assessment (C-CASA): classification of suicidal events in the FDA’s pediatric suicidal risk analysis of antidepressants. Am J Psychiatry. 2007;164(7):1035-43. [pmid: 17606655].
4 American Psychiatric Association. Practice guideline for the assessment and treatment of patients with suicidal behavior. Am J Psychiatry. 2003;160(11 Suppl):1-60. [pmid: 14649920].
5 Platt S, Bille-Brahe U, Kerkhof A, et al. Parasuicide in Europe: the WHO/EURO multicentre study on parasuicide, I: introduction and preliminary analysis for 1989. Acta Psychiatr Scand. 1992;85(2):97-104. [pmid: 1543046].
6 Centers for Disease Control and Prevention. Web-based Injury Statistics Query and Reporting System (WISQARS) Injury Mortality Reports, 1999–2009. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
7 Centers for Disease Control and Prevention. Web-based Injury Statistics Query and Reporting System (WISQARS) Leading Causes of Death Reports, 1999–2009. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
8 Nock MK, Borges G, Bromet EJ, et al. Suicide and suicidal behavior. Epidemiol Rev. 2008;30(1):133-54. [pmid: 18653727].
9 National Center for Health Statistics. Health, United States, 2011: With a Special Feature on Socioeconomic Status and Health. Hyattsville, MD. National Center for Health Statistics. 2012.
10 Clifton E. U.S. suicide rate surged among veterans. [Press release]. IPS-Inter Press Service. 2010. Accessed at http://www.ipsnews.net/2010/01/us-suicide-rate-surged-among-veterans/. 8 April 2013.
11 Bruce ML. Suicide risk and prevention in veteran populations. Ann N Y Acad Sci. 2010;1208:98-103. [pmid: 20955331].
12 Kaplan MS, Huguet N, McFarland BH, et al. Suicide among male veterans: a prospective population-based study. J Epidemiol Community Health. 2007;61(7):619-24. [pmid: 17568055].
13 Miller M, Barber C, Young M, et al. Veterans and suicide: a reexamination of the National Death Index-Linked National Health Interview Survey. Am J Public Health. 2012;102:S154-9. [pmid: 22390591].
14 Gibbons RD, Brown CH, Hur K. Is the rate of suicide among veterans elevated?. Am J Public Health. 2012;102(Suppl 1):S17-9. [pmid: 22390592].
15 Borges G, Angst J, Nock MK, et al. A risk index for 12-month suicide attempts in the National Comorbidity Survey Replication (NCS-R). Psychol Med. 2006;36(12):1747-57. [pmid: 16938149].
16 The NSDUH Report: Suicidal Thoughts and Behaviors Among Adults: 2008 and 2009. NSDUH Report No. 212. Rockville, MD. Substance Abuse and Mental Health Services Administration, Center for Behavioral Health Statistics and Quality. 2010. [pmid: 22012169].
17 Kessler RC, Berglund P, Borges G, et al. Trends in suicide ideation, plans, gestures, and attempts in the United States, 1990–1992 to 2001–2003. JAMA. 2005;293(20):2487-95. [pmid: 15914749].
18 King M, Semlyen J, Tai SS, et al. A systematic review of mental disorder, suicide, and deliberate self harm in lesbian, gay and bisexual people. BMC Psychiatry. 2008;8:70. [pmid: 18706118].
19 White R, Barber C, Azrael D, et al. History of military service and the risk of suicidal ideation: findings from the 2008 National Survey on Drug Use and Health. Suicide Life Threat Behav. 2011;41(5):554-61. [pmid: 21883410].
20 Eaton DK, Kann L, Kinchen S, et al. Youth risk behavior surveillance—United States, 2011. MMWR Surveill Summ. 2012;61(4):1-162. [pmid: 22673000].
21 Ting SA, Sullivan AF, Boudreaux ED, et al. Trends in U.S. emergency department visits for attempted suicide and self-inflicted injury, 1993–2008. Gen Hosp Psychiatry. 2012;34(5):557-65. [pmid: 22554432].
22 Ahmedani BK, Perron B, Ilgen M, et al. Suicide thoughts and attempts and psychiatric treatment utilization: informing prevention strategies. Psychiatr Serv. 2012;63(2):186-9. [pmid: 22302340].
23 Schulberg HC, Bruce ML, Lee PW, et al. Preventing suicide in primary care patients: the primary care physician’s role. Gen Hosp Psychiatry. 2004;26(5):337-45. [pmid: 15474633].
24 Centers for Disease Control and Prevention. Years of Potential Life Lost (YPLL) Before Age 85, 2009. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
25 Corso PS, Mercy JA, Simon TR, et al. Medical costs and productivity losses due to interpersonal and self-directed violence in the United States. Am J Prev Med. 2007;32(6):474-82. [pmid: 17533062].
26 van Spijker BA, van Straten A, Kerkhof AJ, et al. Disability weights for suicidal thoughts and non-fatal suicide attempts. J Affect Disord. 2011;134(1–3):341-7. [pmid: 21652085].
27 Nock MK, Borges G, Bromet EJ, et al. Cross-national prevalence and risk factors for suicidal ideation, plans and attempts. Br J Psychiatry. 2008;192(2):98-105. [pmid: 18245022].
28 Nock MK, Hwang I, Sampson NA, et al. Mental disorders, comorbidity and suicidal behavior: results from the National Comorbidity Survey Replication. Mol Psychiatry. 2010;15(8):868-76. [pmid: 19337207].
29 Beghi M, Rosenbaum JF. Risk factors for fatal and nonfatal repetition of suicide attempt: a critical appraisal. Curr Opin Psychiatry. 2010;23(4):349-55. [pmid: 20520547].
30 Oude Voshaar RC, Cooper J, Murphy E, et al. First episode of self-harm in older age: a report from the 10-year prospective Manchester Self-Harm Project. J Clin Psychiatry. 2011;72(6):737-43. [pmid: 21733475].
31 Suominen K, Isometsa E, Suokas J, et al. Completed suicide after a suicide attempt: a 37-year follow-up study. Am J Psychiatry. 2004;161(3):562-3. [pmid: 14992984].
32 Kuo WH, Gallo JJ. Completed suicide after a suicide attempt. Am J Psychiatry. 2005;162(3):633. [pmid: 15741501].
33 Bergen H, Hawton K, Waters K, et al. How do methods of non-fatal self-harm relate to eventual suicide?. J Affect Disord. 2012;136(3):526-33. [pmid: 22127391].
34 Monnin J, Thiemard E, Vandel P, et al. Sociodemographic and psychopathological risk factors in repeated suicide attempts: gender differences in a prospective study. J Affect Disord. 2012;136(1–2):35-43. [pmid: 21975134].
35 Prinstein MJ, Nock MK, Simon V, et al. Longitudinal trajectories and predictors of adolescent suicidal ideation and attempts following inpatient hospitalization. J Consult Clin Psychol. 2008;76(1):92-103. [pmid: 18229987].
36 Moran P, Coffey C, Romaniuk H, et al. The natural history of self-harm from adolescence to young adulthood: a population-based cohort study. Lancet. 2012;379(9812):236-43. [pmid: 22100201].
37 Li Z, Page A, Martin G, et al. Attributable risk of psychiatric and socio-economic factors for suicide from individual-level, population-based studies: a systematic review. Soc Sci Med. 2011;72(4):608-16. [pmid: 21211874].
38 Nock MK, Hwang I, Sampson N, et al. Cross-national analysis of the associations among mental disorders and suicidal behavior: findings from the WHO World Mental Health Surveys. PLoS Med. 2009;6(8):e1000123. [pmid: 19668361].
39 Bolton JM, Robinson J. Population-attributable fractions of Axis I and Axis II mental disorders for suicide attempts: findings from a representative sample of the adult, noninstitutionalized US population. Am J Public Health. 2010;100(12):2473-80. [pmid: 21068419].
40 Arsenault-Lapierre G, Kim C, Turecki G. Psychiatric diagnoses in 3275 suicides: a meta-analysis. BMC Psychiatry. 2004;4:37. [pmid: 15527502].
41 Horowitz LM, Ballard ED, Pao M. Suicide screening in schools, primary care and emergency departments. Curr Opin Pediatr. 2009;21(5):620-7. [pmid: 19617829].
42 Oquendo MA, Kamali M, Ellis SP, et al. Adequacy of antidepressant treatment after discharge and the occurrence of suicidal acts in major depression: a prospective study. Am J Psychiatry. 2002;159(10):1746-51. [pmid: 12359682].
43 Ekeberg O, Ellingsen O, Jacobsen D. Suicide and other causes of death in a five-year follow-up of patients treated for self-poisoning in Oslo. Acta Psychiatr Scand. 1991;83(6):432-7. [pmid: 1882694].
44 Isometsa ET, Lonnqvist JK. Suicide attempts preceding completed suicide. Br J Psychiatry. 1998;173:531-5. [pmid: 9926085].
45 Nielsen B, Wang AG, Brille-Brahe U. Attempted suicide in Denmark, IV: a five-year follow-up. Acta Psychiatr Scand. 1990;81(3):250-4. [pmid: 2343748].
46 Nordstrom P, Asberg M, Aberg-Wistedt A, et al. Attempted suicide predicts suicide risk in mood disorders. Acta Psychiatr Scand. 1995;92(5):345-50. [pmid: 8619338].
47 Hamza CA, Stewart SL, Willoughby T. Examining the link between nonsuicidal self-injury and suicidal behavior: a review of the literature and an integrated model. Clin Psychol Rev. 2012;32(6):482-95. [pmid: 22717336].
48 Dube SR, Anda RF, Felitti VJ, et al. Childhood abuse, household dysfunction, and the risk of attempted suicide throughout the life span: findings from the Adverse Childhood Experiences Study. JAMA. 2001;286(24):3089-96. [pmid: 11754674].
49 Seguin M, Renaud J, Lesage A, et al. Youth and young adult suicide: a study of life trajectory. J Psychiatr Res. 2011;45(7):863-70. [pmid: 21636096].
50 Tidemalm D, Runeson B, Waern M, et al. Familial clustering of suicide risk: a total population study of 11.4 million individuals. Psychol Med. 2011;41(12):2527-34. [pmid: 21733212].
51 Garssen J, Deerenberg I, Mackenbach JP, et al. Familial risk of early suicide: variations by age and sex of children and parents. Suicide Life Threat Behav. 2011;41(6):585-93. [pmid: 21815914].
52 Marshal MP, Dietz LJ, Friedman MS, et al. Suicidality and depression disparities between sexual minority and heterosexual youth: a meta-analytic review. J Adolesc Health. 2011;49(2):115-23. [pmid: 21783042].
53 Hatzenbuehler M. The social environment and suicide attempts in lesbian, gay, and bisexual youth. Pediatrics. 2011;127(5):896-903. [pmid: 21502225].
54 Fisher HL, Moffitt TE, Houts RM, et al. Bullying victimisation and risk of self harm in early adolescence: longitudinal cohort study. BMJ. 2012;344:e2683. [pmid: 22539176].
55 Ribeiro JD, Pease JL, Gutierrez PM, et al. Sleep problems outperform depression and hopelessness as cross-sectional and longitudinal predictors of suicidal ideation and behavior in young adults in the military. J Affect Disord. 2012;136(3):743-50. [pmid: 22032872].
56 Wong MM, Brower KJ. The prospective relationship between sleep problems and suicidal behavior in the National Longitudinal Study of Adolescent Health. J Psychiatr Res. 2012;46(7):953-9. [pmid: 22551658].
57 Scott KM, Hwang I, Chiu WT, et al. Chronic physical conditions and their association with first onset of suicidal behavior in the world mental health surveys. Psychosom Med. 2010;72(7):712-9. [pmid: 20498290].
58 Conwell Y, Duberstein PR. Suicide in elders. Ann N Y Acad Sci. 2001;932(1):132-50. [pmid: 11411182].
59 Bossarte RM, Knox KL, Piegari R, et al. Prevalence and characteristics of suicide ideation and attempts among active military and veteran participants in a national health survey. Am J Public Health. 2012;102(Suppl 1):S38-40. [pmid: 22390598].
60 Schulberg HC, Lee PW, Bruce ML, et al. Suicidal ideation and risk levels among primary care patients with uncomplicated depression. Ann Fam Med. 2005;3(6):523-8. [pmid: 16338916].
61 Gutierrez PM. Shneidman Award Address. Integratively assessing risk and protective factors for adolescent suicide. Suicide Life Threat Behav. 2006. 2005;36(2):129-35. [pmid: 16704319].
62 Steele MM, Doey T. Suicidal behaviour in children and adolescents, 1: etiology and risk factors. Can J Psychiatry. 2007;52(6 Suppl 1):21S-33. [pmid: 17824350].
63 Luoma JB, Martin CE, Pearson JL. Contact with mental health and primary care providers before suicide: a review of the evidence. Am J Psychiatry. 2002;159(6):909-16. [pmid: 12042175].
64 McCarty CA, Russo J, Grossman DC, et al. Adolescents with suicidal ideation: health care use and functioning. Acad Pediatr. 2011;11(5):422-6. [pmid: 21396897].
65 McNeill YL, Gillies ML, Wood SF. Fifteen year olds at risk of parasuicide or suicide: how can we identify them in general practice?. Fam Pract. 2002;19(5):461-5. [pmid: 12356694].
66 Gaynes BN, West SL, Ford CA, et al. Screening for suicide risk in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(10):822-35. [pmid: 15148072].
67 Olfson M, Weissman MM, Leon AC, et al. Suicidal ideation in primary care. J Gen Intern Med. 1996;11(8):447-53. [pmid: 8872781].
68 Shain BN. Suicide and suicide attempts in adolescents. Pediatrics. 2007;120(3):669-76. [pmid: 17766542].
69 American Academy of Child and Adolescent Psychiatry. Practice parameter for the assessment and treatment of children and adolescents with suicidal behavior. J Am Acad Child Adolesc Psychiatry. 2001;40(7 Suppl):24S-51. [pmid: 11434483].
70 Canadian Coalition for Seniors’ Mental Health. The Assessment of Suicide Risk and Prevention of Suicide. Toronto. Canadian Coalition for Seniors’ Mental Health. 2006.
71 American Medical Association. Guidelines for Adolescent Preventive Services: Recommendations Monograph. Chicago. American Medical Association. 1997.
72 McNamee JE, Offord DR. Prevention of suicide. Canadian Task Force of the Periodic Health Examination. The Canadian Guide to Clinical Preventive Health Care. Ottawa, Canada. Minister of Supply and Services. 1994.
73 Michigan Quality Improvement Consortium. Adult Preventive Services (Ages 18–49). Southfield, MI. Michigan Quality Improvement Consortium. 2008.
74 Michigan Quality Improvement Consortium. Routine Preventive Services for Children and Adolescents (Ages 2–21). Southfield, MI. Michigan Quality Improvement Consortium. 2009.
75 Mann JJ, Apter A, Bertolote J, et al. Suicide prevention strategies: a systematic review. JAMA. 2005;294(16):2064-74. [pmid: 16249421].
76 Julious SA. Efficacy and suicidal risk for antidepressants in paediatric and adolescent patients. Stat Methods Med Res. 2012. Jan. 19. [pmid: 22267546].
77 O’Connor EA, Whitlock EP, Beil TL, et al. Screening for depression in adult patients in primary care settings: a systematic evidence review. Ann Intern Med. 2009;151(11):793-803. [pmid: 19949145].
78 Meltzer HY, Alphs L, Green A, et al. Clozapine treatment for suicidality in schizophrenia: International Suicide Prevention Trial (InterSePT). Arch Gen Psychiatry. 2003;60:82-91. [pmid: 12511175].
79 Cipriani A, Pretty H, Hawton K, et al. Lithium in the prevention of suicidal behavior and all-cause mortality in patients with mood disorders: a systematic review of randomized trials. Am J Psychiatry. 2005;162(10):1805-19. [pmid: 16199826].
80 Substance Abuse and Mental Health Services Administration. SAMHSA’s National Registry of Evidence-Based Programs and Practices. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2011.
81 Weinberg I, Ronningstam E, Goldblatt MJ, et al. Strategies in treatment of suicidality: identification of common and treatment-specific interventions in empirically supported treatment manuals. J Clin Psychiatry. 2010;71(6):699-706. [pmid: 20573329].
82 Sarchiapone M, Mandelli L, Iosue M, et al. Controlling access to suicide means. Int J Environ Res Public Health. 2011;8:4550-62. [pmid: 22408588].
83 Matsubayashi T, Ueda M. The effect of national suicide prevention programs on suicide rates in 21 OECD nations. Soc Sci Med. 2011;73(9):1395-400. [pmid: 21940085].
84 While D, Bickley H, Roscoe A, et al. Implementation of mental health service recommendations in England and Wales and suicide rates, 1997–2006 a cross-sectional and before-and-after observational study. Lancet. 2012;379(9820):1005-12. [pmid: 22305767].
85 National Institute for Health and Clinical Excellence. Self-Harm: The NICE Guideline on Longer-Term Management. National Clinical Guideline No. 133. London. British Psychological Society and the Royal College of Psychiatrists. 2011.
86 Vannoy SD, Robins LS. Suicide-related discussions with depressed primary care patients in the USA: gender and quality gaps A mixed methods analysis. BMJ. 2011;1(2):e000198. [pmid: 22021884].
87 Feldman MD, Franks P, Duberstein PR, et al. Let’s not talk about it: suicide inquiry in primary care. Ann Fam Med. 2007;5(5):412-8. [pmid: 17893382].
88 Davidsen AS. And then one day he’d shot himself. Then I was really shocked: general practitioners’ reaction to patient suicide. Patient Educ Couns. 2011;85(1):113-8. [pmid: 20880655].
89 Frankenfield DL, Keyl PM, Gielen A, et al. Adolescent patients—healthy or hurting? Missed opportunities to screen for suicide risk in the primary care setting. Arch Pediatr Adolesc Med. 2000;154(2):162-8. [pmid: 10665603].
90 Wintersteen MB. Standardized screening for suicidal adolescents in primary care. Pediatrics. 2010;125(5):938-44. [pmid: 20385627].
91 Bruffaerts R, Demyttenaere K, Hwang I, et al. Treatment of suicidal people around the world. Br J Psychiatry. 2011;199(1):64-70. [pmid: 21263012].
92 U.S. Department of Health and Human Services. The Surgeon General’s Call to Action to Prevent Suicide. Rockville, MD. U.S. Public Health Service. 1999.
93 U.S. Department of Health and Human Services. National Strategy for Suicide Prevention: Goals and Objectives for Action. Rockville, MD. U.S. Public Health Service. 2001. [pmid: 20669520].
94 U.S. Department of Health and Human Services. Healthy People 2020: Mental Health Status Improvement. Washington, DC. U.S. Department of Health and Human Services. 2012.
95 Brenner LA, Barnes SM. Facilitating treatment engagement during high-risk transition periods: a potential suicide prevention strategy. Am J Public Health. 2012;102(Suppl 1):S12-4. [pmid: 22390585].
96 U.S. Department of Defense. Defense Centers of Excellence for Psychological Health and Traumatic Brain Injury. Arlington, VA. U.S. Department of Defense. 2012. Accessed at http://www.dcoe.health.mil/default.aspx. 8 April 2013.
97 Knox KL, Litts DA, Talcott GW, et al. Risk of suicide and related adverse outcomes after exposure to a suicide prevention programme in the US Air Force: cohort study. BMJ. 2003;327(7428):1376. [pmid: 14670880].
98 Gaynes BN, West SL, Ford C, et al. Screening for Suicide Risk. Systematic Evidence Review No. 32. Rockville, MD. Agency for Healthcare Research and Quality. 2004. [pmid: 20722129].
99 Reynolds WM. Adult Suicide Ideation Questionnaire: Professional Manual. Odessa, FL. Psychological Assessment Resources. 1991.
100 Osman A, Barrios FX, Gutierrez PM, et al. The Positive and Negative Suicide Ideation (PANSI) Inventory: psychometric evaluation with adolescent psychiatric inpatient samples. J Pers Assess. 2002;79(3):512-30. [pmid: 12511018].
101 Beck AT, Steer RA. Manual for the Beck Hopelessness Scale. San Antonio, TX. Psychological Corporation. 1988.
102 Olden M, Rosenfeld B, Pessin H, et al. Measuring depression at the end of life: is the Hamilton Depression Rating Scale a valid instrument?. Assessment. 2009;16(1):43-54. [pmid: 18676960].
103 Jobes DA, Jacoby AM, Cimbolic P, et al. Assessment and treatment of suicidal clients in a university counseling center. J Couns Psychol. 1997;44(4):368-77.
104 Reynolds WM. Reynolds Adolescent Depression Scale-Second Edition. Hersen M, Segal DL, Hilsenroth M, editors. Comprehensive Handbook of Psychological Assessment. New York. John Wiley & Sons. 2004.
105 Samaraweera S, Sivayogan S, Sumathipala A, et al. RCT of cognitive behaviour therapy in active suicidal ideation—as feasibility study in Sri Lanka. Eur J Psychiatry. 2007;21(3):175-8.
106 Fitzpatrick KK, Witte TK, Schmidt NB. Randomized controlled trial of a brief problem-orientation intervention for suicidal ideation. Behav Ther. 2005;36(4):323-33.
107 Hatcher S, Sharon C, Parag V, et al. Problem-solving therapy for people who present to hospital with self-harm: Zelen randomised controlled trial. Br J Psychiatry. 2011;199:310-6. [pmid: 21816868].
108 Diamond GS, Wintersteen MB, Brown GK, et al. Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2010;49(2):122-31. [pmid: 20215934].
109 Bannan N. Group-based problem-solving therapy in self-poisoning females: a pilot study. Couns Psychother Res. 2010;10(3):201-13.
110 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
111 Higgins JP, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. West Sussex, England. The Cochrane Collaboration. 2012.
112 Borenstein M, Hedges LV, Higgins JP, Rothstein HR. Introduction to Meta-Analysis. West Sussex, England. John Wiley & Sons. 2009.
113 Cohen J. Statistical Power Analysis for the Behavioral Sciences. Hillsdale, NJ. Lawrence Earlbaum Associates. 1988.
114 Bruce ML, Ten Have TR, Reynolds CF III, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081-91. [pmid: 14996777].
115 Bennewith O, Stocks N, Gunnell D, et al. General practice based intervention to prevent repeat episodes of deliberate self harm: cluster randomised controlled trial. BMJ. 2002;324(7348):1254-7. [pmid: 12028981].
116 Rothstein HR, Sutton AJ, Borenstein M. Publication Bias in Meta-Analysis—Prevention, Assessment, and Adjustment. West Sussex, England. John Wiley & Sons. 2012.
117 Crawford MJ, Thana L, Methuen C, et al., editors. Impact of screening for risk of suicide: randomised controlled trial. Br J Psychiatry. 2011;198:379-84. [pmid: 21525521].
118 Holi MM, Pelkonen M, Karlsson L, et al. Detecting suicidality among adolescent outpatients: evaluation of trained clinicians’ suicidality assessment against a structured diagnostic assessment made by trained raters. BMC Psychiatry. 2008;8:97. [pmid: 19116040].
119 Thompson EA, Eggert LL. Using the suicide risk screen to identify suicidal adolescents among potential high school dropouts. J Am Acad Child Adolesc Psychiatry. 1999;38(12):1506-14. [pmid: 10596250].
120 Heisel MJ, Duberstein PR, Lyness JM, et al. Screening for suicide ideation among older primary care patients. J Am Board Fam Med. 2010;23(2):260-9. [pmid: 20207936].
121 Robinson J, Pan YH, Martin C, et al. Does screening high school students for psychological distress, deliberate self-harm, or suicidal ideation cause distress—and is it acceptable? An Australian-based study. Crisis. 2011;32(5):254-63. [pmid: 21940259].
122 Gould MS, Marrocco FA, Kleinman M, et al. Evaluating iatrogenic risk of youth suicide screening programs: a randomized controlled trial. JAMA. 2005;293(13):1635-43. [pmid: 15811983].
123 Allard R, Marshall M, Plante MC. Intensive follow-up does not decrease the risk of repeat suicide attempts. Suicide Life Threat Behav. 1992;22(3):303-14. [pmid: 1440744].
124 Bateman A, Fonagy P. Effectiveness of partial hospitalization in the treatment of borderline personality disorder: a randomized controlled trial. Am J Psychiatry. 1999;156(10):1563-9. [pmid: 10518167].
125 Beautrais AL, Gibb SJ, Faulkner A, et al. Postcard intervention for repeat self-harm: randomised controlled trial. Br J Psychiatry. 2010;197(1):55-60. [pmid: 20592434].
126 Brown GK, Ten HT, Henriques GR, et al. Cognitive therapy for the prevention of suicide attempts: a randomized controlled trial. JAMA. 2005;294(5):563-70. [pmid: 16077050].
127 Carter GL, Clover K, Whyte IM, et al. Postcards from the EDge: 24-month outcomes of a randomised controlled trial for hospital-treated self-poisoning. Br J Psychiatry. 2007;191:548-53. [pmid: 18055960].
128 Carter GL, Willcox CH, Lewin TJ, et al. Hunter DBT project: randomized controlled trial of dialectical behaviour therapy in women with borderline personality disorder. Aust N Z J Psychiatry. 2010;44(2):162-73. [pmid: 20113305].
129 Cedereke M, Monti K, Ojehagen A. Telephone contact with patients in the year after a suicide attempt: does it affect treatment attendance and outcome? A randomised controlled study. Eur Psychiatry. 2002;17(2):82-91. [pmid: 11973116].
130 Clarke T, Baker P, Watts CJ, et al. Self-harm in adults: a randomised controlled trial of nurse-led case management versus routine care only. J Ment Health. 2002;11(2):167-76.
131 Comtois KA, Jobes DA, O’Connor S, et al. Collaborative Assessment and Management of Suicidality (CAMS): feasibility trial for next-day appointment services. Depress Anxiety. 2011;28(11):963-72. [pmid: 21948348].
132 Crawford MJ, Csipke E, Brown A, et al. The effect of referral for brief intervention for alcohol misuse on repetition of deliberate self-harm: an exploratory randomized controlled trial. Psychol Med. 2010;40(11):1821-8. [pmid: 20047702].
133 Currier GW, Fisher SG, Caine ED. Mobile crisis team intervention to enhance linkage of discharged suicidal emergency department patients to outpatient psychiatric services: a randomized controlled trial. Acad Emerg Med. 2010;17(1):36-43. [pmid: 20015106].
134 Evans K, Tyrer P, Catalan J, et al. Manual-Assisted Cognitive-behaviour Therapy (MACT): a randomized controlled trial of a brief intervention with bibliotherapy in the treatment of recurrent deliberate self-harm. Psychol Med. 1999;29(1):19-25. [pmid: 10077290].
135 Guthrie E, Kapur N, Kway-Jones K, et al. Randomised controlled trial of brief psychological intervention after deliberate self poisoning. BMJ. 2001;323(7305):135-8. [pmid: 11463679].
136 Hassanian MH, Sarjami S, Kolahi AA, et al. Postcards in Persia: randomised controlled trial to reduce suicidal behaviours 12 months after hospital-treated self-poisoning. Br J Psychiatry. 2011;198:309-16. [pmid: 21343332].
137 Hawton K, McKeown S, Day A, et al. Evaluation of out-patient counselling compared with general practitioner care following overdoses. Psychol Med. 1987;17(3):751-61. [pmid: 2819914].
138 Kovac SH, Range LM. Does writing about suicidal thoughts and feelings reduce them?. Suicide Life Threat Behav. 2002;32(4):428-40. [pmid: 12501967].
139 Lauterbach E, Felber W, Muller-Oerlinghausen B, et al. Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. 2008;118(6):469-79. [pmid: 18808400].
140 Linehan MM, Armstrong HE, Suarez A, et al. Cognitive-behavioral treatment of chronically parasuicidal borderline patients. Arch Gen Psychiatry. 1991;48(12):1060-4. [pmid: 1845222].
141 Linehan MM, Comtois KA, Murray AM, et al. Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Arch Gen Psychiatry. 2006;63(7):757-66. [pmid: 16818865].
142 Marasinghe RB, Edirippulige S, Kavanagh D, et al. Effect of mobile phone-based psychotherapy in suicide prevention: a randomized controlled trial in Sri Lanka. J Telemed Telecare. 2012;18(3):151-5. [pmid: 22362830].
143 Motto JA, Bostrom AG. A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv. 2001;52(6):828-33. [pmid: 11376235].
144 Rudd MD, Rajab MH, Orman DT, et al. Effectiveness of an outpatient intervention targeting suicidal young adults: preliminary results. J Consult Clin Psychol. 1996;64(1):179-90. [pmid: 8907098].
145 Slee N, Garnefski N, van der Leeden R, et al. Cognitive-behavioural intervention for self-harm: randomised controlled trial. Br J Psychiatry. 2008;192(3):202-11. [pmid: 18310581].
146 Tyrer P, Thompson S, Schmidt U, et al. Randomized controlled trial of brief cognitive behaviour therapy versus treatment as usual in recurrent deliberate self-harm: the POPMACT study. Psychol Med. 2003;33(6):969-76. [pmid: 12946081].
147 Vaiva G, Ducrocq F, Meyer P, et al. Effect of telephone contact on further suicide attempts in patients discharged from an emergency department: randomised controlled study. BMJ. 2006;332(7552):1241-5. [pmid: 16735333].
148 Van Den Bosch LM, Koeter MW, Stijnen T, et al. Sustained efficacy of dialectical behaviour therapy for borderline personality disorder. Behav Res Ther. 2005;43(9):1231-41. [pmid: 16005708].
149 Van Heeringen C, Jannes S, Buylaert W, et al. The management of non-compliance with referral to out-patient after-care among attempted suicide patients: a controlled intervention study. Psychol Med. 1995;25(5):963-70. [pmid: 8588015].
150 Welu TC. A follow-up program for suicide attempters: evaluation of effectiveness. Suicide Life Threat Behav. 1977;7(1):17-20. [pmid: 206990].
151 Szanto K, Kalmar S, Hendin H, et al. A suicide prevention program in a region with a very high suicide rate. Arch Gen Psychiatry. 2007;64(8):914-20. [pmid: 17679636].
152 Almeida OP, Pirkis J, Kerse N, et al. A randomized trial to reduce the prevalence of depression and self-harm behavior in older primary care patients. Ann Fam Med. 2012;10(4):347-56. [pmid: 22778123].
153 Donaldson D, Spirito A, Esposito-Smythers C. Treatment for adolescents following a suicide attempt: results of a pilot trial. J Am Acad Child Adolesc Psychiatry. 2005;44(2):113-20. [pmid: 15689724].
154 Eggert LL, Thompson EA, Randell BP, et al. Preliminary effects of brief school-based prevention approaches for reducing youth suicide—risk behaviors, depression, and drug involvement. J Child Adolesc Psychiatr Nurs. 2002;15(2):48-64. [pmid: 12083753].
155 Green JM, Wood AJ, Kerfoot MJ, et al. Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 2011;342:d682. [pmid: 21459975].
156 Greenfield B, Larson C, Hechtman L, et al. A rapid-response outpatient model for reducing hospitalization rates among suicidal adolescents. Psychiatr Serv. 2002;53:1574-9. [pmid: 12461218].
157 Hazell PL, Martin G, McGill K, et al. Group therapy for repeated deliberate self-harm in adolescents: failure of replication of a randomized trial. J Am Acad Child Adolesc Psychiatry. 2009;48(6):662-70. [pmid: 19454922].
158 King CA, Klaus N, Kramer A, et al. The Youth-Nominated Support Team-Version II for suicidal adolescents: a randomized controlled intervention trial. J Consult Clin Psychol. 2009;77(5):880-93. [pmid: 19803568].
159 Tang TC, Jou SH, Ko CH, et al. Randomized study of school-based intensive interpersonal psychotherapy for depressed adolescents with suicidal risk and parasuicide behaviors. Psychiatry Clin Neurosci. 2009;63(4):463-70. [pmid: 19531111].
160 Wood A, Trainor G, Rothwell J, et al. Randomized trial of group therapy for repeated deliberate self-harm in adolescents. J Am Acad Child Adolesc Psychiatry. 2001;40(11):1246-53. [pmid: 11699797].
161 Hooven C, Walsh E, Pike KC, et al. Promoting CARE: including parents in youth suicide prevention. Fam Community Health. 2012;35(3):225-35. [pmid: 22617413].
162 Robinson J, Yuen HP, Gook S, et al. Can receipt of a regular postcard reduce suicide-related behaviour in young help seekers? A randomized controlled trial. Early Interv Psychiatry. 2012;6(2):145-52. [pmid: 22260366].
163 Esposito-Smythers C, Spirito A, Kahler CW, et al. Treatment of co-occurring substance abuse and suicidality among adolescents: a randomized trial. J Consult Clin Psychol. 2011;79(6):728-39. [pmid: 22004303].
164 Chanen AM, Jackson HJ, McCutcheon LK, et al. Early intervention for adolescents with borderline personality disorder using cognitive analytic therapy: randomised controlled trial. Br J Psychiatry. 2008;193(6):477-84. [pmid: 19043151].
165 Goldberg JF, Allen MH, Miklowitz DA, et al. Suicidal ideation and pharmacotherapy among STEP-BD patients. Psychiatr Serv. 2005;56(12):1534-40. [pmid: 16339615].
166 Ferreira MH, Colombo ES, Guimaraes PS, et al. Suicide risk among inpatients at a university general hospital. Rev Bras Psiquiatr. 2007;29(1):51-4. [pmid: 17435930].
167 Ferreira-Gonzalez I, Busse JW, Heels-Ansdell D, et al. Problems with use of composite end points in cardiovascular trials: systematic review of randomised controlled trials. BMJ. 2007;334(7597):786. [pmid: 17403713].
168 Tepper M, Whitehead J, Filion KB, et al. Cognitive therapy and preventing suicide attempts. JAMA. 2005;294(22):2847-8. [pmid: 16352791].
169 Ghahramanlou-Holloway M, Bhar SS, Brown GK, et al. Changes in problem-solving appraisal after cognitive therapy for the prevention of suicide. Psychol Med. 2012;42(6):1185-93. [pmid: 22008384].
170 Slee N, Spinhoven P, Garnefski N, et al. Emotion regulation as mediator of treatment outcome in therapy for deliberate self-harm. Clin Psychol Psychother. 2008;15(4):205-16. [pmid: 19115441].
171 Tyrer P, Jones V, Thompson S, et al. Service variation in baseline variables and prediction of risk in a randomised controlled trial of psychological treatment in repeated parasuicide: the POPMACT Study. Int J Soc Psychiatry. 2003;49(1):58-69. [pmid: 12793516].
172 Tyrer P, Tom B, Byford S, et al. Differential effects of manual assisted cognitive behavior therapy in the treatment of recurrent deliberate self-harm and personality disturbance: the POPMACT study. J Pers Disord. 2004;18(1):102-16. [pmid: 15061347].
173 Davidson K, Scott J, Schmidt U, et al. Therapist competence and clinical outcome in the Prevention of Parasuicide by Manual Assisted Cognitive Behaviour Therapy trial: the POPMACT study. Psychol Med. 2004;34(5):855-63. [pmid: 15500306].
174 Arensman E, McAuliffe C, Corcoran P, et al. Findings of the POPMACT study. Psychol Med. 2004;34(6):1143-4. [pmid: 15554583].
175 Harned MS, Jackson SC, Comtois KA, et al. Dialectical behavior therapy as a precursor to PTSD treatment for suicidal and/or self-injuring women with borderline personality disorder. J Trauma Stress. 2010;23(4):421-9. [pmid: 20648564].
176 Reynolds SK, Lindenboim N, Comtois KA, et al. Risky assessments: participant suicidality and distress associated with research assessments in a treatment study of suicidal behavior. Suicide Life Threat Behav. 2006;36(1):19-34. [pmid: 16676622].
177 Verheul R, Van Den Bosch LM, Koeter MW, et al. Dialectical behaviour therapy for women with borderline personality disorder: 12-month, randomised clinical trial in the Netherlands. Br J Psychiatry. 2003;182:135-40. [pmid: 12562741].
178 Bateman A, Fonagy P. Treatment of borderline personality disorder with psychoanalytically oriented partial hospitalization: an 18-month follow-up. Am J Psychiatry. 2001;158(1):36-42. [pmid: 11136631].
179 Guthrie E, Kapur N, Kway-Jones K, et al. Predictors of outcome following brief psychodynamic-interpersonal therapy for deliberate self-poisoning. Aust N Z J Psychiatry. 2003;37(5):532-6. [pmid: 14511080].
180 Williamson MK, Pirkis J, Pfaff JJ, et al. Recruiting and retaining GPs and patients in intervention studies: the DEPS-GP project as a case study. BMC Med Res Methodol. 2007;(7):42. [pmid: 17875219].
181 Alexopoulos GS, Reynolds CF III, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. 2009;166(8):882-90. [pmid: 19528195].
182 Bogner HR, Morales KH, Post EP, et al. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. 2007;30(12):3005-10. [pmid: 17717284].
183 Thombs BD, Ziegelstein RC. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT): response to Bogner et al. Diabetes Care. 2008;31(6):e54. [pmid: 18509141].
184 Coyne JC, Koppel J, Colenda CC, et al. Interventions for treatment of depression in primary care. JAMA. 2004;291(23):2814-6. [pmid: 15199023].
185 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. 2011;68(6):627-36. [pmid: 21646579].
186 Gallo JJ, Bogner HR, Morales KH, et al. The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. Ann Intern Med. 2007;146(10):689-98. [pmid: 17502629].
187 Byers AL, Bruce ML, Raue P. Suicidal ideation in non-depressed elderly primary care patients: the PROSPECT study. Am J Geriatr Psychiatry. 2009;17:A86.
188 Carter GL, Clover K, Whyte IM, et al. Postcards from the EDge project: randomised controlled trial of an intervention using postcards to reduce repetition of hospital treated deliberate self poisoning. BMJ. 2005;331(7520):805. [pmid: 16183654].
189 Esposito-Smythers C, Walsh B, Spirito A, et al. Working with the suicidal client who also abuses substances. Cognit Behavir Pract. 2012;19:245-55.
190 Ougrin D. Adding group psychotherapy to routine care does not improve outcomes in adolescents who repeatedly self-harm. Evid Based Ment Health. 2011;14(3):84. [pmid: 21764883].
191 Barnes AJ. Attachment-based family therapy reduces suicidal ideation in adolescents. Evid Based Ment Health. 2011;14(1):8. [pmid: 21266605].
192 Goldney RD. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 2002;32(4):454-6. [pmid: 12501969].
193 Thompson EA, Eggert LL, Randell BP, et al. Evaluation of indicated suicide risk prevention approaches for potential high school dropouts. Am J Public Health. 2001;91(5):742-52. [pmid: 11344882].
194 Randell BP, Eggert LL, Pike KC. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 2001;31(1):41-61. [pmid: 11326768].
195 Robinson J, Hetrick S, Gook S, et al. Study protocol: the development of a randomised controlled trial testing a postcard intervention designed to reduce suicide risk among young help-seekers. BMC Psychiatry. 2009;9:59. [pmid: 19775469].
196 Freedenthal S. Assessing the wish to die: a 30-year review of the suicide intent scale. Arch Suicide Res. 2008;12(4):277-98. [pmid: 18828032].
197 Pena JB, Caine ED. Screening as an approach for adolescent suicide prevention. Suicide Life Threat Behav. 2006;36(6):614-37. [pmid: 17250467].
198 O’Neil ME, Peterson K, Low A, et al. Suicide Prevention Interventions and Referral/Follow-Up Services: A Systematic Review. VA-ESP Project No. 05-225. Washington, DC. U.S. Department of Veterans Affairs, Health Services Research and Development Service. 2012.
199 Hawton K, Townsend E, Arensman E, et al. Psychosocial versus pharmacological treatments for deliberate self harm. Cochrane Database Syst Rev. 2000;2:CD001764. [pmid: 10796818].
200 Carter GL, Clover KA, Bryant JL, et al. Can the Edinburgh Risk of Repetition Scale predict repetition of deliberate self-poisoning in an Australian clinical setting?. Suicide Life Threat Behav. 2002;32(3):230-9. [pmid: 12374470].
201 Cooper J, Kapur N, Dunning J, et al. A clinical tool for assessing risk after self-harm. Ann Emerg Med. 2006;48(4):459-66. [pmid: 16997684].
202 Huth-Bocks AC, Kerr DC, Ivey AZ, et al. Assessment of psychiatrically hospitalized suicidal adolescents: self-report instruments as predictors of suicidal thoughts and behavior. J Am Acad Child Adolesc Psychiatry. 2007;46(3):387-95. [pmid: 17314725].
203 Keane EM, Dick RW, Bechtold DW, et al. Predictive and concurrent validity of the Suicidal Ideation Questionnaire among American Indian adolescents. J Abnorm Child Psychol. 1996;24(6):735-47. [pmid: 8970907].
204 Waern M, Sjostrom N, Marlow T, et al. Does the Suicide Assessment Scale predict risk of repetition? A prospective study of suicide attempters at a hospital emergency department. Eur Psychiatry. 2010;25(7):421-6. [pmid: 20620027].
205 Harriss L, Hawton K. Suicidal intent in deliberate self-harm and the risk of suicide: the predictive power of the Suicide Intent Scale. J Affect Disord. 2005;86(2–3):225-33. [pmid: 15935242].
206 Nimeus A, Alsen M, Traskman-Bendz L. High suicidal intent scores indicate future suicide. Arch Suicide Res. 2002;6(3):211-9.
207 Steeg S, Kapur N, Webb R, et al. The development of a population-level clinical screening tool for self-harm repetition and suicide: the ReACT Self-Harm Rule. Psychol Med. 2012:1-12. [pmid: 22394511].
208 Baldessarini RJ, Tondo L, Davis P, et al. Decreased risk of suicides and attempts during long-term lithium treatment: a meta-analytic review. Bipolar Disord. 2007;9(3):314. [pmid: 17042835].
209 Angst F, Stassen HH, Clayton PJ, et al. Mortality of patients with mood disorders: follow-up over 34–38 years. J Affect Disord. 2002;68(2–3):167-81. [pmid: 12063145].
210 McKnight RF, Adida M, Budge K, et al. Lithium toxicity profile: a systematic review and meta-analysis. Lancet. 2012;379(9817):721-8. [pmid: 22265699].
211 Grandjean EM, Aubry JM. Lithium: updated human knowledge using an evidence-based approach, III: clinical safety. CNS Drugs. 2009;23(5):397-418. [pmid: 19453201].
212 Werneke U, Ott M, Renberg ES, et al. A decision analysis of long-term lithium treatment and the risk of renal failure. Acta Psychiatr Scand. 2012;126(3):186-97. [pmid: 22404233].
213 Angst J, Angst F, Gerber-Werder R, et al. Suicide in 406 mood-disorder patients with and without long-term medication: a 40 to 44 years’ follow-up. Arch Suicide Res. 2005;9(3):279-300. [pmid: 16020171].
214 Hysinger EB, Callahan ST, Caples TL, et al. Suicidal behavior differs among early and late adolescents treated with antidepressant agents. Pediatrics. 2011;128(3):447-54. [pmid: 21824883].
215 Pereira TV, Ioannidis JP. Statistically significant meta-analyses of clinical trials have modest credibility and inflated effects. J Clin Epidemiol. 2011;64(10):1060-9. [pmid: 21454050].
216 Harman JS, Rollman BL, Hanusa BH, et al. Physician office visits of adults for anxiety disorders in the United States, 1985–1998. J Gen Intern Med. 2002;17(3):165-72. [pmid: 11929501].
217 Harman JS, Veazie PJ, Lyness JM. Primary care physician office visits for depression by older Americans. J Gen Intern Med. 2006;21(9):926-30. [pmid: 16918736].
218 Cherry DK, Hing E, Woodwell DA, et al. National Ambulatory Medical Care Survey: 2006 Summary. Hyattsville, MD. National Center for Health Statistics. 2008.
219 U.S. Preventive Services Task Force. Screening for suicide risk: recommendation and rationale. Ann Intern Med. 2004;140(10):820-1. [pmid: 15148071].
220 Desseilles M, Perroud M, Guillaume S, et al. Is it valid to measure suicidal ideation by depression rating scales?. J Affect Disord. 2012;136(3):398-404. [pmid: 22154567].
221 Harrington R, Kerfoot M, Dyer E, et al. Randomized trial of a home-based family intervention for children who have deliberately poisoned themselves. J Am Acad Child Adolesc Psychiatry. 1998;37(5):512-8. [pmid: 9585653].
222 Huey SJ Jr, Henggeler SW, Rowland MD, et al. Multisystemic therapy effects on attempted suicide by youths presenting psychiatric emergencies. J Am Acad Child Adolesc Psychiatry. 2004;43(2):183-90. [pmid: 14726725].
223 Asarnow JR, Baraff LJ, Berk M, et al. An emergency department intervention for linking pediatric suicidal patients to follow-up mental health treatment. Psychiatr Serv. 2011;62(11):1303-9. [pmid: 22211209].
224 Hassanzadeh M, Khajeddin N, Nojomi M, et al. Brief intervention and contact after deliberate self-harm: an Iranian randomized controlled trial. Iranian J Psychiatry Behav Sci. 2010;4(2):5-12.
225 Hawton K, Bancroft J, Catalan J, et al. Domiciliary and out-patient treatment of self-poisoning patients by medical and non-medical staff. Psychol Med. 1981;11(1):169-77. [pmid: 7208740].
226 Hvid M, Vangborg K, Sorensen HJ, et al. Preventing repetition of attempted suicide, II: the Amager Project, a randomized controlled trial. Nord J Psychiatry. 2011;65(5):292-8. [pmid: 21171837].
227 Patsiokas AT. Effects of psychotherapeutic strategies in the treatment of suicide attempters. J Psychother. 1985;22:281.
228 Salkovskis PM, Atha C, Storer D. Cognitive-behavioural problem solving in the treatment of patients who repeatedly attempt suicide: a controlled trial. Br J Psychiatry. 1990;157:871-6. [pmid: 2289097].
229 Bramness JG, Walby FA, Tverdal A. The sales of antidepressants and suicide rates in Norway and its counties 1980–2004. J Affect Disord. 2007;102(1–3):1-9. [pmid: 17223200].
230 van der Sande R, van Rooijen L, Buskens E, et al. Intensive in-patient and community intervention versus routine care after attempted suicide: a randomised controlled intervention study. Br J Psychiatry. 1997;171:35-41. [pmid: 9328492].
231 Hallahan B, Hibbeln JR, Davis JM, et al. Omega-3 fatty acid supplementation in patients with recurrent self-harm: single-centre double-blind randomised controlled trial. Br J Psychiatry. 2007;190:118-22. [pmid: 17267927].
232 Montgomery SA, Roy D, Montgomery DB. The prevention of recurrent suicidal acts. Br J Clin Pharmacol. 1983;15(Suppl 2):183S-8. [pmid: 6824553].
233 Hirsch SR, Walsh C, Draper R. The concept and efficacy of the treatment of parasuicide. Br J Clin Pharmacol. 1983;15(Suppl 2):189S-94. [pmid: 6824554].
234 Battaglia J, Wolff TK, Wagner-Johnson DS, et al. Structured diagnostic assessment and depot fluphenazine treatment of multiple suicide attempters in the emergency department. Int Clin Psychopharmacol. 1999;14(6):361-72. [pmid: 10565804].
235 Verkes RJ, van der Mast RC, Hengeveld MW, et al. Reduction by paroxetine of suicidal behavior in patients with repeated suicide attempts but not major depression. Am J Psychiatry. 1998;155(4):543-7. [pmid: 9546002].
236 Wexler LM, Gone JP. Culturally responsive suicide prevention in indigenous communities: unexamined assumptions and new possibilities. Am J Public Health. 2012;102(5):800-6. [pmid: 22420786].
237 Wortzel HS, Gutierrez PM, Homaifar BY, et al. Surrogate endpoints in suicide research. Suicide Life Threat Behav. 2010;40(5):500-5. [pmid: 21034212].
238 Perlis RH. Hard outcomes: clinical trials to reduce suicide. Am J Psychiatry. 2011;168(10):1009-11. [pmid: 21969041].
239 Asarnow JR. Effectiveness of a family based intervention for adolescent suicide attempters (the SAFETY study). 2005. Accessed at http://clinicaltrials.gov/ct2/show/NCT00692302?cond=%22Self-Injurious+Behavior%22&rank=23. 8 April 2013.
240 de Klerk D. The (cost-) effectiveness of mindfulness-training and cognitive behavioural therapy in adolescents and young adults with deliberate self harm (DSH). 2011. Accesssed at http://clinicaltrials.gov/ct2/show/NCT00694668. 8 April 2013.
241 Goldston DB. Relapse prevention for suicidal dually diagnosed youths (CBT-RP). 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT00589641. 8 April 2013.
242 Hatcher S, Sharon C, House A, et al. The ACCESS study: a Zelen randomised controlled trial of a treatment package including problem solving therapy compared to treatment as usual in people who present to hospital after self-harm: study protocol for a randomised controlled trial. Trials. 2011;12:135. [pmid: 21615951].
243 Hatcher S, Coupe N, Durie M, et al. Te Ira Tangata: a Zelen randomised controlled trial of a treatment package including problem solving therapy compared to treatment as usual in Maori who present to hospital after self harm. Trials. 2011;12:117. [pmid: 21569300].
244 Husain N, Chaudhry N, Durairaj SV, et al. Prevention of: self harm in British South Asian women: study protocol of an exploratory RCT of culturally adapted manual assisted problem solving training (C- MAP). Trials. 2011;12:159. [pmid: 21693027].
245 Mehlum L. Treatment for adolescents with deliberate self harm. 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT00675129?term=NCT00675128&rank=1. 8 April 2013.
246 Pearson M, Konradsen F, Gunnell D, et al. A community-based cluster randomised trial of safe storage to reduce pesticide self-poisoning in rural Sri Lanka: study protocol. BMC Public Health. 2011;11:879. [pmid: 22104027].
247 van Beek W, Kerkhof A, Beekman A. Future oriented group training for suicidal patients: a randomized clinical trial. BMC Psychiatry. 2009;9:65. [pmid: 19811638].
248 van Spijker BA, van Straten A, Kerkhof AJ. The effectiveness of a web-based self-help intervention to reduce suicidal thoughts: a randomized controlled trial. Trials. 2010;11:25. [pmid: 20214777].
249 Wasserman D, Carli V, Wasserman C, et al. Saving and empowering young lives in Europe (SEYLE): a randomized controlled trial. BMC Public Health. 2010;10:192. [pmid: 20388196].
250 Brown GK. A review of Suicide Assessment Measures for Intervention Research With Adults and Older Adults. Philadelphia. University of Pennslyvania. 2001.
251 Beck AT, Steer RA. Manual for Beck Depression Inventory. San Antonio, TX. Psychological Corporation. 1987.
252 Beck AT, Steer RA. Manual for the Beck Depression Inventory-II. San Antonio, TX. Psychological Corporation. 1996.
253 Beck AT, Steer RA. Manual for the Beck Scale for Suicide Ideation. San Antonio, TX. Psychological Corporation. 1991.
254 Harkavy-Friedman J, Asnis GM. Assessment of suicidal behavior: a new instrument. Psych Annals. 1989;19:382-7.
255 Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry. 1960;23:56-62. [pmid: 14399272].
256 Osman A, Gutierrez PM, Kopper BA, et al. The Positive and Negative Suicide Ideation Inventory: development and validation. Psychol Rep. 1998;82(3 Pt 1):783-93. [pmid: 9676490].
257 Paykel ES, Myers JK, Lindenthal JJ, et al. Suicidal feelings in the general population: a prevalence study. Br J Psychiatry. 1974;124:460-9. [pmid: 4836376].
258 Linehan MM. Suicidal Behaviors Questionnaire. Seattle, WA. University of Washington. 1981.
259 Linehan MM. Suicidal Behaviors Questionnaire. Seattle, WA. University of Washington. 1996.
260 Cotton CR, Range LM. Suicidality, hopelessness and attitudes toward life and death in children. Death Stud. 1993;17:185-91. [pmid: 10169709].
261 Broadhead WE, Leon AC, Weissman MM, et al. Development and validation of the SDDS-PC screen for multiple mental disorders in primary care. Arch Fam Med. 1995;4(3):211-9. [pmid: 7881602].
262 Weissman MM, Olfson M, Leon AC, et al. Brief diagnostic interviews (SDDS-PC) for multiple mental disorders in primary care: a pilot study. Arch Fam Med. 1995;4(3):220-7. [pmid: 7881603].
263 Gutierrez PM, Osman A, Barrios FX, et al. Development and initial validation of the Self-Harm Behavior Questionnaire. J Pers Assess. 2001;77(3):475-90. [pmid: 11781034].
264 Muehlenkamp JJ, Cowles ML, Gutierrez PM. Validity of the Self-Harm Behavior Questionnaire with diverse adolescents. J Psychopathol Behav Assess. 2010;32(2):236-45.
265 Reynolds WM. Suicidal Ideation Questionnaire: Professional Manual. Odessa, FL. Psychological Assessment Resource. 1988.
266 Rudd MD. The prevalence of suicidal ideation among college students. Suicide Life Threat Behav. 1989;19(2):173-83. [pmid: 2749860].
267 Cooper-Patrick L, Crum RM, Ford DE. Identifying suicidal ideation in general medical patients. JAMA. 1994;272(22):1757-62. [pmid: 7966924].
268 Cull JG, Gill WS. Suicide Probability Scale Manual. Los Angeles. Western Psychological Services. 1988.
269 Beck AT, Kovacs M, Weissman A. Assessment of suicidal intention: the Scale for Suicide Ideation. J Consult Clin Psychol. 1979;47(2):343-52. [pmid: 469082].
270 Beck AT, Steer RA, Ranieri WF. Scale for Suicide Ideation: psychometric properties of a self-report version. J Clin Psychol. 1988;44(4):499-505. [pmid: 3170753].
271 Lam RW, Michalak EE, Swinson RP. Depression and mania. Assessment Scales in Depression, Mania and Anxiety. Oxfordshire, England. Taylor & Francis. 2005.
272 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
273 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
274 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].