# DISCUSSION

## Summary of Findings

Suicide prevention is a national priority. Primary care could potentially play an important role in helping identify people at increased risk of suicide and provide them with them appropriate treatment. Suicide risk, however, can be difficult to accurately assess because some individuals may attempt to conceal suicidal thoughts and because some may express suicidal thoughts without serious intention to die.196 Even in high-risk populations, suicide is a comparatively rare event and the known risk factors associated with suicide are relatively common even in people who are not at high risk of suicide, thus compromising both positive and negative predictive ability.

While screening instruments have been developed for a quick risk assessment, very few studies have reported diagnostic accuracy characteristics of sensitivity, specificity, or related statistics relative to an interview with a clinician or other trained interviewer. Minimal evidence (two studies) suggests that there are screening tools that can identify adults and older adults in primary care who are at increased risk of suicide, at the cost of many false-positives. Screening accuracy data were even more limited in adolescents. Neither of the instruments demonstrated excellent performance characteristics in adolescents, and the screening populations in which they were tested had relatively poor applicability to general primary patients. Screening studies in adolescents were primarily applicable to high-risk populations, such as those with depression or other mental health issues. Instrument accuracy aside, we identified only very minimal data that examined whether suicide risk screening increased or reduced the likelihood of suicidality or other distress. Our results are consistent with those of an earlier review of suicide screening in adolescents, which concluded that data were very limited and future research was essential to determine whether and how screening can reduce suicide in young people.197

While we found more evidence evaluating the effects of treatment, the included studies included too few deaths to determine whether any type of treatment reduced the risk of suicide deaths. In adults, however, psychotherapy targeting suicide prevention reduced the risk of suicide attempts by an estimated 32 percent. In contrast, psychotherapy did not reduce the risk of suicide attempts in adolescents, and the data did not allow us to rule out the possibility of harm. Psychotherapy also showed small beneficial effects on depression for both adolescents and adults. Other beneficial outcomes were either sparsely reported (e.g. inpatient or emergency health care use), did not show greater improvement with suicide prevention interventions than usual care (e.g., suicidal ideation), or were limited in both ways (e.g., hopelessness, functioning). Psychotherapy trials were primarily in very high-risk populations, with the majority limited to people who had presented to an ED with a suicide attempt.

Interventions that primarily focused on enhancing usual care had little impact on suicide deaths, suicide attempts, or related outcomes. One large-scale trial of older primary care patients, however, did report a 20 percent reduction in the combined outcome of suicide attempts or ideation after a 24-month intervention involving education and training of general practitioners who volunteered to participate in the study.152 Since these providers responded to an invitation for volunteers, they may be more motivated to improve their practice than a typical practitioner.

Our findings were generally consistent with other recent reviews of suicide prevention or management of self-harm.75,85,198,199 Each of these recent reviews generally included the same body of research, but they grouped trials differently. Nonetheless, they all found insufficient evidence for the effect on suicide deaths due to a small number of events. They also all often found moderate-sized, but frequently statistically nonsignificant, reductions in suicide attempts or self-harm, and all were limited by the included trials’ sparse reporting of other outcomes. The most recent and comprehensive of these reviews, published by NICE, concluded that psychological and psychosocial interventions may be effective compared with usual care, although there was uncertainty due to variations in populations, treatment modalities, and comparison arms. Only one intervention included in the NICE review demonstrated a beneficial effect on adolescents.85

Table 13 provides an overall summary of the evidence.

Table 13 Summary of Evidence

Population | # of studies (k), # of observations (n) | Design | Major limitations | Consistency | Applicability | Overall quality | Summary of findings
Key Question 1 (benefits of screening)
Adults and older adults | k=1, n=443 | RCT | Single trial, only 2 weeks followup, limited to adults | NA | Moderate: Primary care patients screening positive for depression in the United Kingdom | Fair | Among primary care patients screening positive for depression, there were no differences in suicidal ideation after 2 weeks between those screened for suicide risk and those screened for other health behaviors; only 1 suicide attempt in the whole trial. Data not reported separately for older adults.
Adolescents | No data | NA | NA | NA | NA | NA | No data
Key Question 2 (accuracy of screening)
Adults | k=1, n=1,001 | Diagnostic accuracy | Few studies, no replication of specific screening instruments, only 1 study had short time period between screener and reference (≤24 hours),67 median time lag between tests ≥6 days in other studies | NA | High: Primary care in the United States67 | Fair | 3 suicide items were examined separately; sensitivity was ≥83% and specificity was ≥81% relative to a nurse-administered structured interview on the same day.
Older adults | k=1, n=626 | Diagnostic accuracy | Few studies, no replication of specific screening instruments, only 1 study had short time period between screener and reference (≤24 hours),67 median time lag between tests ≥6 days in other studies | NA | High: Primary care in the United States120 | Fair | Sensitivity and specificity of suicide-related items on the GDS were 80% for suicidal ideation in the past 2 weeks, at lowest of 3 cut-points examined.
Adolescents | k=2, n=799 | Diagnostic accuracy | Few studies, no replication of specific screening instruments, only 1 study had short time period between screener and reference (≤24 hours),67 median time lag between tests ≥6 days in other studies | Low | Low-Moderate: At risk of dropout from U.S. high school;119 Finnish mental health patients118 | Fair | Study with best applicability to U.S. primary care reported sensitivity of 87% and specificity of 60% for the SRS.
Key Question 3 (harms of screening)
Adults and older adults | k=1, n=443 | RCT | Single trial with only 2-week followup | NA | Moderate: Primary care patients in the United Kingdom | Fair | No increase in suicide attempts or ideation after screening, slightly higher proportion of those who were screened withdrew consent for followup (6.6% of screened vs. 2.2% of unscreened). Data not reported separately for older adults.
Adolescents | k=2, n=2,650 | RCT | Only 2 trials using different instruments, maximum followup of 2 days | Moderate | Low-Moderate: Australian and U.S. high school students screened in classroom setting | Fair | No adverse effects on emotions; Australian youth screening positive found screening more distressing and less worthwhile than those screening negative.
Key Questions 4 & 5 (benefits of treatment): Psychotherapy
Adults | k=19, n=2,460 | RCT | Populations inconsistently described; no data specifically on racial/ethnic minorities | Moderate | Low-Moderate: Many conducted outside of the United States, only trial that involved population-based screening was conducted in Sri Lanka105 | Fair | Sample sizes insufficient to determine group differences in suicide deaths; psychotherapy reduced the risk of suicide attempts by 32% (RR, 0.68 [95% CI, 0.56 to 0.83]); pooled effects showed a small benefit for depression but not suicidal ideation. Most data were from trials of CBT or related interventions. Trials of DBT were limited to female patients with BPD.
Older adults | No data specific to older adults | NA | NA | NA | NA | NA | No trials limited to older adults, no subgroup analyses examining effects in older adults.
Adolescents | k=12, n=2,392 | RCT | Little replication of interventions; populations inconsistently described; no data specifically on racial/ethnic minorities | Moderate | Low-Moderate: Many conducted outside of the United States, the few involving screening were conducted in school settings | Good (developmental group therapy); Fair (other therapies) | Insufficient data on suicide deaths; few approaches reduced suicide attempts or ideation compared with UC; pooled effects showed a small benefit for depression but not suicidal ideation. Some trials showed statistically nonsignificant increase in suicide attempts (by 22% to 113%), raising the possibility of harm.
Key Questions 4 & 5 (benefits of treatment): Medication
Adults (Lithium) | k=1, n=167 | Placebo-controlled RCT | Only 1 trial with high attrition beyond 3 months | NA | Moderate: German adults identified through ED and inpatient screening | Fair | 3 suicide deaths, all in placebo group; short-term nonstatistically significant reduction in suicide attempts (HR for time to suicide attempt, 0.52; p=0.20); no benefit for suicidal ideation compared with placebo plus UC.
Older adults | No data | NA | NA | NA | NA | NA | No trials limited to older adults, no subgroup analyses examining effects in older adults.
Adolescents | No data | NA | NA | NA | NA | NA | No trials limited to adolescents, no subgroup analyses examining effects in adolescents.
Key Questions 4 & 5 (benefits of treatment): Enhanced Usual Care
Adults | k=13, n=8,555 + k=1 population-based study n≈127,000 residents | RCT and 1 CCT151 | Populations inconsistently described; no data specifically on racial/ethnic minorities; little replication of interventions | Moderate | Low-Moderate: Many trials conducted outside the United States | Fair | 1 of 7 trials found reduced risk of deaths, at 2 years followup (1.8% deaths in intervention group vs. 3.5% in control group) in participants who were sent periodic letters expressing interest in patient’s well-being, among persons who refused treatment after a suicide attempt, but effects reduced and no longer statistically significant beyond 2 years;143 reductions in suicide attempts or other health outcomes generally not seen; suicidal ideation and depression were rarely reported.
Older adults | k=2, n=22,360 | RCT | 1 trial limited to those with depression with insufficient power for suicide deaths and attempts;114 large study only reported composite outcome of suicide attempts plus ideation152 | NA | High: 1 conducted in general primary care patients,152 the other identified participants through primary screening for depression114 | Fair | Primary care-based intervention in depressed older adults including care manager showed benefits for depression, mixed results for suicidal ideation, but no benefit for suicide deaths, attempts, or nonsuicidal deaths.114 Education and training for providers reduced the risk of suicide attempts and ideation combined by 20% in a general primary care population of older adults, but had no effect on depression.152
Adolescents | k=1, n=165 | RCT | Single trial with highly selected population, groups not entirely comparable at baseline, insufficient power for suicide attempts | NA | Low: Australia, highly selected population | Fair | No group differences in suicide attempts, suicidal ideation, depression, or hopelessness.
Adults | Psychotherapy: k=3, n=351 Medication: k=1, n=167 Enhanced UC: k=2, n=727 + remaining KQ 4 & 5 trials for paradoxical effects | RCT | Spare reporting of harms; methods of data collection not described | Moderate | Low-Moderate: Most of trials reporting harm conducted in the United States, but 2 of the U.S-based trials were in university students participating in study for class credit | Fair | No psychotherapy or enhanced UC trials identified any harmful effects; participants taking lithium were more likely to drop out of study due to adverse effects (13% taking lithium vs. 2% taking placebo). In full group of KQ 4 & 5 trials, several reported nonstatistically significant increases in suicide attempts or DSH, though most of these trials had few events and wide CIs; 1 trial in the United Kingdom of a practice-based intervention found a 32% (95% CI, 1.02 to 1.70) increase in the odds of DSH in patients with no previous history of self-harm.
Older adults | No data specific to older adults | NA | NA | NA | NA | NA | No trials limited to older adults, no subgroup analyses examining effects in older adults.
Adolescents | Psychotherapy: KQ 4 & 5 trials for paradoxical effects | RCT | No direct reporting of harms | Low | Low-Moderate: Many conducted outside of United States, the few involving screening were conducted in school settings | Good (developmental group therapy); Fair (other therapies) | No trials directly reported harms; 4 of 11 KQ 4 & 5 trials reported statistically nonsignificant increases in suicide attempts or self-harm of 22% or more. Trial with largest increase was very small (n=31 with followup) with few events, but reported 22% to 33% increases in suicide attempts in remaining 2 trials.153

Abbreviations: BPD = borderline personality disorder; CBT = cognitive behavioral therapy; CI = confidence interval; DBT = dialectic behavioral therapy; DSH = deliberate self-harm; ED = emergency department; GDS = Geriatric Depression Scale; HR = hazard ratio; KQ = key question; NA = not applicable; RCT = randomized controlled trial; RR = relative risk; SRS = Suicide Risk Scale; UC = usual care.

## Further Discussion of Screening

A recent study examined whether screening adolescents for suicide risk in primary care was feasible and whether it increases rates of detection and referral.90 This study found that added suicide items to an existing standardized psychosocial history interview in electronic medical records of three different pediatric practices more than doubled the rate of suicide screening in pediatric practices (odds ratio [OR], 2.49 [95% CI, 2.02 to 2.97] for all practices combined). Further, providers detected three to five times more cases of people in need of treatment (OR, 4.33 [95% CI, 3.72 to 4.94] for all practices combined). Rates of referral to treatment were comparable to rates of detection. This study did not examine the proportion who followed up the referral and engaged in treatment, however, nor did it report health outcomes of individuals. Thus, while these data are promising, evidence is still lacking as to whether systematic screening would decrease suicide attempts and deaths.

Given the paucity of data on screening, we also searched for related bodies of literature that might provide information on the usefulness and accuracy of suicide risk screening instruments. This search yielded eight studies that examined how well instruments for suicide risk screening can predict future suicide attempts or deaths in those who were administered the instrument during a suicidal or mental health crisis (i.e., during hospitalization or an ED visit related to a suicide attempt or for mental health reasons).200–207

These studies’ results were widely variable. Sensitivity ranged from 60 to 97 percent and specificity ranged from 25 to 61 percent. The studies differed in instruments examined, target ages, time to followup, and outcomes examined, making it difficult to determine why performance characteristics in some studies were much better. The large (n=9,086) study of the Manchester Self-Harm Rule in adults was based on direct interview and medical records. This study reported sensitivity of 94 to 97 percent, but specificity of only 25 to 26 percent for self-harm (including suicide deaths) in the subsequent 6 months among those who presented to an ED because of an episode of self-harm.201 Another large-scale (n=2,489) study found sensitivity of 67 to 77 percent (males and females reported separately), specificity of 49 to 75 percent, and PPV of 4 percent for suicide deaths in the subsequent 5 years.205

## Further Discussion of Treatment

### Treatment in Adults

We presented evidence primarily on two major types of treatment, psychotherapy and enhanced usual care. The participants in the included adult psychotherapy trials that reported suicide attempts were generally classified as at very high risk of committing suicide, usually stemming from a history of multiple suicide attempts, which resulted in very high incidence of suicide attempts even after treatment. The proportion of control patients with suicide attempts at followup ranged from 11 to 68 percent in the psychotherapy trials. This result contrasts to the screening accuracy studies, which were conducted in general primary care patients. Thus, the indirect evidence linking screening and treatment is not good, based on poor fit between populations in the two bodies of evidence.

While suicide attempts were reduced by a pooled average of 32 percent in adult psychotherapy trials, the interventions’ effects on intermediate outcomes such as suicidal ideation and depression were either small or nonexistent. These results were reported primarily in psychotherapy trials. Control groups received usual care, however, which may be effective in some cases. This is evidenced by the fact that both usual care and suicide prevention-focused treatments generally showed improvement in intermediate outcomes.

Trials of enhanced usual care found that these interventions’ effects on suicide attempts were smaller than in psychotherapy trials and, with only one exception, not statistically significant. Although data were not encouraging, a number of trials with promising results had low power, and these approaches to enhancing usual care may be worth replicating with larger samples. In addition, although most of the enhanced usual care trials were limited to people with recent ED or inpatient treatment for a suicide attempt, a smaller proportion of participants had suicide attempts at followup (0.5% to 28% of control participants). The fact that the incidence of suicide attempts in these trials was lower than in the psychotherapy trials could be due to either the lower overall risk in these patients (e.g., due to enrolling fewer participants with multiple previous suicide attempts) or more effective usual care (which we could not determine with available evidence). Both of these could influence the results. In addition, some of the enhanced usual care interventions alone may not be sufficient to reduce suicide attempts, but may be useful components of a larger systemwide approach that includes psychotherapy.

We found very minimal data on medication’s effectiveness in preventing suicidal behavior. These data were limited to a single, short-term, fair- to poor-quality lithium trial that was plagued by high attrition. This study reported hazard ratios that suggest a benefit compared with placebo, but these results were not statistically significant. While the authors did report a statistically lower rate of suicide deaths per patient-year, this was based on only three suicide deaths and could be biased due to high attrition. Participants taking lithium were more likely to drop out of the study due to adverse effects, but the study did not describe which adverse effects were experienced by the participants.

Lithium is commonly used for treating bipolar disorder and has been shown to reduce the risk of suicide in observational studies208,209 and controlled trials of unipolar and bipolar patients who are not necessarily suicidal compared with placebo or other agents (Peto OR, 0.26 [95% CI, 0.09 to 0.77]).79 The use of lithium in patients screening positive for suicidality has not been thoroughly studied. Lithium is associated with important adverse effects that were not described in the one trial included in this review. These risks include an increased risk of hypothyroidism and hyperparathyroidism, and reduced urinary concentrating ability (leading to thirst, polyuria, progressive renal insufficiency, and, in rare cases, end-stage renal failure or nephrotic syndrome).210,211 Despite these risks, a recent decision analysis concluded that lithium initiation and continuation for bipolar disorder was recommended in most cases.212 Additional adverse effects include tremor, gastrointestinal disturbance, weight gain, dry mouth, and cognitive disturbance, such as difficulties with memory, vigilance, and tracking.210,211

The NICE guidance on long-term self-harm management recommends that drug treatment not be offered as a specific intervention to reduce self-harm because of the potential toxicity of psychoactive medications.85 The NICE guidance, however, recommends providing treatment, including pharmacologic, to treat associated conditions such as depression, substance misuse, BPD, and bipolar disorder, but urges clinicians to be aware of medications’ toxicity and avoid high-toxicity medications such as tricyclic antidepressants. A long-term (44 years) prospective study of people with depressive spectrum disorders who had an inpatient psychiatric admission found that the use of antidepressants alone or with a neuroleptic medication lowered suicide rates, even though those treated with these medications were more severely ill than those who were not.209,213

### Treatment in Adolescents

When identified, statistically nonsignificant increases in suicide attempts were usually found in adolescents. The research on iatrogenic suicidality related to antidepressants suggests that adolescents react differently from adults to pharmacologic treatment.77 In addition, research suggests that risk factors and methods of committing suicide differ between younger versus older teens.214 Thus, different age groups appear to have different treatment needs and risks. The evidence base in adolescents is still small and few approaches have yet to be replicated, which is very important since initial trials have been shown to often overestimate results found in subsequent research.215 In this review, we found such a situation when results for the one intervention that did show beneficial results in a first trial160 were not replicated in two subsequent good-quality trials.155,157

Psychotherapy trials were primarily in high-risk youth, most with a recent suicide attempt or acute suicidal ideation. These samples are consistent with the samples in the screening studies but may have low applicability to youth identified through primary care screening. One trial, however, was conducted in U.S. youth identified through primary care and ED screening.108 This trial generally reported effects that were among the largest of the adolescent trials and should be considered for replication. Another trial in substance abusing adolescents of fairly intensive CBT involving both parents and youth reported an effect size of similar magnitude and should also be considered for replication.163 While suicidal youth need treatment, caution and close monitoring and care coordination is warranted, and these trials suggest that active parental involvement in treatment may be important. Further research is urgently needed.

It is difficult to determine why adolescents may differ from adults in their response to treatment, but we have a few hypotheses. Adolescents are generally more impulsive than adults, which may make suicide attempts more unpredictable and less amenable to treatment. Additionally, given that adolescents have had fewer years to gain experience, they are presumably less skilled at managing or communicating distress than adults. Also, serious mental health issues often have their first onset during adolescence, so treatment may not yet be optimized and youth would have had little chance to learn how to manage their mental health issues. Similarly, many people begin experimentation with substances during adolescence, which may further impair emotional well-being and judgment along with increasing their impulsivity, all of which may contribute to difficulty in preventing suicide attempts. It should be noted, however, that evidence related to potential paradoxically increased suicidality with psychotherapy (in this review) and antidepressant use (in other reviews) is limited to suicide attempts (and ideation, in the case of antidepressants). Deaths in youth are still very rare and data are insufficient to determine whether there are any treatment effects (beneficial or harmful) on suicide deaths.

## Potential for Suicide Screening in Primary Care

Primary care could have an important role to play in identifying patients at increased risk of suicide. Data suggest that a high proportion of people who make a suicide attempt have recently seen a primary care provider. Existing data may even underestimate this opportunity, since they were collected prior to publication of the National Suicide Prevention Strategy93 and before the current trend toward greater treatment of mental health issues in primary care.216–218 While important, global risk factors alone (e.g., age, sex, mental health diagnoses) are insufficient predictors of suicide risk. These factors, however, could be useful in identifying patients who would benefit from ongoing direct monitoring of suicide risk, perhaps in the context of broader mental health screening and monitoring. The USPSTF recommends screening adults and adolescents for depression in health care settings with systems in place to ensure accurate diagnosis, appropriate treatment, and sufficient followup.219 Suicide screening is likely embedded in many depression screening approaches, or could easily be added. One study found fairly strong correlations between the first five items of the SSI (a semistructured clinician-rating scale) and single suicide items on the HRSD (r=0.55) and BDI (r=0.48).220

## Potentially Important Approaches Not Included in This Review

This review did not include a number of important approaches that have relevance to primary care. These approaches were not included either because no eligible trials were found or because they were outside the scope of the review.

Adequately treating underlying mental health issues is an important approach to suicide prevention. Given the high proportion of people with mental health issues among those who commit suicide or make suicide attempts, and given that there are effective treatments available for relevant mental health disorders (e.g., depression, substance misuse, and PTSD), direct treatment for these disorders may reduce suicide attempts and/or deaths. Trials examining the effectiveness of treatment on remission of mental health disorders or reduced symptomatology, however, are inconsistent in reporting of suicide-related outcomes. This leads to concerns about publication bias where those outcomes are reported. In addition, this evidence was outside the scope of our report.

Although we included studies of screening initiated by a recent ED visit or psychiatric hospitalization, we did not include screening studies or treatment trials that were exclusively or primarily conducted in ED or inpatient settings, since this was outside the scope of what could likely be provided or referred to by primary care providers. Of the 15 trials of treatment in these settings we found in our initial searches,221–235 a nonsystematic examination suggests their results are consistent with the included trials. Several psychotherapy trials in adults showed a range of absolute differences between groups in suicide attempts at followup, which ranged from substantial declines to slight increases, and most group differences were not statistically significant. As with the body of evidence included in our review, there were few trials conducted in adolescents.221–223 However, given that the risk of suicide attempt is high soon after discharge, when treatment is unlikely to have taken effect yet, a close examination of this literature may have revealed greater benefits (albeit with very limited applicability to primary care).

We found no medication trial of clozapine that met our inclusion criteria, the one medication that is approved by the Food and Drug Administration for treatment of suicidal behavior. The approval is for patients with schizophrenia and schizoaffective disorders, however, and we excluded trials limited to patients with chronic psychotic illness (including schizophrenia), and found no trials eligible for our review (i.e., no trials in other populations).

We also planned to include trials of interventions addressing restriction of suicide means, given the observational and ecological data supporting this approach to suicide prevention. However, we found no trials that met inclusion criteria.

## Limitations of the Review

There are a number of limitations to this review, some of which are related to the evidence identified and some due to inherent challenges with this topic. As mentioned above, there was little evidence in primary care-relevant populations on the diagnostic accuracy of primary care-feasible screening instruments relative to a clinical interview for finding patients at current increased risk of suicide, and none were conducted in general-risk adolescents. We identified even less information on benefits or harms of screening, and none on adolescents in health care settings. Although the body of evidence for treatment was much larger, it primarily addressed very high-risk patients with a recent ED visit or hospitalization for self-harm, and there was very little evidence on its effectiveness in older adults and racial/ethnic minorities. Differences in suicide rates among different ethnic groups in the United States and across difference countries suggest that cultures vary in motivation for and meaning of suicide, and that risk-based screening as well as culturally-tailored interventions may be important.236

Most of the data in the included studies were for suicide attempts or self-harm or intermediate outcomes such as suicidal ideation or depression. Suicide attempts and self-harm, while important outcomes in their own right, are not good surrogates for suicide death. As such, we cannot assume the reductions in suicide attempts means that the intervention will reduce the number of deaths.237

We also identified a number of inherent difficulties in researching the effects of treatment on suicide risk. First, suicide death is a very rare outcome and power is nearly always going to be insufficient to detect potentially important reductions in single-site trials. Very large collaborative trials are likely required to achieve sufficient power to see effect on suicide deaths.238 If all participants in all psychotherapy trials reporting deaths were treated as a single study that found a 57 percent reduction in suicide deaths (0.62% in the intervention group vs. 1.44% in the control group), four times the participants would have been needed to achieve statistical significance. Power would likely be even more dramatically limited in studies of screen-detected patients. Assuming an annual suicide rate of 100 per 100,000 persons (twice as high as older white males, who have the highest rates of any age-sex-race subgroup) and the ability of treatment to affect a 40 percent reduction in suicide, over 83,000 people per group would be required to see a statistically significant result. Thus, it will always be difficult to build a coherent chain of evidence from broad population-based screening through treatment, since treatment studies will necessarily be limited to very high-risk groups in order to have a hope of having sufficient power to detect a treatment effect.

Second, control groups must include usual care because of the potential for death or other serious adverse events if left untreated, which in many cases will involve extensive treatment. Therefore, results of included studies may underestimate the absolute effects of treatment. Finally, patients at highest risk (in whom there is the best chance of having enough power to show a beneficial effect) are often excluded from studies because their condition is considered dangerously unstable. As such, researchers or Institutional Review Boards may not be willing to risk allocating the most disturbed patients to anything other than the highest possible level of treatment. This may again have the effect of attenuating the benefit that can be found in trials of suicide prevention treatment. Despite the difficulties and challenges, further research in this area is of paramount importance.

## Future Research Needs

A number of areas of needed research have been identified by this review. More trials of treatment in adolescents are needed, perhaps including enhancements to usual care in addition to psychotherapy such as care management or collaborative approaches between specialty and primary care providers. Based on included studies, we hypothesized that interventions targeting parents as well as youth may be most effective; further research examining this hypothesis would be welcomed. In addition, treatment trials targeting high-risk groups such as older adults and Native Americans that are tailored to their cultural and/or developmental needs are needed. Replication of some enhanced usual care approaches in adults may also be valuable, particularly approaches that show at least moderate-sized but statistically nonsignificant effect sizes.132,147,150

More information is also needed on performance characteristics of screening instruments as well as benefits and harms of screening, especially in general-risk adolescents. Information on effectiveness of general versus targeted screening in primary care would also be useful. Use of technology may be helpful for conducting large-scale screening studies.

We identified 11 ongoing trials (Appendix I).239–249 Seven trials are evaluating psychotherapeutic interventions: CBT,239–241,247,248 problem-solving therapy,244 and DBT.245 Two New Zealand trials are evaluating the effectiveness of a six-component treatment package in patients with DSH that includes psychotherapy, improved access, increasing support, and postcards.242,243 The final trials are large-scale, multisite trials. One is evaluating the effectiveness of a safe storage box for pesticides in Sri Lanka (n=200,000); the other is evaluating three suicide prevention interventions (gatekeeper training, awareness training, and professional screening) in 11 European countries (n=11,000).246 Most of the trials target specific high-risk groups, such as adolescents with substance abuse problems and patients with a history of DSH, suicidal thoughts, and/or ideation, which may help fill the evidence gaps.

## Conclusion

Suicide prevention is a topic of high national importance in which primary care providers may have a role to play. Although evidence was limited, primary care-feasible screening tools could likely identify adult patients at increased risk of suicide who may need treatment, and a larger body of evidence showed that psychotherapy can reduce the risk of suicide attempts. There was little evidence on the accuracy of screening in adolescents (and none in general-risk adolescent populations), and treatment did not demonstrate a positive effect. Results in adolescents also did not rule out the possibility of harm (i.e., increased suicide attempts) with some psychotherapeutic treatments. More research on how to effectively identify and treat adolescents at increased risk of suicide is urgently needed.