# RESULTS

## Literature Search

We identified 56 eligible studies for inclusion in this review, reported in 86 publications, from our review of 3,925 abstracts and 303 articles (Figure 4). We identified seven trials addressing screening (KQs 1, 2, and 3): one examined short-term benefits of screening,117 four examined performance characteristics of screening instruments,67,118–120 and three examined adverse effects of screening.117,121,122 Forty-nine trials addressed benefits of treatment (KQs 4 and 5), 36 of which were conducted in adults or mixed adolescent and adult populations105–107,109,114,115,123–152 and 13 in adolescents.108,153–164 The identified trials reported health outcomes, intermediate outcomes, or both. A subset of these trials (k=12) also reported adverse events of treatment, including paradoxical worsening of outcomes, which are discussed under KQ 6.^106,115,123,126,133, 137–139,147,153,156,157^

Figure 4 Literature Flow Diagram

Abbreviations: CE = comparative effectiveness; KQ = key question.

Figure 4 is a flow chart that summarizes the search and selection of articles. There were 6,638 citations identified by searching MEDLINE, PsycInfo, Cochrane Center Register of Controlled Trials, and Cumulative Index to Nursing and Allied Health Literature. An additional 264 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers. After duplicates were removed, 3,925 unique citations were screened at the title/abstract stage. The full text of 303 citations were examined for inclusion for one or more of the six Key Questions. The following number of articles were included for Key Question 1 (n=1), Key Question 2 (n=4), Key Question 3 (n=5), Key Question 4 (n=71), Key Question 5 (n=64), and Key Question 6 (n=14). Reasons for excluding the other articles are available in Appendix D.

## Key Question 1: Do Screening Programs to Detect Suicide Risk Among Adolescents, Adults, and Older Adults in Primary Care Settings Result in Improved Health Outcomes or Intermediate Outcomes? Does the Effect of the Screening Programs Vary by Population Characteristics?

We identified one short-term, fair-quality trial (n=443) that addressed KQ 1. This trial found no clear short-term benefit of screening (i.e., within 2 weeks of screening).117 This trial included adult primary care patients who screened positive for depression (ages 18 to 92 years; mean age, 48 years) identified from four practices in the United Kingdom. Patients were randomized to suicide screening or to answer health and lifestyle questions, with the primary aim of determining whether suicide screening increased the likelihood of suicidal ideation. Intervention-group participants screening positive for suicide risk were given information about helplines and other sources of help and were encouraged to use those resources. When followed up 2 weeks later, there were no statistically significant differences between groups in the proportion feeling that life was not worth living (28% in the intervention group vs. 24% in the control group), wishing they were dead (23% in both groups), or reporting thoughts of taking their own life (15% in the intervention group vs. 11% in the control group). At followup, one control group participant had attempted suicide; there were no suicide attempts in the intervention group. We cannot conclude, however, that screening prevents suicide attempts with only a single attempt in the whole trial, particularly since the direction of effect for other outcomes (e.g., suicidal ideation) did not trend toward benefit in the intervention group. Retention in this trial was only 81 percent at the 2-week followup and the authors did not report allocation concealment.

## Key Question 2: Do Instruments to Screen for Increased Risk of Suicide Accurately Identify Adolescents, Adults, and Older Adults Who Are at Increased Risk in Primary Care Populations? Does the Accuracy of the Screening Instruments Vary by Population Characteristics?

We included four studies that reported on the accuracy of screening instruments for identifying individuals at increased risk of suicide (i.e., experiencing current or recent suicidal ideation, with or without recent suicidal behavior).67,118–120 Two trials reported instrument accuracy in adolescent samples (combined n=799). One trial was conducted in an outpatient mental health setting among youth with a diagnosis of depression. This trial used a three-point clinicians’ summary assessment that was based on a two-item screener.118 The second trial used the Suicide Risk Screen (SRS), a 20-item screener embedded in a broader self-report questionnaire administered in schools by research staff to youth at risk of dropping out of high school.119 A third study examined the clinical utility of three suicide-related items in primary care patients age 18 years and older with prescheduled appointments for any reason (n=1,001),67 and the final study examined a suicide ideation subscale of the GDS-SI in general primary care patients age 65 years and older (n=626) (Table 3).120

Table 3 Test Performance Characteristics of Suicide Screening Instruments (Key Question 2)

Population | Study, Quality | Sample | Prevalence of suicide^*^ | Reference test (time to test) | Instrument (threshold) | Test positive (%) | Sensitivity (%) | Specificity (%) | PPV (%) | NPV (%)
Adolescents | Holi 2008^118^ Fair | Depressed adolescent outpatients ages 13 to 19 years at a psychiatry clinic (n=218) | 27.1% suicidal or self-harming act in past 2 weeks | K-SADS-PL (median, 6 days) | Mental health clinicians’ suicidality assessment (categorized as suicidal or not based on 2 items) | 25.2 | 51.6 (95% CI, 38.6 to 64.5) | 85.3 (95% CI, 78.7 to 90.4) | 58.2 (95% CI, 44.1 to 71.3) | 81.6 (95% CI, 74.8 to 87.2)
Adolescents | Thompson 1999^119^ Fair | High school students ages 14 to 20 years at risk of dropping out of high school (n=581) | 21.7% high risk of suicide (timeframe NR) | CRA after computer-assisted interview with clinician (7 to 10 days) | SRS (4 risk categories; categories I, II, III considered positive screen) | 50.5 | 87 (95% CI, 80.2 to 92.6) | 60 (95% CI, 55.1 to 64.3) | 37.8 (95% CI, 32.2 to 43.6) | 94.4 (95% CI, 91.0 to 96.8)
Adults | Olfson 1996^67^ Fair | Primary care patients ages 18 to 70 years (n=1,001) | 3.3% suicidal ideation during the past month | Nurse-administered structured interview (24 hours) | 3 items from the SDDS-PC (affirmative response): 1) thoughts of death | 20.2 | 100 (95% CI, NR) | 81.0 (95% CI, 78.5 to 83.5) | 5.9 (95% CI, 2.6 to 9.2) | 100 (95% CI, NR)
Adults | Olfson 1996^67^ Fair | Primary care patients ages 18 to 70 years (n=1,001) | 3.3% suicidal ideation during the past month | Nurse-administered structured interview (24 hours) | 2) wishing you were dead | 7.9 | 91.7 (95% CI, 76.1 to 100.0) | 93.1 (95% CI, 91.5 to 94.7) | 13.9 (95% CI, 6.3 to 21.5) | 99.8 (95% CI, 99.5 to 100.0)
Adults | Olfson 1996^67^ Fair | Primary care patients ages 18 to 70 years (n=1,001) | 3.3% suicidal ideation during the past month | Nurse-administered structured interview (24 hours) | 3) feeling suicidal | 3.3 | 83.3 (95% CI, 62.2 to 100.0) | 97.7 (95% CI, 69.8 to 98.6) | 30.3 (95% CI, 14.6 to 46.0) | 99.8 (95% CI, 99.5 to 100.0)
Older adults | Heisel 2010^120^ Fair | Primary care patients ages 65 to 95 years (n=626) | 11% suicidal ideation (timeframe NR)^†^ | SCID suicide items or suicide item from HAM-D (NR) | Suicide subscale (5 items) of the GDS: 1) cut score ≥1 | 26.2 | 79.7 (95% CI, 68.3 to 88.4) | 80.4 (95% CI, 76.9 to 83.6) | 33.5 (95% CI, 26.4 to 41.3) | 97.0 (95% CI, 95.0 to 98.3)
Older adults | Heisel 2010^120^ Fair | Primary care patients ages 65 to 95 years (n=626) | 11% suicidal ideation (timeframe NR)^†^ | SCID suicide items or suicide item from HAM-D (NR) | 2) cut score ≥2 | 12.5 | 55.1 (95% CI, 42.6 to 67.1) | 92.8 (95% CI, 90.3 to 94.8) | 48.7 (95% CI, 37.2 to 60.3) | 94.3 (95% CI, 92.1 to 96.1)
Older adults | Heisel 2010^120^ Fair | Primary care patients ages 65 to 95 years (n=626) | 11% suicidal ideation (timeframe NR)^†^ | SCID suicide items or suicide item from HAM-D (NR) | 3) cut score ≥3 | 5.8 | 34.8 (95% CI, 23.7 to 47.2) | 97.8 (95% CI, 96.2 to 98.9) | 66.7 (95% CI, 49.0 to 81.4) | 92.4 (95% CI, 89.9 to 94.4)

* Percent of participants who scored positive for suicidal behavior on the reference test.

† Combined suicide ideation variable (6.5% endorsed the HAM-D suicide ideation item; 9.9% endorsed the SCID suicide ideation item; 94.4% concordance).

Abbreviations: CI = confidence interval; CRA = Clinician Risk Assessment; GDS = Geriatric Depression Scale; HAM-D = Hamilton Rating Scale for Depression; K-SADS-PL = Schedule for Affective Disorders and Schizophrenia for School-Age Children—Present and Lifetime Version; NPV = negative predictive value; NR = not reported; PPV = positive predictive value; SCID = Structured Clinical Interview for DSM Disorders; SDDS-PC = Symptom-Driven Diagnostic System for Primary Care; SRS = Suicide Risk Screen.

We rated all of these trials as fair quality for a number of reasons. On the positive side, all trials applied the same reference standard to all screened participants and all pulled their sample from a single identified population (rather than pulling from separate high-risk and low-risk populations). The studies generally provided adequate information about the screening and reference tests. The one study in older adults, however, examined three possible cut-points for its scale, without a set-aside validation sample.120 As a result, the performance characteristics associated with the optimal threshold they identified may overestimate the true performance of this screener. The index test was clearly interpreted without knowledge of the reference test in both trials in adults67,120 and the trial of potential high school dropouts;119 however, this information was not reported in the trial of depressed adolescents.118 Only one study specifically reported that the reference test was independent of the screening test,120 and in one study the results of the screening test were definitely used in the reference test.119 The major source of concern with these studies was the time lag between the screening and reference tests. Only one of the trials applied the screening and reference tests within 24 hours for all participants.67 The other studies either did not report the time lag,120 reported a median lag of 6 days (range, 0 to 35 days; unclear if the reference test was always administered after the screener),118 or reported a lag of 7 to 10 days (reference test always followed the screener).119

Although the two studies in adolescents used different approaches to assembling their samples, both represented high-risk groups that had 22 to 27 percent prevalence of suicidal ideation or behavior according to the reference standards. An even higher proportion screened positive (25% to 50%) (Table 3).118,119 One of these studies compared the accuracy of mental health clinicians’ three-level assessment (nonsuicidal, suicidal ideation, and suicide attempt) based on asking two questions about participants’ behavior during the previous 2 weeks (“Have you thought of killing yourself?” and “Have you attempted suicide?”) with the suicide items on the Kiddie Schedule for Affective Disorders and Schizophrenia administered by trained raters.118 This study sample was 82 percent female, with an average age of 16 years. The sensitivity was fairly low (52%) for this instrument, although the specificity was relatively high (85%) and PPV was 58 percent. These results may have low applicability to a general primary care setting, however, given that the screeners were mental health clinicians and the sample was limited to youth who had already screened positive for depression. The other study conducted in adolescents (mean age, 16 years; 42% female) compared a self-administered screening questionnaire (SRS, number of items not reported) with a computer-assisted clinician interview for identifying youth at high risk of suicide. This study reported sensitivity of 87 percent and specificity of 60 percent for the SRS, and fairly low PPV (38%).119 Study authors did not describe the age and sex distribution of their sample. Likewise, they did not describe the timeframe of the suicide-related questions. Additionally, this study used the screening test’s results as part of the reference test, which could inflate agreement between the screening and reference tests.

Another study conducted in adult primary care patients ages 18 to 70 years (66% between the ages of 26 and 55 years) administered a three-item questionnaire in the waiting room before a primary care visit. Each of the items for this instrument related to suicidal ideation during the past month. The items had sensitivities of 83 percent or higher and specificities of 81 percent or higher relative to a nurse-administered structured interview on the same day. The one item asking about “thoughts of death” had the highest sensitivity (100%), while the item about “feeling suicidal” had the greatest specificity (98%).67 The PPVs were quite low for these items, ranging from 6 to 30 percent. The screening and references tests’ independence in this study was unknown.

In older adults, a score of 1 or more on the five items of the GDS-SI yielded both sensitivity and specificity of 80 percent for suicidal ideation during the previous 2 weeks compared with suicide-related items on a structured interview.120 The PPV was fairly low (33%) at a cut-off of 1. The GDS-SI does not ask directly about suicidality or death, but rather asks about feelings of emptiness, worthlessness, and hopelessness, and has two items assessing happiness (or unhappiness). This may have led to poorer sensitivity on the GDS-SI than the three single items explored in the other study in adults.67 Alternatively, other differences in study or population characteristics (e.g., age, prevalence of suicidal ideation), including study quality, may explain possible between-study differences in test performance. The study of the GDS-SI maintained independence between the screening test and reference standard,120 while the other study in adults did not report whether the screening test results could be viewed by the nurses who were administering the reference test.67

Only one study reported test performance characteristics for demographic or clinical subgroups.120 This study reported that test performance characteristics did not differ across sex on the GDS-SI among older adults.

## Key Question 3: Are There Harms Associated With Screening for Suicide Risk in Primary Care Settings? Do the Harms Vary by Population Characteristics?

Three trials reported on potential adverse effects of screening, including the trial of depressed adults in four primary care practices in the United Kingdom that was included in KQ 1 (n=443).117 The two other trials were conducted in high school settings (total randomized, n=2,650).121,122 The trial conducted in depressed adults found no statistically significant increases in suicide attempts or ideation at 2-weeks followup.117 This trial had limited power and the results could be biased by differential ascertainment, since a higher proportion of those who were screened withdrew consent for followup (6.6% of screened vs. 2.2% of unscreened). While the authors did not report this result’s statistical significance, these results do suggest that a subgroup of patients may have been disturbed by the screening. Overall, attrition in this fair-quality study was also somewhat high for such short followup (23% of the screened participants and 19% of the unscreened participants dropped out overall). The impact of increased withdrawal of consent and greater loss to followup in the screened group on results is unclear, but could bias against detecting short-term increases in suicidality after screening.

Both high school-based trials randomly assigned students to be screened for suicide risk on one of two occasions, 1 to 2 days apart.121,122 The suicide screening items were embedded in screening instruments addressing broader mental health issues and current mood state, which were divided into two separate questionnaires that were administered over the course of two separate occasions. The experimental groups in both studies were asked these suicide screening questions on the first day, while the control group answered the suicide screening items during the second day. The larger trial (n=2,342) was conducted in 181 classes in six high schools in New York, which were randomized at the classroom level.122 This study reported no immediate increase in percent reporting suicidal ideation (4.8% in those who had been screened for suicide risk 2 days ago vs. 3.9% in the unscreened group) or mean suicidal ideation scores (mean, 6.5 [SD, 11.5] in the screened group vs. 6.6 [SD, 10.5] in the unscreened group on the Suicidal Ideation Questionnaire-Junior [SIQ-JR]) in response to screening. This trial had no major quality concerns and was rated as good quality. The treatment groups were comparable in terms of age, sex, and race/ethnicity, and there were no differences in attrition between groups overall (6% in the intervention group vs. 7% in the control group) or as a function of depression, substance use, or suicide attempt history.

The other smaller trial (n=308), rated fair quality, was conducted in Australia, and found no differences in anger, confusion, depression, fatigue, or tension based on the Profile of Mood States (POMS) questionnaire between the two groups immediately after being screened for suicide risk or completing other mental health-related items.121 It did find that those who were screened reported higher levels of vigor, although it seems unlikely that suicide screening would be related to increased vigor. During the study’s second session, after students in both groups had answered the suicide risk screening items, only 8.9 percent of the students rated the suicide-related items as moderately or very distressing. A fairly large proportion (31.5%), however, found the items “a little distressing.” Almost three fourths of students found the screening for suicidal ideation and self-harm to be moderately or very “worthwhile.” Those who screened positive reported higher levels of distress and found the screening less worthwhile than those who did not screen positive. While this trial did not report group-specific followup, it did have high attrition overall for one of the forms (POMS) from the first to the second day (33% attrition overall).

While none of available trials in adolescents or adults were definitive, short-term harms due to suicide screening cannot be dismissed based on this evidence. None of the studies examined screening-related risk among demographic subgroups.

## Key Question 4: For Those Identified as Being at Increased Risk of Suicide, Do Behaviorally-Based or Pharmacologic Interventions to Reduce Suicide Risk Result in Improved Health Outcomes? Does the Effect of the Interventions Vary by Population Characteristics? Key Question 5: For Those Identified as Being at Increased Risk of Suicide, Do Behaviorally-Based or Pharmacologic Interventions to Reduce Suicide Risk Result in Improved Intermediate Outcomes? Does the Effect of the Interventions Vary by Population Characteristics?

We discuss health and intermediate outcomes together for all 49 trials that were included for either KQ 4 or KQ 5 to avoid excessive redundancy. Table 4 (for adult trials) and Table 5 (for adolescent trials) list all included trials and outcomes reported by each trial.

Table 4 Included Trials for Benefits and Harms of Treatment With Outcomes Reported in Adults and Older Adults (Key Questions 4 and 5

Intervention category | Study | Population description | N randomized | Country | Suicide deaths | Suicide attempts/DSH | Hospitalization or ED use | Other health outcome | Suicidal ideation | Depression | Hopelessness
Cognitive behavioral therapy | Brown 2005^126, 168,169^ | Adults (18–66 years) with a suicide attempt within 48 hours of visit to ED, identified in ED | 120 | United States | | ■^**^ | | | □ | ■^*^ | ◘
Cognitive behavioral therapy | Evans 1999^134^ | Adults (16–50 years) presenting to participating mental health center or hospital following DSH | 34 | United Kingdom | | □^*^ | | □ | | ■
Cognitive behavioral therapy | Hawton 1987^137^ | Adults (≥16 years) admitted to general hospital following overdose and “continuing problems which they were willing to tackle with the help of the counselors” | 77 | United Kingdom | □ | □^*^ | | □ | | □^*^
Cognitive behavioral therapy | Marasinghe 2012^142^ | Adults (15–74 years) admitted to hospital after attempting self-harm; displayed significant suicidal intent at the interview or on the BSSI | 68 | Sri Lanka | | | | | ■ | ■
Cognitive behavioral therapy | Rudd 1996^144^ | Young adults with suicide attempt or suicidal ideation with mood disorder or suicidal ideation and alcohol (age range NR) | 302 | United States | | | | | □^*^ | □^*^ | □
Cognitive behavioral therapy | Samaraweera 2007^105^ | Adult (15–64 years) sample from a population study, screening positive for suicidality | 10 | Sri Lanka | | | | | ■^**^
Cognitive behavioral therapy | Slee 2008^145,170^ | Adults (15–35 years) visiting a mental health center due to self-harm | 90 | The Netherlands | □ | ■ | ◘ | | | ■^*^
Cognitive behavioral therapy | Tyrer 2003^146, 171–174^ | Adults (16–65 years) presenting to Accident and Emergency Service after episode of DSH, with ≥1 previous attempts | 480 | United Kingdom | □ | □^*^ | | □ | | □^*^
Dialectical behavior therapy | Carter 2010^128^ | Adult female (18–65 years) BPD patients with ≥3 DSH episodes in the past year | 73 | Australia | | □ | ■ | ◘
Dialectical behavior therapy | Linehan 1991^140^ | Adult female (18–45 years) BPD patients with ≥2 episodes of DSH in the past 5 years, including one in the past 8 weeks | 63 | United States | | □^*^ | ■ | | □ | □ | □
Dialectical behavior therapy | Linehan 2006^141, 175,176^ | Adult female (18–45 years) BPD patients with ≥2 episodes of DSH in the past 5 years, including one in the past 8 weeks | 111 | United States | □ | ■^*^ | ■ | | □^*^ | □^*^
Dialectical behavior therapy | van den Bosch 2005^148,177^ | Adult female (18–65 years) BPD patients recruited from mental health institutions and addiction treatment services | 64 | The Netherlands | | □^*^
Problem-solving therapy | Bannan 2012^109^ | Adults (18–53 years) with a self-poisoning episode, previous DSH within past 12 months | 20 | Ireland | | | | | □^*^ | ■^**^ | ■^*^
Problem-solving therapy | Fitzpatrick 2005^106^ | University students (18–24 years) screening positive for suicide (on BSS), participated in study for extra class credit | 110 | United States | □ | | | | ■^**^ | ■^**^ | □^*^
Problem-solving therapy | Hatcher 2011^107^ | Adults (≥16 years) presenting to hospital for self-harm, but not hospitalized for more than 48 hours | 522 | New Zealand | | □^*^ | | | ■^**^ | ■^*^ | ■^*^
Psychodynamic or interpersonal therapy | Bateman 1999^124,178^ | Adult (16–65 years) BPD patients, referred to psychiatric unit | 44 | United Kingdom | | ■^**^ | ■ | ■ | | ■^*^
Psychodynamic or interpersonal therapy | Guthrie 2001^135, 179^ | Adults (18–65 years) presenting to ED after episode of DSH | 119 | United Kingdom | □ | ■^*^ | | | ■^*^ | ◘^*^
Other therapy, with direct therapeutic contact | Comtois 2011^131^ | Adults (19–62 years) evaluated for suicide attempt or imminent risk, but judged safe for discharge; no mental health care available for 2 weeks | 32 | United States | | □^*^ | □ | ■ | ■
Other therapy, without direct therapeutic contact | Kovac 2002^138^ | University students (18–42 years) who screened positive for increased risk of suicide | 121 | United States | | | | | □^*^ | □^*^
Medication: Lithium | Lauterbach 2008^139^ | Adults (≥18 years) with a suicide attempt in past 3 months and depressive spectrum disorder, identified through screening at psychiatric ED and inpatient unit | 167 | Germany | ■ | □
Practice-based interventions | Almeida 2012^152,180^ | General practitioners recruited older adult patients (60–101 years) | 373 GPs, 21,762 patients | Australia | | ■^†^ | | | | □
Practice-based interventions | Bennewith 2002^115^ | Adult (16–95 years) DSH patients identified through case registry, updated weekly, of all DSH patients in hospital Accident and Emergency Service | 1,932 | United Kingdom | | □^*^
Practice-based interventions | Clarke 2002^130^ | Adults (≥20 years) presenting to Accident and Emergency Service following DSH | 526 | United Kingdom | | □^*^ | □
Practice-based interventions | Szanto 2007^151^ | General practitioners (age range NR) providing services to inhabitants of region with high suicide rates | Two geographic locations, n≈127,000 | Hungary | □
Practice-based interventions | Bruce 2004^114, 181–187^ | Depressed older adults (60–94 years), recruited from primary care screening for depression | 598 | United States | □ | □^*^ | | ■ | ◘ | ■
Improving treatment adherence with direct person-to-person contact | Allard 1992^123^ | Individuals with an ED visit for suicide attempt at study hospitals (age range NR) | 150 | Canada | □ | □^*^
Improving treatment adherence with direct person-to-person contact | Cedereke 2002^129^ | Individuals treated at ED for suicide attempt, recruited 1 month after attempt (age range NR) | 216 | Sweden | □ | □^*^ | | □ | ■
Improving treatment adherence with direct person-to-person contact | Crawford 2010^132^ | Adults (18–65 years) presenting to ED following DSH and misusing alcohol | 103 | United Kingdom | | □^*^
Improving treatment adherence with direct person-to-person contact | Currier 2010^133^ | Suicidal adults (18–69 years) identified and enrolled in ED | 122 | United States | | | | □ | □ | □
Improving treatment adherence with direct person-to-person contact | Vaiva 2006^147^ | Adults (18–65 years) with a suicide attempt by drug overdose, cleared for discharge from ED | 605 | France | □ | □^*^
Improving treatment adherence with direct person-to-person contact | van Heeringen 1995^149^ | Adult (≥15 years) suicide attempters referred to Accident and Emergency Services | 516 | Belgium | □ | □^*^
Improving treatment adherence with direct person-to-person contact | Welu 1977^150^ | Adult (≥16 years) suicide attempters brought to ED | 143 | United States | | □^*^
Improving treatment adherence without direct person-to-person contact | Beautrais 2012^125^ | Adults (≥16 years) presenting to psychiatric ED with suicide attempt or DSH | 327 | New Zealand | | □^*^
Improving treatment adherence without direct person-to-person contact | Carter 2007^127, 188^ | Adults (≥16 years) presenting to Toxicology Service for self-poisoning | 772 | Australia | | □^*^ | □
Improving treatment adherence without direct person-to-person contact | Hassanian 2011^136^ | Adolescents and adults (≥12 years) with a hospital admission for self-poisoning | 2,300 | Iran | | ■^*^ | | | ■
Improving treatment adherence without direct person-to-person contact | Motto 2001^143^ | Individuals refusing further treatment 1 month postdischarge inpatient stay after suicide attempt (age range NR) | 843 | United States | ◘ | | | □

* Included in meta-analysis, shown on forest plot figure.

** Difference in statistical significance of results between meta-analysis and original study, usually due to differences in outcomes analyzed (e.g., change from baseline in meta-analysis vs. repeated measures group^*^time effect in study; analyzing risk ratios in meta-analysis vs. odds ratios in study, use of unadjusted results in meta-analysis but adjusted p-values are presented in study).

† Combined outcomes of suicide attempts and suicidal ideation.

■ Statistically significant group differences for half or more of reported outcomes/followups.

◘ Statistically significant group differences for at least one but fewer than half of reported followups or analyses.

□ No statistically significant group differences reported.

Abbreviations: BPD = borderline personality disorder; BSSI = Beck Scale for Suicidal Ideation; DSH = deliberate self-harm; ED = emergency department; NR = not reported.

Table 5 Included Trials for Benefits and Harms of Treatment With Outcomes Reported in Adolescents (Key Questions 4 and 5)

Intervention Category | Study | Population description | N randomized | Country | Suicide deaths | Suicide attempts/DSH | Hospitalization or ED use | Other health outcome | Suicidal ideation | Depression | Hopelessness
Cognitive behavioral therapy | Donaldson 2005^153^ | Adolescents (12–17 years) presenting to ED or inpatient unit after suicide attempt | 39 | United States | | □^*^ | | | □^*^ | □^*^
Cognitive behavioral therapy | Esposito-Smythers 2011^163,189^ | Adolescent (13–17 years) psychiatric inpatients with a suicide attempt in past 3 months or significant suicidal ideation in the past month, and an alcohol or cannabis use disorder | 40 | United States | | ■^*^ | ■ | | □ | □
Cognitive behavioral therapy | Greenfield 2002^156^ | Adolescents (12–17 years) presenting to ED after suicide attempt | 286 | Canada | □ | □^*^ | ■ | □ | □
Developmental group therapy | Green 2011^155,190^ | Adolescents (12–17 years) with two DSH episodes in past 12 months, recruited from mental health services centers | 366 | United Kingdom | □ | □^*^ | □ | □^**^ | □^*^ | □^*^
Developmental group therapy | Hazell 2009^157^ | Adolescents (12–16 years) with two DSH episodes in past 12 months (including one in past 3 months), referred to mental health service | 72 | Australia | | □^*^ | □ | □^*^ | □^*^ | □^*^
Developmental group therapy | Wood 2001^160^ | Adolescents (12–16 years) referred to mental health services after deliberate self-harm | 63 | United Kingdom | | ■^*^ | | □^*^ | □^*^ | □^*^
Psychodynamic or interpersonal therapy | Chanen 2008^164^ | Adolescents (15–18 years) with two or more symptoms of BPD referred to mental health services for acute, severe mental health problems | 86 | Australia | | □^*^ | | □
Psychodynamic or interpersonal therapy | Diamond 2010^108,191^ | Adolescents (12–17 years) identified as suicidal by screening during primary care or ED visits | 66 | United States | | □^*^ | | | ■^**^ | □^*^
Psychodynamic or interpersonal therapy | Tang 2009^159^ | Adolescents (12–18 years) with moderate-severe depression, suicide ideation, previous suicide attempt, moderate-severe anxiety, or significant hopelessness, based on school-based screening. Random sample from participating schools selected for study | 73 | Taiwan | | | | | ■^*^ | ■^*^ | ■
Other therapy, with direct therapeutic contact | Eggert 2002^154,192–194^ | Adolescents (14–19 years) at increased risk of high school dropout who screened positive for increased risk of suicide | 238 | United States | | □ | | | ■ | ■ | ■
Other therapy, with direct therapeutic contact | Hooven 2012^161^ | Adolescents (14–19 years) who screened positive for suicide risk or at least two of the following: moderate depression, moderate suicidal ideation/threats, and/or alcohol and drug use | 615 | United States | | □ | | | ■ | ◘ | ◘
Other therapy, without direct therapeutic contact | King 2009^158^ | Hospitalized adolescents (13–17 years) with suicidal ideation or attempt within the last 4 weeks | 448 | United States | □ | □^*^ | □ | | ◘ | □ | □
Improving treatment adherence without direct person-to-person contact | Robinson 2012^162,195^ | Young individuals (15–24 years) with a history of suicide threats, ideation, attempts, and/or DSH and did not meet entry criteria for service, either because they were not unwell enough or were receiving treatment elsewhere | 165 | Australia | | □ | | | □ | □ | □

* Included in meta-analysis, shown on forest plot figure.

** Difference in statistical significance of results between meta-analysis and original study, usually due to differences in outcomes analyzed (e.g., change from baseline in meta-analysis vs. repeated measures group^*^time effect in study; analyzing risk ratios in meta-analysis vs. odds ratios in study, use of unadjusted results in meta-analysis but adjusted p-values are presented in study).

■Statistically significant group differences for half or more of reported outcomes/followups.

◘Statistically significant group differences for at least one but fewer than half of reported followups or analyses.

□No statistically significant group differences reported.

Abbreviations: DSH = deliberate self-harm; ED = emergency department.

While some treatment trials used the term “suicide attempt,” others used “self-harm” or “deliberate self-harm” (DSH). The use of these terms appeared to be primarily due to differences in terminology between countries, rather than differences in the study populations. Almost all trials in the United Kingdom, Australia, New Zealand, and the Netherlands used the terms “self-harm” or “DSH.” Studies conducted in other countries, including the United States, usually used the term “suicide attempt.” Three trials limited to people with BPD or BPD symptoms used the term “parasuicide” (defined as any intentional, acute self-injurious behavior with or without suicidal intent, including both suicide attempts and self-mutilative behaviors). Most trials did not characterize the “seriousness” or lethality of the suicide attempts or self-harm, and presumably included a range of intent to die. These populations, however, likely differed on the proportion of participants with frequent low-lethality suicide attempts. Unfortunately, we were unable to capture this dimension fully due to inconsistent reporting. We use the term “suicide attempt” when referring to this outcome generically. We use the terminology used in the trial when referring to a specific trial’s results. Table 6 (for adult trials) and Table 7 (for adolescent trials) list the information on previous suicide attempts or self-harm that was provided, as well as demographic information and other population characteristics, such as reporting of substance abuse and depressive disorders. We used the high-lethality results for our outcome when researchers reported on suicide attempts with high lethality or intent to die separately from low-lethality suicide attempts. The relative differences between groups were similar for the different outcomes when multiple suicide or self-harm outcomes were reported in this way (data not shown).

Table 6 Population Characteristics of Included Studies: Adults and Older Adults (Key Questions 4 and 5)

Intervention category | Study | Age range (mean age) | % Female | % Nonwhite | % Substance use diagnosis | % Depressive or mood disorder diagnosis | % Previous suicide attempt (average # of previous attempts) | % Previous DSH (average # of previous DSH)
Cognitive behavior therapy | Brown 2005^126,168,169^ | 18–66 (35) | 61 | 65 | 68 | 77 | 72 (NR) | NR (NR)
Cognitive behavior therapy | Evans 1999^134^ | 16–50 (NR) | NR | NR | NR | NR | NR (NR) | 100 (NR)
Cognitive behavior therapy | Hawton 1987^137^ | ≥16 (29) | 66 | NR | NR | NR | 31 (NR) | NR (NR)
Cognitive behavior therapy | Marasinghe 2012^142^ | 15–74 (31) | 50 | 100 | NR | NR | NR (NR) | NR (NR)
Cognitive behavior therapy | Rudd 1996^144^ | “Young adult” (22) | 18 | 39 | 44 (alcohol only) | 18 | 41 (NR) | NR (NR)
Cognitive behavior therapy | Samaraweera 2007^105^ | 15–64 (36) | 60 | NR | 0 (alcohol dependence) | NR | NR (NR) | NR (NR)
Cognitive behavior therapy | Slee 2008^145,170^ | 15–35 (24) | 90 | 2 | 16 | 89 | 58 (NR)^*^ | NR (13)^*^
Cognitive behavior therapy | Tyrer 2003^146,171–174^ | 16–65 (32) | 68 | 10 | 0 (alcohol or drug dependence) | NR | NR (NR) | 100 (NR)
Dialectical behavior therapy | Carter 2010^128^ | 18–65 (24) | 100 | NR | 69 | NR | NR (NR) | 100 (20)^*^
Dialectical behavior therapy | Linehan 1991^140^ | 18–45 (NR) | 100 | NR | 0 (substance dependence) | NR | NR (NR) | 100 (NR)^§^
Dialectical behavior therapy | Linehan 2006^141,175,176^ | 18–45 (29) | 100 | 13 | 30 | 72 | NR (NR) | 100 (NR)
Dialectical behavior therapy | van den Bosch148,177 | 18–65 (35) | 100 | 3 | 82 | NR | 71 (NR) | 93 (14)║
Problem-solving therapy | Bannan 2012^109^ | 18–53 (29) | NR | NR | 0 (alcohol or drug dependence | 50 | NR (NR) | 100 (2)^¶^
Problem-solving therapy | Fitzpatrick 2005^106^ | 18–24 (19) | 54 | 25 | NR | NR | NR (NR) | NR (NR)
Problem-solving therapy | Hatcher 2011^107^ | ≥16 (34) | 69 | 39 | NR | NR | NR (NR) | 55 (NR)
Psychodynamic or interpersonal therapy | Bateman 1999^124,178^ | 16–65 (32) | 50 | NR | 39 (periodic substance abuse) | 57 | NR (NR) | NR (8–9)║
Psychodynamic or interpersonal therapy | Guthrie 2001^135,179^ | 18–65 (31) | 56 | 12 | NR | NR | 60 (NR) | NR (NR)
Other therapy, with direct therapeutic contact | Comtois 2011^131^ | 19–62 (37) | 62 | 44 | NR | NR | NR (5.4) | NR (NR)
Other therapy, without direct therapeutic contact | Kovac 2002^138^ | 18–42 (23) | 73 | 26 | NR | 54 (previous treatment for depression) | 14 (NR)^†^ | NR (NR)
Medication: Lithium | Lauterbach 2008^139^ | ≥18 (39) | 57 | NR | 8 | 76 | 44 (NR) | NR (NR)
Practice-based interventions | Almeida 2012^152,180^ | 60–101 (72) | 59 | NR | 13 (risky alcohol use) | 8 (per PHQ-9 screen) | 4.2 (NR)^‡‡^ | NR (NR)
Practice-based interventions | Bennewith 2002^115^ | 16–95 (32) | 59 | NR | NR | NR | NR (NR) | 13 (NR)
Practice-based interventions | Clarke 2002^130^ | ≥20 (33) | 56 | NR | 13 (alcohol abuse) | 56 (per HADS screen) | NR (NR) | 47 (NR)
Practice-based interventions | Bruce 2004^114,181–187^ | 60–94 (70) | 72 | 28 | NR | 66 | NR (NR) | NR (NR)
Practice-based interventions | Szanto 2007^151^ | NR (NR) | NR^††^ | NR^††^ | NR | NR | NR (NR) | NR (NR)
Improving treatment adherence with direct person-to-person contact | Allard 1992^123^ | NR (NR) | 57 | NR | 53 | 87 | 50 (2) | NR (NR)
Improving treatment adherence with direct person-to-person contact | Cedereke 2002^129^ | NR (41) | 66 | NR | NR | 42 (mood disorder) | NR (1.1) | NR (NR)
Improving treatment adherence with direct person-to-person contact | Crawford 2010^132^ | 18–65 (37) | 49 | NR | 100 (alcohol misuse) | NR | NR (NR) | NR (NR)
Improving treatment adherence with direct person-to-person contact | Currier 2010^133^ | 18–69 (33) | 57 | 40 | >50 (“over half” tested positive for drugs) | 19 | “majority” (NR) | NR (NR)
Improving treatment adherence with direct person-to-person contact | Vaiva 2006^147^ | 18–65 (36) | 73 | NR | NR | NR | 9 (NR)^‡^ | NR (NR)
Improving treatment adherence with direct person-to-person contact | van Heeringen 1995^149^ | ≥15 (34) | 57 | NR | NR | 15 (mood disorder) | 30 (NR) | 89 (NR)^¶^
Improving treatment adherence with direct person-to-person contact | Welu 1977^150^ | ≥16 (29) | NR | NR | 40 (drink to excess) | NR | 60 (NR) | NR (NR)
Improving treatment adherence without direct person-to-person contact | Beautrais 2012^125^ | ≥16 (34) | 66 | NR | NR | NR | NR (NR) | 18 (0.4)^**^
Improving treatment adherence without direct person-to-person contact | Carter 2007^127,188^ | ≥16 (33) | 68 | NR | NR | NR | NR (NR) | 17 (NR)^¶^
Improving treatment adherence without direct person-to-person contact | Hassanian 2011^136^ | ≥12 (24) | 66 | NR | 9 (illicit drug use) | NR | 34 (NR) | NR (NR)
Improving treatment adherence without direct person-to-person contact | Motto 2001^143^ | NR (33) | 56 | NR | NR | NR | NR (NR) | NR (NR)

* In the past 3 months.

† Previous treatment for suicide attempt.

‡ Four or more attempts in past 3 years.

§ Participants were parasuicidal.

║ Median number of self-mutilation acts.

¶ Self-poisoning.

** In the past 12 months.

†† Two regions were comparable in proportion of females (52%) and older residents (22%).

‡‡ Combined outcome of suicide attempts and suicidal ideation.

Abbreviations: DSH = deliberate self-harm; HADS = Hospital Anxiety and Depression Scale; NR = not reported; PHQ-9 = Personal Health Questionnaire 9-item Depression Scale.

Table 7 Population Characteristics of Included Studies: Adolescents (Key Questions 4 and 5)

Intervention category | Study | Age range (mean age) | % Female | % Nonwhite | % Substance use diagnosis | % Depressive or mood disorder diagnosis | % Previous suicide attempt (average # of previous attempts) | % Previous DSH (average # of previous DSH)
Cognitive behavior therapy | Donaldson 2005^153^ | 12–17 (15) | 82 | 15 | 19 (alcohol) 45 (cannabis) | 29 | 48 (NR) | NR (NR)
Cognitive behavior therapy | Esposito-Smythers 2011^163,189^ | 13–17 (16) | 67 | 11 | 64 (alcohol) 83 (cannabis) 14 (other substance) | 94 | 75 (NR) | 72 (NR)
Cognitive behavior therapy | Greenfield 2002^156^ | 12–17 (14) | 69 | 29 | >50 (~50% report each of alcohol abuse and illegal drug use) | 48 | 37 (NR)^*^ | NR (NR)
Developmental group therapy | Green 2011^155,190^ | 12–17 (NR) | 88 | 6 | NR | 62 | NR (NR) | 100 (21)^§^
Developmental group therapy | Hazell 2009^157^ | 12–16 (15) | 90 | NR | 0 (substance misuse) 4 (dysfunctional alcohol use) | 57 | NR (NR) | 100 (NR)
Developmental group therapy | Wood 2001^160^ | 12–16 (14) | 78 | NR | 44 (intoxicated at least weekly) | 83 | NR (NR) | 79 (4.1)^‡^
Psychodynamic or interpersonal therapy | Chanen 2008^164^ | 15–18 (16) | 76 | NR | 37 (substance abuse) | 15 | NR (NR) | 94 (9.5)║
Psychodynamic or interpersonal therapy | Diamond 2010^108, 191^ | 12–17 (15) | 83 | 74 | NR | 47 | 62 (NR) | NR (NR)
Psychodynamic or interpersonal therapy | Tang 2009^159^ | 12–18 (15) | 66 | NR | 0 (substance abuse) | 100 | NR (NR) | NR (NR)
Other therapy, with direct therapeutic contact | Eggert 2002^154,192–194^ | 14–19 (16) | 49 | 57 | NR | NR | NR (0.2)^†^ | NR (NR)
Other therapy, with direct therapeutic contact | Hooven 2012^161^ | 14–19 (16) | 60 | 34 | NR | NR | NR (NR) | NR (NR)
Other therapy, without direct therapeutic contact | King 2009^158^ | 13–17 (16) | 71 | 16 | 21 (alcohol or substance abuse) | 88 | 75 (NR) | NR (NR)
Improving treatment adherence without direct person-to-person contact | Robinson 2012^162, 195^ | 15–24 (19) | 64 | NR | 25 (substance use or dependence disorder) | 67 | 16 (NR) | 68 (10.7)

* In the past 6 months.

† In the past 1 month.

‡ Self-poisoning.

§ In the past 12 months.

║ Median number of lifetime “parasuicide” episodes.

Abbreviations: DSH = deliberate self-harm; NR = not reported.

We organized treatment trials into three broad intervention groups of psychotherapy, medication, and enhanced usual care. Among the psychotherapy trials, 11 were limited to adolescents.108,153–161,163,164 The remaining trials were limited to adults or included both adolescents and adults. Thus, we discuss the results for psychotherapy trials separately for trials limited to adolescents and those that included adults. Subgroups of intervention types within the psychotherapy and enhanced usual care groups were also defined, but these trials did not explain between-study differences after studies were stratified by age group. Thus, we briefly report on the intervention subgroups, but emphasize overall broad intervention categories for summarizing results. Table 8 (for adult trials) and Table 9 (for adolescent trials) describe intervention characteristics and the control groups in all included trials.

Table 8 Intervention Characteristics of Included Studies: Adults and Older Adults (Key Questions 4 and 5)

Intervention category | Study | Brief description of intervention | Control condition | # of sessions | Duration of treatment (m) | Sessions per week during most intensive phase
Cognitive behavioral therapy | Brown 2005^126, 168,169^ | Individual cognitive therapy | UC by community clinicians, including case management | 10 | 2.5 | 2
Cognitive behavioral therapy | Evans 1999^134^ | Brief manual-based problem-focused individual cognitive therapy | Psychiatric UC: inpatient, outpatient, day-hospital, community treatment | 2–6 | NR | NR
Cognitive behavioral therapy | Hawton 1987^137^ | Brief problem-focused individual therapy | General practitioner care (including referrals as needed) | 1–8 | NR | NR
Cognitive behavioral therapy | Marasinghe 2012^142^ | Brief mobile phone-based counseling and prerecorded messages; one initial in-person session | UC with waitlist | 11 | 6 | 3
Cognitive behavioral therapy | Rudd 1996^144^ | 2-week partial hospitalization (9 hours per day), psychoeducational and psychotherapeutic groups and (as needed) individual crisis counseling | UC: inpatient and/or outpatient care (e.g., individual and/or group therapy, time-limited stress management group, open-ended process-orientated support group) | 18 | 0.5 | 7
Cognitive behavioral therapy | Samaraweera 2007^105^ | Culturally relevant (for Sri Lanka) individual cognitive behavioral | UC, involved referral to local psychiatrist and mental health team. | 3–6 | 0.75 −1 | 1
Cognitive behavioral therapy | Slee 2008^145,170^ | Individual CBT with option for partner or parent participation | UC included psychotropic medications, psychotherapy, and psychiatric hospitalizations | 12 | 5.5 | 1
Cognitive behavioral therapy | Tyrer 2003^146,171–174^ | Brief manual-based problem-focused individual cognitive therapy | UC, initial psychiatric assessment followed by outpatient care, occasional day-patient care or referral back to the general practitioner | 5–7 | 3–6 | NR
Dialectical behavior therapy | Carter 2010^128^ | Team-based, manualized, directive group and individual treatment | UC with 6-month waitlist | 100+ (estimate) | 12 | NR
Dialectical behavior therapy | Linehan 1991^140^ | Team-based, manualized, directive group and individual treatment | UC, given alternative therapy referrals | 104 | 12 | 2
Dialectical behavior therapy | Linehan 2006^141, 175,176^ | Team-based, manualized, directive group and individual treatment | Community treatment by selected experts | 104 | 12 | 2
Dialectical behavior therapy | van den Bosch148,177 | Team-based, manualized, directive group and individual treatment | UC, clinical management from original referral source, attended no more than two sessions per month | 104 | 12 | 2
Problem-solving therapy | Bannan 2012^109^ | Problem-solving therapy group | UC, standard individual therapy in outpatient or day hospitals | 8 | 2 | 2
Problem-solving therapy | Fitzpatrick 2005^106^ | Problem-solving video/slide presentation | Video-matched control; focused on current health issues such as proper diet, exercise and sleep habits | 1 | 1 day | NA
Problem-solving therapy | Hatcher 2011^107^ | Manual-based individual problem-solving therapy | UC, possible referral to multidisciplinary teams, mental health crisis teams, alcohol or drug treatment centers, etc. | 4–9 | 3 | NR
Psychodynamic or interpersonal therapy | Bateman 1999^124, 178^ | Long-term partial hospitalization, guided by psychoanalytic model and twice weekly long-term psychoanalytic group | UC; could involve inpatient admission, partial hospitalization program, outpatient consultation, community center attendance, medication | 400 (estimate) | 17 | 7
Psychodynamic or interpersonal therapy | Guthrie 2001^135, 179^ | Psychodynamic individual interpersonal therapy | UC; assessment by a casualty doctor in the ED; referral to outpatient psychiatry, addiction services, or advised to consult with general practitioner | 4 | 1 | NR
Other therapy, with direct therapeutic contact | Comtois 2011^131^ | Collaborative assessment and management of suicidality | Enhanced UC: intake by psychiatric provider, 1 to 11 visits as needed with case manager for medication management | 4–12 | NR | NR
Other therapy, without direct therapeutic contact | Kovac 2002^138^ | Writing about difficult times with or without encouragement to “reinterpret” the stressful events through writing | Writing about mundane matters; same number of sessions as intervention group | 4 | 0.5 | 2
Medication: Lithium | Lauterbach 2008^139^ | 200 mg/wk increase until sufficient blood level attained (0.6 to 0.8 mmol/L) (with UC) | Placebo with UC | NA | 12 | NA
Practice-based interventions | Almeida 2012^152, 180^ | An educational intervention targeting GPs that included a practice audit with personalized automated feedback, printed educational materials, and 6 monthly newsletters | A practice audit with no feedback, printed materials or newsletters | NA | 24 | NA
Practice-based interventions | Bennewith 2002^115^ | Notified GP of DSH episode, provided letter GP could send to patient and practice guidelines for assessment and treatment | UC, no specialist services | NA | NA | NA
Practice-based interventions | Bruce 2004^114,181–187^ | PCP given treatment guidelines for depression in older adults, assigned care manager to advise PCP and provide psychotherapy if needed; informed if patient reported suicidal ideation | UC plus physician education on depression treatment guideline, notification when patient diagnosed with depression or reported suicidal ideation; risk management guidelines followed in these cases | NA | NA | NA
Practice-based interventions | Clarke 2002^130^ | Case management: comprehensive assessment and determination of treatment needs, monitoring treatment and patient status | UC: triage and medical and psychiatric assessment/treatment as required | NA | NA | NA
Practice-based interventions | Szanto 2007^151^ | 5-year depression-management educational program for GPs and nurses with consultation service, special depression treatment clinics | UC | 4 main provider education sessions with additional optional lectures | 60 | NA
Improving treatment adherence with direct person-to-person contact | Allard 1992^123^ | Specific schedule of treatment prescribed, (starting with weekly visits, then tapering off); outreach in case of missed appointments; content of treatment left to discretion of provider | UC: subjects requiring admission were put under the care of other personnel; otherwise, treated by regular hospital personnel | Up to 19 | 12 | 1
Improving treatment adherence with direct person-to-person contact | Cedereke 2002^129^ | Phone contacts to assess and provide encouragement to stay in/return to treatment if needed | UC | 2 | 8 | 2
Improving treatment adherence with direct person-to-person contact | Crawford 2010^132^ | Appointment card with alcohol counselor; counselor visit included assessment, advice on alcohol reduction, referral to treatment | Information leaflet on alcohol and health | 1 | 1 day | NA
Improving treatment adherence with direct person-to-person contact | Currier 2010^133^ | Extensive clinical assessment within 48 hours of discharge at location of participant’s choice, referral to community resources | UC, offered assessment appointment at clinic within 5 days of discharge, with same content as intervention group visit | 1 | 1 day | NA
Improving treatment adherence with direct person-to-person contact | Vaiva 2006^147^ | Single phone contact 1 or 3 months postdischarge to revisit recommended treatment, encourage re-engagement in treatment if needed, provide crisis counseling as needed | UC, no telephone contact | 1 | 1 day | NA
Improving treatment adherence with direct person-to-person contact | van Heeringen 1995^149^ | Home visits for patients noncompliant with initial treatment referral, followup to check on compliance | All patients referred to outpatient after-care | 1–2 | NR | NR
Improving treatment adherence with direct person-to-person contact | Welu 1977^150^ | Contact immediately after ED discharge by phone; home visit for assessment and treatment plan/referral, continued monitoring | UC; either given an appointment slip for an evaluation at the Community Mental Health Center the next day or immediately hospitalized | NR | 4 | 2
Improving treatment adherence without direct person-to-person contact | Beautrais 2012^125^ | Sent postcards at 2 wk, 6 wk, 3 mo, 6 mo, 9 mo, and 12 mo after DSH episode wishing patient well, inviting them to contact provider | UC, crisis assessment and referral to inpatient community-based mental health services | 0 | 12 | NA
Improving treatment adherence without direct person-to-person contact | Carter 2007^127,188^ | Sent postcards at 1, 2, 3, 6, 8, 10, and 12 mo after DSH episode wishing patient well, inviting them to contact provider | UC | 0 | 12 | NA
Improving treatment adherence without direct person-to-person contact | Hassanian 2011^136^ | Sent postcards at 1, 2, 3, 6, 8, 10, and 12 mo after DSH episode in addition to receiving one on birthday wishing patient well, inviting them to contact provider | UC (which is minimal in Tehran) | 0 | 12 | NA
Improving treatment adherence without direct person-to-person contact | Motto 2001^143^ | 24 letters over 5 years, expressing concern and inviting participant to contact staff member | No further contact | 0 | 60 | NA

Abbreviations: CBT = cognitive behavioral therapy; DSH = deliberate self-harm; ED = emergency department; GP = general practitioner; NA = not applicable; NR = not reported; PCP = primary care provider; UC = usual care.

Table 9 Intervention Characteristics of Included Studies: Adolescents (Key Questions 4 and 5)

Intervention category | Study | Brief description of intervention | Control condition | # of sessions | Duration of treatment (m) | Sessions per week during most intensive phase
Cognitive behavioral therapy | Donaldson 2005^153^ | Individual skills-based treatment and brief contact with parents at each session and 1 to 3 family sessions | Unstructured sessions addressing reported symptoms and problems on same schedule of sessions as intervention group | 12–16 | 6 | 1
Cognitive behavioral therapy | Esposito-Smythers 2011^163,189^ | Individual skills development with youth, parenting and other skills development for parents with separate therapist, and family sessions targeting suicidality and substance misuse | UC, determined and provided by community-based providers, including availability of resource information, emergency and nonemergent appointments | 34+ | 12 | 1
Cognitive behavioral therapy | Greenfield 2002^156^ | Phone contact immediately after ED visit, involving in-depth assessment and treatment | UC, continue treatment initiated in ED, including hospitalization, outpatient care or referral to a variety of community resources | NR | NR | NR
Developmental group therapy | Green 2011^155,190^ | Developmental group psychotherapy | UC, varied by center | 6+ | 1.5+ | 1
Developmental group therapy | Hazell 2009^157^ | Developmental group psychotherapy | UC, provided by community-based adolescent mental health service, such as individual or family counseling, medication, or care coordination activities | 6+ | Up to 12 | 1
Developmental group therapy | Wood 2001^160^ | Developmental group psychotherapy | UC, included family sessions, nonspecific counseling with adolescent, and psychotropic medications | 6+ | 6+ | 1
Psychodynamic or interpersonal therapy | Chanen 2008^164^ | Cognitive analytic therapy | UC, standardized good clinical care with modular treatment package | 24 | 6 | 1
Psychodynamic or interpersonal therapy | Diamond 2010^108, 191^ | Process-oriented and emotion-focused attachment-based family therapy | Facilitated referral process (found provider, set up initial appointment, encouraged attendance) with ongoing clinical monitoring | NR | 3 | NR
Psychodynamic or interpersonal therapy | Tang 2009^159^ | Intensive individual interpersonal psychotherapy | Psychoeducation and irregular individual supportive counseling with teacher who learned basic counseling skills | 18 | 1.5 | 3
Other therapy, with direct therapeutic contact | Eggert 2002^154,192–194^ | Computer-assisted suicide assessment, motivational counseling session, and identification of school-based case manager to support connection between school, parents, and youth | Interviewer implemented school policy and used standardized social connections procedures, including notifying parents and staff personnel | 1 | 1 day | NA
Other therapy, with direct therapeutic contact | Hooven 2012^161^ | C-CARE: Computer-assisted suicide assessment, motivational counseling session, and identification of school-based case manager to support connection between school, parents, and youth P-CARE: 2 parent sessions, reviewing suicide risk, support and communication skills, conflict reduction, youth mood management C+P-CARE: Both of the above | UC, 30-minute interview addressing suicide risk factors, derived from C-CARE interview (involves connection to school resources and parent phone call) | C-CARE:1 P-CARE:2 | NR | NA
Other therapy, without direct therapeutic contact | King 2009^158^ | Youth-nominated support person trained to provide support to the youth | UC | NA | NA | NA
Improving treatment adherence without direct person-to-person contact | Robinson 2012^162, 195^ | Monthly postcards for 12 months, expressing interest in person’s well-being, reminding them about previously identified sources of help, describing 1 of 6 rotating self-help strategies (e.g., physical activity, books, Web sites) | UC, treatment support the individual was receiving at the time (e.g., support from general practitioner, school counselor, private psychiatrist or psychologist) and received initial sources of help interview but no postcards | 0 | 12 | NA

Abbreviations: ED = emergency department; NA = not applicable; NR = not reported; UC = usual care.

### Psychotherapy Interventions

Thirty trials investigated the use of a specific psychotherapeutic treatment approach, usually compared with usual care. Nineteen of these trials were conducted in adults105–107,109,124,126,128,131, 134,135,137,138,140–142,144–146,148 and 11 were conducted in adolescents.108,153–161,163,164 Twenty-one of these trials (combining adult and adolescent trials) used cognitive behavioral treatment (CBT) or an approach that included substantial CBT elements. We describe these interventions broadly as “CBT and related” or “CBT-related.” While this is a heterogeneous group of trials, there were important commonalities among the CBT-related trials in their attention to the connection between thoughts, feelings, and behavior, and all included some type of specific skills development, such as problem solving, managing affect, and communication. We further divided the CBT-related trials into four subgroups: CBT,105,126,134,137,142,144–146,153,156,163 dialectical behavior therapy (DBT) (developed for patients with BPD),128,140,141,148 problem-solving therapy, 106,107,109 and developmental group therapy (in adolescents only).155,157,160 Other nonCBT approaches included psychodynamic or interpersonal approaches108,124,135,159,164 and other approaches that could not be categorized elsewhere. We separated these “other” trials into studies involving direct therapeutic contact131,154,161 and studies not involving direct therapeutic contact in our tables and forest plots.138,158

#### Summary of Psychotherapy Study Results

Adults. Table 10 provides a brief summary of results of all outcomes. Only six of the 19 trials of psychotherapy in adults reported suicide deaths, and we could not determine whether psychotherapy reduced the likelihood of suicide death due to relatively low event rates and small sample sizes. The proportion of adults with a suicide attempt or DSH was reduced by an average of 32 percent in those receiving the intervention compared with usual care (relative risk [RR], 0.68 [95% CI, 0.56 to 0.83]; k=11; n=1,583; I^2^=16.1%) (Figure 5).

Table 10 Summary of Results: Adults

Intervention category | Trials, n | Suicide deaths | Suicide attempt or DSH | Hospital/ED use, other health outcomes | Suicidal ideation | Depression | Hopelessness
Psychotherapy | k=19 n=2,460 | □□□□□ □ 3 deaths in IGs, 7 deaths in CG; insufficient power | ■■■■■^*^ □□□□□□□□ RR, 0.68 (95% CI, 0.56 to 0.83)^‡^ k=11, I^2^=16.1% | Inpatient psychiatric or ED: ■■■■◘ □ Social functioning: ■□□□□ □ Quality of life: ■■□ Other functioning: ■ | ■■■■■ ■□□□□□□ SMD, −0.10 (95% CI, −0.27 to 0.06) k=8, I^2^=26.3% | ■■■■■ ■■■◘□ □□□□□ SMD, −0.37 (95% CI, −0.55 to −0.19)^‡^ k=12, I^2^=60.5% | ■■◘^†^□□ □ Mixed results, sparsely reported
Medication: Lithium | k=1 n=167 | ■ IG: 0% CG: 3.6% (at 13 mo) | □ 1 mo: IG: 2.7% CG: 2.9% 3 mo: IG: 5.9% CG: 16.7% Incident rate/person-year: IG: 12.7 CG: 21.7 | No data | No data | No data | No data
Enhanced usual care | k=13 n=8,555 + k=1 population-based study n≈127,000 residents | ◘□□□□ □ IG: 27 deaths CG: 32 deaths, excluding population-based trial; insufficient power; no group differences in suicide death rate in population-based trial | ■□□□□ □□□□□□ RR, 0.90 (95% CI, 0.80 to 1.02)^‡^ k=11, I^2^=0.2% | Global functioning: □ Functional health status: □ Nonsuicidal deaths: □ Admission to ED/inpatient: □□ | ■■^**^□ Largest effect in Iranian trial with very minimal usual care: % reporting suicidal ideation during study period: IG: 29% CG: 42% | Mean (SD) change from baseline on HRSD □ IG: −5.7 (NR) CG: −5.2 (NR) (at 3 mo) | No data

□=outcome was reported, groups were not statistically different from each other at any followup.

■=outcome was reported, intervention group showed greater improvement than control group at half or more of the followup assessments.

◘=outcome was reported, intervention group showed greater improvement than control group at fewer than half of followup assessments.

* Number of DSH episodes, rather than percent with any attempt/episode.

† Group differences at 6 months, but not 1, 3, 12, or 18 months.

‡ Statistically significant.

** Percent reporting suicidal ideation.

Abbreviations: CI = confidence interval; DSH = deliberate self-harm; HRSD = Hamilton Rating Scale for Depression; NR = not reported; RR = risk ratio; SMD = standardized mean difference; SSI = Scale for Suicidal Ideation (range, 0–38).

Figure 5 Forest Plot of Suicide Attempts in Psychotherapy Trials: Adults

Abbreviations: CI = confidence interval; DSH = deliberate self-harm; RR = relative risk; SA = suicide attempt; SD = standard deviation.

Figure 5 displays a forest plot of the relative risk (RR) of suicide attempts in adult psychotherapy trials (k=11), stratified by type of psychotherapy. The overall RR was 0.68 (95% CI, 0.56 to 0.83). For cognitive behavior therapy trials (k=4), the RR was 0.80 (95% CI, 0.67 to 0.97). For problem-solving therapy trials (k=1), the RR was 0.83 (95% CI, 0.56 to 1.24). For dialectical behavior therapy trials (k=3), the RR was 0.47 (95% CI, 0.30 to 0.74). For psychodynamic/interpersonal therapy trials (k=2), the RR was 0.47 (95% CI, 0.23 to 0.95). For other direct therapy trials (k=1), the RR was 0.41 (95% CI, 0.04 to 3.82). For additional details of Figure 5, go to the Summary of Psychotherapy Studies Results.

Additionally, there was a small beneficial effect on depression (SMD, −0.37 [95% CI, −0.55 to −0.19]; k=12; n=1,653; I^2^=60.5%) (Figure 6).

Figure 6 Forest Plot of Depression in Psychotherapy Trials: Adults

Abbreviations: BDI = Beck Depression Inventory; CI = confidence interval; HADS = Hospital Anxiety and Depression Scale; HRSD = Hamilton Psychiatric Rating Scale for Depression; SD = standard deviation; SMD = standardized mean difference; ZSDS = Zung Self-Rating Depression Scale.

Figure 6 displays a forest plot of the standardized mean difference (SMD) of depression in adult psychotherapy trials (k=12), stratified by type of psychotherapy. The overall SMD was −0.37 (95% CI, −0.55 to −0.19). For cognitive behavior therapy trials (k=5), the SMD was −0.39 (95% CI, −0.70 to −0.08). For problem-solving therapy trials (k=3), the SMD was −0.26 (95% CI, −0.52 to 0.00). For dialectical behavior therapy trials (k=1), the SMD was −0.22 (95% CI, −0.64 to 0.20). For psychodynamic/interpersonal therapy trials (k=2), the SMD was −0.77 (95% CI, −1.32 to −0.22). For other nondirect therapy trials (k=1), the SMD was −0.18 (95% CI, −0.74 to 0.38). For additional details of Figure 6, go to the Summary of Psychotherapy Studies Results.

In general, reductions in depression were reported in both groups, but greater reductions were seen in intervention participants. Psychotherapy did not show greater improvement than usual care for suicidal ideation (SMD, −0.10 [95% CI, −0.27 to 0.06]; k=8; n=964; I^2^=26.3%) (Figure 7); most trials reported improvements in both intervention and control groups. Other health outcomes and hopelessness were sparsely reported and had mixed results.

Figure 7 Forest Plot of Suicidal Ideation in Psychotherapy Trials: Adults

Abbreviations: ASIQ = Adults Suicidal Ideation Questionnaire; BSI = Beck Suicide Ideation Scale; BSS = Beck Suicide Scale; CI = confidence interval; MSSI = Modified Scale for Suicidal Ideation; SBQ = Suicide Behavior Questionnaire; SD = standard deviation; SMD = standardized mean difference; SSI = Scale for Suicidal Ideation.

Figure 7 displays a forest plot of the standardized mean difference (SMD) of suicidal ideation in adult psychotherapy trials (k=8), stratified by type of psychotherapy. The overall SMD was −0.10 (95% CI, −0.27 to 0.06). For cognitive behavior therapy trials (k=2), the SMD was −0.10 (95% CI, −0.78 to 0.58). For problem-solving therapy trials (k=3), the SMD was −0.17 (95% CI, −0.34 to 0.01). For dialectical behavior therapy trials (k=1), the SMD was 0.18 (95% CI, −0.24 to 0.60). For psychodynamic/interpersonal therapy trials (k=1), the SMD was −0.46 (95% CI, −0.87 to −0.06). For other nondirect therapy trials (k=1), the SMD was 0.15 (95% CI, −0.41 to 0.72). For additional details of Figure 7, go to the Summary of Psychotherapy Studies Results.

Adolescents. Table 11 shows a brief summary of results of adolescents. The effects of suicide prevention treatment on deaths could not be determined, as there was only one death in any of the three trials reporting this outcome (Table 11). Suicide attempts were not reduced in adolescents with psychotherapy at 6 to 18 months (RR, 0.99 [95% CI, 0.75 to 1.31]; k=9; n=1,331; I^2^=49.1%) (Figure 8).

Table 11 Summary of Results: Adolescents

Intervention category | Trials, n | Suicide deaths | Suicide attempt or DSH | Hospital/ED use, other health outcomes | Suicidal ideation | Depression | Hopelessness
Psychotherapy | k=12, n=2,392 | □□□ One death (in CG) in all 3 trials | ■■□□□ □□□□□□ RR, 0.99 (95% CI, 0.75 to 1.31) k=9, I^2^=49.1% 4 trials reported ≥22% increase in risk | Inpatient psychiatric: ■■□□□ (at 6–12 mo) Global functioning: ■□□□□ (primarily development group therapy trials) | ■■^*^■■◘ □□□□□□ SMD, −0.22 (95% CI, −0.46 to 0.02) k=6, I^2^=41.2% | ■■^*^◘□□ □□□□□ SMD, −0.36 (95% CI, −0.63 to −0.08)^†^ k=6, I^2^=53.6% | ■■^*^◘□ Sparsely reported, small group differences
Enhanced usual care | k=1, n=165 | No data | □ Self-harm with intent to die: 12 mo: IG: 8.5% CG: 5.9% | No data | □ Serious suicidal ideation in the past 12 mo: 12 mo: IG: 23.3% CG: 23.5% | □ Mean (SD) change from baseline on CESD: IG: −10.0 (NR) CG: −12.0 (NR) (at 12 mo) | □ Mean (SD) change from baseline on BHS: BL: IG: −2.2 (NR) CG: −2.9 (5.6) (at 12 mo)

□=outcome was reported, groups were not statistically different from each other at any followup.

■=outcome was reported, IG showed greater improvement than CG at half or more of the followup assessments.

◘=outcome was reported, IG showed greater improvement than CG at fewer than half of followup assessments.

* Trial with large difference likely used low-effectiveness CG (at 1.5 mo).159

† Statistically significant.

Abbreviations: BHS = Beck Hopelessness Scale; BL = baseline; CG = control group; CI = confidence interval; DSH = deliberate self-harm; IG = intervention group; NR = not reported; RR = risk ratio; SD = standard deviation; SMD = standardized mean difference.

Figure 8 Forest Plot of Suicide Attempts in Psychotherapy Trials: Adolescents

Abbreviations: CI = confidence interval; DSH = deliberate self-harm; RR = relative risk; SA = suicide attempt; SD = standard deviation.

Figure 8 displays a forest plot of the relative risk (RR) of suicide attempts in adolescent psychotherapy trials (k=9), stratified by type of psychotherapy. The overall RR was 0.99 (95% CI, 0.75 to 1.31). For cognitive behavior therapy trials (k=3), the RR was 0.95 (95% CI, 0.28 to 3.16). For problem-solving therapy trials (k=3), the RR was 0.96 (95% CI, 0.62 to 1.48). For psychodynamic/interpersonal therapy trials (k=2), the RR was 1.01 (95% CI, 0.30 to 3.39). For other nondirect therapy trials (k=1), the RR was 0.82 (95% CI, 0.53 to 1.29). For additional details of Figure 8, go to the Summary of Psychotherapy Studies Results.

The CI of the pooled effect was wide, however, and ranged from a 25 percent reduction in risk to a 31 percent increase in risk of suicide attempts. Four of the nine trials reporting this outcome reported a 22 percent or more increase in the risk of a suicide attempt. We cannot rule out the possibility of harm (or benefit) using the existing evidence even though there was a small beneficial effect on depression (SMD, −0.36, [95% CI, −0.63 to −0.08]; k=6; n=631; I^2^=53.6) (Figure 9).

Figure 9 Forest Plot of Depression in Psychotherapy Trials: Adolescents

Abbreviations: BDI = Beck Depression Inventory; CES-D = Center for Epidemiologist Studies Depression Scale; CI = confidence interval; MFQ = Mood and Feelings Questionnaire; SD = standard deviation; SMD = standardized mean difference.

Figure 9 displays a forest plot of the standardized mean difference (SMD) of depression in adolescent psychotherapy trials (k=6), stratified by type of psychotherapy. The overall SMD was −0.36 (95% CI, −0.63 to −0.08). For cognitive behavior therapy trials (k=1), the SMD was −0.43 (95% CI, −1.15 to 0.28). For developmental group therapy trials (k=3), the SMD was −0.17 (95% CI, −0.35 to 0.01). For psychodynamic/interpersonal therapy trials (k=2), the SMD was −0.68 (95% CI, −1.39 to 0.02). For additional details of Figure 9, go to the Summary of Psychotherapy Studies Results.

Although statistical heterogeneity was high, all effects were in the direction of the intervention’s benefit on depression (but most were not statistically significant). In general, reductions in depression were reported in both groups, but greater gains were seen in intervention participants.

No beneficial effect was found for suicidal ideation (SMD, −0.22 [95% CI, −0.46 to 0.02]; k=6; n=629; I^2^=41.2%) (Figure 10), for which both groups generally showed substantial improvement.

Figure 10 Forest Plot of Suicidal Ideation in Psychotherapy Trials: Adolescents

Abbreviations: BSI = Beck Suicidal Ideation Scale; CI = confidence interval; SD = standard deviation; SIQ = Suicide Ideation Questionnaire; SMD = standardized mean difference; SSI = Scale for Suicidal Ideation.

Figure 10 displays a forest plot of the standardized mean difference (SMD) of suicidal ideation in adolescent psychotherapy trials (k=6), stratified by type of psychotherapy. The overall SMD was −0.22 (95% CI, −0.46 to 0.02). For cognitive behavior therapy trials (k=1), the SMD was −0.15 (95% CI, −0.85 to 0.56). For developmental group therapy trials (k=3), the SMD was −0.08 (95% CI, −0.26 to 0.10). For psychodynamic/interpersonal therapy trials (k=2), the SMD was −0.52 (95% CI, −1.15 to 0.11). For additional details of Figure 10, go to the Summary of Psychotherapy Studies Results.

Other health outcomes were sparsely reported and rarely showed beneficial effects for the interventions, although results for feelings of hopelessness were mixed.

Predictors of effect size. Across the body of psychotherapy studies, we found no clear predictors of effect size other than target age (adults vs. adolescents), despite examining a large number of potential factors that could influence effect size for three different outcomes (suicide attempts, suicidal ideation, and depression). While the effect of age was only present for suicide attempts and not suicidal ideation or depression, we present all outcomes by population age group for consistency. Among adolescent trials, interventions that targeted parents as well as youth appeared to be more beneficial.

Detailed Description of Included Psychotherapy Studies in Adults. A total of 19 psychotherapy trials (n=2,460) were included, covering CBT and CBT-related therapies (k=15; n=2,144), psychodynamic therapy (k=2; n=163), and other therapies that could not be clearly categorized based on the information provided (k=2; n=153).

#### Population Characteristics of Psychotherapy Studies in Adults

Risk at enrollment. Most of the psychotherapy trials enrolled participants with a recent suicide attempt or episode of DSH in the recent (up to 8 weeks) past107,126,131,134,135,137,140–142,145,146 or within the past year.109,128 Three trials identified participants at increased risk of suicide through screening: one trial of CBT as part of a population-based epidemiologic study in Sri Lanka105 and two conducted in university settings.106,138 One of the trials included adults evaluated in an ED setting after a suicide attempt or period of acute risk who were judged to be safe for discharge with no mental health care for 2 weeks.131

Age and sex. The average age of trial participants was generally in the mid-20s to mid-30s, when these data were presented. Three American trials focused on young adults or were conducted in university settings, and participants in these trials had average ages ranging from 19 to 23 years.106,138,144 Older adults were underrepresented in these trials. While one trial in Sri Lanka included participants as old as age 74 years,142 the remaining included participants up to their early- or mid-60s,105,124,126,128,131,135,148,165 early- or mid-50s,109,134 age 45 years,140,141 or age 35 years.145 Other than the DBT trials, most trials included populations that were one half to two thirds female. The DBT trials were all limited to females with BPD.

Location and ethnicity. Included trials took place in the United States,106,126,131,138,140,141,144 the United Kingdom,124,134,135,137,146 Australia,128 New Zealand,107 the Netherlands,145,148 Ireland,109 and Sri Lanka.105,142 Few U.S.- or European-based trials reported substantial minority representation. Two of the CBT trials conducted in the United States reported samples that were 65 percent nonwhite (60% African American)126 and 26 percent African American.144 In addition, two of the problem-solving trials (in the United States and New Zealand) reported that 25 to 39 percent of their samples were racial or ethnic minorities, with the largest groups being Asian/Pacific Islanders (15% in the U.S. trial) and Maori (16% in the New Zealand trial).106,107 Finally, one of the “other” category trials included 14 percent African American participants, 10 percent of mixed racial background or “other,” and 11 percent of the remaining participants were evenly divided among Latino, Asian/Pacific Islander, and “unknown” ethnicity.131

Previous history of suicide attempts. Of the 19 psychotherapy trials, most provided some information about suicide attempts or episodes of DSH prior to those that initiated their inclusion in the trial. All (or almost all) participants in seven of the trials had a previous history of DSH,109, 128,134,140,141,146,148 with the average number of previous episodes ranging from two109 to 26 attempts or episodes128 (where reported). Prior attempts or DSH were an inclusion requirement in five of these trials.109,128,140,141,146 Four of the psychotherapy trials did not report the proportion of participants with previous suicide attempts or DSH.105,106,124,142 In the remaining trials, 18 to 72 percent had a previous suicide attempt or DSH.

Mental health issues. Trials were inconsistent in their reporting of mental health diagnoses, and samples were heterogeneous in those that did report them. Table 6 lists information provided by the trials on substance and depressive disorders. All trials of DBT were limited to females with BPD.

Intervention Characteristics of Psychotherapy Studies in Adults. Details of the intervention and control groups for all trials are provided in Table 8 and Appendix G.

CBT trials. The nine trials examining the effects of CBT in adults used a wide variety of approaches, although all attempted to help participants understand the connection between thoughts, feelings, and behavior, and provided some direct skills development in areas such as problem-solving and communication. Four of the CBT trials involved eight sessions or fewer,105, 134,137,146 while the remaining five involved 10 or more sessions, generally lasting 2.5 to 6 months. One trial examined the use of a 2-week intensive outpatient program of daily 9-hour hospital-based care; this was the only trial that used group-based treatment.144 The remaining trials used individual treatment, either with or without sessions with family members. The control groups in these trials received usual care. One trial put control group participants on a waiting list for CBT, but this also group only received usual care.142

DBT trials. The four DBT trials all referenced treatment manuals developed by the author of the U.S.-based trials.128,140,141,148 These interventions were very intensive and involved more than an estimated 100 sessions over a 1-year period. These trials included weekly individual psychotherapy, telephone contacts between sessions, a weekly 2.5-hour skills training group, and weekly support and/or supervision meetings for therapists. Primary targets for DBT are skills-building (e.g., emotional regulation, interpersonal skills), increasing motivation for skillful behavior, ensuring generalization of newly acquired skills to the natural environment, and enhancing therapists’ capabilities and motivation to treat patients effectively. While three of the trials compared DBT with community treatment as the usual care (with or without being on the waitlist for DBT),128,140,148 one trial enlisted therapists judged to be “experts” in the other approaches for the comparison group.141

Problem-solving therapy trials. Three trials focused on teaching participants problem-solving techniques, which is an important component of CBT.106,107,109 The two problem-solving trials in patients with recent self-harm involved four to nine individual or group sessions over a 2- to 3-month period.107,109 These trials compared this approach with usual care, which involved standard individual therapy in outpatient or day hospitals in one trial109 and possible referral to a range of services in the other trial, including multidisciplinary teams, mental health crisis teams, and alcohol or drug treatment centers.107 The third trial was conducted in a university setting and involved a one-time, 40-minute didactic video describing the problem-solving process. The control group in this study viewed a video covering general health topics such as diet, exercise, and sleep habits.106

Psychodynamic/interpersonal therapy trials. Psychodynamic treatment focuses on identifying how unconscious beliefs and unresolved conflicts affect behavior, particularly in interpersonal interactions. The treatment generally involves interpretation of client’s behavior and interpersonal interactions as reflecting underlying beliefs, of which the client is largely unaware. The two trials conducted in adults were very heterogeneous in intensity and ranged from four weekly sessions of manual-based interpersonal therapy135 to long-term outpatient partial hospitalization for an average of 17 months.124

Other trials. Two trials were categorized as “other,” and one involved direct therapeutic contact131 while the other did not.138 The intervention that involved direct therapeutic contact engaged the participant in a collaborative assessment and treatment approach.131 This trial did not dictate specific session-by-session content or the exact number of sessions expected, but rather specified the use of a collaborative approach that was suicide-focused. This approach required providers to begin each session by completing the Suicide Status Form with the patient and ending the session with the development of a treatment plan, which always included a crisis response plan. The other trial had participants write about difficult times four times over the course of 2 weeks, with or without instruction to re-interpret the difficult times, compared with writing about a neutral topic.138

Quality Assessment of Psychotherapy Studies in Adults. Quality assessment results are summarized in Appendix E Table 2. We rated all adult psychotherapy trials as fair quality. The three best-quality psychotherapy trials either definitely or likely used valid random assignment, allocation concealment, blinding of outcomes assessment, and randomized at least 100 participants.107,135,141 The only quality concerns with these trials were relatively low retention at followup for one or more outcomes. Although one of these trials had high (99%) followup for medical records-based outcomes, followup was only 75 percent for self-report outcomes.107 Overall retention in the other two trials was about 80 percent. One of these trials had substantially higher retention in the intervention group (88.5%) than in the control group (71.4%).141 Another trial reported high retention (90% for the main outcomes) and generally good procedures, but failed to report blinding of outcomes assessment.146

Although several more of the trials reported retention of 90 percent or more at one or more followups,105,109,124,134,137,138,142 all of these had multiple other flaws, which were primarily failure to report valid random assignment procedures,124,134,137,138,142 failure to report allocation concealment,105,124,137,142 and/or failure to report or definite lack of complete blinding of outcomes assessment.109,124,137,138 Two of the trials that reported high followup rates were also very small and only randomized between 10 to 20 participants, which makes ensuring comparability between groups difficult.105,109

#### Detailed Results of Psychotherapy Studies in Adults

Suicide deaths (KQ 4). There were a total of 10 suicide deaths in six psychotherapy trials reporting this outcome, among the 970 participants with followup in these trials (Appendix H Table 1).106,135,137,141,145,146 Three suicide deaths occurred among participants in the intervention groups (0.62% of intervention participants across all studies) and seven among those in control groups (1.44% of control group participants across all studies). As such, we have insufficient power to detect effects on such a rare outcome, although available data appeared to exclude a paradoxical harm (i.e., increase in suicide deaths) with psychotherapy.

Suicide attempts (KQ 4). The overall pooled effect for all adult psychotherapy trials reporting suicide attempts demonstrated a 32 percent reduction in suicide attempts (RR, 0.68 [95% CI, 0.56 to 0.83]; k=11; n=1,583; I^2^=16.1%) (Figure 5). All effects were in the direction of a benefit, ranging from a 14 to 71 percent reduction in risk, although the effect was statistically significant for only five of the trials (Table 6). The upper bound of the prediction interval was also less than 1.0, suggesting that this result would likely remain statistically significant if future trials were to be added. Two trials that were not included in the meta-analysis reported average number of suicide attempts per person and both reported fewer attempts in intervention participants than control participants.124,145

Ten of the 15 CBT-related trials reported the proportion of participants with a suicide attempt or self-harm. Overall, CBT-related trials showed a pooled 26 percent reduction in the proportion of participants reporting suicide attempts among those that could be pooled (RR, 0.74 [95% CI, 0.61 to 0.88]; k=8; n=1,406; I^2^=9.7%) (data not shown). The prediction interval in this analysis was bounded by 1.0 on the upper end, also suggesting a fairly robust effect. Results support a beneficial effect in adults for both DBT (limited to females with BPD) and CBT (Appendix H Table 2).

Three of the four remaining trials of psychodynamic and other treatment approaches in adults reported suicide attempts. These trials found reductions ranging from 38 to 69 percent at 6 to 12 months. These reductions, however, were statistically significant in only the two psychodynamic trials (only one of these was statistically significant in the meta-analysis).

Other health outcomes (KQ 4). Other health outcomes were sparsely reported. DBT generally reduced inpatient psychiatric use in female BPD patients at 12 to 18 months, including median inpatient psychiatric days (17 days in the DBT group vs. 51 days in the usual care group),140 and percent with a psychiatric admission (16.6% in the DBT group vs. 48.9% with treatment by community experts) (Appendix H Table 3).141 The other DBT trial, however, found a smaller difference in percent with a psychiatric admission (18.4% in the DBT group vs. 20.0% in the usual care group) and no differences in a number of other measures of inpatient use.128 The very-intensive psychodynamic partial hospitalization intervention in the United Kingdom in adults reported a reduction in average length of stay at 18 months (average of 4 days in the intervention group vs. 22 days in the control group) and 36 months (1.7 days in the intervention group vs. 15.8 days in the control group).124 Similarly, one of the CBT trials found reductions in percent of participants with psychiatric inpatient stays between 6 and 9 months postbaseline (2% in the intervention group vs. 21% in the control group), but no statistically significant differences at other followups.145 In addition, a U.S. trial that engaged participants in a collaborative assessment and treatment approach found comparable declines in inpatient and ED or urgent care use in both groups, although these data were not analyzed statistically.131

Six of the adult psychotherapy trials reported functioning or quality of life outcomes (Appendix H Table 4).124,128,131,134,137,146 Only one of these six trials showed a benefit of treatment. The intervention in this trial was an intensive psychodynamically-oriented partial hospitalization.124 One of the DBT trials also reported a number of other functioning and quality of life outcomes.128 This trial found a benefit of treatment on days in bed and the psychological domain of quality of life, but no group differences in days out of role or the physical, environmental, or social domains of quality of life (data not shown).

Suicidal ideation (KQ 5). Psychotherapy trials generally did not demonstrate a benefit for suicidal ideation (SMD, −0.10 [95% CI, −0.27 to 0.06]; k=8; n=964; I^2^=26.3%), where most trials reported improvement in both the intervention and control groups (Appendix H Table 5). While half of the trials reporting this outcome did show statistically significant group differences, these effects were small.105–107,131,135,142 The trial of brief interpersonal therapy conducted in the United Kingdom had a relatively large and statistically significant effect on suicidal ideation. Scores on the 38-point Scale for Suicide Ideation (SSI) dropped by 8 points in the intervention group and only 1.5 points in the usual care group, for a SMD of 0.46.^135^

Depression (KQ 5). Fifteen of the 19 psychotherapy trials reported depression (Appendix H Table 6). More than half of these trials reported greater improvement in intervention than usual care groups at one or more followups.106,107,109,124,126,134,135,142,145 The pooled effect demonstrated a small beneficial effect (SMD, −0.37 [95% CI, −0.55 to −0.19]; k=12; n=1,653; I^2^=60.5%) (Figure 6). CBT-related interventions improved depression (SMD, −0.32 [95% CI, −0.50 to −0.13]; k=9; n=1,471; I^2^=60.1%) (data not shown), particularly problem-solving therapy and CBT. Benefits were not seen for DBT in female patients with BPD, however. Both of the psychodynamic approaches reported at least medium effect sizes.124,135 The trial of four individual interpersonal treatment sessions in the United Kingdom, for example, reported a reduction of 11.4 points on the Beck Depression Inventory (BDI) (range, 0 to 63) after 6 months compared with a reduction of 4.8 points with usual care (SMD, −0.55). Both of these groups’ average scores were in the “severe” depression range at baseline. At 6-month followup, the intervention group’s average score was in the “mild” range, while the usual care group’s average score was in the “moderate” range.135

Hopelessness (KQ 5). Hopelessness was sparsely reported, and results were mixed in those trials that did report on this outcome (Appendix H Table 7). The greatest benefit was seen in the problem-solving trials, which all reported hopelessness. The pooled effect in these studies showed a small benefit (SMD, −0.47 [95% CI, −0.91 to −0.04]; k=3; n=511; I^2^=61.5%) (data not shown). The largest of these three trials, which included four to nine sessions of manual-based individual problem-solving therapy, found a three-point greater improvement on the Beck Hopelessness Scale. For this trial, both the intervention and usual care groups began in the “moderate” hopelessness range and had average ratings in the “mild” hopelessness range at 12-month followup.

Detailed Description of Included Psychotherapy Studies in Adolescents. Twelve trials examined the effects of psychotherapy on suicide risk in adolescents, including three CBT trials153,156,163 (n=365), three developmental group therapy trials155,157,160 (n=501), three psychodynamically-oriented interventions108,159,164 (n=225), and three that could not be clearly categorized into one of these groups (n=1,301).154,158,161 Two of these provided assessment and direct contact with a counselor or therapist, without describing specific components or approaches,154,161 and the other recruited youth-nominated adults to act as support persons.158

Population Characteristics of Psychotherapy Studies in Adolescents. Three very similar trials examined the effects of developmental group therapy (Tables 4, 7, and 9) in adolescents with recent DSH in the United Kingdom155,160 and Australia.157 Two of these trials additionally required at least two episodes of DSH in the past year.155,157 Samples in the developmental group therapy trials were 78 to 90 percent female with high rates of depression (57% to 83%). Racial and ethnic minorities were minimally represented in the one trial reporting on minority status.155

Of the remaining nine trials, four identified youth at increased risk of suicide through screening.108,154,159,161 One of these trials, which examined interpersonal therapy in the United States, involved screening during primary care or ED visits.108 The others screened high school students in the United States154,161 (one only among youth identified as being at risk of dropping out of high school)154 and Taiwan.159 The remaining three trials included youth with recent suicide attempts or DSH153,156,158 or youth with at least two symptom of BPD identified through mental health referrals.164

Most trials included youth age 12 years to ages 16 to 19 years, but three were limited to older teens (ages 14 or 15 to 19 years).154,161 Samples in six of the trials (including all three developmental group therapy trials) comprised more than three fourths females,108,153,155,157,160,164 and the remaining trials comprised between one half and two thirds females.

Trials were conducted in the United States,108,153,154,154,158,161 Australia,157,164 the United Kingdom,155,160 Canada,156 and Taiwan.159 Only four of these trials reported more than minimal racial or ethnic minority representation. A majority (74%) of the participants in the trial of interpersonal therapy that was based in the United States were African American.153 The two U.S. high school-based trials categorized as “other” with direct therapeutic treatment included 57 and 34 percent nonwhite participants.154,161 The largest racial groups reported in these studies were biracial (32% to 14%).154,161 One of these also reported 12 to 13 percent each African American and Asian/Pacific Islander, with the remainder categorizing themselves as Hispanic/Latino (7%), other (3%), Alaskan Native/Native American (2%), or unknown (9%).154 Twenty-nine percent of the youth in the Canadian CBT trial reported that they were something other than Caucasian, most describing themselves as “other” and small proportions describing themselves as African American (6%) and Hispanic (4%).156

There was a fairly wide range of depressive disorders at baseline among the trials other than developmental group therapy, ranging from 15 to 100 percent with a diagnosis of major depressive disorder. One trial was limited to youth with at least two symptoms of BPD.164 Substance misuse was measured inconsistently and varied widely, from excluding participants with substance abuse diagnoses,159 to about half of the sample reporting both alcohol abuse and illegal drug use,156 to requiring substance abuse in all participants.163

#### Intervention Characteristics of Psychotherapy Studies in Adolescents

CBT trials. Three trials conducted in adolescents examined CBT in the United States153,163 and Canada.156 The most intensive was a U.S.-based trial in participants with co-occurring suicidality and substance abuse. It involved 34 or more individual sessions along with slightly fewer sessions for parents covering CBT concepts and parenting and family sessions as needed with a different therapist. The other trial conducted in the United States used a 12- to 16-session skills-based approach that focused on problem-solving and affect management and included parents in the treatment.153 This trial was the only adolescent psychotherapy trial to use an attention-matched control group, which involved unstructured sessions addressing symptoms and problems, on the same treatment schedule as the active intervention group. The other CBT trial was a Canadian study that was conducted in adolescents and involved a phone followup after an ED visit for a suicide attempt. This call involved a detailed assessment of the suicide attempt and the youth’s support system, followed by an intervention of unknown intensity to reframe misconceptions and address maladaptive behavior and communication patterns.156

Developmental group therapy trials. The developmental group therapy interventions (which all referenced the same treatment manual) involved six weekly group sessions plus optional weekly sessions after completion of the main course.155,157,160 The main course covered relationship issues and communication with peers and family, anger management, and information and discussion about depression, hopelessness, and suicide. In all cases the comparison was usual care.

Psychodynamic/interpersonal therapy trials. The psychodynamic trials used highly heterogeneous intervention approaches, including an 18-session manualized individual interpersonal therapy,159 attachment-based family therapy,108 and cognitive analytic therapy.164 Cognitive analytic therapy was a 6-month, 24-session individual treatment compared with a manualized “usual care” designed to represent good clinical care that could be received in the community. The attachment-based family therapy intervention primarily addressed the core issue of problems with attachment between parent and child.108 The attachment-based family trial had the greatest applicability to U.S. primary care, since adolescents were identified through primary care and ED screening in the United States.108 This trial did not report the total number of sessions or intensity of treatment, but did report that it was of 3 months duration. This was compared with a facilitated referral process and ongoing clinical monitoring. The other trial, of interpersonal therapy, used psychoeducation and irregular supportive counseling with a teacher who had been taught basic counseling skills as the control group.159

Other trials. Finally, three trials were categorized as “other,” two with direct therapeutic contact154,161 and one without.158 The trials with direct therapeutic contact recruited youth from American high schools through screening. One of these two trials limited the screening to youth identified as being at increased risk of dropping out of high school and screening positive for increased suicide risk.154 Both trials included an intervention condition that involved a single session including 1) a 2-hour computer-assisted suicide assessment, 2) brief motivational counseling offering encouragement, empathy, and reinforcement of coping skills, and 3) a facilitated link to an adult at the school who could act as a support person, help the youth access community support, and facilitate communication between the school, parents, and youth. One of them had additional treatment groups evaluating the use of a two-session intervention with parents and the use of both parent and youth components.161 Both trials compared the active treatment group(s) with the usual school protocol for addressing suicidality in students.

The final trial had the youth identify adult support persons who were then trained to provide the youth with support and maintain regular (at least weekly) contact for 3 months following hospital discharge.158 This was compared with usual care.

Quality Assessment of Psychotherapy Studies in Adolescents. Appendix E Table 3 summarizes our quality assessment results. We rated all three developmental group therapy trials as good quality. Retention was excellent in all three of these trials (≥92% in all treatment groups). All three reported blinding of allocation and outcomes assessment, and although two did not explicitly report randomization procedures, randomization was likely valid since they appeared to involve a statistician. Two of the trials were fairly small (n=63 to 72 randomized).157,160 One trial was approximately five times larger than the other two (n=366), yet still had very high followup.155

All of the remaining trials were rated fair quality. Three trials reported valid randomization procedures, allocation concealment, and blinded outcomes assessment and generally good study and analysis procedures; however, retention was below 80 percent in two of these,158,164 and the other was a small CBT trial (n=40) with retention below 90 percent at 6-month followup.163 In addition, the control group appeared to have higher levels of psychopathology than the intervention group, though differences were not statistically significant (e.g., medication use was 88% in the control group vs. 68% in the treatment group, 59% of control participants had a disruptive behavior disorder vs. 42% of the control group, the control group had 40% to 45% more participants with alcohol and cannabis use disorders than the intervention group). All of the remaining trials failed to report at least two of valid random assignments, allocation concealment, or blinding of outcomes assessment or had retention below 90 percent.108,153,154,156, 159

#### Detailed Results of Psychotherapy Studies in Adolescents

Suicide deaths (KQ 4). We found insufficient evidence to judge psychotherapy’s impact on suicide deaths. There was only one suicide death in all three trials of adolescent psychotherapy reporting this outcome (Appendix H Table 8).155,156,158

Suicide attempts (KQ 4). All but one of the 12 psychotherapy trials in adolescents reported suicide attempts or DSH (Appendix H Table 9). The pooled effect for adolescents showed no reduction in suicide attempts in the trials that could be pooled (RR, 0.99 [95% CI, 0.75 to 1.31]; k=9; n=1,331; I^2^=49.1%) (Figure 8). Four of the trials showed statistically nonsignificant increases in risk of 22 to 113 percent, which suggests the possibility of harm.153,156,157,164 The trial that found the largest increase in risk, however, had very few events,153 and another of these four did not see an increase in absolute risk at either 6- or 24-month followup. As such, the results for these trial should be interpreted with caution. Two trials could not be included in the meta-analysis; one of these reported no group differences in attempts with no further detail161 and the other reported no differences in the number of suicide attempts at 2.5 months postbaseline (average of 0.10 attempts in the intervention group vs. 0.11 attempts in the control group).154

While one small, good-quality trial of developmental psychotherapy did report a large positive effect,160 the two good-quality studies attempting to replicate this result failed to show a benefit of treatment. Another trial of CBT showed a comparable effect size, with an 85 percent reduction in suicide attempts;163 however, this was a very small study with only seven suicide attempts total, so findings should be considered preliminary until they can be replicated by a larger trial.

Other health outcomes (KQ 4). The small CBT trial with the very large beneficial effect also showed a 70 percent reduction in percent of participants with an inpatient psychiatric hospitalization and a 73 percent reduction in participants with an ED visit.163 The risk of hospitalization was reduced by 59 percent in the Canadian CBT trial that showed a 33 percent increase in risk of a suicide attempt at 6 months (18% in the intervention group with inpatient stays vs. 43% in the control group; p<0.001).156 There were no differences reported in ED use in this trial, however. There were also no differences in inpatient use in trials of developmental group therapy155,157 or the trial of youth-nominated support persons at any followup, up to 12 months (Appendix H Table 10).158

Developmental group therapy also did not demonstrate a beneficial effect on global functioning (Appendix H Table 11) in any of the trials, according to a World Health Organization instrument designed for children and adolescents (HoNOSCA). However, the pooled effect showed a small but statistically significant benefit (SMD, −0.28 [95% CI, −0.46 to −0.09]; k=3; n=463; I^2^=0%) (Figure 11). The weighted mean difference in change on the HoNOSCA between groups was 1.6 points on a 52-point scale. The trial of cognitive analytic therapy also showed no group differences in functioning.164

Figure 11 Forest Plot of Functioning in Psychotherapy Studies: Adolescents

Abbreviations: CI = confidence interval; SD = standard deviation; SMD = standardized mean difference.

Figure 11 displays a forest plot of the standardized mean difference (SMD) of functioning in adolescent developmental group therapy trials (k=3). The overall SMD was −0.28 (95% CI, −0.46 to −0.09). For additional details of Figure 11, go to the Detailed Results of Psychotherapy Studies in Adolescents.

Suicidal ideation (KQ 5). Eleven of the 12 trials of psychotherapy in adolescents reported suicidal ideation; psychotherapy did not demonstrate a consistent benefit (Appendix H Table 12). The pooled effect was small and not statistically significant (SMD, −0.22 [95% CI, −0.46 to 0.02]; k=6; n=629; I^2^=41.2%) (Figure 10), but five of the trials could not be included in the meta-analysis. Results in the five trials excluded from the meta-analysis were mixed: three reported no group differences in rate of change154,163 or change from baseline at either 2 or 6 months (−1.4 in the intervention group vs. −1.5 in the control group on the Spectrum of Suicidal Behavior Scale at 6 months),156 one reported group differences in change over time only for the treatment group that included both youth and parent components,161 and one found greater improvement in the intervention group on the SIQ-JR at 1.5 months but not 3 months.158 Overall, five of the 11 trials reported a statistically significant effect at one or more followups.108,154,158,159, 161 One of these trials had good applicability to primary care in the United States and examined interpersonal therapy in U.S. adolescents identified through screening in the ED or primary care.108 This trial reported a 3.8-point reduction on a 38-point scale in the intervention group over 6 months compared with a 3.6-point increase in the usual care group. This was the largest effect size (SMD, −0.19) for the trials included in the meta-analysis,108 other than the Taiwanese trial.159 The Taiwanese trial used a control group that was likely less effective than usual care in the United States, involving psychoeducation and irregular supportive counseling with a teacher who had received basic instruction in counseling techniques, compared with 18 sessions of individual interpersonal therapy in Taiwanese adolescents.159

Depression (KQ 5). All but two of the adolescent trials reported depression (Appendix H Table 13), and the pooled effect showed a small benefit (SMD, −0.36 [95% CI, −0.63 to −0.08]; k=6; n=631; I^2^=53.6%) (Figure 9), and again several trials could not be included in the meta-analysis.154,158,161,163 Results in those excluded from the meta-analysis were mixed, and only three trials altogether reported statistically significant group differences.154,159,161 The trial with the largest effect had a control group that was likely less effective than usual care in the United States.159 A typical effect was a four-point difference in improvement on a 63-point scale and both groups ending the trial in the “mild” depression range, such as that seen in the trial of U.S. adolescents identified through primary care and ED screening.108

Hopelessness (KQ 5). Hopelessness was only reported in four of the adolescent psychotherapy trials,154,158,159,161 and the largest benefit was seen in the Taiwanese trial of interpersonal psychotherapy involving a control group that may not be comparable to U.S. usual care (Appendix H Table 14).159 Two other trials reported statistically significant group differences, one showed a benefit only at the 1-month followup,161 and the other had a very small effect of questionable clinical importance: the intervention group showed a 0.5-point greater improvement on a two-item scale with unknown range.154

Predictors of Treatment Effect for Psychotherapy Trials. Intervention approaches were very heterogeneous. We attempted to capture both treatment intensity (number of sessions, duration of treatment, and sessions per week during the acute phase) and some specific intervention components (as described in the Methods section) to examine characteristics using both meta-regression and qualitative approaches that were associated with beneficial effects. We also examined some additional study characteristics, including: whether the study was conducted in the United States, time to followup, percent of participants in the sample with suicide attempts prior to the index attempt (or a history of multiple attempts, if there was no index attempt), and whether the participant was recruited into the study in the immediate aftermath of a suicide attempt. All meta-regressions were controlled for age of the sample (adolescents vs. adults). We were unable to fully characterize all trials due to inconsistent reporting. These results should be considered exploratory and hypothesis-generating rather than definitive due to the challenges in accurately identifying the characteristics and the large number of characteristics explored.

For suicide attempts, trials of adolescents were less likely to show a benefit than trials that were predominantly or entirely adults. Only four (33%) of the psychotherapy trials in adolescents reported a 20 percent or greater reduction in risk of suicide attempts compared with 82 percent of the adult psychotherapy trials. Similarly, all but one (86%) of the psychotherapy trials conducted in the United States reported at least a 20 percent reduction in the risk of a suicide attempt; 55 percent of the trials conducted elsewhere reported reductions of that magnitude. A number of other factors were at least qualitatively associated with beneficial effects, such as time to followup, number of treatment sessions, treatment intensity during the acute treatment phase, and using a multimodal treatment approach. Trials with followup longer than 6 months, that included more than six treatment sessions, with more than one session per week during the acute treatment phase, and that used multimodal treatment were more likely to report at least a 20 percent reduction in risk of suicide attempts. The trials in adolescents were generally not evenly distributed over these characteristics, however. After controlling for the target age (adolescents vs. adults) in the meta-regression, none of these factors were statistically significant. Thus, disentangling the effects of these components from the effects of the age of the sample was impossible.

Although the meta-regression did not reveal a relationship between the proportion of patients with previous suicide attempts and effect size, one trial directly examined whether those with previous self-harm showed the same level of benefit as those who had only a single episode (for which they were recruited into the study).107 The problem-solving treatment was beneficial in patients with a history of self-harm (RR, 0.39 [95% CI, 0.07 to 0.60]; p=0.03) but not for those who had no prior episodes of self-harm. It was unclear if this was an a priori hypothesis or an exploratory analysis.

Within the group of adolescent psychotherapy trials, interventions that targeted parents as well as youth appeared to be more likely to be beneficial. The two trials that included full participation of parents had two of the three largest effect sizes for suicide attempts.108,163 In addition, one trial compared three different intervention arms with usual care: a youth-targeted intervention, a parent-targeted intervention, and both the youth and parent interventions combined.161 This trial found that only the combined youth and parent intervention was effective in improving suicidal ideation, depression, and hopelessness.

The age of the individuals in the sample did not appear to be related to effect size for suicidal ideation in a slightly different subset of studies. Further, studies that were conducted in the United States generally had smaller effects (in contrast to the results for suicide attempts). In addition, trials with shorter followup tended to show greater effects on suicidal ideation. The three trials with the largest effects, however, all had less than 6 months of followup and were all conducted outside of the United States.105,109,159 These were conducted in Taiwan, Sri Lanka, and Ireland. These were all small trials (n randomized ranged from 10 to 73) and at least one used a control group that would likely be less effective than usual care treatment in the United States.159 Thus, while it may make intuitive sense that shorter followup would be associated with greater effect sizes for suicidal ideation, the effects of followup time and country cannot be disentangled from each other in this sample. None of these three trials reported suicide attempts.

No clear or consistent relationships emerged between treatment or study characteristics and effect size for depression.

### Medication Interventions

Study Characteristics of the Medication Trial. We included one fair-quality, placebo-controlled trial of a medication to prevent suicide (Table 4), which examined the effectiveness of lithium plus usual care in preventing suicide in patients with depression-spectrum disorders and a recent suicide attempt (n=167 randomized).139 This trial was conducted in Germany and did not report participants’ racial and ethnic background (Table 6). Fifty-seven percent of the sample was female, and the average age was 39 years (age range not reported). Many of these participants (76%) also had a major depressive disorder diagnosis. This trial suffered from low retention, as only 31 percent of participants were retained at final 13-month followup. Thirteen of the 17 suicide attempts documented by the study and all three of the suicide deaths, however, occurred during the first 3 months, when retention was acceptable.

Results of the Medication Trial. This trial reported three suicide deaths. All three of these deaths occurred among participants taking placebo medications (p=0.05 for difference in incidence rate) (Table 10). This study did not describe how suicide deaths were assessed or the number of participants contributing to this analysis. At both 2- and 3-month followup, there were fewer suicide attempts in the intervention group than in the control group among those with followup data, but statistical significance was not reported (3.6% with suicide attempt in those taking lithium vs. 7.2% in those taking placebo at 2 months, 6.0% in the lithium group vs. 9.1% in the placebo group at 3 months). These groups did not differ in cumulative survival without a suicide attempt over the entire 13 months of followup (hazard ratio, 0.517; p=0.21, adjusted for age, sex, and prior suicide attempts). Suicide attempts were based on self-report and did not appear to be corroborated by medical records or in any other way. Those taking lithium did not differ from those taking placebo in suicidal ideation at followup.

### Enhanced Usual Care

Seventeen trials attempted to enhance usual care through a variety of approaches; all attempted to improve either the quality or format of recommended treatment (in either primary or specialty care) or improve patient adherence to usual care, with little to no direct therapeutic counseling or specific prescription for a psychotherapeutic approach that should be used (Table 4). One of these trials was limited to adolescents and young adults (ages 15 to 24 years),162 two to older adult primary care patients,114,152 and the remaining included wide age ranges covering primarily adults. Population characteristics for all trials in the group can be found in Table 6 (adults and older adults) and Table 7 (adolescents).

Both trials in older adults were highly relevant to primary care populations. One, the Prevention of Suicide in Primary Care Elderly: Collaborative Trial (PROSPECT), addressed only depressed older adults (ages 60 to 94 years) and was the only trial that used primary care-based (depression) screening in the United States to identify eligible study participants.114 The other trial of older adults was a large cluster-randomized trial (randomized at the provider level) that included all patients older than age 60 years on the panels of participating providers, so it was not limited to patients who screened positive for suicidal ideation or had known risk factors for suicide, but was representative of a general Australian primary care population.152

One of the included trials was a nonrandomized, population-based, practice-based intervention trial that compared an intervention and a control region in the county with the highest suicide rate in Hungary and reported suicide rates per 100,000 persons as its outcome, rather than following an identified sample of individuals.151 This study is described separately from the other adult-focused trials.

All of the remaining trials targeted participants who had an ED visit or inpatient stay related to a suicide attempt or self-harm, and were either limited to adults across a wide age range or primarily addressed adults but included some adolescents (Table 6). We divided the trials into three subgroups: practice-based interventions,115,130 interventions to improve treatment adherence with direct person-to-person contact,123,129,132,133,147,149,150 and interventions to improve treatment adherence without person-to-person contact.125,127,136,143 We group the three subcategories together when discussing results, however, since treatment approach did not appear to have an impact on treatment results.

Summary of Results for Enhanced Usual Care Trials. Seven of the 17 enhanced usual care trials reported deaths, including PROSPECT in older adults. PROSPECT reported only a single suicide death, found no group differences in suicide attempts, and found a reduction in all-cause mortality after 5 years.114 Depression and suicidal ideation were also reduced in the intervention group through 8 months (for suicidal ideation) and 24 months (for depression). The Hungarian population-based trial found no reduction in suicide deaths from a 5-year provider-education intervention that also offered free consultation and a depression clinic for referral.151 After 5 years, the suicide rate was 40.7 per 100,000 in the intervention region and 47.1 per 100,000 in the control region. The trial in adolescents did not report deaths.162

Among the remaining trials, the largest trial reported a 49 percent reduction in suicide deaths at 2-year followup (1.8% in the intervention group vs. 3.5% in the control group; one-tailed p=0.04).143 There were very few deaths across all trials, however, and this outcome was too sparsely reported to conclude that suicide deaths were reduced. Combining data from six trials (excluding the population-based trial151), there were 27 suicide deaths in the intervention groups (2.0% of participants with followup) and 32 in control groups (2.3%). Summary of results can be found in Table 10 (adults), Table 11 (adolescents), and Table 12 (older adults).

Table 12 Summary of Results: Older Adults

Intervention category | Trials, n | Suicide deaths | Suicide attempt or DSH | Hospital/ED use, other health outcomes | Suicidal ideation | Depression | Hopelessness
Enhanced usual care | k=2 n=22,360 | □ 1 death (in IG) | ■□ 20%–23% reduction in risk of suicide attempt or combined outcome of suicide attempt or suicidal ideation | Nonsuicidal deaths: □ | ◘^*^ % reporting ideation: 8 mo: IG: 17.2% CG: 18.6% 12 mo: IG: 14.6% CG: 13.4% | ■□ Greater reduction in depression in IG than CG in depressed sample; no group differences in percent screening positive for depression in general primary care sample (24 mo) | No data

□=outcome was reported, groups were not statistically different from each other at any followup.

■=outcome was reported, intervention group showed greater improvement at one or more followups than control group.

◘=outcome was reported, IG showed greater improvement than CG at fewer than half of followup assessments.

* Statistically significant at 4- and 8-month followup but not at 12, 18, or 24 months.

Abbreviations: CG = control group; DSH = deliberate self-harm; ED = emergency department; IG = intervention group.

Thirteen of the 17 enhanced usual care trials (including PROSPECT114 and the adolescent trial162) reported on suicide attempts, and all but one136 found no differences in suicide attempts between 4 and 24 months (RR, 0.91 [95% CI, 0.80 to 1.02]; k=13; n=6,592; I^2^=0.0%) (Figure 12).

Figure 12 Forest Plot of Suicide Attempts in Enhanced Usual Care Studies

Abbreviations: CI = confidence interval; DSH = deliberate self-harm; RR = relative risk; SA = suicide attempt; SD = standard deviation.

Figure 12 displays a forest plot of the relative risk (RR) of suicide attempts in enhanced usual care studies (k=13), which includes practice-based interventions and direct and indirect interventions to improve treatment adherence. In the PROSPECT trial among older adults, the RR was 0.77 (95% CI, 0.13 to 4.56). Among the trials in adults (k=11), the RR was 0.90 (95% CI, 0.80 to 1.02), and among the trials in adolescents (k=1), the RR was 1.44 (95% CI, 0.36 to 5.76). The overall RR was 0.91 (95% CI, 0.80 to 1.02). For additional details of Figure 12, go to the Summary of Results for Enhanced Usual Care Trials.

While these findings were generally consistent, they should not be considered precise. These results are consistent with a small to moderate decrease in suicide attempts or no effect. Other health and intermediate outcomes were very sparsely reported.

#### Detailed Study Characteristics of Enhanced Usual Care Trials

Trials in older adults. Both of the trials in older adults were practice-based interventions;114,152 that is, they involved education with or without other supports to primary care providers in treating patients at increased risk of suicide. The U.S.-based PROSPECT included older adults who screened positive for depression in primary care.114 This trial’s primary aim was reducing suicidal ideation as well as depression. It was one of only two trials limited to older adults (ages 60 to 94 years; 31% age 75 years or older) and the only enhanced usual care trial that identified patients through primary care screening. The PROSPECT intervention involved giving primary care providers treatment guidelines and assigning a care manager to monitor the patient, inform the provider if the patient was suicidal, advise the primary care provider on treatment, and provide psychotherapy if needed. Seventy-two percent of the participants were female and 28 percent were nonCaucasian. PROSPECT was rated fair quality (Appendix E Table 2). It had fairly low retention (69% in each group) and also did not blind outcomes assessors, although it did have high standards for interrater reliability for outcomes assessment (Table 12).114

The other trial in older adults was conducted in an Australian primary care population.152 All patients who were age 60 years and older in participating general practitioners’ practices were eligible for the study (age range, 60 to 101 years; average age, 72 years). This study provided an educational intervention on assessment and treatment of depression and self-harm for clinicians and provided personalized direct feedback on assessment and handling of 20 consecutive patients. This trial was also rated fair quality because it did not provide adequate detail on the method of outcomes data collection, including blinding of outcomes assessors and mode of assessment (mailed questionnaire, phone interview, in-person interview, etc.).152

Population-based trial. The population-based trial compared intervention and control regions in the county with the highest suicide rate in Hungary.151 The intervention and control regions were noncontiguous in the same county, and comparable in proportion of female (52%) and older residents (22% age 60 years or older), and both were predominantly rural. The intervention involved four main training sessions on depression and suicide over 5 years for general practitioners and nurses, plus three additional lectures on suicide and depression-related topics per year, a free consultation service to all providers, and a referral specialty depression management clinic.151 This trial was rated fair quality (Appendix E Table 2); it was not an RCT, and reported only population-based outcomes (e.g., rate of suicide death per 100,000 persons). The trial did not describe how it obtained data on the population size. In addition, it was unclear if police and coroners were aware of the intervention; if not, it is possible that reporting of suicides could have been affected by the intervention.

Trial in adolescents. The Australian trial in adolescents was limited to adolescents and young adults (ages 15 to 24 years) with a history of suicide threats, ideation, or attempts, but who did not meet entry criteria for service in the mental health facility associated with the study because they were either receiving treatment elsewhere or were not unwell enough to qualify for services.162 Sixty-four percent of participants were female and ethnicity was not reported in this trial. Two thirds met criteria for a mood disorder and 68 percent had a lifetime history of DSH. It was unclear whether participants were recruited upon presentation to the facility, or if researchers searched records and recruited participants who had failed to qualify for services, or if some other recruitment method was used. All participants received 12 monthly hand-written postcards that inquired about their well-being, reminded them of sources of help they had identified in the baseline phone interview with the study coordinator, and promoted one of six self-help strategies (e.g., physical activity, early morning light exposure, Web sites or self-help books based on CBT). This trial was rated fair quality (Appendix E Table 3). Retention was fairly low and somewhat differential at 12 months (74% in the intervention group and 63% in control group), and was unacceptably high at 18 months. In addition, groups were not entirely comparable at baseline; intervention group participants were more likely to have history of DSH (64% vs. 53% in past year), higher incidence of substance abuse (31% vs. 19%), and lower incidence of anxiety disorders (51% vs. 75%).

Study Characteristics of Other Enhanced Usual Care Trials. All of the remaining enhanced usual care trials were limited to people with a recent ED visit or inpatient stay for a suicide attempt or self-harm (Table 6). Average ages were generally mid-20s to mid-30s. The trial with the youngest average age (24 years) included participants as young as age 12 years,136 but most trials reporting age requirements were limited to those ages 16 or 18 years and older. Almost all trials were between one half and two thirds female. One trial was limited to patients screening positive for alcohol misuse or whose ED visit was due to alcohol use.132 Another trial with a mailed letter-based intervention was limited to people who had refused further treatment 1 month after an inpatient stay for a suicide attempt.143

Only one trial reported racial/ethnic minority representation: 36 percent of participants were African American, 13 percent were Hispanic, and less than 1 percent were Native American in this trial. Evidence of substance misuse and depressive disorders were inconsistently reported and varied substantially between studies.133 Trials were conducted in nine different countries, primarily in developed countries in North America, Europe, and Oceania. One trial was conducted in Iran136 and three were conducted in the United States.133,143,150

We rated all but one127 of the other 13 adult enhanced usual care trials as fair quality (Appendix E Table 2). These ratings stem from a variety of quality-related concerns. Several trials reported all three of valid random assignment, allocation concealment, and blinding of outcomes assessment along with 100 percent for medical records-based outcomes115,125,127,147 (including the good-quality trial127), but most were rated fair because they either had lower followup for self-reported outcomes or included only medical records-based outcomes, which can underestimate suicide attempts. Several additional trials reported both valid random assignment and allocation concealment along with high followup of medical records-based outcomes, but outcomes blinding was either not reported130,132 or not present.136 In the trial without outcomes assessment blinding, assessment of suicidal ideation was based on only a single item, but assessment of DSH was based on both self-report and medical records, rather than relying solely on medical records. One trial based in the United States had very long (15 years) and complete followup, but was rated as fair quality because authors did not report randomization methods, allocation concealment, or blinding of outcomes assessors, and only minimal information was provided about outcomes measurement methods.143

Intervention Descriptions of Enhanced Usual Care Trials. Intervention characteristics are shown in Table 8 and Appendix G.

Practice-based intervention trials. In addition to the two trials in older adults114,152 and the population-based trial,151 two other trials examined practice-based interventions. One of these trials examined intensive case management, which included a comprehensive needs assessment, development of a treatment plan, and ongoing monitoring of treatment and the patient’s health status.130 The other U.K.-based trial notified general practitioners when their patient came to the Accident and Emergency Service for DSH, sent them practice guidelines for assessment and treatment, and gave the provider a letter to send to the patient encouraging them to come in for a visit.115

Trials improving adherence to usual care with direct person-to-person contact. These seven trials used a wide variety of intervention approaches that all involved contact with patients identified in an ED to better manage or improve adherence to recommended treatments, rather than providing additional treatment, such as psychotherapy. Most of these seven trials involved only one or two contacts, usually limited to assessment and referral or encouragement to follow up with an already provided referral.129,132,133,147,149 One of these trials made special efforts to contact the patient very soon after discharge from the ED (within 48 hours), using a mobile crisis team to meet at the place of the patient’s choosing.133 Another trial that was limited to patients who misuse alcohol included provision of a referral to an alcohol assessment and counseling session, from which a referral for more extensive treatment could be made.132 Another was more extensive and akin to case management, involving phone contact immediately after ED discharge, a home visit for assessment and development of a treatment plan, and continued treatment monitoring.150 The final trial dictated a specific schedule of visits and procedures for outreach in case of missed appointments, but the content of the treatment was left to the discretion of the provider.123 Control groups all involved treatment or referrals as usual.

Trials improving adherence to usual care without direct person-to-person contact. Similar to the trial in adolescents, four interventions were limited to a series of mailed cards or letters that expressed concern, wished the patient well, and invited them to contact their provider or a research staff member. This study included six125 to nine136 contacts conducted over the course of 12 months to 24 letters over 5 years.143 The comparison was with usual care in all cases. The Iranian trial reported that usual care was minimal in Iran,136 so was likely not as effective as usual care in the United States.

#### Detailed Results of Enhanced Usual Care Trials

Suicide deaths (KQ 4). PROSPECT found only one suicide death total (in the intervention group) (Appendix H Table 1).114 The population-based trial in Hungary reported suicide rates per 100,000 persons for each of the five intervention years, and found no differences between groups; at 5 years, the suicide death rates were 40.7 in the intervention group and 47.1 in the control group.151 The trial in adolescents did not report suicide deaths.162

There were 59 deaths across all remaining enhanced usual care trials between 1- and 5-years followup. Twenty-seven of these deaths (2.0% of participants with followup) occurred in the intervention groups and 32 deaths (2.3% of participants with followup) occurred in the control groups. A trial based in the United States that sent 24 letters over 5 years found reductions in suicide deaths at 2 years (1.8% in the intervention group vs. 3.5% in the control group; one-tailed p=0.043), but survival curves began to converge after that and the groups no longer differed at 5 years (3.9% in the intervention group vs. 4.6% in control group) or at any point thereafter.143 This trial also examined nonsuicidal deaths and found no differences at either 5 or 15 years, but did not report nonsuicidal mortality at 2-years followup.

Suicide attempts (KQ 4). Thirteen of the 17 enhanced usual care trials reported suicide attempts, including PROSPECT and the trial in adolescents (Appendix H Table 2). The pooled effect (including PROSPECT114 and the adolescent trial162) showed no benefit of treatment (RR, 0.91 [95% CI, 0.80 to 1.02]; k=13; n=6,592; I^2^=0.0%) (Figure 12). Results were almost identical when PROSPECT114 and the adolescent trial162 were dropped from the analysis (RR, 0.90 [95% CI, 0.80 to 1.02]; k=11; n=6,075; I^2^=0.2%) (Figure 12). Most of the trials showed statistically nonsignificant effects that were consistent with a benefit or with no effect, but with wide CIs. The Iranian postcard-based trial was the only one that reported a statistically significant reduction in the risk of suicide attempts after 12 months among those who received the intervention (3.0%) compared with those who did not (5.1%).136 This trial also reported that usual care in Iran was minimal, so would likely be less effective than usual care in the United States. The large Australian trial in general primary care older adults reported a composite outcome of suicide attempt or ideation, and found a statistically significant 20% reduction in the intervention group.152

Among the trials that attempted to improve treatment adherence through direct contact with the patient, there appeared to be a trend of larger effects with shorter followup. The two trials reporting the largest positive effects were the alcohol assessment and counseling session at 6-months followup (38% reduction in DSH)132 and the case management intervention at 4-months followup (36% reduction in suicide attempts).150 Effects at 12 to 13 months ranged from 0 to 21 percent reduction in suicide attempts,129,147,149 and the trial with the longest followup (24 months) reported a 16 percent increase in suicide attempts.123

Other health outcomes (KQ 4). Among patients with major depression, PROSPECT reported a reduction in all-cause mortality after 5 years; the mortality rate in the intervention group was 44.7 deaths per 1,000 person-years (95% CI, 34.1 to 57.6) compared with 49.7 in the control group (95% CI, 37.4 to 64.6), for an adjusted hazard ratio of 0.55 (95% CI, 0.36 to 0.84).114

Aside from PROSPECT, only five trials reported other health outcomes, none with statistically significant group differences (Appendix H Tables 3 and 4). A Swedish trial of two phone contacts to assess the patient and provide encouragement to stay in or return to treatment if needed found no group differences in global assessment of functioning.129 The trial based in the United States using the mobile crisis team found no group differences in symptoms or functional health status.133 Neither trial reporting health care use found group differences in ED130 or inpatient admissions.127 No differences in nonsuicidal mortality were seen in the trial of a letter-based intervention in the United States among suicide attempters refusing further treatment.143

Intermediate outcomes (KQ 5). In PROSPECT, the proportion of patients reporting suicidal ideation was reduced in the intervention group at 4- and 8-month followup, but not at the 12-, 18-, or 24-month followup (Appendix H Table 5).114 The intervention participants, however, reported lower depression scale scores than control participants at all but one of the followups, although absolute differences were small (Appendix H Table 6). The largest group difference in change in depression from baseline was seen at the 4-month followup, when the intervention group reported an average 7.4-point drop on the Hamilton Rating Scale for Depression (HRSD) compared with a 4-point drop in the control group. Both groups began the study below the cut-off indicating moderate depression, but above the “normal” range, and both groups stayed above the “normal” range at all followups. Effect of the intervention on depression varied by ethnicity in PROSPECT: white intervention participants showed 2- to 4-point greater reductions in the HRSD than nonwhite (primarily African American) participants. There were no group differences in the large Australian trial of older adults,152 in which 8 percent of participants scored in the “moderate depression” range or higher on the nine-item depression scale of the Patient Health Questionnaire at baseline and at followup.

The trial in adolescents found no group differences in suicidal ideation, depression, or hopelessness at 12-month followup (Appendix H Tables 12, 13, and 14, respectively).162 Twenty-three percent in both groups reported having suicidal ideation at some point between baseline and 12-month followup, and both groups showed substantial improvement in depression, which averaged above the cut-off for probable depression at both baseline and followup in both groups. Study authors found modest improvements in hopelessness in both groups; both groups started and ended in the “mild” hopelessness range.

Three additional trials reported intermediate outcomes (Appendix H Table 5). The intervention group in the Swedish trial showed slightly greater reductions in suicidal ideation than the control group between the 1-month (before the first intervention call took place) and 12-month assessments.129 Scores on the SSI dropped by 2.1 points in the intervention group and 1.0 point in the control group. Initial SSI scores, however, were the lowest of all the included trials that used the SSI, and the modest difference in improvement between the groups seems unlikely to represent a clinically significant effect on the 38-point scale. The American mobile crisis team trial reported no group differences in the SSI over 3 months, although both groups showed greater reductions in this trial than the previous one (approximately six-point reductions in both groups).133 In the Iranian trial, fewer participants in the intervention group answered “yes” to the question “Did you have any suicidal thoughts during the study period?” after 12 months (29% in the intervention group vs. 42% in the control group; p<0.05).136

The same American trial that reported no group differences in suicidal ideation also reported no group differences in depression (Appendix H Table 5).133 Both groups’ average HRSD scores declined by about five points, and were above the cut-off for moderate depression at both time points. No other enhanced usual care trials reported hopelessness (Appendix H Table 7).

## Key Question 6: For Those Identified as Being at Increased Risk of Suicide, What Are the Harms of Behaviorally-Based or Pharmacologic Treatment to Reduce Suicide Risk? Do the Harms Vary by Population Characteristics?

### Psychotherapy Interventions

Adults. Very few psychotherapy trials in adults reported adverse effects beyond the trials’ main outcomes. One CBT trial in adults reported that none of the suicide attempts were a result of study participation.126 The trial of a video-based problem-solving intervention reported that no participants withdrew from the study due to worsening symptoms.106 Finally, a study of writing as a means for reducing suicidal ideation reported that three participants asked to speak with a research supervisor because they became upset after writing or because their writing revealed current suicidal ideation.138 We cannot determine whether this is truly a harm (triggering suicidal ideation) or a potential benefit (connecting the participant with treatment they may not have sought otherwise).

One trial reported a nonstatistically significant increase in suicide deaths.137 This trial was very small (n=80), however, and had only one death in either group and very wide CIs associated with the effect, so is unlikely to reflect a truly harmful effect.

Adolescents. Four of the 11 trials reporting suicide attempts reported nonstatistically significant increases in suicide attempts of 22 to 113 percent (Figure 8).153,156,157 Although one was a very small trial with few events and very wide CIs associated with the effect, the other two likely had enough events to represent more stable effects, although they were statistically nonsignificant. The possibility of harm cannot be ruled out in currently or recently suicidal adolescents undergoing CBT or developmental group therapy.

### Medication Interventions

The trial of lithium treatment reported that 13 percent of the participants taking lithium dropped out of the study due to adverse effects compared with 2 percent of those taking the placebo, although the statistical significance of this difference was not reported.139 Overall dropout rates were comparable between groups. Specific adverse effects were not reported.

### Enhanced Usual Care

Adverse effects were rarely reported in trials of interventions that attempted to enhance usual care. One trial of a mobile assessment team reported that no adverse events were reported in either treatment group.133 Another trial involving a single phone call at either 1 or 3 months postsuicide attempt to check in with the patient and encourage (re-)engagement in treatment reported a combined “adverse events” outcome of death, suicide attempt, or loss to followup, which was statistically similar in all groups (1-month call, 23%; 3-month call, 28%; control group, 30%; p=0.25).147 This type of composite outcome can be problematic, as deaths and loss to followup are of very different importance.166,167

One trial showed a nonstatistically significant increase in deaths after 12 months, but this was based on only a single suicide death (in the intervention group), so this cannot be said to represent clear evidence of harm.114 Two trials showed nonstatistically significant increases in suicide attempts of 11 percent in a practice-based intervention in the United Kingdom115 and 16 percent in a trial with a prescribed schedule of visits.123 CIs were very wide for the latter trial, so the effect is unlikely to represent true harm. The trial of the practice-based intervention, however, did some further exploration of the effect and found a statistically significant harmful effect in the subset of participants with no prior history of DSH, in whom the odds of DSH during 1-year followup were increased by 32 percent (95% CI, 1.02 to 1.70).115 This was a fairly low-intensity intervention for patients presenting to the Accident and Emergency Service after DSH. Researchers notified general practitioners of their patient’s DSH episode and sent them assessment and treatment guidelines, along with a letter they could send to the patient inviting them to make an appointment. How this intervention could be harmful is difficult to understand, but it is worth noting that there may be risks associated with this intervention.