# METHODS

## Scope and Purpose

This systematic review provides updated evidence regarding the accuracy and reliability of instruments used to screen for increased suicide risk, benefits and harms of screening for increased suicide risk, and benefits and harms of treatment to prevent suicide. The USPSTF will use this review to update its 2004 recommendation for primary care practices. This review includes all trials from the previous review98 that met current inclusion/exclusion criteria, as well as newly identified studies.

## Key Questions and Analytic Framework

We developed an analytic framework (Figure 3) and Key Questions (KQs) using USPSTF methods to guide our literature search, in consultation with liaisons from the USPSTF. The KQs we examined were:

1. Do screening programs to detect suicide risk among adolescents, adults, and older adults in primary care settings result in improved health outcomes (decreased suicide attempts, decreased suicide deaths, improved functioning, improved quality of life, or improved health status) or intermediate outcomes (decreased suicidal ideation, depressive symptomatology, or hopelessness)? Does the effect of screening programs vary by population characteristics (i.e., sex, age, race/ethnicity, other)?
2. Do instruments to screen for increased risk of suicide accurately identify adolescents, adults, and older adults who are at increased risk in primary care populations? Does the accuracy of the screening instruments vary by population characteristics?
3. Are there harms associated with screening for suicide risk in primary care settings? Do the harms vary by population characteristics?
4. For those identified as being at increased risk of suicide, do interventions to reduce suicide risk (behaviorally-based, including home visits or counseling for environmental change, or pharmacologic) result in improved health outcomes (decreased suicide attempts, decreased suicide deaths, improved functioning, improved quality of life, or improved health status)? Does the effect of the interventions vary by population characteristics?
5. For those identified as being at increased risk of suicide, do interventions to reduce suicide risk (behaviorally-based, including home visits or counseling for environmental change, or pharmacologic) result in improved intermediate outcomes (suicidal ideation, decreased access to means of suicide, increased treatment of previously undiagnosed mental health conditions, decreases in depressive symptomatology or hopelessness)? Does the effect of screening programs vary by population characteristics?
6. For those identified as being at increased risk of suicide, what are the harms of behaviorally-based or pharmacologic treatment to reduce suicide risk? Do the harms vary by population characteristics?

Figure 3 Analytic Framework

* All studies must report at least one suicide-specific outcome measure.

Figure 3 is an analytic framework that depicts the six Key Questions described in the Methods section of the report. In general, the figure illustrates how screening for suicide risk in pimary care (all populations) may result in the identification of individuals at risk for suicide or deliberate self-harm who may be candidates for intervention. Interventions may result in changes in intermediate outcomes (e.g., decreased suicide ideation) or health outcomes (e.g., decreased suicidal behavior, decreased suicide death). The analytic framework also depicts the possible adverse events occuring after screening or treatment.

Population characteristics include: sex; age; race/ethnicity; comorbid medical illness; history of previous suicide attempts; and social, mental health, or other psychological factors.

## Data Sources and Searches

In addition to considering all studies from the previous review for inclusion in the current review, we searched MEDLINE, PsycINFO, Cumulative Index for Nursing and Allied Health Literature, and the Cochrane Collaboration Registry of Controlled Trials for studies published since January 2002 through July 17, 2012 (Appendix B) to bridge from the previous review (which searched through June 2002). As this review was intended as an update, we did not substantially change the scope of the previous review. Additionally, we did not conduct database searches for research published during the period covered by the previous review. For literature published prior to January 2002, however, we hand-searched reference lists and tables of included and excluded studies in the previous review and additional relevant reviews to ensure that all pertinent literature was identified. A medical librarian also conducted grey literature searches of government agencies (e.g., Agency for Healthcare Research and Quality [AHRQ], Institute of Medicine, VA, and NICE), professional organizations (e.g., American Psychiatric Association, American Psychological Association, American Academy of Child and Adolescent Psychiatry, and the American Association of Suicidology), and other organizations (e.g., Robert Wood Johnson Foundation, World Health Organization, British Medical Journal Clinical Evidence, and the Campbell Collaboration) that may sponsor or publish relevant research for synthesized evidence published outside of peer-reviewed journals. We also used news and table-of-contents alerts from Google, ScienceDirect, and HighWire Press to help us identify potentially eligible trials that were published between bridge searches.

## Study Selection

Two investigators independently reviewed abstracts and articles against specified inclusion and exclusion criteria. Disagreements were resolved by consultation with the larger project team. Appendix C details our inclusion and exclusion criteria. Excluded studies and reasons for exclusion are listed in Appendix D.

This review had no restrictions on participants’ ages, country in which the study took place, or minimum time to followup. We excluded trials that only included patients with chronic psychotic disorders or mental health conditions other than depression, substance misuse, PTSD, or BPD.

For KQs 1, 4, and 5 (benefits of screening or treatment), we required included trials to list reduction in suicide, suicide attempts, or suicidal ideation as a primary aim. As such, trials targeting detection or general management of disorders such as depression or substance misuse that reported suicide-related outcomes were not included unless it was clear that suicide prevention was a primary aim of the study. Trials of treatment in the ED or inpatient setting were excluded, as were intervention approaches that could not be replicated in health care settings (e.g., media campaigns and public policy interventions). However, we did include trials if participants were identified through an ED or inpatient service (including intake assessments and randomization) as long as the intervention occurred after discharge. We excluded trials that compared two competing treatment approaches unless there was also a control condition. Control conditions for these trials included usual care or nonspecific supportive care.

For KQ 2 (test performance characteristics), screening instruments had to meet one of two requirements: 1) designed to identify suicidal thoughts or behaviors (i.e., we did not include studies that looked at the sensitivity of depression screeners to identify people who are experiencing suicidal thoughts) or 2) included a constellation of attitudes thought to be essentially synonymous with suicidality without expressly including the desire to kill oneself, such as the Geriatrics Depression Scale–Suicide Ideation (GDS-SI) subscale. The GDS-SI measures hopelessness, worthlessness, emptiness, absence of happiness, and lack of perception that it is wonderful to be alive. Included studies reported sensitivity, specificity, positive predictive value (PPV), or negative predictive value (NPV) relative to a valid reference standard administered within a short period of time of the screening test (preferably 24 hours), or provided the raw data to calculate one or more of these statistics.

The reference standard for included studies had to involve an interview that included more than one or two items and was administered by a mental health clinician or, if using a structured or semistructured interview, other trained staff. These interviews had to target current or very recent suicidal ideation and behavior (within the previous 2 weeks). We also considered a medical chart notation of suicidality to be a valid reference standard if the study confirmed that the chart notes were the result of an acceptable interview process, such as a psychological assessment in a mental health facility. We excluded trials whose reference standard was future suicidal behavior (i.e., behavior that occurred more than 3 months after the screening), as we were addressing accuracy of screening tools to identify persons who are currently suicidal for interventions, rather than distal prognostic value, especially with unknown treatment occurring in the interim. We also excluded trials if the reference standard was a prediction as to whether a person had recently made a suicide attempt or were admitted to an inpatient mental health facility.

All trials meeting inclusion criteria for KQs 1, 2, 4, or 5 were also examined for reported harms (KQs 3 and 6), including a paradoxical effect on suicidality. We also consulted experts in the field to identify harms that might not have been identified by the trials but were still serious enough to warrant caution in implementing suicide risk screening. We also inquired about harms that could be identified through observational study designs. Despite this effort, we identified no other harms that outweighed the benefit of avoiding a suicide death or attempt.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the methodological quality of each study using predefined, design-specific quality criteria based on methods developed by the USPSTF and supplemented by the Quality Assessment of Diagnostic Accuracy Studies tool for the quality assessment of diagnostic accuracy (screening) studies (Appendix E Table 1). Briefly, we assessed trials for randomization procedures, blinding (allocation, outcomes assessment, and, if appropriate, participants and interventionists), comparability between groups (in recruitment and assessment procedures, retention, and baseline characteristics), overall study retention, and analysis methods (handling of missing data, appropriate use of statistical procedures, potential for selective reporting of outcomes). In general, good-quality trials blinded researchers who performed assessment or randomization tasks, had followup data on 90 percent or more of participants, reported group-specific followup with less than 10 percentage-point differences between the groups, and used validated instruments or otherwise acceptable measurement procedures. We rated trials as poor quality if attrition in the treatment and control groups differed by more than 20 percentage points, if overall attrition was higher than 40 percent, or if other important flaws were identified (e.g., groups clearly or very likely not comparable at baseline, assessment procedures differed between groups). We also rated trials as poor quality if we identified so many minor flaws or missing pieces of information that we had low confidence that the study’s results were valid. We resolved disagreements in quality assessment through discussion and, if necessary, consultation with a third reviewer. We excluded studies rated as poor-quality from this review.

One investigator abstracted data from all included studies into a standard evidence table and a second investigator checked the data for accuracy. Data abstracted included details on study design, population, recruitment procedures, interventions, and outcomes. We also abstracted a set of treatment components identified by a recent review examining training manuals of empirically supported treatments for suicidality.81 These researchers organized treatment components into 12 conceptually-defined treatment factors: multimodal treatment, clear treatment framework, suicidality as an explicit target behavior, agreed-upon strategy to manage suicidal crises, attention to affect, focus on treatment relationship, active therapist, interpretations, exploratory interventions, supportive interventions, change-oriented interventions, and support for therapists (see Appendix F for description of these categories).

## Data Synthesis and Analysis

For all KQs, we created tables showing results along with important study characteristics, which we critically examined to identify the range of results and potential associations with effect size. We found few trials that addressed KQs 1, 2, and 3 (benefits and harms of screening). As a result, we synthesized these trials qualitatively only and provide ranges of results, separately for different age groups, where applicable. We identified a substantial body of evidence addressing the benefits of treatment (KQs 4 and 5). We examined these data qualitatively and quantitatively. We examined trials limited to adolescents separately from those that were either limited to adults or that included mixed samples of adults and adolescents.

For KQs 4 and 5, we conducted random effects meta-analyses to estimate the effect size of suicide prevention interventions on suicide attempts, suicidal ideation, depression (for subsets of homogeneous trials), hopelessness, and global functioning. We ran separate meta-analyses for the psychotherapy interventions and enhanced usual care interventions, grouped by specific intervention subgroup. We also ran analyses separately for adults and adolescents. We used Stata Version 11.2 (StataCorp LP, College Station, TX) for all statistical analysis.

Risk ratios were analyzed for suicide attempts, based on the raw numbers of events and numbers of participants with followup. We analyzed standardized mean differences (SMDs) in change from baseline for the continuous outcomes (suicidal ideation, depression, and global functioning). We calculated standard deviations (SDs) of change from baseline using a standard formula, which requires estimating the correlation between baseline and followup scores for each outcome.

Correlations between baseline and followup were estimated as follows. For global functioning, one of the included trials reported both baseline and followup means and SDs as well as the means and SDs for change scores, which allowed us to calculate the correlation between baseline and followup (0.41 in the intervention group and 0.71 in the control group). We found no trials that provided enough information to allow us to calculate the correlation for depression or suicidal ideation. Because of this, we based our estimates on reports of test-retest reliability,99–104 but assumed lower correlations than those reported in test-retest studies, since followup intervals were substantially longer in the included trials than in the test-retest studies. We also assumed that correlations would be slightly higher in the control groups than the intervention group (since the intervention may override the natural history). For depression, we estimated the correlation between baseline and followup to be 0.50 for the intervention group and 0.60 in the control group. We assumed the correlation to be 0.20 in the intervention group and 0.30 in the control group for suicidal ideation. We encountered discrepancies in statistical significance between our calculated results in the meta-analysis and results reported in the trials.105–109 In most cases, this resulted from the fact that the trial ran a repeated measures analysis examining change over time, as opposed to the simple change from baseline to one followup point in our meta-analysis.106–109

One trial for which we found a discrepancy between published results and meta-analysis results, however, did not report analysis methods.105 This trial also did not appear to have performed a repeated measures or adjusted analysis, which could explain the discrepancy. It is possible that the correlations between baseline and followup that we estimated were substantially lower than the true correlation in this study, resulting in the discrepancy in statistical significance. We ran a sensitivity analysis assuming higher correlations (a less conservative analysis) to see if this discrepancy in statistical significance was eliminated and found that the discrepancy remained even with very high correlations (0.80 to 0.90 for suicidal ideation). We felt these high correlations were unlikely to be generalizable to other included trials, so we kept our original estimates.

We assessed the presence of statistical heterogeneity among the studies using standard chi-square tests and we estimated the magnitude of heterogeneity using the I^2^ statistic.110 We applied the Cochrane Collaboration’s rules of thumb for interpreting I^2^: less than 40 percent likely represents unimportant heterogeneity, 30 to 65 percent represents moderate heterogeneity, and 50 to 90 percent represents substantial heterogeneity; above 75 percent indicates considerable heterogeneity among the studies.111 We also included prediction intervals in forest plots, which provide an estimate of where 95 percent of newly conducted trials would fall, assuming the between-study variability in the included trials held for new trials.112 The prediction intervals are shown with pooled estimates on forest plots by the horizontal lines, which go out from the diamond showing the 95 percent confidence interval (CI) of the pooled effect. We interpreted effect sizes according to Cohen’s rules of thumb, in which SMDs of 0.2 to less than 0.5 are considered small, 0.5 to less than 0.8 are medium, and 0.8 and above are large.113

The meta-analysis adjusted for the cluster randomization of two trials114,115 by dividing the sample sizes in these studies by a design effect, which is based on average cluster size and the estimated intraclass correlation (ICC).111 We estimated the ICC to be 0.05 since the cluster randomized trials in these trials randomized at the level of medical clinic, which we believed would have a low ICC. We performed tests of publication bias that examine whether the distribution of the effect sizes was symmetric with respect to effect precision (which is related to study n) using funnel plots and Egger’s linear regression method. We conducted these analyses only for the three outcomes that included at least 10 trials: suicide attempts (psychotherapy and enhanced usual care trials analyzed separately), suicidal ideation (psychotherapy trials only), and depression (psychotherapy trials only).116

We used meta-regressions to explore heterogeneity in effect sizes among the KQ 4 and 5 trials for suicide attempts, suicidal ideation, and depression when at least 10 trials reported the outcome and the predictor of interest. Continuous variables were left as continuous variables, and categorical variables were converted to dummy variables. Since other work77 and our initial qualitative analysis suggested that suicidality effects may be different between adolescents and adults, we included an indicator variable set to “1” if the trial was limited to adolescents and “0” if it was all or predominantly adults in all regression models. For all trials combined we examined the following study characteristics: whether the trial was limited to participants with a recent suicide attempt, the proportion of participants with suicide attempts prior to the index attempt that qualified them for the included trial (or the proportion with any suicide attempt, if none was required for inclusion in the trial), and whether the trial was conducted in the United States, all controlling for population age and time to followup. Additional components were examined for the psychotherapy trials: number of sessions, duration of the intervention (in months), number of sessions per week during the acute treatment phase, and the 12 treatment components described by Weinberg and colleagues (Appendix F).

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the work of the USPSTF. We worked with four USPSTF liaisons at key points in the review, particularly in the development of the KQs, analytic framework (Figure 3), and the inclusion and exclusion criteria (Appendix C), as well as finalizing the evidence synthesis. AHRQ had no role in the study selection, quality assessment, or evidence synthesis, and an AHRQ Medical Officer only provided oversight of the project, reviewed the draft report, and assisted in the external review of the report.