# INTRODUCTION

## Condition Definition

Suicide is the act of intentionally inflicting one’s own death. While suicide deaths are uncommon, suicide attempts and ideation (thought of killing oneself or wishing oneself dead) are less rare. Suicidal ideation is much more common than suicide attempts and is often a precursor of suicide and can be targeted by intervention. Self-harm is the broader term that encompasses suicide attempts and self-injurious behavior without the conscious or certain intent to cause one’s own death. It can be difficult, however, to determine the intent of the patients who injure themselves. Among adults, for example, almost half with a lifetime history of a suicide attempt report that their attempt was a cry for help and they did not want to die.1 While the current review is focused on suicide, suicide attempts, and suicidal ideation, studies examining self-harm rather than suicide attempts may be included in this review if the majority of cases are either suicide-related or are cases with unknown intent. While we use the term “suicide attempt” preferentially over “self-harm” when discussing primary research, we do use the terms the authors use in their description of the study. Table 1 defines a number of suicide-related terms.

Table 1 Definitions of Suicide-Related Terms

Term | Definition
Suicide | Death caused by self-directed injurious behavior with any intent to die as a result of the behavior.2
Suicide attempt | A nonfatal self-directed potentially injurious behavior with any intent to die as a result of the behavior. A suicide attempt may or may not result in injury.2
Suicidal self-directed violence | Behavior that is self-directed and deliberately results in injury or the potential for injury to oneself. There is evidence, whether implicit or explicit, of suicidal intent. This encompasses suicide deaths and suicide attempts.2
Other suicidal behavior and preparatory acts | Acts or preparation toward making a suicide attempt, but before potential for harm has begun. This can include anything beyond a verbalization or thought, such as assembling a method (e.g., buying a gun, collecting pills) or preparing for one’s death by suicide (e.g., writing a suicide note, giving things away).2,3 Referred to as “aborted suicide attempt” by the American Psychiatric Association.4
Suicidal ideation | Passive thoughts about wanting to be dead or active thoughts about killing oneself, not accompanied by preparatory behavior.3
Self-harm | An act with nonfatal outcome, in which an individual deliberately initiates a nonhabitual behavior that, without intervention from others, will cause self-harm, or deliberately ingests a substance in excess of the prescribed or generally recognized therapeutic dosage, and which is aimed at realizing changes which the subject desired via the actual or expected physical consequences.5
Suicidal behavior | Includes suicide, suicide attempts, other suicidal behavior, and preparatory acts.

## Prevalence

### Suicide Deaths

Suicide was the tenth leading cause of death in the United States in 2009, accounting for 36,897 deaths, with an age-adjusted rate of 11.8 deaths per 100,000 individuals.6,7 Suicide attempts and death rates vary by sex, age, and race (Figures 1 and 2). The suicide rates in the United States held relatively steady between 1990 and the early 2000s in most age-sex subgroups, other than a steady decline in Caucasian males age 65 years or older.8,9 Overall suicide rates, however, have gradually increased over the last decade, particularly between 2005 and 2009, for both males and females.9 The suicide rate in general primary care patients in the United States is unknown.

Figure 1 Suicide Injury Death Rates Among Males in the United States, 2009

* Hispanic also includes white Hispanics and black Hispanics.

Source: Centers for Disease Control and Prevention, Web-based Injury Statistics Query and Reporting System.6

Figure 1 displays the 2009 crude suicide death rates among males in the United States by race (nonHispanic white, black, American Indian/Alaskan Native, Asian/Pacific Islander, and Hispanic) and age (eight age groups ranging from younger than age 14 years to 75 years or older). Males show marked differences in suicide risk by race. For highlighted details of Figure 1, go to the Prevalence section of the report.

Figure 2 Suicide Injury Death Rates Among Females in the United States, 2009

* Hispanic also includes hhite Hispanics and black Hispanics.

Source: Centers for Disease Control and Prevention, Web-based Injury Statistics Query and Reporting System.6

Figure 2 displays the 2009 crude suicide death rates among females in the United States by race (nonHispanic white, black, American Indian/Alaskan Native, Asian/Pacific Islander, and Hispanic) and age (eight age groups ranging from younger than 14 years to 75 years or older). In this figure, the highest rates of suicide deaths are among American Indian/Alaskan Native and nonHispanic white females. For additional details of Figure 2, go to the Prevalence section of the report.

In 2009, men were four times more likely to die from suicide than women (age-adjusted suicide death rates per 100,000 of 19.2 and 4.9, respectively).6 Men accounted for 79 percent of all reported suicides.7 For women, suicide deaths are generally at the highest during early- to mid-adulthood and gradually decline in the later years. These peak ages, however, are earlier for American Indian/Alaskan Native and Asian/Pacific Islander women.

Males show marked differences in suicide risk by race. American Indian/Alaskan Native males have very high rates of suicide in the adolescent and early adult years, peaking at 42.2 per 100,000 in the ages of 19 to 24 years, and declining as age increases. In contrast, the suicide rate in nonHispanic white males increases steadily throughout their lifespan, peaking at 39.1 per 100,000 among men age 75 years and older. Black males have overall lower rates of suicide than nonHispanic white or American Indian/Alaskan Native males; these rates generally show bimodal distribution that peaks during the early 20s (13.8 per 100,000) and again at age 75 years and older (12.2 per 100,000).6

Military personnel and veterans also appear to be at increased risk of suicide. In 2007, the Department of Veterans Affairs (VA) reported a suicide rate of 56.8 per 100,000 veterans among men ages 18 to 29 years,10 a rate that represented a 26 percent increase since 2005.^11^ Data prior to 2006 are conflicting on whether former military personnel were more likely to commit suicide than the general population,12,13 but most recent data suggest that suicide rates are elevated in youngest male veterans (ages 17 to 24 years; Operation Enduring Freedom/Operation Iraqi Freedom era veterans), whose crude suicide rates were almost four times higher than nonveterans.14

### Suicide Attempts

In the United States, lifetime prevalence of a suicide attempt in adults is 4.6 percent, with about 0.5 percent of adults reporting attempting suicide in the past year.1,15 The 12-month prevalence for suicide attempts is higher at 1.2 percent in younger adults (ages 18 to 25 years).16 Despite the fact that men are more likely to die from suicide, women have a greater lifetime prevalence of suicide attempts than men.1 When asked to rate the seriousness of their attempt, however, men and women had similar rates of attempts during which they truly intended to die. The odds of inflicting self-harm without a true intent of dying was almost three times higher for women than men.17 Suicide attempt risk is increased in sexual minorities; most analyses report at least an 80 percent increase in risk, and several report more than double that risk.18 Interestingly, male veterans did not report higher rates of suicide attempts than civilians on the 2008 National Survey on Drug Use and Health.19

According to the 2011 Youth Behavior Risk Surveillance System (YRBSS), 7.8 percent of high school students reported attempting suicide at least once during the previous 12 months, and 2.4 percent of students made a suicide attempt that required treatment due to their self-injury.20 As with adults, the prevalence of suicide attempts in high school students was higher among females (9.8%) than males (5.8%), and prevalence varied by age (younger grades had higher risk) and race and ethnicity, especially in females (13.5% in Hispanic females compared with 7.9% in white and 8.8% in black females).20

Rates of emergency department (ED) visits in the United States were 153 per 100,000 persons in 2010, almost doubling since 1993 to 1996 (from 84 per 100,000 persons).9,21 Almost all subgroups had comparable increases, including males and females, blacks and whites, and three of the five age groups examined (15 to 19 years, 30 to 49 years, and ≥50 years). Most of this increase appeared to be driven by low-lethality self-harm, as the proportion of visits coded as urgent or emergent decreased from 95 (1993 to 1996) to 70 (2005 to 2008) per 100,000 persons.21

### Suicidal Ideation

Among adults, 13.5 percent have seriously thought about committing suicide during their lifetime,1 and 2.6 to 3.7 percent have seriously thought about committing suicide during the past year.15,22 These rates are higher in younger adults and females.16 Rates of suicidal ideation in primary care are widely variable, but are most commonly in the 2.4 to 3.3 percent range in general primary care populations.23 As with suicide attempts (and in contrast to suicide deaths), veterans are not more likely to report suicidal ideation than nonveterans.19

Sixteen percent of students (in 9th to 12th grades) seriously considered attempting suicide during the previous 12 months according to the YRBSS.20 Again, this prevalence was higher among female students (19.3%) than male students (12.5%). Prevalence also varied by age and race and ethnicity (white and Hispanic females had higher prevalence than black females, and white and Hispanic males had higher prevalence than black males).20 Nearly 13 percent of students have made a suicide plan during the past year.20

## Burden

In addition to the individual devastation of thousands of families who are bereaved by suicide, the burden of suicide on the United States as a whole is substantial. In 2009, suicide accounted for over 1.4 million years of potential life lost (YPLL) before age 85 years, which is nearly 4 percent of the total YPLL in the United States.24 In 2000, the total lifetime medical care cost of self-inflicted injuries, including suicide attempts and deaths, was $1 billion, which is in addition to over $32 billion for lost productivity.25 The average medical care cost associated with a suicide death was $2,596, and the average medical care cost of a nonfatal self-inflicted injury (e.g., attempted suicide) that required hospitalization was $7,234.^25^ A study estimating disability weights for suicidal ideation and suicide attempts found suicidal ideation to be comparable to alcohol or cocaine dependence and suicide attempts to be comparable to heroine dependence or early Parkinson’s disease.26

## Etiology and Natural History

### Onset

While suicidal behavior can appear in very young children, suicide attempts and deaths are very rare before adolescence.6 For some race-sex subgroups, late adolescence and early adulthood mark the greatest risk for suicide attempts and death.6 This is also the most common period for first onset of suicidal ideation and suicide attempts.1

### Progression From Ideation to Attempt (Contextual Questions 1 and 2)

For those with suicidal ideation, 15.6 percent will make an attempt within 12 months,15 while 31.8 percent will progress to an attempt at some point in their lifetime.27 That is, only about one third of those with suicidal ideation will ever attempt suicide. For those who do make an attempt, however, 60 percent will attempt suicide during the first year after the onset of suicidal ideation.27 Developing a suicidal plan is a key step in this progression that roughly doubles the risk of an attempt to 31.9 percent within 12 months15 and 54.4 percent over a lifetime.27

Eighty percent of those attempting suicide have a psychiatric illness at the time they attempt suicide. The actual risk of ideation and the formulation of a plan, however, depends largely on the particular disorder.28 While depression is a better predictor of suicide ideation, for example, disorders characterized by severe anxiety or agitation (e.g., posttraumatic stress disorder [PTSD]) or poor impulse control (e.g., conduct disorder or substance use disorders) better predict which individuals go on to formulate a plan or attempt suicide.

### Multiple Suicide Attempts

Among those who attempt suicide, an estimated 16 percent will make a second suicide attempt within the following year.29 In a naturalistic study of adults in Australia who had made a suicide attempt, for example, the median time until first re-attempt was 241 days for middle-aged adults and 173 days for older adults.30 An estimated 2 percent will die as a result of suicide in the subsequent year,29 and suicide deaths continue to accumulate, with reports of 5 percent or more dying by suicide after 9 years and as many as 13 percent after 37 years.31 Some studies, however, have reported lower rates of re-attempts and deaths.30,32 One study of patients treated for self-harm in England in which patients used self-poisoning found that this method was associated with a lower risk of re-attempt than other methods of self-harm.33 Among those who have made suicide attempts, the risk of another attempt varies somewhat by sex: repeat attempts in males are more likely to be associated with substance abuse, while in females, PTSD and high levels of depression are associated with repeat attempts.34

In a study of young adolescents (ages 12 to 15 years) with a psychiatric inpatient stay, 36.4 percent of those with previous suicide attempts made a suicide attempt within 18 months of discharge compared with 12.7 percent of those who had not made a previous attempt.35 Most adolescents who self-reported a history of self-harm on a telephone interview did not report continued self-harm into young adulthood, however, particularly among boys.36 This study did not report factors that were associated with continuation, such as treatment history.

## Risk Factors

Suicide risk in the United States varies according to age, sex, and race. The presence of a psychiatric disorder also increases the risk of suicide, particularly affective disorders (e.g., depression),37–39 schizophrenia,37 PTSD,38,39 and substance use disorders.37,38 As many as 87 percent of those who die as a result of suicide meet the criteria for a psychiatric disorder before their death.40 Among U.S. adults, a lifetime history of depression more than doubles the odds of a suicide attempt. A history of a psychotic disorder, PTSD, and dysthymia all increase the odds of suicide by more than 50 percent.39 Depression is likely present in 50 to 79 percent of youth suicide attempts, though the depression is not always recognized.41 Other clinically-relevant variables can increase the risk of suicide attempt. For example, a prior suicide attempt is a major risk factor for future suicide attempts42 and completed suicides.43–46 Further, having a history of nonsuicidal self-harm is an independent risk factor for attempting suicide, as is borderline personality disorder (BPD).47

Other important risk factors for suicide include the presence of a serious adverse childhood experience (e.g., family violence, physical or sexual abuse, incarcerated family members, or familial mental illness),48,49 family history of suicide (especially parental),50,51 sexual minority status,18,52,53 and possibly history of being bullied,54 sleep disturbance,55,56 and chronic medical conditions such as epilepsy and chronic pain.57 Among males, socioeconomic factors such as low income level, occupation, and being unemployed are also associated with suicide.37

Among older adults, social isolation, spousal bereavement, neuroticism, affective disorders (e.g., unipolar major depression), physical illness, and functional impairment are all associated with an increased risk of suicide attempt.58 Several studies indicate that suicidal ideation is rare among seriously ill older adults without clinically significant mood disturbances.58

Risk factors among military veterans include prolonged combat injury (specifically traumatic brain injury), separation from service within the previous 12 months, PTSD, and other psychiatric illnesses (e.g., depression).11,59

Individual risk factors, however, have only limited ability to predict suicide in an individual at any particular time. A large portion of Americans have one of these enumerated risk factors for suicide; however, only a small proportion will attempt suicide, and even fewer will die by suicide. For example, among a sample of adult patients judged by physicians to be in need of treatment for depression, 90 percent were identified as having a low risk of self-harm, based on self-reported suicidal ideation.60 In addition, focus on risk factors alone ignores the role of protective factors and the balance between them.61 Concern for suicide increases with multiple risk factors and high levels of distress.38,62

## Rationale for Screening

Data from the late 1980s and early 1990s indicates that 38 percent of adults of all ages in the United States visited their primary care providers within 1 month of committing suicide. This rate was even higher (50% to 70%) in older adults.63 Further, nearly 90 percent of suicidal youth were seen for primary care visits during the previous 12 months compared with 70 to 80 percent of nonsuicidal youth.64,65 If any of the available screenings tools were accurate and feasible for use in primary care, this could represent an important opportunity for identifying people at increased risk of suicide.

## Screening Strategies

The previous U.S. Preventive Services Task Force (USPSTF) review66 identified only one study of test characteristics for a suicide screening test.67 Numerous instruments, however, have been developed that may have utility in primary care settings (Appendix A). We examined these instruments for the current review and reviewed approaches to screening in general and high-risk populations. The recommendations for suicide screening in clinical practice from other health organizations are available in Table 2. The American Academy of Pediatrics recommends broad-based screening for suicide risk in adolescents,68 while other groups limit their recommendations for suicide risk screening to known high-risk patients.69–71

Table 2 Suicide Screening Recommendations of Other Organizations

Organization, Year of Recommendation | Recommendation
American Academy of Child and Adolescent Psychiatry, 2001 | Recommends that clinicians be aware of patients at high risk for suicide.69
American Academy of Pediatrics, 2007 | Recommends pediatricians ask questions about mood disorders, sexual orientation, suicidal thoughts, and other risk factors associated with suicide during the medical history taking at routine medical care visits.68
American Medical Association, 1997 | All adolescents should be asked annually about behaviors or emotions that indicate recurrent or severe depression or risk of suicide, and screen for depression or suicidal risk in those with risk factors such as family dysfunction, declining school grades, history of abuse, etc.71
Canadian Coalition for Seniors’ Mental Health, 2006 | Health care providers should assess for suicide risk among those with risk factors, such as prior suicidal behavior.70
Canadian Task Force on Preventive Health Care, 1994 | There is poor evidence to include or exclude routine evaluation of suicide risk during a periodic health examination.72
Michigan Quality Improvement Consortium, 2008/2009 | Recommends a periodic health maintenance examination in adults,73 including a behavioral assessment that evaluates suicide threats. It also recommends education and counseling for suicide threats among parents, children, and adolescents.74

## Treatment Approaches

Psychotherapy and pharmacotherapy are the primary interventions used in clinical settings. Given the high rate of mental health disorders among those who die by suicide, an underlying mental health condition (e.g., depression, PTSD) is often an important treatment target.4 Studies seeking to improve physician treatment and management of depression have lowered suicide rates in several countries outside the United States.75 Meta-analyses of randomized, controlled trials (RCTs) of antidepressants have generally not shown an impact on suicide attempts and deaths; however, effects on suicide attempts may be age-related. Antidepressants appear to reduce the risk of suicidal ideation and attempts in older adults, but some meta-analyses suggest a possible increase in suicidal ideation and attempts in teens and young adults (ages 18 to 29 years) taking antidepressants, particularly those with major depressive disorder and those taking paroxetine.76,77 Other medications can be appropriate for other subgroups, including some antipsychotics (e.g., clozapine) for individuals with schizophrenia78 and mood stabilizers (e.g., lithium) for individuals with bipolar disorder.79

A wide variety of psychotherapy interventions are used to reduce suicide risk. The National Registry of Evidence-Based Programs and Practices, maintained by the Substance Abuse and Mental Health Services Administration, includes 19 interventions that include suicidal ideation or behavior as an outcome.80 These programs include interventions targeting adolescents, adults, and older adults. These interventions include both treatment and screening approaches in a variety of settings, although some programs primarily target depression or substance abuse. A recent review examined training manuals of empirically supported treatments for suicidality and identified several factors that were common to all the interventions they examined. These factors include having a clear treatment framework, having an agreed-upon strategy to manage suicidal crises, attention to affect (e.g., emphasizing the emotional experiences of the patient, especially those experiences that contribute to suicide risk, and facilitating tolerance of feelings, thoughts, opposing feelings/thoughts, and ambiguity), the therapist taking an active role in treatment, exploratory interventions, and a focus on change-oriented interventions.81

## System- and Policy-Level Suicide Prevention Approaches

While many risk factors for suicide cannot be altered, some prevention targets particular steps in the progression from suicide ideation to suicide attempt, although this evidence base is limited. One example is education of physicians and “community gatekeepers,” such as those in the military, who can then direct individuals to treatment.75

Restricting access to lethal means has also been found to prevent suicide.75 Completed suicides have decreased following firearm control legislation (e.g., waiting periods and licensing requirements), pesticide restrictions, detoxification of domestic gas, restrictions on barbiturates, mandatory use of catalytic converters in automobiles, construction of barriers at jumping sites, use of lower toxicity antidepressants, introduction of “safe rooms” in prisons and hospitals, and reducing drug pack size for paracetamol and salicylate.75,82 Such environmental restrictions are likely to be most effective when the proposed method is popular, highly lethal, widely available, and not easily substituted by a similar means.

A study of 21 developed nations (including the United States) demonstrated that the presence of a national policy to prevent suicide is associated with a lower rate of suicide, particularly in males.83 In this study, suicide rates in males dropped by an estimated 1.4 per 100,000 person-years after the implementation of a national policy. In England and Wales, implementation of mental health service recommendations in regional health trusts was similarly associated with lower suicide rates.84 Specific components associated with the greatest reductions in suicide rates included 24-hour crisis care, introduction of substance abuse policies for treatment of patients with dual diagnosis, and multidisciplinary review after suicide.

## Role of Primary Care

Specific therapeutic approach aside, primary care providers may have an important role to play in identifying those in need of treatment and coordinating with specialty providers, as well as attending to the physical health needs of patients with a history of suicide attempts. A recent large-scale review by the National Institute of Clinical Excellence (NICE) on management of self-harm recommends the following for primary care providers in the United Kingdom.85

1. If a person presents in primary care with a history of self-harm and a risk of repetition, consider referring them to community mental health services for assessment. If they are younger than age 18 years, consider referring them to child and adolescent mental health specialists. Make referral a priority when: levels of distress are rising, high, or sustained; the risk of self-harm is increasing or unresponsive to attempts to help; the person requests further help from specialist services; and/or levels of distress in parents or caretakers of children and young people are rising, high, or sustained despite attempts to help.
2. If a person who self-harms is receiving treatment or care in primary care as well as secondary care, primary and secondary health and social care professionals should ensure they work cooperatively, routinely sharing up-to-date care and risk management plans. In these circumstances, primary health and social care professionals should attend care planning meetings.
3. Primary care professionals should monitor the physical health of people who self-harm. Pay attention to the physical consequences of self-harm as well as other physical health care needs.

## Current Clinical Practice in the United States

In a study of U.S. primary care providers, suicide was discussed in only 11 percent of encounters with patients who had (unbeknownst to their providers) screened positive for suicidal ideation.86 Similarly, only 36 percent of U.S. primary care physicians explored suicide in encounters with standardized patients portraying major depression, adjustment disorder, or those who sought out antidepressants.87 Danish general practitioners participating in in-depth interviews about how they handled mental health issues felt that greater clinical experience led to an increased likelihood of discussing suicide risk with their patients.88

Less than one quarter of surveyed primary care pediatricians or family practice physicians in Maryland reported that they frequently or always screened adolescents for suicide risk factors in a mailed survey, despite the fact that nearly 75 percent thought that physicians can be effective in preventing some teen suicides.89 Only one third of the providers, however, thought they had enough time during well-child visits and sufficient training to screen for suicide.89 Indeed, training of providers can increase screening rates. One trial found that 36 percent of providers screened their patients for suicide in low-income practices of mostly black youth before receiving an intervention designed to increase screening rates. These same providers screened 82 percent of patients after the training.90 Similarly, providers in this study detected increased suicide risk in 0.8 percent of their patients before training, and in 3.6 percent of their patients after training.90

Patients appear to be reluctant to discuss suicidal feelings. Among patients who endorsed suicidal ideation on a screening questionnaire that their provider did not see, for example, only 7 percent had initiated a conversation about suicidal feelings.86 A psychological autopsy study of 571 suicide cases whose last contact with a health care professional was within 28 days of their death found that suicide was only discussed in 22 percent of the visits. Likewise, suicide was only discussed during 21 percent of the visits occurring on the same day that the person committed suicide.44

Unfortunately, many people contemplating suicide do not seek or receive treatment for their distress. Only 26 percent of adolescents with suicidal ideation received mental health treatment or psychotropic medications during the previous year, and only 16 percent received care during the subsequent year.64 Similarly, a survey conducted in 2002 and 2003 found that only 46 percent of U.S. adults who had suicidal ideation and had attempted suicide received any mental health care during the previous year.91

## Current U.S. Initiatives

In 1999, the U.S. Surgeon General, in collaboration with multiple government agencies, issued a call to develop a national strategy to prevent suicide.92 This strategy was a blueprint for addressing suicide prevention that included 15 key recommendations covering increasing awareness, enhancing services, and advancing the science of suicide prevention. This effort led to the development of the 2001 National Strategy for Suicide Prevention (NSSP), a comprehensive report that was developed with input from researchers, practitioners, federal agencies, nongovernmental organizations and groups, and consumers.93 This report enumerated specific goals and objectives related to suicide prevention, four of which were directly related to primary care:

- NSSP 5.1: By 2005, increase the proportion of primary care clinicians, other health care providers, and health and safety officials who routinely assess the presence of lethal means (including firearms, drugs, and poisons) in the home and educate about actions to reduce associated risks.
- NSSP 7.2: By 2005, develop guidelines for assessment of suicidal risk among persons receiving care in primary health care services, EDs, and specialty mental health and substance abuse treatment centers, and implement these guidelines in a proportion of these settings.
- NSSP 7.9: By 2005, incorporate screening for depression, substance abuse, and suicide risk as a minimum standard of care for assessment in primary care settings, hospice, and skilled nursing facilities for all federally-supported health care programs (e.g., Medicaid, TRICARE [formerly Civilian Health and Medical Program of Uniformed Services], Medicare, and State Health Insurance Assistant Program).
- NSSP 7.10: By 2005, include screening for depression, substance abuse, and suicide risk as measurable performance items in the Health Plan Employer Data and Information Set.

An updated NSSP report is due soon, so these objectives may soon change. The National Action Alliance for Suicide Prevention is a public-private partnership with the mission of advancing the NSSP. It has a number of task forces tackling difference aspects of the NSSP that fall into three broad categories: infrastructure (e.g., research prioritization, data, and surveillance), high-risk populations (e.g., Native Americans and Alaskan Natives; lesbian, gay, bisexual, and transgender persons; military/veterans), and interventions (e.g., clinical care and interventions, clinic workforce preparedness). In addition, Healthy People 2020 has published two goals related to suicide prevention:

- Mental Health Mood Disorder (MHMD)-1: Reduce suicide rate. Target 10.2 suicides per 100,000 (from baseline of 11.3 per 100,000 in 2007).94
- MHMD-2: Reduce suicide attempts by adolescents. Target 1.6 suicide attempts per 100 (from baseline of 1.9 suicide attempts per 100 in 2009).94

The Department of Defense and VA also promote research and policies to prevent suicide among military personnel and veterans.95 The VA has established two centers that focus on suicide research and instituted a number of population-based initiatives, including public awareness campaigns for service members and veterans, a 24-hour suicide crisis hotline, a gun safety program, and a program to improve identification of suicidal veterans in VA and community EDs. This program provides suicidal veterans with a brief ED-based intervention, links them to services at the VA, and ensures appropriate followup care.96 The U.S. Air Force has also implemented a comprehensive suicide prevention program that has reduced the suicide rate by 33 percent between 1987 and 1996 and 1997 through 2007.^97^

## Previous USPSTF Recommendation

In 2004, the USPSTF concluded there was insufficient evidence to recommend for or against routine screening by primary care clinicians to detect suicide risk in the general population (I statement). The previous review found limited evidence that screening tests can reliably detect suicide risk in primary care populations. There was a fairly large body of evidence examining the effects of treatment on suicide attempts and suicide deaths in adolescents and/or adults (33 RCTs and two cohort studies). Few trials, however, showed benefit of treatment and many trials were underpowered for these rare outcomes. In addition, evidence showed that nonpharmacologic treatment could reduce depressive symptoms and suicidal ideation in high-risk older adolescents and adults. The USPSTF found no evidence on the harms of screening, and only two trials addressed harms of nonpharmacologic treatment, with contradictory results.