# Evidence Tables

Appendix H Table 1 Suicide Deaths: Adults and Older Adults

Appendix H Table 2 Suicide Attempts or Episodes of Deliberate Self-Harm: Adults and Older Adults

Appendix H Table 3 Other Health Outcomes: Hospitalization or Emergency Department Use, Adults

Appendix H Table 4 Other Health Outcomes: Functioning, Quality of Life, and Other, Adults

Appendix H Table 5 Intermediate Outcomes: Suicidal Ideation, Adults and Older Adults

Appendix H Table 6 Intermediate Outcomes: Depression, Adults and Older Adults

Appendix H Table 7 Intermediate Outcomes: Hopelessness, Adults

Appendix H Table 8 Suicide Deaths: Adolescents

Appendix H Table 9 Suicide Attempts or Episodes of Deliberate Self-Harm: Adolescents

Appendix H Table 10 Other Health Outcomes: Hospitalization or Emergency Department Use, Adolescents

Appendix H Table 11 Other Health Outcomes: Functioning, Adolescents

Appendix H Table 12 Intermediate Outcomes: Suicidal Ideation, Adolescents

Appendix H Table 13 Intermediate Outcomes: Depression, Adolescents

Appendix H Table 14 Intermediate Outcomes: Hopelessness, Adolescents