# Detailed Intervention Descriptions

Appendix G Table 1 Detailed Intervention Descriptions Among Adult and Older Adult Studies

Appendix G Table 2 Detailed Intervention Descriptions Among Adolescent Studies