# Quality Assessment

Appendix E Table 1 Quality Assessment Tools

Appendix E Table 2 Quality Assessment of Included Studies: Adults and Older Adults (Key Questions 4 and 5)

Appendix E Table 3 Quality Assessment of Included Studies: Adolescents (Key Questions 4 and 5)