# Excluded Studies

Exclusion Codes:
E1a. Suicide prevention was not primary aim
E1b. Study not relevant for other reason
E1c. Focus on treatment-emergent suicide
E1d. Focus on nonsuicidal self-harm
E2. Wrong setting
E3. Comparative effectiveness study
E4. Instrument does not target suicide risk
E5. No relevant outcomes
E6a. Limited to those with comorbidities
E6b. Limited to patients in midst of suicidal crisis
E6c. Wrong population
E6d. Not limited to those with increased suicide risk
E7a. Not one of the specified interventions
E7b. Not primary care feasible or referable
E7c. Timing of intervention
E8. Wrong study design
E9a. High or differential attrition
E9b. Other quality issues
E10. NonEnglish publication
E11. Instrument not brief
E12. Unable to locate
E13. Trial pending assessment/ongoing study

1 Medication may help prevent suicide in teens. Brown University Child Adolesc Psychopharmacol Update. Mar. 2003;5(3):1-4. KQ4E8, KQ5E8, KQ6E8.
2 Rate of repeated suicide attempts halved with cognitive therapy. Drug Benefit Trends. 2005;17(9):402. KQ4E8, KQ5E8, KQ6E8.
3 Protective effects of adjunctive lithium for at-risk suicidal patients. Brown University Psychopharmacol Update. Dec. 2008;19(12):1. KQ4E8, KQ5E8, KQ6E8.
4 Alexopoulos GS, Reynolds CF III, Bruce ML, et al. Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. Aug. 2009;166(8):882-90. KQ6E5. [pmid: 19528195].
5 Allard R, Marshall M, Plante MC. Intensive follow-up does not decrease the risk of repeat suicide attempts. Suicide Life Threat Behav. 1992;22(3):303-14. KQ5E5. [pmid: 1440744].
6 Almeida OP, Pirkis J, Kerse N, et al. A randomized trial to reduce the prevalence of depression and self-harm behavior in older primary care patients. Ann Fam Med. Jul. 2012;10(4):347-56. KQ6E5. [pmid: 22778123].
7 Aoun S. Deliberate self-harm in rural Western Australia: results of an intervention study. Aust N Z J Ment Health Nurs. Jun. 1999;8(2):65-73. KQ4E8, KQ5E8, KQ6E5. [pmid: 10661074].
8 Arensman E, McAuliffe C, Corcoran P, et al. Findings of the POPMACT study. Psychol Med. 2004;34(6):1143-4. KQ6E5. [pmid: 15554583].
9 Asarnow JR, Baraff LJ, Berk M, et al. An emergency department intervention for linking pediatric suicidal patients to follow-up mental health treatment. Psychiatr Serv. 2011;62(11):1303-9. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 22211209].
10 Aseltine RH Jr, DeMartino R. An outcome evaluation of the SOS Suicide Prevention Program. Am J Public Health. Mar. 2004;94(3):446-51. KQ4E2, KQ5E2, KQ6E2. [pmid: 14998812].
11 Aseltine RH Jr, James A, Schilling EA, et al. Evaluating the SOS suicide prevention program: a replication and extension. BMC Public Health. 2007;7:161. KQ4E2, KQ5E2, KQ6E2. [pmid: 17640366].
12 Awata S, Bech P, Koizumi Y, et al. Validity and utility of the Japanese version of the WHO-Five Well-Being Index in the context of detecting suicidal ideation in elderly community residents. Int Psychogeriatr. Feb. 2007;19(1):77-88. KQ1E8, KQ2E4, KQ3E8. [pmid: 16970832].
13 Bannan N. Group-based problem-solving therapy in self-poisoning females: A pilot study. Couns Psychother Res. 2010;10(3):201-13. KQ4E5, KQ6E5.
14 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. 2011;68(6):627-36. KQ6E5. [pmid: 21646579].
15 Barkin SL, Finch SA, Ip EH, et al. Is office-based counseling about media use, timeouts, and firearm storage effective? Results from a cluster-randomized, controlled trial. Pediatrics. Jul. 2008;122(1):e15-e25. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 18595960].
16 Barnes AJ. Attachment-based family therapy reduces suicidal ideation in adolescents. Evid Based Ment Health. Feb. 2011;14(1):8. KQ6E5. [pmid: 21266605].
17 Bateman A, Fonagy P. Effectiveness of partial hospitalization in the treatment of borderline personality disorder: a randomized controlled trial. Am J Psychiatry. Oct. 1999;156(10):1563-9. KQ6E5. [pmid: 10518167].
18 Bateman A, Fonagy P. Treatment of borderline personality disorder with psychoanalytically oriented partial hospitalization: an 18-month follow-up. Am J Psychiatry. Jan. 2001;158(1):36-42. KQ6E5. [pmid: 11136631].
19 Battaglia J, Wolff TK, Wagner-Johnson DS, et al. Structured diagnostic assessment and depot fluphenazine treatment of multiple suicide attempters in the emergency department. Int Clin Psychopharmacol. Nov. 1999;14(6):361-72. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 10565804].
20 Bauer J. Clinical highlights. Cognitive therapy can prevent repeat suicide attempts. RN. Nov. 2005;68(11):24. KQ4E8, KQ5E8, KQ6E8. [pmid: 16052875].
21 Beautrais AL, Gibb SJ, Faulkner A, et al. Postcard intervention for repeat self-harm: randomised controlled trial. Br J Psychiatry. Jul. 2010;197(1):55-60. KQ5E5, KQ6E5. [pmid: 20592434].
22 Beck AT. Community-based cognitive therapy for suicide attempters. 2004. http://www.mrw.interscience.wiley.com/cochrane/clcentral/articles/073/CN-00497073/frame.html. Accessed November 20, 2011. KQ4E8, KQ5E8, KQ6E8.
23 Bennewith O, Stocks N, Gunnell D, et al. General practice based intervention to prevent repeat episodes of deliberate self harm: cluster randomised controlled trial. BMJ. May. 25. 2002;324(7348):1254-7. KQ5E5. [pmid: 12028981].
24 Berrino A, Ohlendorf P, Duriaux S, et al. Crisis intervention at the general hospital: An appropriate treatment choice for acutely suicidal borderline patients. Psychiatry Res. 2011;186(2–3):287-92. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 20667602].
25 Biggam FH. The development of social problem-solving interventions in young offender mental health services: a focus upon self-harm and suicide risk. Social Problem Solving and Offending Evidence, Evaluation and Evolution. Hoboken, NJ. John Wiley & Sons Ltd. 2005:145-62. KQ4E8, KQ5E8, KQ6E8.
26 Bogner HR, Morales KH, Post EP, et al. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. 2007;30(12):3005-10. KQ6E5. [pmid: 17717284].
27 Brent DA, Greenhill LL, Compton S, et al. The Treatment of Adolescent Suicide Attempters study (TASA): predictors of suicidal events in an open treatment trial. J Am Acad Child Adolesc Psychiatry. Oct. 2009;48(10):987-96. KQ4E3, KQ5E3, KQ6E3. [pmid: 19730274].
28 Brown GK, Wiltsey Stirman S. Psychiatric telephone contact following emergency department discharge reduces suicide re-attempts in people originally admitted for attempted suicide. Evid Based Ment Health. Feb. 2007;10(1):19. KQ4E8, KQ5E8, KQ6E8. [pmid: 17255388].
29 Bruce ML, Ten Have TR, Reynolds CF III, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. Mar. 3. 2004;291(9):1081-91. KQ6E5. [pmid: 14996777].
30 Burleson JA, Kaminer Y, Goldston DB, et al. Suicidal ideation among alcohol-use disordered adolescents in treatment and aftercare. 68th Annual Scientific Meeting of the College on Problems of Drug Dependence. Scottsdale, AZ. 2005. KQ4E1a, KQ5E1a, KQ6E1a.
31 Byers AL, Bruce ML, Raue P. Suicidal ideation in non-depressed elderly primary care patients: The PROSPECT Study. Am J Geriatr Psychiatry. 2009;17:A86. KQ6E5.
32 Carpenter DJ, Fong R, Kraus JE, et al. Meta-analysis of efficacy and treatment-emergent suicidality in adults by psychiatric indication and age subgroup following initiation of paroxetine therapy: a complete set of randomized placebo-controlled trials. J Clin Psychiatry. Feb. 22. 2011;72(11):1503-14. KQ4E8, KQ5E8, KQ6E8. [pmid: 21367354].
33 Carter GL, Clover KA, Bryant JL, et al. Can the Edinburgh Risk of Repetition Scale predict repetition of deliberate self-poisoning in an Australian clinical setting?. Suicide Life Threat Behav. 2002;32(3):230-9. KQ2E8, KQ3E8. [pmid: 12374470].
34 Carter GL, Clover K, Whyte IM, et al. Postcards from the EDge project: randomised controlled trial of an intervention using postcards to reduce repetition of hospital treated deliberate self poisoning. BMJ. Oct. 8. 2005;331(7520):805. KQ6E5. [pmid: 16183654].
35 Carter GL, Clover K, Whyte IM, et al. Postcards from the EDge: 24-month outcomes of a randomised controlled trial for hospital-treated self-poisoning. Br J Psychiatry. Dec. 2007;191:548-53. KQ5E5, KQ6E5. [pmid: 18055960].
36 Carter GL, Willcox CH, Lewin TJ, et al. Hunter DBT project: randomized controlled trial of dialectical behaviour therapy in women with borderline personality disorder. Aust N Z J Psychiatry. Feb. 2010;44(2):162-73. KQ6E5. [pmid: 20113305].
37 Catanese AA, John MS, Di Battista J, et al. Acute cognitive therapy in reducing suicide risk following a presentation to an emergency department. Behav Change. 2009;26(1):16-26. KQ4E8, KQ5E8, KQ6E5.
38 Cedereke M, Monti K, Ojehagen A. Telephone contact with patients in the year after a suicide attempt: does it affect treatment attendance and outcome? A randomised controlled study. Eur Psychiatry. Apr. 2002;17(2):82-91. KQ6E5. [pmid: 11973116].
39 Chamberlain P, Goldney R, Delfabbro P, et al. Suicidal ideation. The clinical utility of the K10. Crisis. 2009;30(1):39-42. KQ2E4, KQ3E4. [pmid: 19261567].
40 Chan SS, Wong CS, Chiu HF. The validity of proxy-based NEO-Five Factor Inventory data in suicide research: a study of 18- to 64-year-old Hong Kong Chinese who attempted suicide. East Asian Arch Psychiatry. Jun. 2011;21(2):58-63. KQ1E8, KQ2E5, KQ3E8. [pmid: 21838208].
41 Chanen AM, Jackson HJ, McCutcheon LK, et al. Early intervention for adolescents with borderline personality disorder using cognitive analytic therapy: randomised controlled trial. [Erratum appears in Br J Psychiatry. 2009 Feb;194(2):191]. Br J Psychiatry. Dec. 2008;193(6):477-84. KQ6E5. [pmid: 19043151].
42 Chen WJ, Chen CC, Ho CK, et al. Community-based case management for the prevention of suicide reattempts in Kaohsiung, Taiwan. Community Ment Health J. 2012. Feb. 3. KQ4E8, KQ5E8, KQ6E8. [pmid: 22302211].
43 Chioqueta AP, Stiles TC. Psychometric properties of the Beck Scale for Suicide Ideation: a Norwegian study with university students. Nord J Psychiatry. 2006;60(5):400-4. KQ2E5, KQ3E8. [pmid: 17050298].
44 Chowdhury E, Hicks RC, Kreitman N. Evaluation of an after-care service for parasuicide (attempted suicide) patients. Soc Psychiatry. 1973;8:67-81. KQ4E9b, KQ5E9b, KQ6E9b.
45 Ciffone J. Suicide prevention: a classroom presentation to adolescents. Soc Work. Mar. 1993;38(2):197-203. KQ3E1b, KQ6E2. [pmid: 8480248].
46 Clarke T, Baker P, Watts CJ, et al. Self-harm in adults: A randomised controlled trial of nurse-led case management versus routine care only. J Ment Health. 2002;11(2):167-76. KQ5E5, KQ6E5.
47 Collins JC, McFarland BH. Divalproex, lithium and suicide among Medicaid patients with bipolar disorder. J Affect Disord. Apr. 2008;107(1–3):23-8. KQ4E8, KQ5E8, KQ6E5. [pmid: 17707087].
48 Comtois KA, Jobes DA, O'C S, et al. Collaborative assessment and management of suicidality (CAMS): feasibility trial for next-day appointment services. Depress Anxiety. Nov. 2011;28(11):963-72. KQ6E5. [pmid: 21948348].
49 Cooper J, Kapur N, Dunning J, et al. A clinical tool for assessing risk after self-harm. Ann Emerg Med. Oct. 2006;48(4):459-66. KQ1E8, KQ2E8, KQ3E8. [pmid: 16997684].
50 Cooper J, Kapur N, kway-sJones K. A comparison between clinicians' assessment and the Manchester Self-Harm Rule: a cohort study. Emerg Med J. Oct. 2007;24(10):720-1. KQ1E8, KQ2E8, KQ3E8. [pmid: 17901275].
51 Corson K, Gerrity MS, Dobscha SK. Screening for depression and suicidality in a VA primary care setting: 2 items are better than 1 item. Am J Manag Care. Nov. 2. 2004;10(11 Part 2):839-45. KQ2E4, KQ3E4. [pmid: 15609737].
52 Coryell W, Arndt S, Turvey C, et al. Lithium and suicidal behavior in major affective disorder: a case-control study. Acta Psychiatr Scand. Sep. 2001;104(3):193-7. KQ4E8, KQ5E8, KQ6E5. [pmid: 11531655].
53 Cotgrove A, Zirinsky L, Black D, et al. Secondary prevention of attempted suicide in adolescence. Am J Adolesc. 1995;18:569-77. KQ4E7c, KQ5E7c, KQ6E7c.
54 Cottrell DJ. Group therapy does not reduce repeated deliberate self-harm in adolescents. Evid Based Ment Health. Feb. 2010;13(1):17. KQ4E8, KQ5E8, KQ6E8. [pmid: 20164514].
55 Coyne JC, Koppel J, Colenda CC, et al. Interventions for treatment of depression in primary care. JAMA. Jun. 16. 2004;291(23):2814-6. KQ6E5. [pmid: 15199023].
56 Crane C, Barnhofer T, Duggan DS, et al. Mindfulness-based cognitive therapy and self-discrepancy in recovered depressed patients with a history of depression and suicidality. Cognit Ther Res. 2008;32(6):775-87. KQ4E5, KQ5E5, KQ6E5. [pmid: 19249017].
57 Crawford MJ, Csipke E, Brown A, et al. The effect of referral for brief intervention for alcohol misuse on repetition of deliberate self-harm: an exploratory randomized controlled trial. Psychol Med. Nov. 2010;40(11):1821-8. KQ5E5, KQ6E5. [pmid: 20047702].
58 Davidson K, Scott J, Schmidt U, et al. Therapist competence and clinical outcome in the Prevention of Parasuicide by Manual Assisted Cognitive Behaviour Therapy trial: the POPMACT study. Psychol Med. Jul. 2004;34(5):855-63. KQ6E5. [pmid: 15500306].
59 De Leo D, Dello Buono M, Dwyer J. Suicide among the elderly: the long-term impact of a telephone support and assessment intervention in northern Italy. Br J Psychiatry. Sep. 2002;181:226-9. KQ4E8, KQ5E8, KQ6E8. [pmid: 12204927].
60 De Leo D, Heller T. Intensive case management in suicide attempters following discharge from inpatient psychiatric care. Aust J Prim Health. 2007;13(3):49-58. KQ4E9a, KQ5E9a, KQ6E9a.
61 de Wilde EJ, van de LP, Goldschmeding J, et al. Self-report of suicidal thoughts and behavior vs. school nurse evaluations in Dutch high-school students. Crisis. 2011;32(3):121-7. KQ1E1a, KQ2E1a, KQ3E1a. [pmid: 21616760].
62 Delgado-Gomez D, Blasco-Fontecilla H, Alegria AA, et al. Improving the accuracy of suicide attempter classification. Artif Intell Med. Jul. 2011;52(3):165-8. KQ2E8, KQ3E8. [pmid: 21696929].
63 Diamond GS, Wintersteen MB, Brown GK, et al. Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Feb. 2010;49(2):122-31. KQ6E5. [pmid: 20215934].
64 Draper B, Hirsch S. Treatment of a parasuicide patients with mianserin, nomifensine and placebo, a double blind placebo controlled trial. Forthcoming. 1982. KQ4E12, KQ5E12, KQ6E12.
65 Dube P, Kurt K, Bair MJ, et al. The p4 screener: evaluation of a brief measure for assessing potential suicide risk in 2 randomized effectiveness trials of primary care and oncology patients. Prim Care Companion J Clin Psychiatry. 2010;12(6):2010. KQ2E6a, KQ3E6a. [pmid: 21494337].
66 Edelstein BA, Heisel MJ, McKee DR, et al. Development and psychometric evaluation of the reasons for living--older adults scale: a suicide risk assessment inventory. Gerontologist. Dec. 2009;49(6):736-45. KQ2E5, KQ3E8. [pmid: 19546114].
67 Eggert LL, Thompson EA, Randell BP, et al. Preliminary effects of brief school-based prevention approaches for reducing youth suicide--risk behaviors, depression, and drug involvement. J Child Adolesc Psychiatr Nurs. Apr. 2002;15(2):48-64. KQ6E5. [pmid: 12083753].
68 Eskin M, Ertekin K, Demir H. Efficacy of a problem-solving therapy for depression and suicide potential in adolescents and young adults. Cognit Ther Res. 2008;32:971-82. KQ4E9a, KQ5E9a, KQ6E9a.
69 Esposito-Smythers C, Spirito A, Kahler CW, et al. Treatment of co-occurring substance abuse and suicidality among adolescents: a randomized trial. J Consult Clin Psychol. Dec. 2011;79(6):728-39. KQ6E5. [pmid: 22004303].
70 Esposito-Smythers C, Walsh B, Spirito A, et al. Working with the suicidal client who also abuses substances. Cognit Behavir Pract. 2012;19:245-55. KQ6E5.
71 Evans J, Evans M, Morgan HG, et al. Crisis card following self-harm: 12-month follow-up of a randomised controlled trial. Br J Psychiatry. Aug. 2005;187:186-7. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 16055834].
72 Evans K, Tyrer P, Catalan J, et al. Manual-assisted cognitive-behaviour therapy (MACT): a randomized controlled trial of a brief intervention with bibliotherapy in the treatment of recurrent deliberate self-harm. Psychol Med. Jan. 1999;29(1):19-25. KQ6E5. [pmid: 10077290].
73 Evans MO, Morgan HG, Hayward A, et al. Crisis telephone consultation for deliberate self-harm patients: effects on repetition. Br J Psychiatry. Jul. 1999;175:23-7. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 10621764].
74 Fleischhaker C, Bohme R, Sixt B, et al. Dialectical behavioral therapy for adolescents (DBT-A): a clinical trial for patients with suicidal and self-injurious behavior and borderline bymptoms with a one-year follow-up. Child Adolesc Psychiatry Ment Health. 2011;5(1):3. KQ4E8, KQ5E8, KQ6E5. [pmid: 21276211].
75 Fleischmann A, Bertolote JM, Wasserman D, et al. Effectiveness of brief intervention and contact for suicide attempters: a randomized controlled trial in five countries. Bull World Health Organ. Sep. 2008;86(9):703-9. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 18797646].
76 Fliege H, Kocalevent RD, Walter OB, et al. Three assessment tools for deliberate self-harm and suicide behavior: evaluation and psychopathological correlates. J Psychosom Res. Jul. 2006;61(1):113-21. KQ2E8, KQ3E8. [pmid: 16813853].
77 Folse VN, Eich KN, Hall AM, et al. Detecting suicide risk in adolescents and adults in an emergency department: a pilot study. J Psychosoc Nurs Ment Health Serv. Mar. 2006;44(3):22-9. KQ1E8, KQ2E5, KQ3E8. [pmid: 16583873].
78 Folse VN, Hahn RL. Suicide risk screening in an emergency department: engaging staff nurses in continued testing of a brief instrument. Clin Nurs Res. Aug. 2009;18(3):253-71. KQ2E5, KQ3E8. [pmid: 19411625].
79 Fountoulakis KN, Pantoula E, Siamouli M, et al. Development of the Risk Assessment Suicidality Scale (RASS): a population-based study. J Affect Disord. May. 20. 2012;138(3):449-57. KQ1E5, KQ2E5, KQ3E5. [pmid: 22301115].
80 Fu KW, Liu KY, Yip PS. Predictive validity of the Chinese version of the Adult Suicidal Ideation Questionnaire: psychometric properties and its short version. Psychol Assess. Dec. 2007;19(4):422-9. KQ2E8, KQ3E8. [pmid: 18085934].
81 Fu YX, Shen JL, Dang W. Effects of psychological intervention on the young people of attempted suicide. Chin Ment Health J. 2007;21(8):571-4. KQ4E10, KQ5E10, KQ6E10.
82 Fujisawa D, Tanaka E, Sakamoto S, et al. The development of a brief screening instrument for depression and suicidal ideation for elderly: the Depression and Suicide Screen. Psychiatry Clin Neurosci. Dec. 2005;59(6):634-8. KQ2E8, KQ3E8. [pmid: 16401236].
83 Gaddis GM. Improving the design of the assessment of emergency department patients at risk for self-harm. Ann Emerg Med. Oct. 2006;48(4):467-9. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, KQ6E8. [pmid: 16997685].
84 Gallo JJ, Bogner HR, Morales KH, et al. The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):689-98. KQ6E5. [pmid: 17502629].
85 Gau SS, Chen CH, Lee CT, et al. Development of a Chinese version of the Suicide Intent Scale. Suicide Life Threat Behav. Jun. 2009;39(3):332-42. KQ2E5, KQ3E8. [pmid: 19606924].
86 Gilbody SM. IMPACT collaborative care programme reduces suicide ideation in depressed older adults. Evid Based Ment Health. May. 2007;10(2):51. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 17459982].
87 Goldney R. Manual assisted cognitive behaviour therapy is as effective as treatment as usual for deliberate self harm, but is more cost effective. Evid Based Ment Health. Feb. 2004;7(1):15. KQ4E8, KQ5E8, KQ6E8. [pmid: 14769659].
88 Goldney RD. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 2002;32(4):454-6. KQ6E5. [pmid: 12501969].
89 Gratz KL, Gunderson JG. Preliminary data on an acceptance-based emotion regulation group intervention for deliberate self-harm among women with borderline personality disorder. Behav Ther. Mar. 2006;37(1):25-35. KQ4E1d, KQ5E1d, KQ6E1d. [pmid: 16942958].
90 Green JM, Wood AJ, Kerfoot MJ, et al. Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 2011;342:d682. KQ6E5. [pmid: 21459975].
91 Grunebaum MF, Ellis SP, Duan N, et al. Pilot randomized clinical trial of an SSRI vs bupropion: effects on suicidal behavior, ideation, and mood in major depression. Neuropsychopharmacology. Feb. 2012;37(3):697-706. KQ4E3, KQ5E3, KQ6E3. [pmid: 21993207].
92 Guthrie E, Kapur N, kway-Jones K, et al. Randomised controlled trial of brief psychological intervention after deliberate self poisoning. BMJ. Jul. 21. 2001;323(7305):135-8. KQ6E5. [pmid: 11463679].
93 Guthrie E, Kapur N, kway-Jones K, et al. Predictors of outcome following brief psychodynamic-interpersonal therapy for deliberate self-poisoning. Aust N Z J Psychiatry. Oct. 2003;37(5):532-6. KQ6E5. [pmid: 14511080].
94 Gutierrez PM, Watkins R, Collura D. Suicide risk screening in an urban high school. Suicide Life Threat Behav. 2004;34(4):421-8. KQ2E5, KQ3E8. [pmid: 15585463].
95 Hallahan B, Hibbeln JR, Davis JM, et al. Omega-3 fatty acid supplementation in patients with recurrent self-harm. Single-centre double-blind randomised controlled trial. Br J Psychiatry. Feb. 2007;190:118-22. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 17267927].
96 Hallfors D, Brodish PH, Khatapoush S, et al. Feasibility of screening adolescents for suicide risk in "real-world" high school settings. Am J Public Health. Feb. 2006;96(2):282-7. KQ2E5, KQ3E8. [pmid: 16380568].
97 Hanbury A, Wallace L, Clark M. Use of a time series design to test effectiveness of a theory-based intervention targeting adherence of health professionals to a clinical guideline. Br J Health Psychol. Sep. 2009;14(Pt:3):3-18. KQ1E8, KQ2E8, KQ3E8, KQ4E5, KQ5E5, KQ6E5. [pmid: 18851769].
98 Harned MS, Chapman AL, xter-Mazza ET, et al. Treating co-occurring Axis I disorders in recurrently suicidal women with borderline personality disorder: a 2-year randomized trial of dialectical behavior therapy versus community treatment by experts. J Consult Clin Psychol. Dec. 2008;76(6):1068-75. KQ4E5, KQ5E5, KQ6E5. [pmid: 19045974].
99 Harned MS, Jackson SC, Comtois KA, et al. Dialectical behavior therapy as a precursor to PTSD treatment for suicidal and/or self-injuring women with borderline personality disorder. J Trauma Stress. Aug. 2010;23(4):421-9. KQ6E5. [pmid: 20648564].
100 Harned MS, Chapman AL, xter-Mazza ET, et al. Treating co-occurring Axis I disorders in recurrently suicidal women with borderline personality disorder: A 2-year randomized trial of dialectical behavior therapy versus community treatment by experts. Personality Disorders: Theory, Research, and Treatment. 2009;S(1):35-45. KQ4E5, KQ5E5, KQ6E5.
101 Harrington R, Kerfoot M, Dyer E, et al. Randomized trial of a home-based family intervention for children who have deliberately poisoned themselves. J Am Acad Child Adolesc Psychiatry. May. 1998;37(5):512-8. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 9585653].
102 Harriss L, Hawton K. Suicidal intent in deliberate self-harm and the risk of suicide: the predictive power of the Suicide Intent Scale. J Affect Disord. Jun. 2005;86(2–3):225-33. KQ2E8, KQ3E8. [pmid: 15935242].
103 Hassanian MH, Sarjami S, Kolahi AA, et al. Postcards in Persia: randomised controlled trial to reduce suicidal behaviours 12 months after hospital-treated self-poisoning. Br J Psychiatry. 2011;198:309-16. KQ6E5. [pmid: 21343332].
104 Hassanzadeh M, Khajeddin N, Nojomi M, et al. Brief intervention and contact after deliberate self-harm: an Iranian randomized controlled trial. Iranian J Psychiatry Behav Sci. 2010;4(2):5-12. KQ4E7c, KQ5E7c, KQ6E7c.
105 Hatcher S. The Manchester Self Harm Rule had good sensitivity but poor specificity for predicting repeat self harm or suicide. Evid Based Med. Jun. 2007;12(3):89. KQ1E8, KQ2E8, KQ3E8. [pmid: 17537897].
106 Hatcher S, Sharon C, Parag V, et al. Problem-solving therapy for people who present to hospital with self-harm: Zelen randomised controlled trial. Br J Psychiatry. Oct. 2011;199:310-6. KQ6E5. [pmid: 21816868].
107 Hawton K, Gath D, Smith E. Management of attempted suicide in Oxford. BMJ. Oct. 27. 1979;2(6197):1040-2. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 519277].
108 Hawton K, Bancroft J, Catalan J, et al. Domiciliary and out-patient treatment of self-poisoning patients by medical and non-medical staff. Psychol Med. Feb. 1981;11(1):169-77. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 7208740].
109 Healy DJ, Barry K, Blow F, et al. Routine use of the Beck Scale for Suicide Ideation in a psychiatric emergency department. Gen Hosp Psychiatry. Jul. 2006;28(4):323-9. KQ2E9b, KQ3E9b. [pmid: 16814632].
110 Heisel MJ, Flett GL. The development and initial validation of the geriatric suicide ideation scale. Am J Geriatr Psychiatry. Sep. 2006;14(9):742-51. KQ1E8, KQ2E8, KQ3E8. [pmid: 16943171].
111 Heisel MJ, Duberstein PR, Lyness JM, et al. Screening for suicide ideation among older primary care patients. J Am Board Fam Med. Mar. 2010;23(2):260-9. KQ3E8. [pmid: 20207936].
112 Heisel MJ, Conwell Y, Pisani AR, et al. Concordance of self- and proxy-reported suicide ideation in depressed adults 50 years of age or older. Can J Psychiatr Nurs. Apr. 2011;56(4):219-26. KQ2E8, KQ3E8. [pmid: 21507278].
113 Hendin H, Al Jurdi RK, Houck PR, et al. Evidence for significant improvement in prediction of acute risk for suicidal behavior. J Nerv Ment Dis. Aug. 2010;198(8):604-5. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, KQ6E8. [pmid: 20699729].
114 Hendin H, Al Jurdi RK, Houck PR, et al. Role of intense affects in predicting short-term risk for suicidal behavior: a prospective study. J Nerv Ment Dis. Mar. 2010;198(3):220-5. KQ2E8, KQ3E8. [pmid: 20216000].
115 Henriksson S. Increased antidepressant use and fewer suicides in Jamtland county, Sweden, after a primary care educational programme on the treatment of depression. Acta Psychiatr Scand. 2006;114:159-67. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 16889586].
116 Herman SM. Is the SADPERSONS Scale accurate for the veterans affairs population?. Psychol Services. 2006;3(2):137-41. KQ1E1a, KQ2E8, KQ3E8.
117 Hirayasu Y, Kawanishi C, Yonemoto N, et al. A randomized controlled multicenter trial of post-suicide attempt case management for the prevention of further attempts in Japan (ACTION-J). BMC Public Health. 2009;9:364. KQ4E5, KQ5E5, KQ6E5. [pmid: 19781096].
118 Hirsch SR, Walsh C, Draper R. Parasuicide. A review of treatment interventions. J Affect Disord. Dec. 1982;4(4):299-311. KQ4E8, KQ5E8, KQ6E8. [pmid: 6298293].
119 Hirsch SR, Walsh C, Draper R. The concept and efficacy of the treatment of parasuicide. Br J Clin Pharmacol. 1983;15(Suppl 2):189S-94S. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 6824554].
120 Hirschfeld RM, Russell JM. Assessment and treatment of suicidal patients. N Engl J Med. Sep. 25. 1997;337(13):910-5. KQ4E8, KQ5E8, KQ6E8. [pmid: 9302306].
121 Holi MM, Pelkonen M, Karlsson L, et al. Psychometric properties and clinical utility of the Scale for Suicidal Ideation (SSI) in adolescents. BMC Psychiatry. 2005;5:8. KQ2E9b, KQ3E8. [pmid: 15691388].
122 Holi MM, Pelkonen M, Karlsson L, et al. Detecting suicidality among adolescent outpatients: evaluation of trained clinicians' suicidality assessment against a structured diagnostic assessment made by trained raters. BMC Psychiatry. 2008;8:97. KQ3E8. [pmid: 19116040].
123 Hooven C, Walsh E, Pike KC, et al. Promoting CARE: Including parents in youth suicide prevention. Fam Community Health. Jul. 2012;35(3):225-35. KQ6E5. [pmid: 22617413].
124 Horowitz LM, Wang PS, Koocher GP, et al. Detecting suicide risk in a pediatric emergency department: development of a brief screening tool. Pediatrics. May. 2001;107(5):1133-7. KQ2E1b, KQ3E1b. [pmid: 11331698].
125 House A. Brief psychodynamic interpersonal therapy after deliberate self poisoning reduced suicidal ideation and deliberate self harm. Evid Based Ment Health. Feb. 2002;5(1):14. KQ4E8, KQ5E8, KQ6E8. [pmid: 11915817].
126 Houston JP, Degenhardt EL, Ahl J, et al. Suicidal ideation changes in depressed bipolar I patients with olanzapine-fluoxetine combination. 157th Annual Meeting of the American Psychiatric Association. 2004 May 1. New York. Hoboken, NJ. John Wiley & Sons. 2004:NR707. KQ4E8, KQ5E8, KQ6E8.
127 Houston JP, Ahl J, Meyers AL, et al. Reduced suicidal ideation in bipolar I disorder mixed-episode patients in a placebo-controlled trial of olanzapine combined with lithium or divalproex. J Clin Psychiatry. Aug. 2006;67(8):1246-52. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 16965203].
128 Huey SJ Jr, Henggeler SW, Rowland MD, et al. Multisystemic therapy effects on attempted suicide by youths presenting psychiatric emergencies. J Am Acad Child Adolesc Psychiatry. Feb. 2004;43(2):183-90. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 14726725].
129 Huth-Bocks AC, Kerr DC, Ivey AZ, et al. Assessment of psychiatrically hospitalized suicidal adolescents: self-report instruments as predictors of suicidal thoughts and behavior. J Am Acad Child Adolesc Psychiatry. Mar. 2007;46(3):387-95. KQ1E8, KQ2E8, KQ3E8. [pmid: 17314725].
130 Hvid M, Wang AG. Preventing repetition of attempted suicide--I. Feasibility (acceptability, adherence, and effectiveness) of a Baerum-model like aftercare. Nord J Psychiatry. 2009;63(2):148-53. KQ4E8, KQ5E8, KQ6E8. [pmid: 19016074].
131 Hvid M, Vangborg K, Sorensen HJ, et al. Preventing repetition of attempted suicide-II. The Amager Project, a randomized controlled trial. Nord J Psychiatry. Oct. 2011;65(5):292-8. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 21171837].
132 Innamorati M, Pompili M, Serafini G, et al. Psychometric properties of the suicidal history self-rating screening scale. Arch Suicide Res. Jan. 2011;15(1):87-92. KQ1E8, KQ2E8, KQ3E8. [pmid: 21294003].
133 Jacobson J, Osteen P, Sharpe T, et al. Randomized trial of suicide gatekeeper training for social work students. Res Soc Work Pract. May. 2012;22(3):270-81. KQ4E5, KQ5E5, KQ6E5.
134 Johnson RM, Frank EM, Ciocca M, et al. Training mental healthcare providers to reduce at-risk patients' access to lethal means of suicide: evaluation of the CALM Project. Arch Suicide Res. Jul. 2011;15(3):259-64. KQ4E5, KQ5E5, KQ6E5. [pmid: 21827315].
135 Joiner TE Jr, Pfaff JJ, Acres JG. A brief screening tool for suicidal symptoms in adolescents and young adults in general health settings: reliability and validity data from the Australian National General Practice Youth Suicide Prevention Project. Behav Res Ther. Apr. 2002;40(4):471-81. KQ2E8, KQ3E8. [pmid: 12008659].
136 Joiner TE Jr, Ribeiro JD. Assessment and management of suicidal behavior in children and adolescents. Pediatr Ann. Jun. 2011;40(6):319-24. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, KQ6E8. [pmid: 21678891].
137 Jones G, Gavrilovic JJ, McCabe R, et al. Treating suicidal patients in an acute psychiatric day hospital: A challenge to assumptions about risk and overnight care. J Ment Health. 2008;17(4):375-87. KQ4E1a, KQ5E1a, KQ6E1a.
138 Kaczmarek TL, Hagan MP, Kettler RJ. Screening for suicide among juvenile delinquents: reliability and validity evidence for the Suicide Screening Inventory (SSI). Int J Offender Ther Comp Criminol. Apr. 2006;50(2):204-17. KQ2E2, KQ3E8. [pmid: 16510890].
139 Kaslow NJ, Leiner AS, Reviere S, et al. Suicidal, abused African American women’s response to a culturally informed intervention. J Consult Clin Psychol. Aug. 2010;78(4):449-58. KQ4E9a, KQ5E9a, KQ6E9a. [pmid: 20658802].
140 Keane EM, Dick RW, Bechtold DW, et al. Predictive and concurrent validity of the Suicidal Ideation Questionnaire among American Indian adolescents. J Abnorm Child Psychol. Dec. 1996;24(6):735-47. KQ2E8. [pmid: 8970907].
141 Kellner CH, Fink M, Knapp R, et al. Relief of expressed suicidal intent by ECT: a consortium for research in ECT study. Am J Psychiatry. 2005;162(5):977-82. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 15863801].
142 Kene-Allampalli P, Hovey JD, Meyer GJ, et al. Evaluation of the reliability and validity of two clinician-judgment suicide risk assessment instruments. Crisis. 2010;31(2):76-85. KQ2E5, KQ3E8. [pmid: 20418213].
143 Kim GH, Kim K, Park H. Outcomes of a program to reduce depression. West J Nurs Res. Jun. 2011;33(4):560-76. KQ4E9, KQ5E9, KQ6E9. [pmid: 21078916].
144 King CA, Kramer A, Preuss L, et al. Youth-Nominated Support Team for Suicidal Adolescents (Version 1): a randomized controlled trial. J Consult Clin Psychol. Feb. 2006;74(1):199-206. KQ4E6c, KQ5E6c, KQ6E6c. [pmid: 16551158].
145 King CA, O’Mara RM, Hayward CN, et al. Adolescent suicide risk screening in the emergency department. Acad Emerg Med. Nov. 2009;16(11):1234-41. KQ1E1a, KQ2E1a, KQ3E1a. [pmid: 19845554].
146 King CA, Klaus N, Kramer A, et al. The Youth-Nominated Support Team-Version II for suicidal adolescents: A randomized controlled intervention trial. J Consult Clin Psychol. Oct. 2009;77(5):880-93. KQ1E1b, KQ2E1b, KQ3E1b, KQ6E5. [pmid: 19803568].
147 King KA, Strunk CM, Sorter MT. Preliminary effectiveness of surviving the teens([REGISTERED]) suicide prevention and depression awareness program on adolescents’ suicidality and self-efficacy in performing help-seeking behaviors. J Sch Health. Sep. 2011;81(9):581-90. KQ4E2, KQ5E2, KQ6E2. [pmid: 21831072].
148 Knox KL, Stanley B, Currier GW, et al. An emergency department-based brief intervention for veterans at risk for suicide (SAFE VET). Am J Public Health. Mar. 2012;102(S1):S33-S37. KQ4E8, KQ5E8, KQ6E8. [pmid: 22390597].
149 Kovac SH, Range LM. Does writing about suicidal thoughts and feelings reduce them?. Suicide Life Threat Behav. 2002;32(4):428-40. KQ4E5. [pmid: 12501967].
150 Kovac SH. Cognitive change writing instructions versus exposure writing instructions used by undergraduates exhibiting suicidal thoughts and/or behaviors. Diss Abstr Int: Section B: The Sciences and Engineering. 2002;62(7-B):3381. KQ4E8, KQ5E8, KQ6E8.
151 LaFromboise T, Howard-Pitney B. The Zuni life skills development curriculum: Description and evaluation of a suicide prevention program. J Couns Psychol. Oct. 1995;42(4):479-86. KQ4E2, KQ5E2, KQ6E2. [pmid: 8205222].
152 Langhinrichsen-Rohling J, Arata C, O’Brien N, et al. Sensitive research with adolescents: just how upsetting are self-report surveys anyway?. Violence Vict. Aug. 2006;21(4):425-44. KQ3E8. [pmid: 16897911].
153 Larzelere RE, Andersen JJ, Ringle JL, et al. The child suicide risk assessment: a screening measure of suicide risk in pre-adolescents. Death Stud. Nov. 2004;28(9):809-27. KQ2E6c, KQ3E6c. [pmid: 15493076].
154 Lauterbach E, Ahrens B, Felber W, et al. Suicide prevention by lithium SUPLI--challenges of a multi-center prospective study. Arch Suicide Res. 2005;9(1):27-34. KQ4E9a, KQ5E9a, KQ6E9a. [pmid: 16040577].
155 Lauterbach E, Felber W, Muller-Oerlinghausen B, et al. Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. Dec. 2008;118(6):469-79. KQ5E5. [pmid: 18808400].
156 Lehfeld H, Althaus DA, Hegerl U, et al. Suicide attempts: results and experiences from the German Competency Network on Depression. Adv Psychosom Med. 2004;26:137-43. KQ1E7b, KQ2E8, KQ3E7b, KQ4E7b, KQ5E7b, KQ6E7b. [pmid: 15326867].
157 Lerner MS, Clum GA. Treatment of suicide ideators: A problem-solving approach. Behav Ther. 1990;21(4):403-11. KQ4E9b, KQ5E9b, KQ6E9b.
158 Levy KN, Meehan KB, Yeomans, et al. Transference-focused psychotherapy reduces treatment drop-out and suicide attempters compared with community psychotherapist treatment in borderline personality disorder. Evid Based Ment Health. Nov. 2010;13(4):119. KQ4E8, KQ5E8, KQ6E8. [pmid: 21036981].
159 Liberman RP, Eckman T. Behavior therapy vs insight-oriented therapy for repeated suicide attempters. Arch Gen Psychiatry. Oct. 1981;38(10):1126-30. KQ4E2, KQ5E2, KQ6E2. [pmid: 7027988].
160 Linehan MM, Armstrong HE, Suarez A, et al. Cognitive-behavioral treatment of chronically parasuicidal borderline patients. Arch Gen Psychiatry. Dec. 1991;48(12):1060-4. KQ6E5. [pmid: 1845222].
161 Linehan MM, Comtois KA, Brown MZ, et al. Suicide Attempt Self-Injury Interview (SASII): development, reliability, and validity of a scale to assess suicide attempts and intentional self-injury. Psychol Assess. Sep. 2006;18(3):303-12. KQ1E1a, KQ2E4, KQ3E8. [pmid: 16953733].
162 Linehan MM, Comtois KA, Murray AM, et al. Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Arch Gen Psychiatry. 2006;63(7):757-66. KQ6E5. [pmid: 16818865].
163 Links P. Ongoing contact for 2 years after discharge was associated with greater survival in patients at risk of post crisis suicide. Evid Based Ment Health. Feb. 2002;5(1):19. KQ4E8, KQ5E8, KQ6E8. [pmid: 11915822].
164 Links P, Bergmans Y, Cook M. Psychotherapeutic interventions to preventing repeated suicidal behavior. Brief Treat Crisis Interv. 2003;3:445-64. KQ4E8, KQ5E8, KQ6E8.
165 Lung FW, Lee MB. The five-item Brief-Symptom Rating Scale as a suicide ideation screening instrument for psychiatric inpatients and community residents. BMC Psychiatry. 2008;8:53. KQ1E1a, KQ2E8, KQ3E8. [pmid: 18597675].
166 Marasinghe RB, Edirippulige S, Kavanagh D, et al. Effect of mobile phone-based psychotherapy in suicide prevention: a randomized controlled trial in Sri Lanka. J Telemed Telecare. 2012. Feb. 23. KQ4E5, KQ6E5. [pmid: 22362830].
167 McLeavey BC, Daly RJ, Ludgate JW, et al. Interpersonal problem-solving skills training in the treatment of self-poisoning patients. Suicide Life Threat Behav. 1994;24(4):382-94. KQ4E5, KQ5E5, KQ6E5. [pmid: 7740595].
168 McMain S. Dialectic behaviour therapy reduces suicide attempts compared with non-behavioural psychotherapy in women with borderline personality disorder. Evid Based Ment Health. Feb. 2007;10(1):18. KQ4E8, KQ5E8, KQ6E8. [pmid: 17255387].
169 McNeill YL, Gillies ML, Wood SF. Fifteen year olds at risk of parasuicide or suicide: how can we identify them in general practice?. Fam Pract. Oct. 2002;19(5):461-5. KQ1E1a, KQ2E1a, KQ3E1a. [pmid: 12356694].
170 Mishara BL, Houle J, Lavoie B. Comparison of the effects of four suicide prevention programs for family and friends of high-risk suicidal men who do not seek help themselves. Suicide Life Threat Behav. Jun. 2005;35(3):329-42. KQ4E3, KQ5E3, KQ6E3. [pmid: 16156493].
171 Mitchell P. Primary prevention and early intervention. Evaluation of the National Youth Suicide Strategy. Melbourne. Australian Institute of Family Studies. 2000. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, KQ6E8.
172 Modai I, Ritsner M, Kurs R, et al. Validation of the Computerized Suicide Risk Scale--a backpropagation neural network instrument (CSRS-BP). Eur Psychiatry. Apr. 2002;17(2):75-81. KQ2E6a, KQ3E6a. [pmid: 11973115].
173 Modai I, Kuperman J, Goldberg I, et al. Fuzzy logic detection of medically serious suicide attempt records in major psychiatric disorders. J Nerv Ment Dis. Oct. 2004;192(10):708-10. KQ2E8, KQ3E8. [pmid: 15457116].
174 Moller HJ. Efficacy of different strategies of aftercare for patients who have attempted suicide. J R Soc Med. Nov. 1989;82(11):643-7. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 2556579].
175 Moller HJ. Attempted suicide: efficacy of different aftercare strategies. Int Clin Psychopharmacol. Jun. Suppl 6. 1992;6:58-69. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 1331231].
176 Montgomery DB, Roberts A, Green M, et al. Lack of efficacy of fluoxetine in recurrent brief depression and suicidal attempts. Eur Arch Psychiatry Clin Neurosci. 1994;244(4):211-5. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 7888419].
177 Montgomery SA, Montgomery D. Pharmacological prevention of suicidal behaviour. J Affect Disord. Dec. 1982;4(4):291-8. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 6131083].
178 Montgomery SA, Roy D, Montgomery DB. The prevention of recurrent suicidal acts. Br J Clin Pharmacol. 1983;15(Suppl 2):183S-8S. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 6824553].
179 Morey LC, Lowmaster SE, Hopwood CJ. A pilot study of manual-assisted cognitive therapy with a therapeutic assessment augmentation for borderline personality disorder. Psychiatry Res. Aug. 15. 2010;178(3):531-5. KQ4E5, KQ5E3, KQ6E3. [pmid: 20537722].
180 Morgan HG, Jones EM, Owen JH. Secondary prevention of non-fatal deliberate self-harm. The green card study. Br J Psychiatry. Jul. 1993;163:111-2. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 8353677].
181 Motto JA, Bostrom AG. A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv. Jun. 2001;52(6):828-33. KQ5E5, KQ6E5. [pmid: 11376235].
182 Mulder RT, Joyce PR, Frampton CM, et al. Antidepressant treatment is associated with a reduction in suicidal ideation and suicide attempts. Acta Psychiatr Scand. Aug. 2008;118(2):116-22. KQ4E3, KQ5E3, KQ6E3. [pmid: 18384467].
183 Nelson C, Johnston M, Shrivastava A. Improving risk assessment with suicidal patients: a preliminary evaluation of the clinical utility of the Scale for Impact of Suicidality--Management, Assessment and Planning of Care (SIS-MAP). Crisis. Jan. 1. 2010;31(5):231-7. KQ1E1a, KQ2E11, KQ3E5. [pmid: 21134842].
184 Nimeus A, Hjalmarsson SF, Sunnqvist C, et al. Evaluation of a modified interview version and of a self-rating version of the Suicide Assessment Scale. Eur Psychiatry. Oct. 2006;21(7):471-7. KQ2E5, KQ3E8. [pmid: 16545548].
185 Nimeus A, Alsen M, Traskman-Bendz L. High suicidal intent scores indicate future suicide. Arch Suicide Res. 2002;6(3):211-9. KQ1E1a, KQ2E8, KQ3E8.
186 Nutting PA, Dickinson LM, Rubenstein LV, et al. Improving detection of suicidal ideation among depressed patients in primary care. Ann Fam Med. Nov. 2005;3(6):529-36. KQ1E1a, KQ2E8, KQ3E1a, KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 16338917].
187 Ono Y, Awata S, Iida H, et al. A community intervention trial of multimodal suicide prevention program in Japan: a novel multimodal community intervention program to prevent suicide and suicide attempt in Japan, NOCOMIT-J. BMC Public Health. 2008;8:315. KQ4E7b, KQ5E7b, KQ6E7b. [pmid: 18793423].
188 Oquendo MA, Galfalvy HC, Currier D, et al. Treatment of suicide attempters with bipolar disorder: a randomized clinical trial comparing lithium and valproate in the prevention of suicidal behavior. Am J Psychiatry. Oct. 2011;168(10):1050-6. KQ4E3, KQ5E3, KQ6E3. [pmid: 21768611].
189 Osman A, Gutierrez PM, Jiandani J, et al. A preliminary validation of the Positive and Negative Suicide Ideation (PANSI) inventory with normal adolescent samples. J Clin Psychol. Apr. 2003;59(4):493-512. KQ2E8, KQ3E8. [pmid: 12652640].
190 Ougrin D. Adding group psychotherapy to routine care does not improve outcomes in adolescents who repeatedly self-harm. Evid Based Ment Health. Aug. 2011;14(3):84. KQ6E5. [pmid: 21764883].
191 Ougrin D, Latif S. Specific psychological treatment versus treatment as usual in adolescents with self-harm: systematic review and meta-analysis. Crisis. 2011;32(2):74-80. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, KQ6E8. [pmid: 21616756].
192 Ougrin D, Zundel T, Ng A, et al. Trial of Therapeutic Assessment in London: randomised controlled trial of Therapeutic Assessment versus standard psychosocial assessment in adolescents presenting with self-harm. Arch Dis Child. Feb. 2011;96(2):148-53. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5, KQ6E5. [pmid: 21030367].
193 Oyama H, Koida J, Sakashita T, et al. Community-based prevention for suicide in elderly by depression screening and follow-up. Community Ment Health J. Jun. 2004;40(3):249-63. KQ1E7b, KQ2E5, KQ3E5, KQ4E5, KQ5E5, KQ6E5. [pmid: 15259630].
194 Oyama H, Ono Y, Watanabe N, et al. Local community intervention through depression screening and group activity for elderly suicide prevention. Psychiatry Clin Neurosci. Feb. 2006;60(1):110-4. KQ1E7b, KQ3E7b. [pmid: 16472368].
195 Oyama H, Fujita M, Goto M, et al. Outcomes of community-based screening for depression and suicide prevention among Japanese elders. Gerontologist. Dec. 2006;46(6):821-6. KQ1E7b, KQ3E7b. [pmid: 17169937].
196 Oyama H, Goto M, Fujita M, et al. Preventing elderly suicide through primary care by community-based screening for depression in rural Japan. Crisis. 2006;27(2):58-65. KQ1E7b, KQ2E8, KQ3E7b, KQ4E7b, KQ5E7b, KQ6E7b. [pmid: 16913326].
197 Oyama H, Sakashita T, Hojo K, et al. A community-based survey and screening for depression in the elderly: the short-term effect on suicide risk in Japan. Crisis. 2010;31(2):100-8. KQ1E7b, KQ2E8, KQ3E7b, KQ4E7b, KQ5E7b, KQ6E7b. [pmid: 20418216].
198 Patsiokas AT. Effects of psychotherapeutic strategies in the treatment of suicide attempters. J Psychother. 1985;22:281. KQ4E7c, KQ5E7c, KQ6E7c.
199 Payne CM. Assessing the utility of the Diagnostic Predictive Scales-8 within a school-based mental health screening design. Diss Abstr Int Section A: Humanities and Social Sciences. 2009;70(6-A). 1924. KQ1E1a, KQ2E9b, KQ3E8.
200 Pearson M, Konradsen F, Gunnell D, et al. A community-based cluster randomised trial of safe storage to reduce pesticide self-poisoning in rural Sri Lanka: study protocol. BMC Public Health. 2011;11:879. KQ4E13, KQ5E13, KQ6E13. [pmid: 22104027].
201 Perera-Ramani EA, Kathriarachchi ST. Problem-solving counseling as a therapeutic tool on youth suicidal behavior in the suburban population in Sri Lanka. Indian Journal of Psychiatry. 2011;53(1):30-5. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 21431005].
202 Pettit JW, Garza MJ, Grover KE, et al. Factor structure and psychometric properties of the Modified Scale for Suicidal Ideation among suicidal youth. Depress Anxiety. 2009;26(8):769-74. KQ1E1a, KQ2E5, KQ3E8. [pmid: 19434622].
203 Pfaff JJ, Almeida OP. Detecting suicidal ideation in older patients: identifying risk factors within the general practice setting. Br J Gen Pract. Apr. 2005;55(513):269-73. KQ1E1a, KQ2E1a, KQ3E1a. [pmid: 15826433].
204 Pompili M, Baldessarini RJ, Tondo L, et al. Response to intravenous antidepressant treatment by suicidal vs. nonsuicidal depressed patients. J Affect Disord. Apr. 2010;122(1–2):154-8. KQ4E8, KQ5E8, KQ6E8. [pmid: 19709752].
205 Posner K, Brown G, Stanley B, et al. The Columbia-Suicide Severity Rating Scale: initial validity and internal consistency findings from three multisite studies with adolescents and adults. Am J Psychiatry. 2011:1-12. KQ1E1b, KQ2E8, KQ3E5. [pmid: 21205810].
206 Price RB, Nock MK, Charney DS, et al. Effects of intravenous ketamine on explicit and implicit measures of suicidality in treatment-resistant depression. Biol Psychiatry. Sep. 1. 2009;66(5):522-6. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E8, KQ6E8. [pmid: 19545857].
207 Raj MAJ, Kumaraiah V, Bhide AV. Cognitive-behavioural intervention in deliberate self-harm. Acta Psychiatr Scand. Nov. 2001;104(5):340-5. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 11722314].
208 Raja M, Azzoni A, Koukopoulos AE. Psychopharmacological treatment before suicide attempt among patients admitted to a psychiatric intensive care unit. J Affect Disord. Feb. 2009;113(1–2):37-44. KQ4E8, KQ5E8, KQ6E8. [pmid: 18541308].
209 Randall JR, Rowe BH, Colman I. Emergency department assessment of self-harm risk using psychometric questionnaires. Can J Psychiatry. Jan. 2012;57(1):21-8. KQ2E8. [pmid: 22296964].
210 Randell BP, Eggert LL, Pike KC. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 2001;31(1):41-61. KQ6E5. [pmid: 11326768].
211 Range LM, Kovac SH. Can writing autobiographical essays lessen suicidal thinking?. Arch Suicide Res. 2002;6(4):373-82. KQ4E9b, KQ5E9b, KQ6E9b.
212 Rathus JH, Miller AL. Dialectical behavior therapy adapted for suicidal adolescents. Suicide Life Threat Behav. 2002;32(2):146-57. KQ4E8, KQ5E8, KQ6E8. [pmid: 12079031].
213 Raymond S, Mishara B, Routhier D, et al. New suicide prevention program for youth : evaluation results. Revue Quebecoise de Psychologie. 2003;24(1):255-71. KQ4E10, KQ5E10, KQ6E10.
214 Read SL. Postcards from the edge: homelessness poses extra challenge in reducing self harm. BMJ. Oct. 22. 2005;331(7522):966. KQ4E8, KQ5E8, KQ6E8. [pmid: 16239706].
215 Reeves H, Batra S, May RS, et al. Efficacy of risperidone augmentation to antidepressants in the management of suicidality in major depressive disorder: a randomized, double-blind, placebo-controlled pilot study. J Clin Psychiatry. Aug. 2008;69(8):1228-336. KQ4E9a, KQ5E9a, KQ6E9a. [pmid: 18681749].
216 Reynolds SK, Lindenboim N, Comtois KA, et al. Risky assessments: participant suicidality and distress associated with research assessments in a treatment study of suicidal behavior. Suicide Life Threat Behav. 2006;36(1):19-34. KQ1E8, KQ2E8, KQ3E8, KQ6E5. [pmid: 16676622].
217 Rhee WK, Merbaum M, Strube MJ, et al. Efficacy of brief telephone psychotherapy with callers to a suicide hotline. Suicide Life Threat Behav. Jun. 2005;35(3):317-28. KQ4E5, KQ5E5, KQ6E5. [pmid: 16156492].
218 Ribeiro JD, Braithwaite SR, Pfaff JJ, et al. Examining a brief suicide screening tool in older adults engaging in risky alcohol use. Suicide Life Threat Behav. 2012. May. 31. KQ2E5. [pmid: 22646731].
219 Rieu J, Bui E, Rouch V, et al. Efficacy of ultrabrief cognitive and behavioural therapy performed by psychiatric residents on depressed inpatients. Psychother Psychosom. 2011;80(6):374-6. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 21968526].
220 Rihmer Z, Belso N, Kalmar S. Antidepressants and suicide prevention in Hungary. Acta Psychiatr Scand. Mar. 2001;103(3):238-9. KQ4E8, KQ5E8, KQ6E8. [pmid: 11240584].
221 Roaldset JO, Bjorkly S. Patients’ own statements of their future risk for violent and self-harm behaviour: a prospective inpatient and post-discharge follow-up study in an acute psychiatric unit. Psychiatry Res. Jun. 30. 2010;178(1):153-9. KQ2E5, KQ4E8, KQ5E8, KQ6E8. [pmid: 20452048].
222 Robinson J, Hetrick S, Gook S, et al. Study protocol: the development of a randomised controlled trial testing a postcard intervention designed to reduce suicide risk among young help-seekers. BMC Psychiatry. 2009;9:59. KQ6E5. [pmid: 19775469].
223 Robinson J, Yuen HP, Gook S, et al. Can receipt of a regular postcard reduce suicide-related behaviour in young help seekers? A randomized controlled trial. Early Interv Psychiatry. May. 2012;6(2):145-52. KQ6E5. [pmid: 22260366].
224 Robles-Garcia R, Paez AF, Ascensio GM, et al. Evaluation of suicide risk in children: psychometric properties of the Spanish version of the Risk of Suicide Questionnaire (RSQ). Actas Esp Psiquiatri. Sep. 2005;33(5):292-7. KQ2E10, KQ3E10. [pmid: 16155811].
225 Rotheram-Borus MJ, Piacentini J, Cantwell C, et al. The 18-month impact of an emergency room intervention for adolescent female suicide attempters. J Consult Clin Psychol. Dec. 2000;68(6):1081-93. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 11142542].
226 Rudd MD, Rajab MH, Orman DT, et al. Effectiveness of an outpatient intervention targeting suicidal young adults: preliminary results. J Consult Clin Psychol. Feb. 1996;64(1):179-90. KQ4E5, KQ6E5. [pmid: 8907098].
227 Rudd MD, Mandrusiak M, Joiner TE Jr, et al. The emotional impact and ease of recall of warning signs for suicide: a controlled study. Suicide Life Threat Behav. Jun. 2006;36(3):288-95. KQ3E1a, KQ6E1a. [pmid: 16805656].
228 Salkovskis PM, Atha C, Storer D. Cognitive-behavioural problem solving in the treatment of patients who repeatedly attempt suicide. A controlled trial. Br J Psychiatry. Dec. 1990;157:871-6. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 2289097].
229 Samaraweera S, Sivayogan S, Sumathipala A, et al. RCT of cognitive behaviour therapy in active suicidal ideation - as feasibility study in Sri Lanka. Eur J Psychiatry. 2007;21(3):175-8. KQ4E5, KQ6E5.
230 Samuelsson M, Jokinen J, Nordstrom AL, et al. CSF 5-HIAA, suicide intent and hopelessness in the prediction of early suicide in male high-risk suicide attempters. Acta Psychiatr Scand. Jan. 2006;113(1):44-7. KQ2E8, KQ3E8. [pmid: 16390368].
231 Santa Mina EE, Gallop R, Links P, et al. The Self-Injury Questionnaire: evaluation of the psychometric properties in a clinical population. J Psychiatr Ment Health Nurs. Apr. 2006;13(2):221-7. KQ2E5, KQ3E8. [pmid: 16608478].
232 Schuppert HM, Giesen-Bloo J, van Gemert TG, et al. Effectiveness of an emotion regulation group training for adolescents--a randomized controlled pilot study. Clin Psychol Psychother. Nov. 2009;16(6):467-78. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 19630069].
233 Scott MA, Wilcox HC, Schonfeld IS, et al. School-based screening to identify at-risk students not already known to school professionals: the Columbia suicide screen. Am J Public Health. Feb. 2009;99(2):334-9. KQ2E9b, KQ3E8. [pmid: 19059865].
234 Shaffer D, Vieland V, Garland A, et al. Adolescent suicide attempters. Response to suicide-prevention programs. JAMA. Dec. 26. 1990;264(24):3151-5. KQ4E2, KQ5E2, KQ6E2. [pmid: 2255023].
235 Shaffer D, Scott M, Wilcox H, et al. The Columbia Suicide Screen: validity and reliability of a screen for youth suicide and depression. J Am Acad Child Adolesc Psychiatry. Jan. 2004;43(1):71-9. KQ2E9b, KQ3E8. [pmid: 14691362].
236 Slee N, Garnefski N, van der LR, et al. Cognitive-behavioural intervention for self-harm: randomised controlled trial. Br J Psychiatry. Mar. 2008;192(3):202-11. KQ6E5. [pmid: 18310581].
237 Slee N, Spinhoven P, Garnefski N, et al. Emotion regulation as mediator of treatment outcome in therapy for deliberate self-harm. Clin Psychol Psychother. Jul. 2008;15(4):205-16. KQ6E5. [pmid: 19115441].
238 Smyth CL, MacLachlan M. The context of suicide: an examination of life circumstances thought to be understandable precursors to youth suicide. J Ment Health. Feb. 2004;13(1):83-92. KQ2E5, KQ3E8.
239 Spirito A, Boergers J, Donaldson D, et al. An intervention trial to improve adherence to community treatment by adolescents after a suicide attempt. J Am Acad Child Adolesc Psychiatry. Apr. 2002;41(4):435-42. KQ4E5, KQ5E5, KQ6E5. [pmid: 11931600].
240 Spirito A. Group treatment plus usual care decreased the risk of deliberate self harm in adolescents who repeatedly harm themselves. Evid Based Ment Health. May. 2002;5(2):55. KQ4E8, KQ5E8, KQ6E8. [pmid: 12026904].
241 Steeg S, Kapur N, Webb R, et al. The development of a population-level clinical screening tool for self-harm repetition and suicide: the ReACT Self-Harm Rule. Psychol Med. Mar. 7. 2012:1-12. KQ2E8. [pmid: 22394511].
242 Stevens J, Klima J, Chisolm D, et al. A trial of telephone services to increase adolescent utilization of health care for psychosocial problems. J Adolesc Health. 2009;45(6):564-70. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 19931828].
243 Stewart CD, Quinn A, Plever S, et al. Comparing cognitive behavior therapy, problem solving therapy, and treatment as usual in a high risk population. Suicide Life Threat Behav. 2009;39(5):538-47. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 19929153].
244 Sturm J, Ploderl M, Fartacek C, et al. Physical exercise through mountain hiking in high-risk suicide patients. A randomized crossover trial. Acta Psychiatr Scand. 2012. Apr. 6. KQ4E7a, KQ5E7a, KQ6E7a. [pmid: 22486584].
245 Szanto K, Kalmar S, Hendin H, et al. A suicide prevention program in a region with a very high suicide rate. Arch Gen Psychiatry. 2007;64(8):914-20. KQ5E5, KQ6E5. [pmid: 17679636].
246 Tang TC, Jou SH, Ko CH, et al. Randomized study of school-based intensive interpersonal psychotherapy for depressed adolescents with suicidal risk and parasuicide behaviors. Psychiatry Clin Neurosci. Aug. 2009;63(4):463-70. KQ1E8, KQ2E8, KQ3E8, KQ4E5, KQ6E5. [pmid: 19531111].
247 Taylor LMW, Oldershaw A, Richards C, et al. Development and pilot evaluation of a manualized cognitive-behavioural treatment package for adolescent self-harm. [References]. Behav Cogn Psychother. 2011;39(5):619-25. KQ4E8, KQ5E8, KQ6E8. [pmid: 21392417].
248 Thombs BD, Ziegelstein RC. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT): response to Bogner et al. Diabetes Care. Jun. 2008;31(6):e54. KQ6E5. [pmid: 18509141].
249 Thompson D, Goebert D, Takeshita J. A program for reducing depressive symptoms and suicidal ideation in medical students. Acad Med. Oct. 2010;85(10):1635-9. KQ4E8, KQ5E8, KQ6E8. [pmid: 20881686].
250 Thompson EA, Eggert LL. Using the suicide risk screen to identify suicidal adolescents among potential high school dropouts. J Am Acad Child Adolesc Psychiatry. Dec. 1999;38(12):1506-14. KQ3E8. [pmid: 10596250].
251 Thompson EA, Eggert LL, Randell BP, et al. Evaluation of indicated suicide risk prevention approaches for potential high school dropouts. Am J Public Health. May. 2001;91(5):742-52. KQ6E5. [pmid: 11344882].
252 Torhorst A, Moller HJ, Burk F, et al. The psychiatric management of parasuicide patients: a controlled clinical study comparing different strategies of outpatient treatment. Crisis. Mar. 1987;8(1):53-61. KQ4E9b, KQ5E9b, KQ6E9b. [pmid: 3595176].
253 Torhorst A, Moller HJ, Schmid-Bode KW. Comparing a 3-month and a 12-month outpatient aftercare program for parasuicide repeaters. Moller HJ, Schmidtke A, Welz R, editors. Current Issues of Suicidology. Berlin, Germany. Springer-Verlag. 1988:19-24. KQ4E9b, KQ5E9b, KQ6E9b.
254 Trivedi MH, Wisniewski SR, Morris DW, et al. Concise Health Risk Tracking scale: a brief self-report and clinician rating of suicidal risk. J Clin Psychiatry. Jun. 2011;72(6):757-64. KQ2E5, KQ3E8. [pmid: 21733476].
255 Tsai WP, Lin LY, Chang HC, et al. The effects of the gatekeeper suicide-awareness program for nursing personnel. Perspect Psychiatr Care. Jul. 2011;47(3):117-25. KQ1E1b, KQ2E1b, KQ3E1b. [pmid: 21707626].
256 Tyrer P, Thompson S, Schmidt U, et al. Randomized controlled trial of brief cognitive behaviour therapy versus treatment as usual in recurrent deliberate self-harm: the POPMACT study. Psychol Med. Aug. 2003;33(6):969-76. KQ6E5. [pmid: 12946081].
257 Tyrer P, Jones V, Thompson S, et al. Service variation in baseline variables and prediction of risk in a randomised controlled trial of psychological treatment in repeated parasuicide: the POPMACT Study. Int J Soc Psychiatry. Mar. 2003;49(1):58-69. KQ6E5. [pmid: 12793516].
258 Tyrer P, Tom B, Byford S, et al. Differential effects of manual assisted cognitive behavior therapy in the treatment of recurrent deliberate self-harm and personality disturbance: the POPMACT study. J Pers Disord. Feb. 2004;18(1):102-16. KQ6E5. [pmid: 15061347].
259 Unutzer J, Tang L, Oishi S, et al. Reducing suicidal ideation in depressed older primary care patients. J Am Geriatr Soc. Oct. 2006;54(10):1550-6. KQ4E1a, KQ5E1a, KQ6E1a. [pmid: 17038073].
260 Vaiva G, Ducrocq F, Meyer P, et al. Effect of telephone contact on further suicide attempts in patients discharged from an emergency department: randomised controlled study. BMJ. May. 27. 2006;332(7552):1241-5. KQ5E5. [pmid: 16735333].
261 van Beek W, Kerkhof A, Beekman A. Future oriented group training for suicidal patients: a randomized clinical trial. BMC Psychiatry. 2009;9:65. KQ4E13, KQ5E13, KQ6E5. [pmid: 19811638].
262 Van Den Bosch LM, Koeter MW, Stijnen T, et al. Sustained efficacy of dialectical behaviour therapy for borderline personality disorder. Behav Res Ther. Sep. 2005;43(9):1231-41. KQ5E5, KQ6E5. [pmid: 16005708].
263 van der Sande R, van RL, Buskens E, et al. Intensive in-patient and community intervention versus routine care after attempted suicide. A randomised controlled intervention study. Br J Psychiatry. Jul. 1997;171:35-41. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 9328492].
264 Van Heeringen C, Jannes S, Buylaert W, et al. The management of non-compliance with referral to out-patient after-care among attempted suicide patients: a controlled intervention study. Psychol Med. Sep. 1995;25(5):963-70. KQ5E5, KQ6E5. [pmid: 8588015].
265 van Spijker BA, van Straten A, Kerkhof AJ. The effectiveness of a web-based self-help intervention to reduce suicidal thoughts: a randomized controlled trial. Trials. 2010;(11):25. KQ4E13, KQ5E13, KQ6E5. [pmid: 20214777].
266 Verheul R, Van Den Bosch LM, Koeter MW, et al. Dialectical behaviour therapy for women with borderline personality disorder: 12-month, randomised clinical trial in The Netherlands. Br J Psychiatry. Feb. 2003;182:135-40. KQ6E5. [pmid: 12562741].
267 Verkes RJ, van der Mast RC, Hengeveld MW, et al. Reduction by paroxetine of suicidal behavior in patients with repeated suicide attempts but not major depression. Am J Psychiatry. Apr. 1998;155(4):543-7. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 9546002].
268 Vijayakumar L, Umamaheswari C, Shujaath Ali ZS, et al. Intervention for suicide attempters: a randomized controlled study. Indian J Psychiatry. Jul. 2011;53(3):244-8. KQ4E7c, KQ5E7c, KQ6E7c. [pmid: 22135444].
269 Vitiello B, Brent DA, Greenhill LL, et al. Depressive symptoms and clinical status during the Treatment of Adolescent Suicide Attempters (TASA) Study. J Am Acad Child Adolesc Psychiatry. Oct. 2009;48(10):997-1004. KQ4E3, KQ5E3, KQ6E3. [pmid: 20854770].
270 Waern M, Sjostrom N, Marlow T, et al. Does the Suicide Assessment Scale predict risk of repetition? A prospective study of suicide attempters at a hospital emergency department. Eur Psychiatry. Nov. 2010;25(7):421-6. KQ1E8, KQ2E8, KQ3E8. [pmid: 20620027].
271 Walter G. Nessun Dorma (“None Shall Sleep”)... At least not before we digest Treatment of Adolescent Suicide Attempters (TASA). J Am Acad Child Adolesc Psychiatry. Oct. 2009;48(10):977-8. KQ4E3, KQ5E3, KQ6E3. [pmid: 20854766].
272 Wasserman D, Carli V, Wasserman C, et al. Saving and empowering young lives in Europe (SEYLE): a randomized controlled trial. BMC Public Health. 2010;10:192. KQ1E13, KQ2E5, KQ3E13, KQ4E13, KQ5E13, KQ6E13. [pmid: 20388196].
273 Waterhouse J, Platt S. General hospital admission in the management of parasuicide. A randomised controlled trial. Br J Psychiatry. Feb. 1990;156:236-42. KQ4E1b, KQ5E1b, KQ6E1b. [pmid: 2180527].
274 Weinberg I, Gunderson JG, Hennen J, et al. Manual assisted cognitive treatment for deliberate self-harm in borderline personality disorder patients. J Pers Disord. Oct. 2006;20(5):482-92. KQ4E1d, KQ5E1d, KQ6E1d. [pmid: 17032160].
275 Weisler RH, Khan A, Trivedi MH, et al. Analysis of suicidality in pooled data from 2 double-blind, placebo-controlled aripiprazole adjunctive therapy trials in major depressive disorder. J Clin Psychiatry. Apr. 2011;72(4):548-55. KQ4E7a, KQ5E7a, KQ6E7a. [pmid: 20816039].
276 Welu TC. A follow-up program for suicide attempters: evaluation of effectiveness. Suicide Life Threat Behav. 1977;7(1):17-20. KQ5E5, KQ6E5. [pmid: 206990].
277 Wilcox HC, Kellam SG, Brown CH, et al. The impact of two universal randomized first- and second-grade classroom interventions on young adult suicide ideation and attempts. Drug Alcohol Depend. Jun. 1. Suppl 1. 2008;95:S60-S73. KQ4E2, KQ5E2, KQ6E2. [pmid: 18329189].
278 Williams JM, Duggan DS, Crane C, et al. Mindfulness-based cognitive therapy for prevention of recurrence of suicidal behavior. J Clin Psychol. Feb. 2006;62(2):201-10. KQ4E8, KQ5E8, KQ6E8. [pmid: 16342287].
279 Williamson MK, Pirkis J, Pfaff JJ, et al. Recruiting and retaining GPs and patients in intervention studies: the DEPS-GP project as a case study. BMC Medical Research Methodology. 2007;7:42. KQ6E5. [pmid: 17875219].
280 Wills CE, Franklin M. The Manchester Self Harm Rule had good sensitivity but poor specificity for predicting repeat self harm or suicide. Evid Based Nurs. Apr. 2007;10(2):61. KQ1E8, KQ2E8, KQ3E8. [pmid: 17384113].
281 Wingate LR, Van Orden KA, Joiner TE Jr, et al. Comparison of compensation and capitalization models when treating suicidality in young adults. J Consult Clin Psychol. Aug. 2005;73(4):756-62. KQ4E2, KQ5E2, KQ6E2. [pmid: 16173865].
282 Winter D, Sireling L, Riley T, et al. A controlled trial of personal construct psychotherapy for deliberate self-harm. Psychol Psychother. Mar. 2007;80(Pt:1):1-37. KQ4E9a, KQ5E9a, KQ6E9a. [pmid: 17346377].
283 Wintersteen MB. Standardized screening for suicidal adolescents in primary care. Pediatrics. May. 2010;125(5):938-44. KQ1E8, KQ2E5, KQ3E8. [pmid: 20385627].
284 Wood A, Trainor G, Rothwell J, et al. Randomized trial of group therapy for repeated deliberate self-harm in adolescents. J Am Acad Child Adolesc Psychiatry. Nov. 2001;40(11):1246-53. KQ6E5. [pmid: 11699797].
285 Yaseen Z, Katz C, Johnson MS, et al. Construct development: The Suicide Trigger Scale (STS-2), a measure of a hypothesized suicide trigger state. BMC Psychiatry. 2010;10:110. KQ2E1b, KQ3E1b. [pmid: 21144063].
286 Yip PS, Cheung YB. Quick assessment of hopelessness: a cross-sectional study. Health Qual Life Outcomes. 2006;4:13. KQ2E8, KQ3E8. [pmid: 16509984].
287 Zisook S, Kasckow JW, Lanouette NM, et al. Augmentation with citalopram for suicidal ideation in middle-aged and older outpatients with schizophrenia and schizoaffective disorder who have subthreshold depressive symptoms: a randomized controlled trial. J Clin Psychiatry. Jul. 2010;71(7):915-22. KQ4E6a, KQ5E6a, KQ6E6a. [pmid: 20361918].
288 Zisook S, Lesser IM, Lebowitz B, et al. Effect of antidepressant medication treatment on suicidal ideation and behavior in a randomized trial: an exploratory report from the Combining Medications to Enhance Depression Outcomes Study. J Clin Psychiatry. Oct. 2011;72(10):1322-32. KQ4E3, KQ5E3, KQ6E3. [pmid: 22075098].