# Inclusion/Exclusion Criteria

Category | Included | Excluded
Included Conditions | Suicidal behavior, suicide deaths | Studies limited to episodes of self-harm where there is no intention of death
Population | All ages KQs 1–3 (screening): either; - Unselected primary care or comparable; - Primary care patients at elevated risk due to comorbid condition or history of deliberate self-harm; KQs 4–6 (treatment benefits and harms):; - People with a high risk of suicide; - People with a history of suicidal behavior; - People with selected mental health disorders (depression [unipolar and bipolar], substance use, PTSD, borderline personality disorder) | Studies limited to patients with a history of a chronic psychotic disorder, including schizophrenia Studies of physician-assisted suicide in terminally ill Studies targeting suicide while hospitalized, incarcerated, in an institutional setting, or on active military duty Studies limited to patients with mental health disorders, unless suicide is primary outcome and the mental health disorder is depression (unipolar or bipolar), substance abuse, PTSD, or borderline personality disorder Studies limited to people with medical disorders (e.g., chronic pain, traumatic brain injury) Studies limited to people in the midst of a suicidal crisis, identified through their use of health care services related to a suicide attempt (e.g., in the ED) KQ 6 (harms of treatment): trials that are not limited to people at elevated risk of suicide
Intervention | KQs 1–3 (screening): Brief^*^ standardized instrument designed to identify people at high risk of suicide; self-report, clinician-administered, or electronically delivered ^*^No more than 15 minutes if completed prior to clinician visit (e.g., in the waiting room), or no more than 5 minutes if used during a visit KQs 4–6 (treatment):; - Primary outcome is suicide prevention; - Behavioral, pharmacologic; must target suicidal behavior or ideation; - Include helplines, on-line interventions; - Include counseling or home visits for environmental change to reduce access to means of suicide; - Conducted in primary care, referable from primary care, or feasible^**^ for implementation in a health care setting; ^**^criteria for feasibility: Who Targeted: Individual-level identification of being a patient/in need of intervention Who Delivered: Usually involves primary care clinicians (family practice physicians, internal medicine, obstetrics-gynecology, pediatrics, general practitioner), other physicians, nurses, nurse practitioners, physician assistants, or related clinical staff (dietitians, health educators, mental health practitioners, or other counselors) in some direct or indirect way, or is seen as connected to the health care system by the participant How Delivered: To individuals or in small groups (15 or less). Generally involve no more than 8 group sessions total, and intervention time period is no longer than 12 months Where Delivered: Could be delivered anywhere (including via the Web, interactive technologies, in the home) Components: Must not include components that could not be replicated in most health care settings, including environmental components (media message, signage) or intervenes on groups in closed (pre-existing) social networks (e.g., worksites or churches), or use of authority figures (e.g. military commanders, workplace supervisors) | KQs 4–6 (intervention): Intervention involving components that could not be replicated in most health care settings, including environmental components (media message, signage) or intervenes on groups in closed (pre-existing) social networks (e.g., worksites or churches), or use of authority figures (e.g., military commanders, workplace supervisors) Primary target is not suicide prevention Intervention initiated in ED or inpatient setting
Comparator | KQs 1, 3 (benefits and harms of screening): Usual care, no screening KQs 4–6 (benefits and harms of treatment): Usual primary or specialty care, placebo medication along with behaviorally-based treatment, compared with active agent plus same behaviorally-based treatment | KQs 4–6: Comparing two active treatments or two different screening instruments, both offered in addition to usual care
Outcomes | KQs 1, 4–5 (benefits of screening and treatment): Primary (must report at least one):; - KQs 1, 4: suicide attempts, episodes of deliberate self-harm, suicide deaths; - KQ 5: suicidal ideation; Secondary (will be abstracted if available):; - KQs 1,4: improved level of functioning, improved quality of life or improved health status; - KQ 5: decreased depressive severity, decreased hopelessness, decreased access to means of suicide, increased identification and treatment of previously unrecognized mental health condition (depression, PTSD, substance abuse, borderline personality disorder); KQ 2 (screening instruments): sensitivity, specificity, positive predictive value, negative predictive value KQ 3 (harms of screening): paradoxical increase in suicidal ideation or behavior, negative effects of false-positives (such as overtreatment), others as reported in screening trials KQ 6: paradoxical increase in suicidal ideation or behavior, serious adverse effects, withdrawals due to adverse effects of medications, others as reported in treatment trials | KQs 4–6 (treatment): Trials only reporting rate of identification of those at high risk (e.g., trials of clinician training to identify people at high risk of suicide that report no patient outcomes) KQ 1 (benefits of screening): Rate of identification of those at high risk (e.g., trials of clinician training to identify people at high risk of suicide that report no patient outcomes)
Timing | No minimum followup
Setting | KQs 2–3 (screening):; - Health care (primary or specialty, including ED); - School or community setting (if population comparable to general primary care); KQs 1, 4–6 (treatment):; - Health care (primary or specialty, including ED); - Community; - School-based health clinics | KQs 2–3: Settings other than health care, schools, or community (e.g., worksite, church, residential, institutional, corrections, active duty military) KQs 1, 4–6 (treatment): curriculum-based interventions in schools, conducted through school counselors/nurses (interventions in school health clinics are acceptable)
Country | All countries
Study Design | KQs 1, 3–6 (benefits and harms of screening and treatment): RCT, CCT KQ 2 (screening instruments): study of diagnostic accuracy reporting sensitivity and specificity (or comparable statistics) compared with an independently-assessed gold standard, such as a structured interview. KQ 6 (harms of pharmacologic treatment):; - Comparative cohort studies; - Large registry or noncomparative observational studies for rare harms | All other designs
Language | English | NonEnglish

Abbreviations: CCT = controlled clinical trial; ED = emergency department; KQ = key question; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial.