# Literature Search Strategies

## Primary Research

Database: Ovid MEDLINE(R) without Revisions 1996 to July 17, 2012, Ovid MEDLINE(R) Daily Update July 17, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations July 17, 2012< July 17, 2012> [Clinical Trials]

1. suicide/ or suicidal ideation/ or suicide, attempted/
2. Self-Injurious Behavior/
3. suicid$.ti.
4. parasuicid$.ti.
5. self harm$.ti.
6. 1 or 2 or 3 or 4 or 5
7. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
8. (clinical trial or controlled clinical trial or randomized controlled trial).pt.
9. random$.ti,ab.
10. control groups/ or double-blind method/ or single-blind method/
11. clinical trial$.ti,ab.
12. controlled trial$.ti,ab.
13. 7 or 8 or 9 or 10 or 11 or 12
14. 6 and 13
15. limit 14 to yr= “2002 -Current”
16. limit 15 to english language

Database: Ovid MEDLINE(R) without Revisions 1996 to July 17, 2012, Ovid MEDLINE(R) Daily Update July 17, 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations July 17, 2012 [Screening Instruments]

1. suicide/ or suicidal ideation/ or suicide, attempted/
2. Self-Injurious Behavior/
3. suicid$.ti.
4. parasuicid$.ti.
5. self harm$.ti.
6. (Suicide Ideation adj3 questionnaire$).ti,ab.
7. (Suicide Ideation adj3 scale$).ti,ab.
8. (Suicide Ideation adj3 survey$).ti,ab.
9. (Suicide Ideation adj3 inventory).ti,ab.
10. (suicide intent adj3 questionnaire$).ti,ab.
11. (suicide intent adj3 scale$).ti,ab.
12. (suicide intent adj3 survey$).ti,ab.
13. (suicide intent adj3 inventory$).ti,ab.
14. (Hopelessness adj3 questionnaire$).ti,ab.
15. (Hopelessness adj3 scale$).ti,ab.
16. (Hopelessness adj3 survey$).ti,ab.
17. (Hopelessness adj3 inventory).ti,ab.
18. ((Harkavy$ or Asnis$) and suicid$).ti,ab.
19. suicide probability.ti,ab.
20. (suicidal ideation adj3 questionnaire$).ti,ab.
21. (suicidal ideation adj3 scale$).ti,ab.
22. (suicidal ideation adj3 survey$).ti,ab.
23. (suicidal ideation adj3 inventory).ti,ab.
24. suicide status form.ti,ab.
25. (suicide behavio$ adj3 questionnaire$).ti,ab.
26. (suicide behavio$ adj3 scale$).ti,ab.
27. (suicide behavio$ adj3 survey$).ti,ab.
28. (suicide behavio$ adj3 inventory).ti,ab.
29. (paykel$ and suicid$).ti,ab.
30. (self harm adj3 questionnaire$).ti,ab.
31. (self harm adj3 scale$).ti,ab.
32. (self harm adj3 survey$).ti,ab.
33. (self harm adj3 inventory).ti,ab.
34. (manchester and self harm).ti,ab.
35. suicide assessment.ti,ab.
36. (beck depression and suicid$).ti,ab.
37. (hamilton rating and suicid$).ti,ab.
38. (symptom driven diagnos$ and suicid$).ti,ab.
39. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38
40. "Sensitivity and Specificity"/
41. "Predictive Value of Tests"/
42. ROC Curve/
43. Receiver operat$.ti,ab.
44. ROC curve$.ti,ab.
45. sensitivit$.ti,ab.
46. specificit$.ti,ab.
47. predictive value.ti,ab.
48. accuracy.ti,ab.
49. False Negative Reactions/
50. False Positive Reactions/
51. Diagnostic Errors/
52. "Reproducibility of Results"/
53. Reference Values/
54. Reference Standards/
55. Observer Variation/
56. Psychometrics/
57. Psychometric$.ti,ab.
58. 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57
59. 39 and 58
60. limit 59 to english language
61. limit 60 to yr="2002-Current"

Database: PsycINFO 2002 to July Week 2 2012

1. Suicide/
2. Attempted Suicide/
3. Suicidal Ideation/
4. Suicide Prevention/
5. Self Injurious Behavior/
6. Self Destructive Behavior/
7. suicid$.ti.
8. parasuicid$.ti.
9. self harm$.ti.
10. or/1–9
11. treatment outcome clinical trial.md.
12. experiment controls/
13. controlled trial$.ti,ab,id,hw.
14. clinical trial$.ti,ab,id,hw.
15. random$.ti,ab,id,hw.
16. or/11–15
17. 10 and 16
18. Beck Depression.tm.
19. Suicid$.tm.
20. hopelessness.tm.
21. harkavy$.tm.
22. asnis$.tm.
23. paykel$.tm.
24. self harm.tm.
25. hamilton rating.tm.
26. symptom driven.tm.
27. or/18–26
28. 27 and suicid$.mp.
29. 10 or 28
30. Test Reliability/
31. Test Validity/
32. sensitivit$.ti,ab.
33. specificit$.ti,ab.
34. predictive value.ti,ab.
35. accuracy.ti,ab.
36. or/30–35
37. 29 and 36
38. 17 or 37
39. limit 38 to english language
40. limit 39 to yr="2002 -Current"

Database: CINAHL: Clinical trials or screening instruments

S16 s3 or s13 Limiters - Published Date from: 20020101-20120717; Language: English
S15 s3 or s13 Limiters - Language: English
S14 s3 or s13
S13 s9 and s12
S12 s10 OR s11
S11 (TI sensitiv*) OR (AB sensitiv*) OR (TI specificit*) OR (AB specificit*) OR (TI accuracy) OR (AB accuracy) OR (TI psychometric*) OR (AB psychometric*)
S10 ( (MH "Sensitivity and Specificity") ) OR (MH "Predictive Validity") OR (MH "ROC Curve") OR (MH "False Negative Results") OR (MH "False Positive Results") OR (MH "Diagnostic Errors") OR (MH "Reproducibility of Results") OR (MH "Reference Values") OR (MH Psychometrics)
S9 S5 OR S8
S8 S6 AND S7
S7 (TX suicid*)
S6 (TX harkavy*) OR (TX asnis*) OR (TX suicide n1 probability) OR (TX suicide n1 status) OR (TX paykel*) OR (TX suicide n1 assessment) OR (TX beck n1 depression) OR (TX hamilton n1 rating) OR (TX symptom n1 driven)
S5 s1 AND s4
S4 (TX questionnaire*) OR (TX scale*) OR (TX survey*) OR (TX inventory*)
S3 s1 AND s2
S2 (MH "Randomized Controlled Trials") OR (MH "Clinical Trials") OR (MH "Random Assignment") OR (MH "Single-Blind Studies") OR (MH "Double-Blind Studies") OR (MH "Triple-Blind Studies") OR TX clinical n1 trial* OR TX controlled n1 trial* OR PT Clinical trial OR PT randomized controlled trial
S1 (MH suicide) OR (MH "Suicidal ideation") OR (MH "Suicide, Attempted") OR (MH "Injuries, Self-Inflicted") OR (TI suicid*) OR (TI parasuicid*) OR (TI self n1 harm)

Database: CCRCT, July 2012

(suicid*) or (parasuicid*) or (self next harm), from 2002 to 2012 in Clinical Trials

## Systematic Reviews

Database: CDSR <Issue 4 of 12, Apr 2011>

(suicide*):ti,ab,kw or (suicidal*):ti,ab,kw or (self next harm):ti,ab,kw, from 2004 to 2011

Database: DARE

(((suicide*):TI OR (suicidal*):TI OR ("self harm"):TI OR ("self-harm"):TI) and (Systematic review:ZDT and Abstract:ZPS) FROM 2004 TO 2011)

Database: PubMed

1 "Suicide"[Majr:NoExp] OR "Suicide, Attempted"[Majr] OR "Suicidal Ideation"[Majr]
2 #1 AND systematic[sb] Limits: English, Publication Date from 2004 to 3000
3 suicid*[ti]
4 #3 AND systematic[sb] AND (in process[sb] OR publisher[sb] OR pubmednotmedline[sb]) Limits: English, Publication Date from 2004 to 3000
5 #2 OR #4

Database: PsycINFO <2002 to April Week 2 2011>

Search Strategy:

1. *Attempted Suicide/ or *Suicide Prevention/ or *Suicide/
2. *suicidal ideation/
3. 1 or 2
4. limit 3 to ("0830 systematic review" or 1200 meta analysis)
5. Meta Analysis/
6. meta analysis.id.
7. (systematic: adj3 (review: or overview)).ti,ab.
8. 5 or 6 or 7
9. 3 and 8
10. 4 or 9
11. limit 10 to (english language and yr="2004 -Current")