# Suicide Risk Screening Instruments

Appendix A Table 1 Suicide Risk Screening Instruments250

Appendix A Table 2 Selected Depression and Hopelessness Screening Instruments