# REFERENCES

1 Scattoloni J. Screening for Oral Cancer: A Brief Evidence Update for the U.S. Preventive Services Task Force. AHRQ Pub No. 05-0564-B. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
2 U.S. Preventive Services Task Force. Screening for Oral Cancer: Recommendation Statement. AHRQ Pub No. 05-0564-A. Rockville, MD. Agency for Healthcare Research and Quality. 2004.
3 World Health Organization. International Classification of Diseases for Oncology. 3rd ed. Geneva. World Health Organization. 2000.
4 van der Waal R, van der Waal I. Oral non-squamous malignant tumors; diagnosis and treatment. Med Oral Patol Oral Cir Bucal. 2007;12(7):e486-91. [pmid: 17978771].
5 Brocklehurst P, Kujan O, Glenny AM, Oliver R, Sloan P, Ogden G, et al. Screening programmes for the early detection and prevention of oral cancer. Cochrane Database Syst Rev. 2010;(11):CD004150. [pmid: 21069680].
6 Warnakulasuriya S, Johnson NW, van der Waal I. Nomenclature and classification of potentially malignant disorders of the oral mucosa. J Oral Pathol Med. 2007;36(10):575-80. [pmid: 17944749].
7 Kademani D. Oral cancer. Mayo Clin Proc. 2007;82(7):882-87.
8 Petti S. Pooled estimate of world leukoplakia prevalence: a systematic review. Oral Oncol. 2003;39(8):770-80. [pmid: 13679200].
9 Napier SS, Speight PM. Natural history of potentially malignant oral lesions and conditions: an overview of the literature. J Oral Pathol Med. 2008;37(1):1-10. [pmid: 18154571].
10 Scully C, Bagan J. Oral squamous cell carcinoma overview. Oral Oncol. 2009;45(4-5):301-08. [pmid: 19249237].
11 American Cancer Society. Cancer Facts & Figures 2011. Atlanta. American Cancer Society. 2011. Accessed at http://www.cancer.org/research/cancerfactsfigures/cancerfactsfigures/cancer-facts-figures-2011 on 29 March 2013.
12 Lingen MW, Kalmar JR, Karrison T, Speight PM. Critical evaluation of diagnostic aids for the detection of oral cancer. Oral Oncol. 2008;44(1):10-22. [pmid: 17825602].
13 National Cancer Institute. SEER*StatDatabase: Incidence - SEER 17 Regs Research Data + Hurricane Katrina Impacted Louisiana Cases, Nov 2010 Sub (2000–2008). Bethesda, MD. National Cancer Institute. 2011.
14 National Cancer Institute. SEER*StatDatabase: Mortality - All COD, Aggregated With State, Total U.S. (1969–2008). Bethesda, MD. National Cancer Institute. 2011.
15 Warnakulasuriya S. Global epidemiology of oral and oropharyngeal cancer. Oral Oncol. 2009;45(4-5):309-16. [pmid: 18804401].
16 Petti S. Lifestyle risk factors for oral cancer. Oral Oncol. 2009;45(4-5):340-50. [pmid: 18674956].
17 Hashibe M, Brennan P, Benhamou S, Castellsague X, Chen C, Curado MP, et al. Alcohol drinking in never users of tobacco, cigarette smoking in never drinkers, and the risk of head and neck cancer: pooled analysis in the International Head and Neck Cancer Epidemiology Consortium. J Natl Cancer Inst. 2007;99(10):777-89. [pmid: 17505073].
18 Patton LL. The effectiveness of community-based visual screening and utility of adjunctive diagnostic aids in the early detection of oral cancer. Oral Oncol. 2003;39(7):708-23. [pmid: 12907211].
19 Patton LL, Epstein JB, Kerr AR. Adjunctive techniques for oral cancer examination and lesion diagnosis: a systematic review of the literature. J Am Dent Assoc. 2008;139(7):896-905. [pmid: 18594075].
20 Schlecht HP. Oral human papillomavirus infection: hazard of intimacy. JAMA. 2012;307(7):724-5. [pmid: 22282320].
21 Brown LM, Check DP, Devesa SS. Oropharyngeal cancer incidence trends: diminishing racial disparities. Cancer Causes Control. 2011;22(5):753-63. [pmid: 21380619].
22 Syrjänen S, Lodi G, von Bültzingslöwen I, Aliko A, Arduino P, Campisi G, et al. Human papillomaviruses in oral carcinoma and oral potentially malignant disorders: a systematic review. Oral Dis. 2011;17(Suppl 1):58-72. [pmid: 21382139].
23 Kreimer AR, Clifford GM, Boyle P, Franceschi S. Human papillomavirus types in head and neck squamous cell carcinomas worldwide: a systematic review. Cancer Epidemiol Biomarkers Prev. 2005;14(2):467-75. [pmid: 15734974].
24 Shillitoe EJ. The role of viruses in squamous cell carcinoma of the oropharyngeal mucosa. Oral Oncol. 2009;45(4-5):351-5. [pmid: 18952492].
25 ClinicalTrials.gov. Epstein-Barr Detection in Squamous Cell Carcinoma and Healthy Oral Mucosa. NCT01039272. Bethesda, MD. National Institutes of Health. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT01039272 on 29 March 2013.
26 Gillison ML, Broutian T, Pickard RK, Tong ZY, Xiao W, Kahle L, et al. Prevalence of oral HPV infection in the United States, 2009–2010. JAMA. 2012;307(7):693-703. [pmid: 22282321].
27 National Institute of Dental and Craniofacial Research. Detecting Oral Cancer: A Guide for Health Care Professionals. Bethesda, MD. National Institutes of Health. 2011. Accessed at http://www.nidcr.nih.gov/OralHealth/Topics/OralCancer/DetectingOralCancer.htm on 29 March 2013.
28 Patton LL, Epstein JB, Kerr AR. Adjunctive techniques for oral cancer examination and lesion diagnosis: a systematic review of the literature. J Am Dent Assoc. 2008;139(7):896-905. [pmid: 18594075].
29 Rethman MP, Carpenter W, Cohen EE, Epstein J, Evans CA, Flaitz CM, et al. Evidence-based clinical recommendations regarding screening for oral squamous cell carcinomas. J Am Dent Assoc. 2010;141(5):509-20. [pmid: 20436098].
30 Centers for Disease Control and Prevention. QuickStats: percentage of adults aged ≥18 years who have ever had an oral cancer examination, by smoking status and age group—National Health Interview Survey, United States, 2008. MMWR Morb Mortal Wkly Rep. 2009;58(36):1013.
31 U.S. Department of Health and Human Services. Healthy People 2020 Topics and Objectives: Oral Health. Washington, DC. U.S. Department of Health and Human Services. 2011. Accessed at http://www.healthypeople.gov/2020/topicsobjectives2020/overview.aspx?topicid=32 on 29 March 2013.
32 Sankaranarayanan R, Mathew B, Jacob BJ, Thomas G, Somanathan T, Pisani P, et al. Early findings from a community-based, cluster-randomized, controlled oral cancer screening trial in Kerala, India. Cancer. 2000;88(3):664-73. [pmid: 10649262].
33 Ramadas K, Sankaranarayanan R, Jacob BJ, Thomas G, Somanathan T, Mahé C, et al. Interim results from a cluster randomized controlled oral cancer screening trial in Kerala, India. Oral Oncol. 2003;39(6):580-8. [pmid: 12798401].
34 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm on 29 March 29, 2013.
35 National Institute for Health and Clinical Excellence. The Guidelines Manual 2009. London. National Institute for Health and Clinical Excellence. 2012. Accessed at http://www.nice.org.uk/media/615/64/The_guidelines_manual_on 29 March 2013.
36 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-8. [pmid: 1834807].
37 Sankaranarayanan R, Ramadas K, Thomas G, Muwonge R, Thara S, Mathew B, et al. Effect of screening on oral cancer mortality in Kerala, India: a cluster-randomised controlled trial. Lancet. 2005;365(9475):1927-33. [pmid: 15936419].
38 Downer MC, Evans AW, Hughes Hallet CM, Jullien JA, Speight PM, Zakrzewska JM. Evaluation of screening for oral cancer and precancer in a company headquarters. Community Dent Oral Epidemiol. 1995;23(2):84-8. [pmid: 7781305].
39 Jullien JA, Downer MC, Zakrzewska JM, Speight PM. Evaluation of a screening test for the early detection of oral cancer and precancer. Community Dent Health. 1995;12(1):3-7. [pmid: 7697560].
40 Mathew B, Sankaranarayanan R, Sunilkumar KB, Kuruvila B, Pisani P, Nair MK. Reproducibility and validity of oral visual inspection by trained health workers in the detection of oral precancer and cancer. Br J Cancer. 1997;76(3):390-4. [pmid: 9252209].
41 Mehta FS, Gupta PC, Bhonsle RB, Murti PR, Daftary DK, Pindborg JJ. Detection of oral cancer using basic health workers in an area of high oral cancer incidence in India. Cancer Detect Prev. 1986;9(3-4):219-25. [pmid: 3742502].
42 Downer MC, Moles DR, Palmer S, Speight PM. A systematic review of test performance in screening for oral cancer and precancer. Oral Oncol. 2004;40(3):264-73. [pmid: 14747057].
43 Kujan O, Glenny AM, Oliver RJ, Thakker N, Sloan P. Screening programmes for the early detection and prevention of oral cancer. Cochrane Database Syst Rev. 2006;(3):CD004150. [pmid: 16856035].
44 Elango KJ, Anandkrishnan N, Suresh A, Iyer SK, Ramaiyer SK, Kuriakose MA. Mouth self-examination to improve oral cancer awareness and early detection in a high-risk population. Oral Oncol. 2011;47(7):620-4. [pmid: 21646040].
45 Scott SE, Rizvi K, Grunfeld EA, McGurk M. Pilot study to estimate the accuracy of mouth self-examination in an at-risk group. Head Neck. 2010;32(10):1393-401. [pmid: 20146330].
46 Su WW, Yen AM, Chiu SY, Chen TH. A community-based RCT for oral cancer screening with toluidine blue. J Dent Res. 2010;89(9):933-7. [pmid: 20525960].
47 Lagakos SW. The challenge of subgroup analyses—reporting without distorting. N Engl J Med. 2006;355(2):113-7. [pmid: 16801354].
48 Wang R, Lagakos SW, Ware JH, Hunter DJ, Drazen JM. Statistics in medicine—reporting of subgroup analyses in clinical trials. N Engl J Med. 2007;357(21):2189-94. [pmid: 18032770].
49 Warnakulasuriya KA, Nanayakkara BG. Reproducibility of an oral cancer and precancer detection program using a primary health care model in Sri Lanka. Cancer Detect Prev. 1991;15(5):331-4. [pmid: 1751941].
50 Warnakulasuriya S, Pindborg JJ. Reliability of oral precancer screening by primary health care workers in Sri Lanka. Community Dent Health. 1990;7(1):73-9. [pmid: 2357611].
51 Subramanian S, Sankaranarayanan R, Bapat B, Somanathan T, Thomas G, Mathew B, et al. Cost-effectiveness of oral cancer screening: results from a cluster randomized controlled trial in India. Bull World Health Organ. 2009;87(3):200-6. [pmid: 19377716].
52 Speight PM, Palmer S, Moles DR, Downer MC, Smith DH, Henriksson M, et al. The cost-effectiveness of screening for oral cancer in primary care. Health Technol Assess. 2006;10(4):1-144. [pmid: 16707071].
53 Dedhia RC, Smith KJ, Johnson JT, Roberts M. The cost-effectiveness of community-based screening for oral cancer in high-risk males in the United States: a Markov decision analysis approach. Laryngoscope. 2011;121(5):952-60. [pmid: 21384383].
54 Koepsell TD, Weiss NS. Screening. Epidemiologic Methods: Studying the Occurrence of Illness. New York. Oxford University Press. 2003:442-63.
55 Lang TA, Secic M. How to Report Statistics in Medicine: Annotated Guildelines for Authors, Editors, and Reviewers. Philadelphia. American College of Physicians. 2006.
56 HealthPartners Dental Group and Clinics. Oral Cancer Guideline. Minneapolis, MN. HealthPartners. 2007.