# DISCUSSION

Subjects in a high-prevalence population who were screened for oral cancer had no significant difference in incidence or mortality rates from oral cancer compared with subjects who were not screened. Screened patients, however, had oral cancer diagnosed at lower stages, with greater 5-year survival. This may simply reflect lead- or length-time bias. Within the subset of participants who were at high risk for oral cancer because of using tobacco or alcohol, screened subjects had a lower mortality rate from oral cancer. This evidence is suggestive, since it came from a subgroup analysis in a single study that was not based on rigorous subgroup methods.47,48 We found no evidence on screening for oral cancer in the general or a selected high-risk U.S. population. The most applicable evidence came from studies in the United Kingdom of dental practices (two studies38,39) and self-examination (one study45).

Study designs and test performance characteristics for the oral screening examination varied widely, making it difficult to synthesize evidence and draw conclusions about the evidence as a whole. All studies were hampered by an imperfect reference standard of repeated screening by a presumed more expert examiner and by combining the detection of potentially malignant lesions with cancers. Thus, for screening approaches that appear promising and potentially applicable to the U.S. health care setting, longitudinal followup for impact on cancers would be necessary.

Although potentially confounded by population risk or other factors, it appeared that advanced health workers or dentists conducted the most accurate examinations. Among older adults (age 40 years or older) at somewhat increased risk due to alcohol and tobacco use, dental examinations were 71 to 77 percent sensitive, with positive predictive values of 67 to 86 percent and high specificity (98% to 99%). However, few lesions were detected and clear determination of high-risk status was not reported. In contrast to expert or trained screening examinations, self-examinations in India and London were not sensitive. Adding toluidine blue to the screening examination did not significantly improve the identification of premalignant or malignant lesions, nor impact the incidence of oral cancer, and we found no acceptable evidence for other adjunctive devices.

## Other Systematic Reviews

We identified two systematic reviews that addressed KQ 1.^5,29^ The only evidence these reviews included was from the same Trivandrum trial described above. These reviews did not identify any additional studies meeting our inclusion criteria. Both reviews concluded that there was insufficient evidence for or against using visual inspection and palpation to screen for oral cancer in the general population. These reviews, however, suggested that the screening examination might decrease mortality from oral cancer among people who use tobacco or alcohol.

Four systematic reviews addressed KQ 2.^5,28,29,42^ These systematic reviews did not identify any additional studies meeting our inclusion criteria. No systematic review found evidence to support using any adjunctive method for screening.5,28,29,42 One of the systematic reviews assessed the test characteristics of the oral screening examination by conducting a meta-analysis of eight primary studies.42 The weighted pooled value for sensitivity was 0.848 (95% CI, 0.730 to 0.919) and specificity was 0.965 (95% CI, 0.930 to 0.982). That review included primary studies that did not meet our inclusion criteria, including two large studies with artificially high sensitivity and low specificity.49,50 These studies skewed the pooled results in the meta-analysis, making the test performance characteristics much different than those found in most of the primary studies in our review.

## Cost-Effectiveness

Three cost-effectiveness studies found that screening high-risk individuals (variously defined, but including several of these: age older than 40 years, male sex, regular use of tobacco and alcohol) for oral cancer may be cost-effective. One study analyzed the cost-effectiveness of screening based on the experience in the Trivandrum trial (India).51 In that setting, the incremental cost was U.S. $835 per year of life saved when screening everyone and U.S. $156 per year of life saved when screening only individuals at high risk due to using tobacco or alcohol. A second health technology assessment simulated various screening approaches in primary medical or dental care in the United Kingdom using a decision-analysis model; only opportunistic screening of high-risk individuals by general dentists (and perhaps medical doctors) was potentially cost-effective, but only if treatment was presumed to prevent precancerous disease progression and malignant transformation.52 Little evidence was located to support this assumption. A third Markov decision-analysis model set in the United States suggested that annual screening of men older than age 40 years who smoked or drank alcohol using trained community health workers and a community outreach program might prove cost-effective compared with no screening; however, these results were primarily intended to inform future research for screening program development.53

## Limitations

Screening for a PMD or oral cancer is based on the premise that treating the lesion will prevent its progression to oral cancer or to higher stages of oral cancer, thus decreasing morbidity and mortality.54 This requires that subjects who screen positive present for followup to receive definitive diagnosis and treatment. In the RCT,37 followup was 63 percent; in studies of test performance, followup ranged from 21^44^ to 86 percent.46 Low percentages of patients presenting for followup would diminish the effect of screening on clinical outcomes. The treatment interventions available for subjects with true-positive lesions identified in the RCT were not described.37

The screening methods tested in several of these studies may not be generalizable to the U.S. population, where the health care model does not incorporate home visits or health workers. Also, all evidence comes from Taiwan, India, and the United Kingdom, and two of these countries have markedly different oral cancer incidence and mortality rates from the United States (Table 2).

Table 2 National Incidence and Mortality Rates of Lip and Oral Cavity Cancer Only, IARC 2008^19^

Country | Study site | Incidence rate^*^ | Mortality rate^*^
Taiwan | Keelung County | 16.1 | 6.0
India | Trivandrum District | 7.5 | 5.2
United States | --- | 5.0 | 0.7
United Kingdom | London | 3.6 | 1.0

* Age-adjusted rates per 100,000 persons. Unlike SEER data, the International Agency for Research on Cancer (IARC) reports data for the lip and oral cavity without including the pharynx.

Test performance suggested by screening studies conducted in countries other than the United Kingdom will likely misrepresent test performance in the United States, a country with a lower prevalence of disease.54 The prevalence of leukoplakia is 1.9 percent in the United States, for example, but 26.9 percent in Taiwan.8 Also, although a high-risk subgroup of alcohol and tobacco users showed a mortality benefit in the Indian RCT, these results were based on post-hoc subgroup analysis and could also reflect numerous other differences in behavioral risk factors between the United States and Asia.

Results among selected higher-risk groups in populations similar to the United States may not apply when high-risk groups are not similarly characterized as to risk factors. Dental examination studies in the United Kingdom did not clearly specify high-risk status with regard to smoking and alcohol use. Thus, while some results may apply to members of the U.S. population who use tobacco or alcohol, this possibility would need to be confirmed using clear, reproducible definitions of high risk and screening approaches compatible with the U.S. health care system.

None of the studies in our review reported on harms from the screening test itself or from false-positive or false-negative test results. Screening using visual inspection and palpation should be low risk. However, any time devoted to it would reduce opportunity for other interventions that might have greater impact on health outcomes. Positive predictive values for the oral screening examination ranged from 17^45^ to 87 percent,38,40 with better results confined to more expert examiners. The wide range of results indicates the potential for many false-positive screening results. These might incur unnecessary patient anxiety, time and cost of followup visits, and biopsy-related harms. Except for mouth self-examination, which was generally unsupported by available evidence, negative predictive values were 98 to 99.3 percent, indicating few false-negative screening examinations.

The designs of the primary studies related to KQ 2 had considerable heterogeneity, as they were conducted using different screening examinations by people with different levels of training, in different clinical settings, in different countries, and using study populations with various ages and risk factors. All studies of test performance used examinations conducted by a clinician more highly trained than the screener as the reference standard. The outcomes of the primary studies also showed considerable heterogeneity, with wide variation in test performance characteristics. In addition to the range of positive predictive values described above, sensitivity ranged from 18^44^ to 94.3 percent.40 Sensitivity is important, as it reflects the screening test's ability to identify most people who have the disease.54,55

## Current U.S. Recommendations

The American Dental Association does not recommend screening for oral cancer, but does suggest that clinicians remain alert for signs of potentially malignant lesions or early-stage cancers in all patients while performing routine visual and tactile examinations.29 However, that suggestion has the lowest rating for strength of recommendation. The HealthPartners Dental Group and Clinics states “visual examination of the oral soft tissues, extraoral head and neck tissues and palpation of head and neck lymph nodes is considered the standard of care as part of a complete dental examination,” but does not describe the strength of the recommendation.56

## Future Research Needs

Screenings conducted by advanced health workers in the Trivandrum District achieved good sensitivity and positive predictive value. Similar advanced health workers in the U.S. health care model might be dental hygienists. Screening by general dentists in the United Kingdom was moderately sensitive as well for detecting PMDs and oral cancers. Longitudinal followup of applicable screening studies would clarify the screening impact on cancers. Targeted screening in those subjects who are at high risk for oral cancer due to patterns of tobacco or alcohol use could maximize screening's efficiency as well as effect on mortality from oral cancer. A clear definition of high-risk patients, with examination of the accuracy and impact of screening among such high-risk patients by dental hygienists, dentists, or other trained experts in U.S. settings would clarify if there is any role for screening in any high-risk group in the United States. If HPV becomes a more prominent risk factor for oral cancer, the benefits of screening and selection of high-risk populations could change.

## Conclusion

Evidence for the effect of oral screening on morbidity and mortality from oral cancer comes from a single, large RCT (n=191,873) conducted in a population with high disease prevalence who were screened by advanced health workers during home visits. Screened subjects had no significant difference in incidence or mortality rates from oral cancer compared with subjects who were not screened. Screened subjects, however, had oral cancer diagnosed at lower stages and with greater 5-year survival. Exploratory analyses in the subgroup who used tobacco or alcohol (n=84,600) showed screened subjects had a lower mortality rate from oral cancer than subjects who were not screened. Evidence for the performance characteristics of the screening examination came from seven primary studies (n=86,513) conducted primarily in high-prevalence settings. The studies had considerable heterogeneity in design and showed wide variation in performance characteristics: sensitivity for oral cancer or PMD ranged from 18 to 94.3 percent and specificity from 54 to 99.9 percent, the positive predictive value ranged from 17 to 86.6 percent, and the negative predictive value from 73 to 99.3 percent. Among older adults (age 40 years or older) in the United Kingdom at somewhat increased risk due to alcohol and tobacco use, dental examinations were 71 to 77 percent sensitive, with positive predictive values of 67 to 86 percent and high specificity (98% to 99%). However, test performance reflected detection of potentially malignant lesions as well as actual cancers, the reference standard was flawed, few lesions were detected, and clear determination of high-risk status was not reported. In contrast to expert or trained screening examinations, self-examinations in India and London were clearly insensitive. We found no evidence on screening the general or a selected high-risk U.S. population for oral cancer. No study reported on harms from the screening test or from false-positive or false-negative test results. Adjunctive toluidine blue dye to enhance the screening examination did not significantly improve detection of lesions nor reduce oral cancer incidence compared with a placebo-dye screening examination. No study evaluating other adjuncts (chemiluminescent lighting, autofluorescent lighting, or brush cytopathology) met our inclusion criteria.