# RESULTS

## Literature Search

Our literature search (Figure 2) retrieved 1,722 citations and we selected 89 of these for full-text review. In addition, we reviewed nine studies identified in previous USPSTF searches.32,33,37-43 After our full-text review, we excluded 88 studies (Appendix C). Three articles pertaining to KQ 1 report the same trial after each of the three rounds of screening.32,33,37 Seven articles pertaining to KQ 2 report test performance characteristics of different screening modalities.38-41,44-46

Figure 2 Literature Flow Diagram

Figure 2 is a literature flow chart that summarizes the search and selection of articles. There were 1,722 citations identified through our literature searches. The full text of 89 citations were examined for inclusion for one or more of the Key Questions; 9 additional articles were identified from the previous USPSTF review and interim searches. Reasons for excluding the other articles are available in the Appendix. We included 10 articles; 3 for Key Question 1 and 7 for Key Question 2.

## Key Question 1 Does Screening for Oral Cancer Reduce Morbidity or Mortality?

### Summary of Results

Evidence for this KQ is derived from a single large, fair-quality RCT conducted in India—the Trivandrum Oral Cancer Screening Study.37 Screened subjects had oral cancer diagnosed at lower stages with greater 5-year survival than patients who were not screened. Within the subgroup of participants who used tobacco or alcohol, screened subjects had a significantly lower mortality rate from oral cancer than subjects in the control group. We found no evidence on screening for oral cancer in either the general U.S. population or a selected high-risk U.S. population.

### Study Details

This RCT was conducted in the Trivandrum District in the state of Kerala, India, an area with the fourth highest incidence rate of oral cancer in the world (16.3 per 100,000 men and 7.7 per 100,000 women during 1991 to 1992) due to the prevalence of chewing betel quid and smoking tobacco.32 In this cluster-randomized design, 13 administrative districts were assigned to a screening intervention for their residents or to serve as controls. In the seven districts assigned to screening, advanced health workers conducted a visual inspection and palpation during home visits. The health workers referred residents with abnormal lesions to a specialty clinic. Screening was repeated every 3 years for at most three rounds. The diagnostic accuracy of this screening examination was reported in a companion study40 and is described under KQ 2. In control districts, health workers provided routine care and health messages, advising those subjects who used alcohol or tobacco to stop doing so.

In total, there were 191,873 eligible subjects throughout the study period, as more residents became eligible with each round: 59,894 residents in screened districts and 54,707 in control districts after the first round, 78,969 in screened districts and 74,739 in control districts after the second round, and 96,517 in the screened districts and 95,356 in the control districts after the third round. In the first two rounds, more eligible residents in the screened districts smoked tobacco, chewed tobacco (mainly as betel quid), or drank alcohol than in the control districts. The prevalence of these risk factors became more balanced by the third round, with no significant differences between screened and control districts in the proportions of eligible men or women who chewed tobacco or drank alcohol. Despite this, smoking remained more prevalent in the screened districts: 63 percent of men in screened districts smoked, whereas 56 percent in control districts smoked (p=0.0455); 3 percent of women in screened districts smoked, whereas 1 percent in control districts smoked (p=0.0633). In the screened districts, 87,655 (91% of those eligible) were screened at least once over the three rounds of screening: 34,343 (36%) were screened once, 24,210 (25%) were screened twice, and 29,102 (30%) were screened three times.

Clinical outcomes included oral cancer incidence, stage at diagnosis, survival, and deaths due to oral cancer. These outcomes were ascertained from cancer registries, hospital records, pathology laboratories, and death records. Outcomes were calculated using intention-to-screen analyses. After the third round, 5,145 residents had oral lesions on the screening examination. Of these residents, 3,218 (63%) received followup care at the specialty clinic, where 2,383 were confirmed to have a potentially malignant lesion or oral cancer. The cumulative incidence rate of oral cancer during the 9 years after screening began did not differ significantly between the screened and control districts: 43.7 per 100,000 person-years in the screened districts versus 37.6 per 100,000 person-years in the control districts (rate ratio [RR], 1.16 [95% CI, 0.70 to 1.92]). The oral cancers within the screened districts were at lower stages when diagnosed than within the control districts: 25 percent in the screened district versus 13 percent in the control districts were at stage I; 17 versus 11 percent were at stage II; 18 versus 22 percent were at stage III; and 33 versus 44 percent were at stage IV, respectively. The screened districts had a significantly greater proportion of stage I or stage II oral cancer cases (41%) compared with the control districts (23%; p=0.004). Residents with oral cancer from the screened districts had a 50 percent 5-year survival rate, while those from control districts had only a 34 percent 5-year survival rate (p=0.009). The overall mortality rate from oral cancer, however, did not differ significantly between the two groups: 16.4 per 100,000 person-years in the screened districts versus 20.7 per 100,000 person-years in the control districts (RR, 0.79 [95% CI, 0.51 to 1.22]).

Study investigators also stratified their analyses by subjects' tobacco or alcohol use. Among the 84,600 eligible subjects who used tobacco or alcohol (44% of the total), subjects in the screened districts had no significant difference in incidence of oral cancer (81.1 per 100,000 in the screened districts vs. 83.3 per 100,000 in the control districts; RR, 0.97 [95% CI, 0.66 to 1.44]), but significantly lower mortality from oral cancer than subjects in the control districts (29.9 per 100,000 in the screened districts vs. 45.4 per 100,000 in the control districts; RR, 0.66 [95% CI, 0.45 to 0.95]). Among subjects who did not use tobacco or alcohol, there were no significant differences in incidence or mortality from oral cancer between screened and control districts. The authors concluded that oral cancer screening conducted by trained health workers reduced oral cancer mortality in people who were at high risk due to using tobacco or alcohol.

This study was rated fair quality despite its randomized design, specific eligibility requirements, large sample size, validated screening test, ascertainment of outcomes equally for both groups, use of objective outcomes, and intention-to-treat analysis. Limitations detailed in other systematic reviews5,29 include imbalance in baseline risk factors, inadequate accounting for clustering in the analysis, low compliance with followup, possible lead-time and length-time bias, reporting outcomes cumulatively (rather than for each round of screening), and not reporting adverse effects of screening or how lesions were treated. The higher prevalence of risk factors in the screened group may have diluted the apparent effectiveness of screening. This imbalance was addressed somewhat by the subgroup analyses according to tobacco or alcohol use, although the analyses were not prespecified. A better approach would have been examining effect modification by tobacco or alcohol use with tests for interaction.47,48 Finally, despite its large size, the study was underpowered. In the sample size calculations, each district was assumed to accumulate 110,000 person-years of observation over the 9 years. The seven districts randomized to screening, however, accumulated only 469,089 person-years of observation, while the six control districts accumulated only 419,748 person-years of observation.

## Key Question 2 What Are the Performance Characteristics of the Screening Oral Examination as a Means of Identifying Oral Cancer or Potentially Malignant Disorders for Oral Cancer?

### Summary of Results

Evidence from seven fair- to good-quality primary studies38-41,44-46 showed considerable heterogeneity in design and wide variation in performance characteristics (Table 1). Most were conducted in settings (Taiwan, India) with much higher incidence and mortality from lip and oral cancer than the United States. Across all studies, sensitivity for oral cancer or PMD ranged from 18 to 94.3 percent, and specificity from 54 to 99.9 percent. The positive predictive value ranged from 17 to 86.6 percent and the negative predictive value from 73 to 99.3 percent. In two studies of screening by general dentists in the United Kingdom,38,39 which is more comparable to the United States in oral cancer incidence and mortality, one good-quality study among 2,027 relatively high-risk dental patients age 40 years and older found that dental examination showed a sensitivity of 74 percent and a specificity of 99 percent, with a positive predictive value of 67 percent.39 Another fair-quality study among a mixed sample of 292 workers with unknown smoking or alcohol use habits found a similar sensitivity (71%), specificity (99%), and positive predictive value (86%).38 These results reflect detection of PMDs as well as oral cancers, reflect an imperfect reference standard (more expert examination), and thus need to be confirmed with longitudinal followup. One fair- to poor-quality, very small trial of self-examination in patients age 45 years and older in the United Kingdom found very low sensitivity, specificity, and predictive values.45 The only study that evaluated an adjunctive screening method in Taiwan found no improvement in clinical outcomes when toluidine blue gargle preceded the dental oral examination.46 None of the studies reported on harms from the screening test or from false-positive or false-negative test results. No studies evaluating other adjuncts (chemiluminescent lighting, autofluorescent lighting, or brush cytopathology) met our inclusion criteria.

Table 1 Evidence for Key Question 2: Studies of Performance Characteristics of the Oral Cancer Screening Examination

Author, year Country | Participants, behaviors, and setting^*^ | Criteria for positive screening test | Identity and training of screeners | Reference standard | Results | Comments | Quality rating
Examination by health workers
Mehta et al, 1986^41^ India | 1,921 tobacco users age ≥35 years residing in Trivandrum District, India; proportion using alcohol NR Subjects' homes | Presence of nodular leukoplakia, submucous fibrosis, ulcers, or growths suggestive of oral cancer | Basic health workers (high school + 1 year) who received 2 or 5 days of training on how to perform oral exams and classify lesions | Dentist's exam 6 months after screening exam | Sensitivity=59% (16/27) Specificity=98% (1,859/1,894) PPV=31% (16/51) NPV=99% (1,859/1,870) | Selected for reference exam from 39,331 who were screened. Unclear if dentists were aware of screening results when performing their exams. Study conducted in a high-risk population. | Fair
Mathew et al, 1997^40^ India | 2,069 persons age 35 to 64 years residing in Trivandrum District, India; proportion using tobacco or alcohol NR Subjects' homes | Presence of homogeneous leukoplakia, ulcerated leukoplakia, verrucous leukoplakia, erythroplakia, nodular leukoplakia, submucous fibrosis, or growths suggestive of oral cancer | Advanced health workers (university graduates) who received 6 weeks of training on oral visual inspection and detection of lesions | Physician's exam 1 to 6 months after screening exam | Sensitivity=94.3% (200/212) Specificity=98.3% (1,826/1,857) PPV=86.6% (200/231) NPV=99.3% (1,826/1,838) | Selected for re-exam from about 9,000 screened based on population density. Substudy of RCT among general population.37 | Good
Examination by general dentists
Jullien et al, 1995^39^ United Kingdom | 2,027 patients and relatives age ≥40 years of a general dental or medical practice in London; 38% smoked, all drank alcohol Dental hospital or medical practice | White patch, red patch, or ulcer of >2 weeks duration or presence of specific lesions: lichen planus, lupus erythematosus, submucous fibrosis, or actinic keratosis | General dental practitioner, community dental officer, or junior hospital dentist | Dental specialist at the same visit | Sensitivity=74% (40/54) Specificity=99% (1,953/1,973) PPV=67% (40/60) NPV=99% (1,953/1,967) | Participation rate NR. Dental clinic patients might be more likely to have oral lesions than general population, and screeners may perform more thorough exams. | Good
Downer et al, 1995^38^ United Kingdom | 309 persons age ≥40 years employed by a commercial company in London; proportion using tobacco or alcohol NR Company dental practice | White patch, red patch, or ulcer of >2 weeks duration | General dentists with no special training | Oral medicine specialist at same visit | Sensitivity=71% (12/17) Specificity=99% (290/292) PPV=86% (12/14) NPV=98% (290/295) | 53% of those eligible participated; sample enriched from second work site. | Fair
Mouth self-examination
Elango et al, 2011^44^ India | 34,766 persons age >10 years residing in Trivandrum District, India (47% ≥40 years); 33% of men and 3% of women used tobacco, betel quid, or alcohol (17.6% total) Subjects' homes | Presence of white patch, red patch, nonhealing ulcer, difficulty opening mouth, other oral symptoms | Subjects performing mouth self-exam as described in brochure | Health worker with 1 month of training on oral cancer conducted exam 4 weeks after screening exam | Sensitivity=18% (39/219) Specificity=99.9% (34,532/34,547) PPV=72% (39/54) NPV=99% (34,532/34,712) | 72% of those eligible were examined by health worker. 87% performed mouth self-exam. Only 21% (8/39) with potentially malignant lesions confirmed by health worker followed up at screening clinic | Fair
Scott et al, 2010^45^ United Kingdom | 53 persons age ≥45 years who smoked (as identified by a general practitioner) residing in London; proportion using alcohol NR Research department | Presence of ulcer, white patch, red patch, lump, or swelling | Subjects performing mouth self-exam as described in a leaflet, after a screening exam by a dentist | Dentist, at same visit | Sensitivity=33% (4/12) Specificity=54% (22/41) PPV=17% (4/23) NPV=73% (22//30) | 22% of those invited participated. Mouth self-exam conducted in research department after dentist's exam with dentist in the room. Small sample size. Study conducted in a high-risk population. | Fair
Toluidine blue
Su et al, 2010^46^ Taiwan | 7,975 persons age ≥15 years (61% ≥40 years) who smoked cigarettes or chewed betel quid residing in Keelung, Taiwan; proportion using alcohol NR Community setting | Presence of any visible lesion including submucous fibrosis, leukoplakia, erythroplakia, lichen planus, ulcer, hyperkeratosis, candidiasis | Dentists with at least 3 years of practice and additional training; exam with or without toluidine blue | Incidence of oral cancer from National Cancer Registry during 4 to 5 years of followup | Malignant transformation rate in toluidine blue group: 129 per 100,000 person-years Malignant transformation rate in placebo dye group: 420 per 100,000 person-years Relative malignant transformation rate, toluidine blue vs. placebo dye: 0.31 (95% CI, 0.03 to 2.94) Annual incidence of oral cancer in toluidine blue group: 28.0 per 100,000 person-years Annual incidence in placebo dye group: 35.4 per 100,000 person-years Relative incidence of oral cancer, toluidine blue vs. placebo dye: 0.79 (95% CI, 0.24 to 1.23) | 78% of those eligible participated. Study conducted in a high-risk population. | Fair

* Participants who had reference standard.

Abbreviations: NR: not reported; NPV: negative predictive value; PPV: positive predictive value; RCT: randomized, controlled trial

### Study Details

Screening by health workers. Two studies conducted in the Trivandrum District in Kerala, India assessed screening examinations by health workers.40,41 One fair-quality study assessed screening by basic health workers who had a high school diploma, a 1-year certification course, and an additional 2 or 5 days of training about oral cancer screening.41 The basic health workers made home visits, screening residents who were age 35 years or older and used tobacco—an estimated 25 percent of the population. The health workers advised subjects who had a lesion that was suspicious for a potentially malignant or malignant disorder to follow up at an oral cancer detection center. They advised subjects who had a lesion that was not suspicious for malignancy to stop using tobacco and have periodic re-examinations. The basic health workers screened 39,331 subjects, referring 523 (1.3%) to the oral cancer detection center. Of those referred, 351 (67%) reported to the referral center. A sample of 1,921 (5%) screened subjects were re-examined by a dentist after 6 months to assess the basic health worker's screening examination. Screened subjects—some of whom had a referable lesion on the screening examination—were selected for re-examination if they lived near someone with a referable lesion. Using the dentist's examination as a reference standard, the screening examination by the basic health worker showed a sensitivity of 59 percent, specificity of 98 percent, positive predictive value of 31 percent, and negative predictive value of 99 percent. This study was rated as fair quality because of low adherence with referral by screen-positive subjects, because of the delay between screening test and reference standard administration, and because it did not report whether subjects with known oral lesions were excluded or whether dentists were aware of the results of the basic health worker's examination.

A good-quality study40 was conducted as part of the RCT described under KQ 1^37^ after the RCT had recruited 9,000 subjects over a 5-month period. As part of the RCT, screening was performed by advanced health workers who were university graduates with 6 weeks of special training. Screening examinations took place in subjects' homes using visual inspection and palpation. Subjects were eligible for screening if they were ages 35 to 64 years and lived in a district randomized to screening. A subset of 2,069 (23% of those screened as part of the RCT) subjects were re-examined to assess the advanced health workers' screening examination. Subjects were re-examined if they lived in densely populated areas, whether they had screened positive or negative. The re-examination was conducted in the subjects' homes by the original screening health care worker and one of three physicians 1 to 6 months after the screening examination. Using the physicians' examination as the reference standard, the advanced health workers' repeat examination showed a sensitivity of 94.3 percent, specificity of 98.3 percent, positive predictive value of 86.6 percent, and negative predictive value of 99.3 percent. Although the proportion using tobacco or alcohol in this substudy is not reported, 44 percent in the overall study used tobacco or alcohol.37

Screening by general dentists. Two studies conducted in London assessed screening by general dentists.38,39 In the larger, good-quality study, subjects age 40 years or older were recruited from outpatients at a dental hospital or their relatives and from an inner-city medical practice.39 All subjects drank alcohol and 38 percent smoked tobacco. Screening examinations took place at the dental hospital or the medical practice. Subjects were examined by a general dental practitioner, a community dental officer, or a junior hospital dentist. Screening dentists were educated as to what constituted a positive or negative screen, but were given no special training. Each subject was examined independently by a dental specialist during the same visit.

Study dentists screened 2,027 subjects. The screening dentist identified 60 lesions, 40 of which were confirmed as being abnormal by the specialist dentist. Using the specialty dentist's examination as the reference standard, the screening dentist's examination showed a sensitivity of 74 percent, specificity of 99 percent, positive predictive value of 67 percent, and negative predictive value of 99 percent.

In the smaller, fair-quality study, a commercial company's staff members who were age 40 years or older were invited for screening.38 Screening was conducted at the on-site company dental practice by two general dentists who had not received any special training. During the same visit, each subject was subsequently examined independently by a specialist in oral medicine who was not aware of the screening dentist's findings.

Among 553 eligible staff at headquarters, 292 (53%) were screened. Seventeen staff from a separate company work site were also included in the analysis, providing a total of 309 subjects. The proportion using tobacco or alcohol was not reported. The screening dentist identified 14 abnormal lesions, 12 of which were confirmed as being abnormal by the oral medicine specialist. Using the oral medicine specialist's examination as a reference standard, the examination by the screening dentist showed a sensitivity of 71 percent, specificity of 99 percent, positive predictive value of 86 percent, and negative predictive value of 98 percent. This study was rated fair quality because of low participation rates and contamination from the second work site.

Mouth self-examination. Two fair-quality studies assessed mouth self-examination for oral cancer screening.44,45 One study was conducted among 48,080 subjects older than age 10 years who were living in two administrative units of the Trivandrum District in Kerala, India.44 Full-color brochures were distributed to all households in the study area. The brochures explained oral cancer and its risk factors, described mouth self-examination with words and pictures, and told people to report to the oral cancer screening clinic within 3 to 4 weeks if they found any of the abnormal lesions described.

Four weeks after the brochures were distributed, health workers with 1 month of training in oral cancer screening conducted a visual oral examination on 34,766 subjects (72% of those eligible for the study). Of these, 18 percent (33% of men and 3% of women) smoked cigarettes, chewed betel quid, or drank alcohol. Eighty-seven percent of subjects had actually performed the mouth self-examination and 54 subjects found lesions. Health workers confirmed 39 of these lesions as being abnormal. Only eight (21%) of the subjects with confirmed abnormal lesions presented for followup at the screening clinic. The health workers identified another 180 abnormal lesions that had not been found by self-examination. Using the health worker's examination as the reference standard, the mouth self-examination showed a sensitivity of 18 percent, specificity of 99.9 percent, positive predictive value of 72 percent, and negative predictive value of 99 percent. We rated this study as fair quality because it was unclear whether the health workers were aware of the screening results when performing their examinations.

The other study of self-examination recruited subjects who smoked and were age 45 years or older. A general practitioner in London identified 243 potential subjects, but only 53 (22%) participated in the screening exercise.45 First, a dentist in an oral health services research department conducted an oral screening examination. Next, subjects were given a leaflet with text and pictures describing an oral self-examination. Then, the subjects conducted their own self-examinations with the dentist still in the room but not assisting. Among the 53 subjects, 23 found a lesion. The dentist's examination confirmed four of these lesions as being abnormal. However, the dentist's examination identified eight additional abnormal lesions. Using the dentist's examination as the reference standard, mouth self-examination showed a sensitivity of 33 percent, specificity of 54 percent, positive predictive value of 17 percent, and negative predictive value of 73 percent. We rated this study as fair quality because the dentist conducted an examination first (essentially teaching the subjects) and stayed in the room while subjects conducted their self-examination (influencing the self-examination), it included a small sample size, and the study's participation rate was low.

Toluidine blue. One fair-quality study evaluated toluidine blue for screening.46 As part of a mass community screening program, 7,975 subjects living in Keelung County, Taiwan, who smoked cigarettes or chewed betel quid were screened for oral cancer. Subjects were randomized to gargle with toluidine blue solution or with placebo dye solution before the screening examination. Subjects were then examined by one of six dentists who had at last 3 years of practice experience and additional training. The patient was referred for biopsy if a dentist found an abnormal lesion. The investigators followed up with the subjects longitudinally through national cancer and death registries for incidence of oral cancer, survival status, and death during 4 to 5 years after the screening examination.

Among the 4,080 subjects who gargled with toluidine blue, the dentist identified 389 participants (9.5%) with suspicious lesions. Among the 3,895 who gargled with placebo dye, the dentist identified 322 (8.3%) with suspicious lesions (p=0.047). Patients with suspicious lesions detected by screening were referred for biopsy; 86 percent of patients referred to biopsy (82.3% who gargled with toluidine blue and 91.0% who gargled with placebo dye) complied with this recommendation. However, there was no significant difference in the RR for potentially malignant or malignant lesions based on the biopsy results: 187 potentially malignant or malignant lesions were identified among those who gargled with toluidine blue (4.6%), while 170 potentially malignant or malignant lesions were identified among those who gargled with placebo dye (4.4%; RR, 1.05 [95% CI, 0.75 to 1.41]).

Use of toluidine blue did not significantly improve identification of less advanced lesions. The malignant transformation rate from potentially malignant lesions to oral cancer was 129 per 100,000 person-years among those who gargled with toluidine blue versus 420 per 100,000 person-years among those who gargled with placebo dye (RR, 0.31 [95% CI, 0.03 to 2.94]). The annual incidence rate of oral cancer was 28.0 per 100,000 person-years among those who gargled with toluidine blue versus 35.4 per 100,000 person-years among those who gargled with placebo dye (RR, 0.79 [95% CI, 0.24 to 1.23]). We rated this study as fair quality despite its large size and randomized, double-blind design because it had a differential compliance with followup for diagnostic biopsy that could have impacted the findings and a limited spectrum of patients.