# METHODS

## Data Sources and Searches

We searched Ovid Medline for English-language articles published between January 2008 and July 11, 2011. Relevant studies from the previous USPSTF evidence review covering 1994 through 2001^1^ are included, as are studies from a bridge search covering 2001 through 2008 (see Appendix A for methods and search strategy). Our current search strategy used MeSH terms and key word variations in the title or abstract to identify citations related to oral cancer, screening, and diagnostic accuracy (Appendix B).

## Study Selection

One investigator reviewed the citations retrieved at the title and abstract level, identifying possibly relevant articles. Two investigators independently reviewed citations identified at the full-text level. Disagreements were resolved by discussion and consultation with a third reviewer.

For KQ 1, studies were included if they were RCTs, meta-analyses, or systematic reviews that compared a screening test or combination of tests with no screening or usual care in adult populations (at least 80% of subjects were age 18 years or older) and reported morbidity or mortality outcomes. For KQ 2, studies were included if they compared a uniformly applied screening test for oral cancer with a reference standard (second examination, other test, or longitudinal followup) that was applied to all persons with positive screens and at least a sample of persons with negative screens. Relevant studies identified by previous USPSTF searches were carried forward to our review. Finally, we examined bibliographies of the articles retrieved for additional relevant studies.

## Data Extraction and Quality Assessment

A single investigator extracted study characteristics and results. A second investigator confirmed data. Two investigators rated the studies for internal validity using USPSTF criteria supplemented by standards from established criteria for assessing systematic reviews, RCTs, or diagnostic accuracy.34-36 Per USPSTF methods, articles that were rated as having poor quality were excluded from further consideration.

## Data Synthesis and Analysis

We describe the evidence in text and tables by KQ and summarize it qualitatively. We did not synthesize the data quantitatively, since there was scant evidence for KQ 1 and the evidence for KQ 2 was too heterogeneous to pool. For KQ 2, we report sensitivity, specificity, positive predictive value, and negative predictive value where possible.

## Role of the Funding Source

This research was partially conducted by the Agency for Healthcare Research and Quality (AHRQ) and then updated and finalized under contract to support the work of the USPSTF. AHRQ staff provided oversight and reviewed the draft synthesis.