# INTRODUCTION

## Background

In 2004, the U.S Preventive Services Task Force (USPSTF) found insufficient evidence in its review1 to recommend for or against screening for oral cancer.2 In this review, we are updating the evidence search and analysis to allow this recommendation to be reconsidered.

### Disease Condition

Oral cancer includes cancers of the lip, oral cavity, and pharynx.3 Ninety percent of cancers of the oral cavity are squamous cell carcinomas (SCCs) arising from the mucosal lining. The other 10 percent of oral cancers are malignant melanomas, salivary gland tumors, sarcomas of the soft tissues or jaw bones, nonHodgkin's lymphomas, or metastases from extra-oral primary tumors.4

### Etiology and Natural History

Most oral cancer is preceded by visible nonmalignant lesions.5 Since not all nonmalignant lesions progress to cancer, the World Health Organization recommends classifying them as “potentially malignant disorders” (PMDs), rather than “precancers,” “precursor lesions,” or “premalignant lesions.”6 PMDs are oral lesions that include leukoplakia, erythroplakia, lesions of the palate from reverse smoking (placing the lighted end of a cigarette in the mouth), submucous fibrosis, and actinic keratosis (with potential for lip cancer). Whether lichen planus and discoid lupus erythematosus are potentially malignant is controversial. There are also rare hereditary diseases (e.g., dyskeratosis congenita and epidermolysis bullosa) that involve PMDs.6

Most PMDs are oral leukoplakia or erythroplakia.7 An estimated 2.6 percent of the world's population has oral leukoplakia.8 While the reported malignant transformation rate varies widely,9 a pooled estimate is 1.36 percent per year.8 An estimated 0.2 to 0.8 percent worldwide has erythroplakia,7 which has a malignant transformation rate above 85 percent.10

### Prevalence and Burden of Disease

According to data from the American Cancer Society, an estimated 39,400 new cases of cancer of the oral cavity and pharynx were expected in 2011, leading to an estimated 7,900 deaths.11 Based on 2004 to 2008 Surveillance Epidemiology and End Results (SEER) data, the overall age-adjusted incidence rate of oral cancer in the United States was 10.6 per 100,000 individuals and the median age at diagnosis was 62 years.12 Incidence rates begin to increase at approximately ages 35 to 44 years (Figure 1).13,14 Men had higher incidence rates for oral cancer than women in all racial and ethnic groups. In the past, black men and women had higher incidence rates than white men and women,7,10,15 but recent data show white men and women (Hispanic and nonHispanic) having higher incidence rates than black men and women.12

Figure 1 Incidence13 and Mortality14 Rates of Cancer of the Oral Cavity and Pharynx in the United States by Age, SEER 2008

Figure 1 displays the incidence and mortality rates of cancer of the oral cavity and pharynx in the United States by age according to 2008 SEER data. The rates increase with age.

Based on 2004 to 2008 SEER data, the age-adjusted mortality rate was 2.5 per 100,000 individuals per year and the median age of death from oral cancer was 67 years.12 Men had higher mortality rates for oral cancer than women and black men, specifically, had the highest mortality rates. The mortality rate for oral cancer has been decreasing in the United States since 1975.

Based on 2001 to 2007 SEER data, the relative 5-year survival for all those diagnosed with oral cancer was 60.8 percent compared with the general population.12 Relative 5-year survival decreased with more advanced cancer stage at diagnosis, from 82.4 percent for localized disease, to 55.5 percent for regional lymph node spread, to 33.2 percent for disease with distant metastases.12 The lifetime risk for oral cancer was 1.02 percent, meaning one in 98 men and women will be diagnosed with oral cancer during his or her lifetime.12

### Risk Factors

Several lifestyle factors, particularly tobacco use, affect an individual's risk of acquiring oral cancer. Worldwide, 20 to 30 percent of oral cancer cases are attributable to cigarette smoking.16 A pooled analysis of 15 studies estimated the effects of smoking cigarettes among people who never drank alcohol.17 Compared with never-smokers, all smokers combined had an adjusted odds ratio (OR) of 1.35 (95% confidence interval [CI], 0.90 to 2.01) for cancer of the oral cavity. The adjusted OR showed a dose-response relationship with smoking intensity and duration. Compared with never-smokers, smokers of 31 to 40 cigarettes (1.5 to 2 packs) per day had an adjusted OR of oral cancer of 2.92 (95% CI, 0.91 to 9.44), with an increased adjusted OR of 3.23 (95% CI, 1.54 to 6.77) in those who smoked more than 40 years. Thus, while all levels of cigarette smoking increase risk of oral cancer at a population level, relatively heavy or long-term use is required to identify individuals or subgroups with substantial risk. The same pooled analysis estimated the effects of drinking alcohol among people who never smoked.17 Those who ever drank alcohol had an adjusted OR of 1.17 (95% CI, 0.92 to 1.48) for cancer of the oral cavity compared with never-drinkers. The adjusted ORs did not show a dose-response relationship.

An earlier case-control study that adjusted for smoking status (as well as other factors), however, found increasing adjusted ORs for oral or pharyngeal cancer with increasing frequency of alcohol consumption: up to 8.8 (95% CI, 5.4 to 14.3) for men and 9.1 (95% CI, 3.9 to 21.0) for women who had 30 or more alcoholic drinks per week compared with men and women who had less than one alcoholic drink per week.18 This study also examined possible synergistic effects of smoking and drinking alcohol. The adjusted OR for oropharyngeal cancer increased to 37.7 for men who both smoked 40 or more (two packs) cigarettes a day for 20 or more years and had 30 or more alcoholic drinks per week.18 Thus, relatively heavy alcohol use (50% to 100% above recommended levels for moderate drinking) convey increased risk of oral or pharyngeal cancer, which is exponentially increased further in heavy, long-term male smokers.

Whether age itself is a risk factor for oral cancer or is simply a marker for longer exposure to other risk factors remains unclear. In the pooled analysis of 15 studies, analyses for smoking risks among never-drinkers were stratified by age, race, ethnicity, education level, and study design. These analyses found no strong differences between the strata. Similarly, analyses for risks of drinking alcohol among those who never smoked were stratified by age, sex, race/ethnicity, education level, study region, and source of control subjects. Again, no differences between strata were found.17

Southeast and south Asia have some of the highest incidence and mortality rates from oral cancer in the world.19 This is attributed to smoking tobacco, reverse smoking, and chewing betel quid.7,16 Betel quid contains areca nut, lime, flavorings, and tobacco wrapped in betel leaves. It is chewed by 25 to 50 percent of the populations of southeast and south Asia.16

Human papillomavirus (HPV) is also associated with oral SCC and PMDs.20 The tonsil, oropharynx, and the base of the tongue are specific oral SCC sites with a high prevalence of HPV.21 In a pooled analysis of 39 studies, HPV was significantly more likely to be detected in tissue samples from patients with oral SCC (OR, 3.98 [95% CI, 2.62 to 6.02]) or PMDs (OR, 3.87 [95% CI, 2.87 to 5.21]) compared with similar samples from control subjects.22 Globally, the prevalence of HPV in oral SCC is 23.5 percent.23 Patients with HPV-positive oral cancer are diagnosed an average of 5 years younger and have improved survival compared with patients with HPV-negative oral cancer.21,24 The role of the Epstein-Barr virus in oral cancer is currently being investigated.24,25

Exposure to ultraviolet light also increases an individual's risk of lip cancer.15 Other risk factors for oral cancer include infection with Candida or bacterial flora and a compromised immune system.10

The presence of infectious and environmental risk factors for oral cancer suggests multiple pathways for its pathogenesis. While some oral cancers originate through tobacco and alcohol use, others originate through oral HPV infection and associated sexual behavior.21,26 The overall decrease in the incidence rate of oral cancer in the United States since 1979^12^ is attributed to declines in cigarette smoking and alcohol consumption.21 While blacks used to have higher incidence rates of oral cancer than whites, whites now have higher incidence rates than blacks. This change is attributed to increases in oral cancer related to HPV infection among whites (particularly in younger age cohorts), along with decreases in both HPV-related and HPV-unrelated oral cancers among blacks.21 The prevalence of oral HPV infection is associated with age, sex, life-time number of sexual partners, and number of cigarettes smoked per day.26

### Current Clinical Practice

According to the World Health Organization and the National Institute of Dental and Craniofacial Research, an oral cancer screening examination should include a visual inspection of the face, neck, lips, labial mucosa, buccal mucosa, gingiva, floor of the mouth, tongue, and palate. Mouth mirrors can help visualize all surfaces. This examination should also include palpating the regional lymph nodes, tongue, and floor of the mouth. Any abnormality that lasts for more than 2 weeks should be re-evaluated and considered for biopsy.27

Several adjunctive devices have been developed to aid in screening. Toluidine blue (also known as tolonium chloride) is a dye that stains rapidly dividing cells, helping to visually identify abnormal tissue. Chemiluminescent and autofluorescent lighting devices are also used to help visualize abnormal tissue based on the premise that abnormal tissue has different absorptive and reflective characteristics than normal tissue. In brush cytopathology, a clinician uses a brush to obtain a full-thickness sample of cells from a suspicious lesion. The cells are then fixed on a slide, stained, and analyzed under a microscope to determine whether the lesion is potentially malignant.28,29

In a 2008 survey of adults in the United States, 29.4 percent reported ever having an oral cancer screening examination that involved pulling on their tongue or feeling their neck.30 Increasing the proportion of oral cancers detected at the earliest stage by 10 percent is an objective of Healthy People 2020, by increasing the proportion of adults who have received an oral cancer screening examination from a dentist or dental hygienist during the previous year.31

## Previous USPSTF Recommendation

In 2004,^2^ the USPSTF reviewed available data and concluded there was insufficient evidence to recommend for or against routine screening for oral cancer in adults. The recommendation was based on early32 and interim33 reports of a cluster-randomized, controlled trial of screening by health care workers in India, which found no differences in mortality rates from oral cancer between the screened and control groups. Our review found eight randomized, controlled trials (RCTs) using various treatments for oral leukoplakia that showed treatment promotes remission. These studies were small, however, and had less than 2 years of followup.

## Scope and Purpose

The USPSTF requested this targeted update to focus on the evidence gap in the conceptual framework about screening for oral cancer (i.e., any test or combination of tests used to detect PMDs or cancer of the lip, oral cavity, or pharynx). The two key questions are:

Key Question 1 (KQ 1): Does screening for oral cancer reduce morbidity or mortality?

Key Question 2 (KQ 2): What are the performance characteristics of the screening oral examination as a means of identifying oral cancer or PMDs for oral cancer?